# Appendix A Exact Search Strings

Medline
| CBPR Definitions <1966 to October Week 5 2002>
| Citations: 1–106
| 1 (community based participatory research or cbpr).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (25)
| 2 (participatory research or action research or participatory action research or participatory evaluation or community driven research or action cience or collaborative inquiry or empowerment evaluation).mp. (775)
| 3 1 or 2 (781)
| 4 limit 3 to english language (735)
| 5 limit 4 to yr=1970-2002 (728)
| 6 (definition or defined or operationalized or concept).mp. (270565)
| 7 5 and 6 (51)
| 8 from 7 keep 1–51 (51)
| 9 essential elements.mp. (918)
| 10 5 and 9 (2)
| 11 characteristics.mp. (256291)
| 12 5 and 11 (28)
| 13 characterization.mp. (158371)
| 14 5 and 13 (6)
| 15 exp Benchmarking/ or best practices.mp. (2948)
| 16 5 and 15 (3)
| 17 exp HEALTH PLANNING GUIDELINES/ or guidelines.mp. or exp GUIDELINES/or exp PRACTICE GUIDELINES/ (72227)
| 18 5 and 17 (21)
| 19 7 or 10 or 12 or 14 or 16 or 18 (106)
| Grants <1966 to October Week 5 2002>
| Citations: 1–18
| 1 (community based participatory research or cbpr).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (25)
| 2 (participatory research or action research or participatory action research or participatory evaluation or community driven research or action science or collaborative inquiry or empowerment evaluation).mp. (775)
| 3 1 or 2 (781)
| 4 limit 3 to english language (735)
| 5 limit 4 to yr=1970-2002 (728)
| 6 exp Financing, Organized/ or grants.mp. or exp Research Support/ or funders.mp. or exp Organizations, Nonprofit/ (143381)
| 7 exp FOUNDATIONS/ (3079)
| 8 exp Research Support/ or exp Financing, Organized/ or exp Foundations/ or grant-making.mp. (136115)
| 9 6 or 7 or 8 (143381)
| 10 5 and 9 (18)
| 11 “Support, U.S. Gov&#39;t, P.H.S.”/ (0)
| 12 “Support, U.S. Gov&#39;t, P.H.S.”/ (0)
| 13 from 10 keep 1–18 (18)
| Focused Research <1966 to October Week 5 2002>
| Citations: 1–85
| 1 (community based participatory research or cbpr).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (25)
| 2 (participatory research or action research or participatory action research or participatory evaluation or community driven research or action science or collaborative inquiry or empowerment evaluation).mp. (775)
| 3 1 or 2 (781)
| 4 limit 3 to english language (735)
| 5 limit 4 to yr=1970-2002 (728)
| 6 exp RESEARCH/ (373152)
| 7 exp health services research/ (45193)
| 8 6 or 7 (412661)
| 9 5 and 8 (368)
| 10 exp Epidemiologic Methods/ (1804128)
| 11 exp Randomized Controlled Trials/ or exp Research Design/ or exp Clinical Trials/ (266464)
| 12 5 and 11 (91)
| 13 limit 5 to randomized controlled trial (16)
| 14 12 or 13 (106)
| 15 outcomes.mp. or exp “OUTCOME ASSESSMENT (HEALTH CARE)”/ or exp “OUTCOME AND PROCESS ASSESSMENT (HEALTH CARE)”/ or exp TREATMENT OUTCOME/(220882)
| 16 5 and 15 (103)
| 17 from 16 keep 1–103 (103)
| 18 14 not 17 (85)
| 19 from 18 keep 1–85 (85)
| Outcomes <1966 to October Week 5 2002>
| Citations: 1–103
| 1 (community based participatory research or cbpr).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (25)
| 2 (participatory research or action research or participatory action research or participatory evaluation or community driven research or action science or collaborative inquiry or empowerment evaluation).mp. (775)
| 3 1 or 2 (781)
| 4 limit 3 to english language (735)
| 5 limit 4 to yr=1970-2002 (728)
| 6 exp RESEARCH/ (373152)
| 7 exp health services research/ (45193)
| 8 6 or 7 (412661)
| 9 5 and 8 (368)
| 10 exp Epidemiologic Methods/ (1804128)
| 11 exp Randomized Controlled Trials/ or exp Research Design/ or exp Clinical Trials/ (266464)
| 12 5 and 11 (91)
| 13 limit 5 to randomized controlled trial (16)
| 14 12 or 13 (106)
| 15 outcomes.mp. or exp “OUTCOME ASSESSMENT (HEALTH CARE)”/ or exp “OUTCOME AND PROCESS ASSESSMENT (HEALTH CARE)”/ or exp TREATMENT OUTCOME/(220882)
| 16 5 and 15 (103)
| 17 from 16 keep 1–103 (103)
| Other Research <1966 to October Week 5 2002>
| Citations: 1–200
| 1 (community based participatory research or cbpr).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (25)
| 2 (participatory research or action research or participatory action research or participatory evaluation or community driven research or action science or collaborative inquiry or empowerment evaluation).mp. (775)
| 3 1 or 2 (781)
| 4 limit 3 to English language (735)
| 5 limit 4 to yr=1970-2002 (728)
| 6 exp RESEARCH/ (373152)
| 7 exp health services research/ (45193)
| 8 6 or 7 (412661)
| 9 5 and 8 (368)
| 10 exp Epidemiologic Methods/ (1804128)
| 11 exp Randomized Controlled Trials/ or exp Research Design/ or exp Clinical Trials/ (266464)
| 12 5 and 11 (91)
| 13 limit 5 to randomized controlled trial (16)
| 14 12 or 13 (106)
| 15 outcomes.mp. or exp “OUTCOME ASSESSMENT (HEALTH CARE)”/ or exp “OUTCOME AND PROCESS ASSESSMENT (HEALTH CARE)”/ or exp TREATMENT OUTCOME/(220882)
| 16 5 and 15 (103)
| 17 from 16 keep 1–103 (103)
| 18 14 not 17 (85)
| 19 from 18 keep 1–85 (85)
| 20 9 not 14 (274)
| 21 20 not 16 (225)
| Pre-1970s <1966 to January Week 2 2003>
| Citations: 1–5
| 1 (community based participatory research or cbpr).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (27)
| 2 participatory research or action research or participatory action research or participatory evaluation or community driven research or action science or collaborative inquiry or empowerment evaluation).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (775)
| 3 1 or 2 (781)
| 4 limit 3 to english language (734)
| 5 limit 4 to yr=1902-1969 (5)
| 6 from 5 keep 1–5 (5)
| Author Searches
| Allen, A (4)
| Bird, M (1)
| Freeman, E (2)
| Hatch, J (12)
| Jones-Saumty, D (7)
| Lubic, R (37)
| Tsark (4)
| Bass, E B (4)
| Bruce, T (5)
| Citrin, T (5)
| Cunningham, W (6)
| Fraticelli, B (1)
| Ford, J (6)
| Geiger, J (1)
| Glasgow, R E (18)
| Israel, B A (10)
| Kahn, R (1)
| Levine, D (27)
| Lurie, N (17)
| Manson, S M (22)
| Minkler, M (11)
| Ramirez-Valles (9)
| Randolph, L (7)
| Rubin, V (1)
| Sabol, B J (4)
| Seifer, S (18)
| White, G (3)
| Whitehead, T L (3)
[underlined: TEAG Call Suggestions] | Jason Powell <1966 to February Week 3 2003>
| # Search History Results Display
| 1 powell j$.au. - 1369
| 2 exp mental health - 7598
| 3 1 and 20 - 0
[underlined: TEAG Call Suggestions] | Disabled Community <1966 to February Week 3 2003>
| Citations: 1–187
| 1 exp Disabled Persons/ and exp Consumer Participation/ (443)
| 2 exp united states/ (685785)
| 3 1 and 2 (187)
| 4 from 3 keep 1–187 (187)
[underlined: TEAG Call Suggestions] | James Taylor- East Boston <1966 to February Week 3 2003>
| Citations: 1–5
| 1 taylor j$.au. (4017)
| 2 exp Community Health Centers/ (5375)
| 3 1 and 2 (5)
[underlined: TEAG Call Suggestions] | Occupational Health and Community <1966 to February Week 3 2003>
| Citations: 1–59
| 1 michaels d$.au. (82)
| 2 exp WORKPLACE/ or exp Occupational Health Services/ or exp Occupational Diseases/ (80878)
| 3 1 and 2 (14)
| 4 from 3 keep 1–14 (14)
| 5 participation or participatory or community).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading] (136235)
| 6 2 and 5 (1425)
| 7 exp united states/ (685785)
| 8 6 and 7 (412)
| 9 exp HEALTH SERVICES RESEARCH/ or exp RESEARCH/ (402905)
| 10 8 and 9 (59)
| 11 from 10 keep 1–59 (59)
[underlined: TEAG Call Suggestions] | James Taylor- Ear Infections <1966 to February Week 3 2003>
| Citations: 1–16
| 1 taylor j$.au. (4017)
| 2 exp Community Health Centers/ (5375)
| 3 1 and 2 (5)
| 4 boston.in. (92574)
| 5 1 and 4 (62)
| 6 3 and 4 (0)
| 7 east boston.in. (33)
| 8 1 and 7 (0)
| 9 exp EAR DISEASES/ or exp EAR/ (109870)
| 10 1 and 9 (16)
| 11 from 10 keep 1–16 (16)
[underlined: TEAG Call Suggestions] | Rehab Review <1966 to February Week 3 2003>
| 1 exp REHABILITATION/ or exp REHABILITATION NURSING/ or exp REHABILITATION CENTERS/ or exp REHABILITATION, VOCATIONAL/ (136504)
| 2 exp Consumer Participation/ (18041)
| 3 1 and 2 (825)
| 4 exp united states/ (685785)
| 5 3 and 4 (213)
| 6 limit 5 to review articles (9)
| 7 from 6 keep 1–9 (9)
[underlined: TEAG Call Suggestions] | Rehab Research <1966 to February Week 3 2003>
| Citations: 1–37
| 1 exp REHABILITATION/ or exp REHABILITATION NURSING/ or exp REHABILITATION CENTERS/ or exp REHABILITATION, VOCATIONAL/ (136504)
| 2 exp Consumer Participation/ (18041)
| 3 1 and 2 (825)
| 4 exp united states/ (685785)
| 5 3 and 4 (213)
| 6 limit 5 to review articles (9)
| 7 from 6 keep 1–9 (9)
| 8 exp research/ or exp health services research/ (402905)
| 9 5 and 8 (37)
| 10 from 9 keep 1–37 (37)
[underlined: TEAG Call Suggestions] | David Michaels <1966 to February Week 3 2003>
| Citations: 1–14
| 1 michaels d$.au. (82)
| 2 exp WORKPLACE/ or exp Occupational Health Services/ or exp Occupational Diseases/ (80878)
| 3 1 and 2 (14)
| 4 from 3 keep 1–14 (14)
[underlined: TEAG Call Suggestions] | Valles
| Citations: 1–6
| Randy Stroecker
[underlined: TEAG Call Suggestions] | Glenn White
[underlined: TEAG Call Suggestions] | Barbara Isreal

SOCIOFILE
| Citations: 1–45
| Community based participatory research or cbpr or (( “community based participatory”) or (“community driven” or “collaborative inquiry”)) and(research)
| Citations: 0
| Randy Stroecker

PSYCHINFO
| Citations: 1–76
| Community based participatory research or cbpr or ((action research) in DE) and (community or empowerment or participation) and (health or medical or medicine)
| Citations: 1–23
| Phil Brown
| Citations: 0
| Randy Shaw
| Citations: 1–11
| Mikkelsen
| Citations: 2
| Stoecker-Randy in AU1 AU: Stoecker,-Randy

COCHRANE
| Citations: 1–3
| Cochrane Reviews: Community based participatory research
| Citations: 1
| Cochrane Health Technology Assessment
| Citations: 1–12
| Empowerment
| Citations: 1–176
| Community Action Research (176)