# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Abstraction Forms/Quality Rating Forms

Appendix C Evidence Tables

Appendix D Expert Meeting Attendees/Technical Expert Advisory Group Members /Peer Review