# List of Acronyms/Abbreviations

ACPR: | acute C-peptide response to arginine
AHRQ: | Agency for Healthcare Research and Quality
ADA: | American Diabetes Association
ALG: | antilymphocyte globulin
AIR_arg_: | acute insulin response to arginine
AIR_g_ : | acute insulin response to glucose
ATC: | American Transplant Congress
ATG: | antithymocyte globulin
AUC_C-p_: | area under the curve, C-peptide
AUC_i_: | area under the curve, insulin
BLA: | biologics license application
BP: | blood pressure
CI: | confidence interval
CITR: | Collaborative Islet Transplant Registry
CMV: | cytomegalovirus
DCCT: | Diabetes Control and Complications Trial
DM: | diabetes mellitus
EBV: | Epstein-Barr virus
EDIC: | Epidemiology of Diabetes Interventions and Complications
EPC: | Evidence-based Practice Center
ER: | emergency room
FDA: | U.S. Food and Drug Administration
GAD: | glutamic acid decarboxylase
G-CSF: | granulocyte colony-stimulating factor
HDRF: | Juvenile Diabetes Research Foundation
HFS: | Hypoglycemia Fear Survey
Hosp: | hospital
hr(s).: | hour(s)
IA: | islet alone
IAK: | islet after kidney
ICA: | islet cell antigens
ICR: | Islet Cell Resource
IEq: | islet equivalents
IEq/kg: | islet equivalents per kilogram of body weight
IND: | investigational new drug
ITN: | Immune Tolerance Network
ITR: | International Islet Transplant Registry
indep: | independent
IPITA: | International Pancreas and Islet Transplant Association
IPTR: | International Pancreas Transplant Registry
ITA: | islet transplant alone
ITN: | Immune Tolerance Network
IVGTT: | intravenous glucose tolerance test
JDRF(I): | Juvenile Diabetes Research Foundation (International)
JDFI: | Juvenile Diabetes Foundation International
K_G_ : | glucose disposal
KTA: | kidney transplant alone
LFT(s): | liver function test(s)
MeSH^®^: | Medical Subject Headings^®^
MMF: | mycophenolate mofetil
mo(s).: | month(s)
N, n: | number
NCCR: | National Center for Research Resources
NIDDK: | National Institute of Diabetes and Digestive and Kidney Diseases
NIH: | National Institutes of Health
OGTT: | oral glucose tolerance testing
OPTN: | Organ Procurement and Transplantation Network
PAK: | pancreas after kidney
PRA: | panel reactive antibodies
pt(s): | patients
PTA: | pancreas transplant alone
PTLD: | post-transplant lymphoproliferative disorder
QoL: | quality of life
SD: | standard deviation
SIK: | simultaneous islet/kidney
SIL: | simultaneous islet/liver
SPK: | simultaneous pancreas/kidney
TEP: | Technical Expert Panel
tx: | transplant(ation)
U: | University
UNOS: | United Network for Organ Sharing
U.S.: | United States
UTI: | urinary tract infection
w/: | with
yr(s): | year(s)