# Listing of Excluded Studies

Adams A B, Shirasugi N, Durham M M, et al. Calcineurin inhibitor-free CD28 blockade-based protocol protects allogeneic islets in nonhuman primates. Diabetes. 2002;51(2):265-70. [pmid: 11812731].
animal model study
Alejandro R, Lehmann R, Ricordi C, et al. Long-term function (6 years) of islet allografts in type 1 diabetes. Diabetes. 1997;46(12):1983-9. [pmid: 9392484].
pre-Edmonton study
Alejandro R, Mintz D H, Noel J, et al. Islet cell transplantation in type I diabetes mellitus. Transplant Proc. 1987;19(1 Pt 3):2359-61. [pmid: 3152660].
pre-Edmonton
Ballinger W F, Lacy P E. Transplantation of intact pancreatic islets in rats. Surgery. 1972;72(2):175-86. [pmid: 4262169].
animal model study
Bartlett S T, Schweitzer E J, Kuo P C, et al. Prevention of autoimmune islet allograft destruction by engraftment of donor T cells. Transplantation. 1997;63(2):299-303. [pmid: 9422420].
animal model study
Beattie G M, Montgomery A M, Lopez A D, et al. A novel approach to increase human islet cell mass while preserving beta-cell function. Diabetes. 2002;51(12):3435-9. [pmid: 12453897].
animal model study; islet preparation methods
Bechstein W O. Long-term outcome of pancreas transplantation. Transplant Proc. 2001;33(12):1652-4. [pmid: 11377549].
review; not an original report of clinical outcomes
Benhamou P Y, Oberholzer J, Toso C, et al. Human islet transplantation network for the treatment of Type I diabetes: first data from the Swiss-French GRAGIL consortium (1999-2000). Groupe de Recherche Rhin Rhjne Alpes Geneve pour la transplantation d'Ilots de Langerhans. Diabetologia. 2001;44(7):859-64. [pmid: 11508270].
pre-Edmonton study
Bertuzzi F, Grohovaz F, Maffi P, et al. Successful transplantation of human islets in recipients bearing a kidney graft. Diabetologia. 2002;45(1):77-84. [pmid: 11845226].
pre-Edmonton study
Biancone L, Ricordi C. Pancreatic islet transplantation: an update. Cell Transplant. 2002;11(4):309-11. [pmid: 12162371].
review; not an original report of clinical outcomes
Birmingham K. Skepticism surrounds diabetes xenograft experiment. Nat Med. 2002;8(10):1047. [pmid: 12457165].
xenotransplantation study
Boker A, Rothenberg L, Hernandez C, et al. Human islet transplantation: update. World J Surg. 2001;25(4):481-6. [pmid: 11344402].
review; not an original report of clinical outcomes
Bonner-Weir S, Sharma A. Pancreatic stem cells. J Pathol. 2002;197(4):519-26. [pmid: 12115867].
islet regeneration therapy
Bosi E, Braghi S, Maffi P, et al. Autoantibody response to islet transplantation in type 1 diabetes. Diabetes. 2001;50(11):2464-71. [pmid: 11679423].
does not report clinical outcomes
Bottino R, Balamurugan A N, Bertera S, et al. Preservation of human islet cell functional mass by anti-oxidative action of a novel SOD mimic compound. Diabetes. 2002;51(8):2561-7. [pmid: 12145171].
islet preparation methods
Bretzel R G, Brandhorst D, Brandhorst H, et al. Improved survival of intraportal pancreatic islet cell allografts in patients with type-1 diabetes mellitus by refined peritransplant management. J Mol Med. 1999;77(1):140-3. [pmid: 9930966].
pre-Edmonton
Carlsson P O, Palm F, Mattsson G. Low revascularization of experimentally transplanted human pancreatic islets. J Clin Endocrinol Metab. 2002;87(12):5418-23. [pmid: 12466329].
animal model study
Check E. Diabetes trial stirs debate on safety of xenotransplants. Nature. 2002;419(6902):5. [pmid: 12645536].
xenotransplantation study
Contreras J L, Smyth C A, Bilbao G, et al. 17beta-Estradiol protects isolated human pancreatic islets against proinflammatory cytokine-induced cell death: molecular mechanisms and islet functionality. Transplantation. 2002;74(9):1252-9. [pmid: 12451262].
animal model study
Contreras J L, Smyth C A, Bilbao G, et al. Simvastatin induces activation of the serine-threonine protein kinase AKT and increases survival of isolated human pancreatic islets. Transplantation. 2002;74(8):1063-9. [pmid: 12451262].
animal model study
Cretin N, Caulfield A, Fournier B, et al. Insulin independence and normalization of oral glucose tolerance test after islet cell allotransplantation. Transpl Int. 2001;14(5):343-5. [pmid: 11692219].
pre-Edmonton study
Curran M A, Ochoa M S, Molano R D, et al. Efficient transduction of pancreatic islets by feline immunodeficiency virus vectors1. Transplantation. 2002;74(3):299-306. [pmid: 12177606].
genetics study
Davalli A M, Maffi P, Socci C, et al. Insights from a successful case of intrahepatic islet transplantation into a type 1 diabetic patient. J Clin Endocrinol Metab. 2000;85(10):3847-52. [pmid: 11061548].
pre-Edmonton
Edlund H. Pancreatic organogenesis--developmental mechanisms and implications for therapy. Nat Rev Genet. 2002;3(7):524-32. [pmid: 12094230].
islet regeneration therapy
Efrat S. Cell replacement therapy for type 1 diabetes. Trends Mol Med. 2002;8(7):334-40. [pmid: 12114113].
islet regeneration therapy
Fiorina P, Folli F, Bertuzzi F, et al. Long-term beneficial effect of islet transplantation on diabetic macro- /microangiopathy in type 1 diabetic kidney-transplanted patients. Diabetes Care. 2003;26(4):1129-36. [pmid: 12663585].
pre-Edmonton study
Fraga D W, Sabek O, Hathaway D K, et al. A comparison of media supplement methods for the extended culture of human islet tissue. Transplantation. 1998;65(8):1060-6. [pmid: 9583866].
culture methods; no outcomes
Fraker C A, Alejandro R, Ricordi C. Use of oxygenated perfluorocarbon toward making every pancreas count. Transplantation. 2002;74(12):1811-2. [pmid: 12499906].
review; islet preparation methods
Gores P F, Najarian J S, Stephanian E, et al. Insulin independence in type I diabetes after transplantation of unpurified islets from single donor with 15-deoxyspergualin. Lancet. 1993;341(8836):19-21. [pmid: 8093268].
pre-Edmonton
Hering B J, Matsumoto I, Sawada T, et al. Impact of two-layer pancreas preservation on islet isolation and transplantation. Transplantation. 2002;74(12):1813-6. [pmid: 12499907].
islet preparation methods
Herold K C, Hagopian W, Auger J A, et al. Anti-CD3 monoclonal antibody in new-onset type 1 diabetes mellitus. N Engl J Med. 2002;346(22):1692-8. [pmid: 12037148].
not an original report of clinical outcomes
Hricik D E, Anton H A, Knauss T C, et al. Outcomes of African American kidney transplant recipients treated with sirolimus, tacrolimus, and corticosteroids. Transplantation. 2002;74(2):189-93. [pmid: 12151730].
immunosuppression study
Kaufman D B, Platt J L, Rabe F L, et al. Differential roles of Mac-1+ cells, and CD4+ and CD8+ T lymphocytes in primary nonfunction and classic rejection of islet allografts. J Exp Med. 1990;172(1):291-302. [pmid: 2113565].
animal model study
Kawai T, Sogawa H, Koulmanda M, et al. Long-term islet allograft function in the absence of chronic immunosuppression: a case report of a nonhuman primate previously made tolerant to a renal allograft from the same donor. Transplantation. 2001;72(2):351-4. [pmid: 11477369].
animal model study
Kendall D M, Rooney D P, Smets Y F, et al. Pancreas transplantation restores epinephrine response and symptom recognition during hypoglycemia in patients with long-standing type I diabetes and autonomic neuropathy. Diabetes. 1997;46(2):249-57. [pmid: 9000702].
whole organ transplant study
Kendall D, MacIndoe J, Stegall M, et al. Pancreatic islet transplantation for patients with type 1 diabetes mellitus. ICSI Technology Assessment Report. 2002. Available at: www.icsi.org.
review; not an original report of clinical outcomes
Knight R J, Schanzer H, Guy S, et al. Impact of kidney-pancreas transplantation on the progression of peripheral vascular disease in diabetic patients with end-stage renal disease. Transplant Proc. 1998;30(5):1947-9. [pmid: 9723347].
whole organ transplant
Kuroda Y, Kawamura T, Suzuki Y, et al. A new, simple method for cold storage of the pancreas using perfluorochemical. Transplantation. 1988;46(3):457-60. [pmid: 3051554].
animal model study; islet preparation methods
Lakey J R, Kneteman N M, Rajotte R V, et al. Effect of core pancreas temperature during cadaveric procurement on human islet isolation and functional viability. Transplantation. 2002;73(7):1106-10. [pmid: 12490784].
islet preparation methods
Lakey J R, Tsujimura T, Shapiro A M, et al. Preservation of the human pancreas before islet isolation using a two-layer (UW solution-perfluorochemical) cold storage method. Transplantation. 2002;74(12):1809-11. [pmid: 12499905].
islet preparation methods
Lakey J R, Warnock G L, Rajotte R V, et al. Variables in organ donors that affect the recovery of human islets of Langerhans. Transplantation. 1996;61(7):1047-53. [pmid: 8623183].
islet preparation methods
Lakey J R, Warnock G L, Shapiro A M, et al. Intraductal collagenase delivery into the human pancreas using syringe loading or controlled perfusion. Cell Transplant. 1999;8(3):285-92. [pmid: 10442741].
islet preparation methods
Lakey J R T, Tsujimura T, Shapiro A M J, et al. Human pancreas preservation prior to islet isolation. Cell Preservation Technology. 2002;1(1):81.
islet preparation methods
Lechner A, Habener J F. Stem/progenitor cells derived from adult tissues: potential for the treatment of diabetes mellitus. Am J Physiol Endocrinol Metab. 2003;284(2):E259-66. [pmid: 12531740].
islet regeneration therapy
Linetsky E, Bottino R, Lehmann R, et al. Improved human islet isolation using a new enzyme blend, liberase. Diabetes. 1997;46(7):1120-3. [pmid: 9200645].
islet preparation methods
Malaisse W J. Comment to: Benhamou PY, et al. (2001) Human islet transplantation network for the treatment of Type I diabetes: first data from the Swiss-French GRAGIL consortium (1999-2000). Diabetologia 44: 859–864. Diabetologia. 2001;44(12):2239. [pmid: 11793029].
pre-Edmonton study
Matsumoto S, Kuroda Y. Perfluorocarbon for organ preservation before transplantation. Transplantation. 2002;74(12):1804-9. [pmid: 12499904].
islet preparation methods
Matsumoto S, Qualley S A, Goel S, et al. Effect of the two-layer (University of Wisconsin solution- perfluorochemical plus O2) method of pancreas preservation on human islet isolation, as assessed by the Edmonton Isolation Protocol. Transplantation. 2002;74(10):1414-9. [pmid: 12451242].
islet preparation methods
McAlister V C, Gao Z, Peltekian K, et al. Sirolimus-tacrolimus combination immunosuppression. Lancet. 2000;355(9201):376-7. [pmid: 10665560].
immunosuppression; whole organ transplant study
Meyer C, Hering B J, Grossmann R, et al. Improved glucose counterregulation and autonomic symptoms after intraportal islet transplants alone in patients with long-standing type I diabetes mellitus. Transplantation. 1998;66(2):233-40. [pmid: 9701271].
pre-Edmonton study
Montgomery S P, Xu H, Tadaki D K, et al. Combination induction therapy with monoclonal antibodies specific for CD80, CD86, and CD154 in nonhuman primate renal transplantation. Transplantation. 2002;74(10):1365-9. [pmid: 12451232].
animal model study
Morrison C P, Wemyss-Holden S A, Dennison A R, et al. Islet yield remains a problem in islet autotransplantation. Arch Surg. 2002;137(1):80-3. [pmid: 11772222].
islet preparation methods
Movassat J, Beattie G M, Lopez A D, et al. Exendin 4 up-regulates expression of PDX 1 and hastens differentiation and maturation of human fetal pancreatic cells. J Clin Endocrinol Metab. 2002;87(10):4775-81. [pmid: 12364473].
animal model study
Oberholzer J, Triponez F, Mage R, et al. Human islet transplantation: lessons from 13 autologous and 13 allogeneic transplantations. Transplantation. 2000;69(6):1115-23. [pmid: 10762216].
autologous transplants
Parker D C, Greiner D L, Phillips N E, et al. Survival of mouse pancreatic islet allografts in recipients treated with allogeneic small lymphocytes and antibody to CD40 ligand. Proc Natl Acad Sci U S A. 1995;92(21):9560-4. [pmid: 7568172]. [pmcid: 40841].
animal model study
Pipeleers D, Keymeulen B, Chatenoud L, et al. A view on beta cell transplantation in diabetes. Ann N Y Acad Sci. 2002;958:69-76. [pmid: 12021085].
review; not an original report of clinical outcomes
Preiksaitis J K, Sandhu J, Strautman M. The risk of transfusion-acquired CMV infection in seronegative solid-organ transplant recipients receiving non-WBC-reduced blood components not screened for CMV antibody (1984 to 1996): experience at a single Canadian center. Transfusion. 2002;42(4):396-402. [pmid: 12076284].
whole organ transplants
Recasens M, Ricart M J, Valls-Sole J, et al. Long-term follow-up of diabetic polyneuropathy after simultaneous pancreas and kidney transplantation in type 1 diabetic patients. Transplant Proc. 2002;34(1):200-3. [pmid: 11959247].
whole organ transplants
Reckard C R, Ziegler M M, Barker C F. Physiological and immunological consequences of transplanting isolated pancreatic islets. Surgery. 1973;74(1):91-9. [pmid: 4146046].
animal model study
Ricordi C, Lacy P E, Scharp D W. Automated islet isolation from human pancreas. Diabetes. 1989;38(Suppl 1):140-2. [pmid: 2642838].
islet preparation methods
Ricordi C, Tzakis A G, Carroll P B, et al. Human islet isolation and allotransplantation in 22 consecutive cases. Transplantation. 1992;53(2):407-14. [pmid: 1738936].
pre-Edmonton
Robertson R P, Lanz K J, Sutherland D E, et al. Prevention of diabetes for up to 13 years by autoislet transplantation after pancreatectomy for chronic pancreatitis. Diabetes. 2001;50(1):47-50. [pmid: 11147793].
autologous transplants
Sanchez-Fueyo A, Domenig C, Strom T B, et al. The complement dependent cytotoxicity (CDC) immune effector mechanism contributes to anti-CD154 induced immunosuppression. Transplantation. 2002;74(6):898-900. [pmid: 12364878].
animal model study
Semakula C, Pambuccian S, Gruessner R, et al. Clinical case seminar: hypoglycemia after pancreas transplantation: association with allograft nesidiodysplasia and expression of islet neogenesis-associated peptide. J Clin Endocrinol Metab. 2002;87(8):3548-54. [pmid: 12161473].
whole organ transplant; hypoglycemia
Shalev A, Pise-Masison C A, Radonovich M, et al. Oligonucleotide microarray analysis of intact human pancreatic islets: identification of glucose-responsive genes and a highly regulated TGFbeta signaling pathway. Endocrinology. 2002;143(9):3695-8. [pmid: 12193586].
genetics study
Shapiro J. Eighty years after insulin: parallels with modern islet transplantation. CMAJ. 2002;167(12):1398-400. [pmid: 12473643]. [pmcid: 137363].
review; not an original report of clinical outcomes
Scharp D W, Lacy P E, Santiago J V, et al. Insulin independence after islet transplantation into type I diabetic patient. Diabetes. 1990;39(4):515-8. [pmid: 2108071].
pre-Edmonton
Smith R, Press M. Report of the 20th Workshop of the AIDPIT Study Group (Artificial Insulin Delivery Systems, Pancreas and Islet Transplantation). Diabetologia. 2001;44(11):58-62. [pmid: 11774824].
review; not an original report of clinical outcomes
Socci C, Falqui L, Davalli A M, et al. Fresh human islet transplantation to replace pancreatic endocrine function in type 1 diabetic patients. Report of six cases. Acta Diabetol. 1991;28(2):151-7. [pmid: 1777651].
pre-Edmonton
Stevens R B, Matsumoto S, Marsh C L. Is islet transplantation a realistic therapy for the treatment of type 1 diabetes in the near future?. Clin Diabetes. 2001;19(2):51-60.
review; not an original report of clinical outcomes
Tibell A, Bolinder J, Hagstrom-Toft E, et al. Experience with human islet transplantation in Sweden. Transplant Proc. 2001;33(4):2535-6. [pmid: 11406240].
pre-Edmonton study
Tsujimura T, Kuroda Y, Kin T, et al. Human islet transplantation from pancreases with prolonged cold ischemia using additional preservation by the two-layer (UW solution/perfluorochemical) cold-storage method. Transplantation. 2002;74(12):1687-91. [pmid: 12499881].
islet preparation methods
Valdes Gonzalez R. Xenotransplantation's benefits outweigh risks. Nature. 2002;420(6913):268. [pmid: 12447418].
xenotransplantation study
van Duijnhoven E M, Christiaans M H, Boots J M, et al. A late episode of post-transplant diabetes mellitus during active hepatitis C infection in a renal allograft recipient using tacrolimus. Am J Kidney Dis. 2002;40(1):195-201. [pmid: 12087579].
immunosuppression study
Vu M D, Qi S, Xu D, et al. Tacrolimus (FK506) and sirolimus (rapamycin) in combination are not antagonistic but produce extended graft survival in cardiac transplantation in the rat. Transplantation. 1997;64(12):1853-6. [pmid: 9422432].
animal model study; immunosuppression
Warnock G L, Kneteman N M, Ryan E A, et al. Long-term follow-up after transplantation of insulin-producing pancreatic islets into patients with type 1 (insulin-dependent) diabetes mellitus. Diabetologia. 1992;35(1):89-95. [pmid: 1541386].
pre-Edmonton
White S A, James R F, Swift S M, et al. Human islet cell transplantation--future prospects. Diabet Med. 2001;18(2):78-103. [pmid: 11251671].
review; not an original report of clinical outcomes
White S A, Robertson G S, London N J, et al. Human islet autotransplantation to prevent diabetes after pancreas resection. Dig Surg. 2000;17(5):439-50. [pmid: 11124546].
autologous transplantation
Yamaoka T. Regeneration therapy of pancreatic beta cells: towards a cure for diabetes?. Biochem Biophys Res Commun. 2002;296(5):1039-43. [pmid: 12207876].
islet regeneration therapy