# References and Included Studies

Adams A B, Shirasugi N, Durham M M, et al. Calcineurin inhibitor-free CD28 blockade-based protocol protects allogeneic islets in nonhuman primates. Diabetes. 2002;51:265-70. [pmid: 11812731].
Adang E M, Engel G L, van Hooff J P, et al. Comparison before and after transplantation of pancreas-kidney and pancreas-kidney with loss of pancreas--a prospective controlled quality of life study. Transplantation. 1996;62(6):754-8. [pmid: 8824472].
Alejandro R. New developments in islet isolation technology. City of Hope Rachmiel Levine Symposium; 2002 Oct 9–12; Anaheim, CA.
Alejandro R. Islet transplant immunosuppressive strategies and clinical results. 1st Islet Transplant Congress, November 13–16, 2003a, Miami, FL
Alejandro R, Ferreira JV, Froud T, et al. Insulin independence in 13 patients following transplantation of cultured human islets. American Transplant Congress (ATC) 2003, Washington, DC, Abstract 568.
Alejandro R, Lehmann R, Ricordi C, et al. Long-term function (6 years) of islet allografts in type 1 diabetes. Diabetes. 1997;46:1983-9. [pmid: 9392484].
American Diabetes Association. Pancreas transplantation for patients with type 1 diabetes. Diabetes Care. 2003;26:S120. [pmid: 12502636].
American Diabetes Association. Position statement: Pancreas transplantation for patients with type 1 diabetes. Diabetes Care. 2000;23(1):117. [pmid: 10857980].
American Diabetes Association. Report and recommendations of the San Antonio conference on diabetic neuropathy. Consensus statement. Diabetes. 1988;37:1000-4. [pmid: 3290003].
American Diabetes Association. Standards of Medical Care for Patients with Diabetes Mellitus. Diabetes Care. 2003;26:S33-S50. [pmid: 12502618].
Annenberg Second Annual Symposium: Islet Transplantation 2002 and Beyond. December 5–7, Rancho Mirage, CA.
Ault A. Edmonton's islet success tough to duplicate elsewhere. Lancet. 2003;361:2054. [pmid: 14594002].
Baidal DA, Froud T, Ferreira JV, et al. Evaluation of islet allograft function in type 1 DM patients following intrahepatic islet cell transplantation. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 015.
Baidal D A, Froud T, Ferreira J V, et al. The bag method for islet cell infusion. Cell Transplant. 2003;12:809-813. [pmid: 14653627].
Ballinger W F, Lacy P E. Transplantation of intact pancreatic islets in rats. Surgery. 1972;72:175-86. [pmid: 4262169].
BCBSA Technology Evaluation Center. Use of intermittent or continuous interstitial fluid glucose monitoring in patients with diabetes mellitus. TEC Assessments 2002; 17(2):1–43. Available online at: http://bcbs.com/tec/vol17/17_02.pdf.
Becker B N, Brazy P C, Becker Y T. Simultaneous pancreas-kidney transplantation reduces excess mortality in type 1 diabetic patients with end-stage renal disease. Kidney Int. 2000;57(5):2129-35. [pmid: 10792634].
Berney T, Bucher P, Kessler L, et al. Islet after kidney (IAK) transplantation in patients with type 1 diabetes using a novel immunosuppression protocol: preliminary results of the GRAGIL 1B multicenter trial. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 013.
Berney T, Bucher P, Mathe Z, et al. Successful application of the Edmonton protocol to solitary islet transplant (SIT), islet after kidney (IAK) and simultaneous islet-kidney (SIK) transplantation at the University of Geneva. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003a, Dublin, Ireland, Abstract 014.
Berney T, Bucher P, Mathe Z, et al. Islet of Langerhans allogeneic transplantation at the University of Geneva in the steroid-free era. American Transplant Congress (ATC) 2003b, Washington, DC, Abstract 401.
Bertuzzi F, Grohovaz F, Maffi P, et al. Successful [correction of Succesful] transplantation of human islets in recipients bearing a kidney graft. Diabetologia. 2002;45(1):77-84. [pmid: 11845226].
Birkeland S A, Beck-Nielsen H, Rohr N, et al. Steroid-free immunosuppression in kidney-islet transplantation: a long-term follow-up. Transplantation. 2002;73(9):1527. [pmid: 12023637].
Bolli G B. Hypoglycaemia unawareness. Diabetes Metab. 1997;23:29-35. [pmid: 9342540].
Brandhorst H, Brandhorst D, Hesse F, et al. Successful human islet isolation utilizing recombinant collagenase. Diabetes. 2003;52(5):1143-6. [pmid: 12716744].
Brendel MD, Hering BJ, Schultz AO, et al. International Islet Transplant Registry update of worldwide human islet transplantations. 19th International Congress of the Transplantation Society 2002 August 25–30; Miami, FL.
Bretzel R G, Brandhorst D, Brandhorst H, et al. Improved survival of intraportal pancreatic islet cell allografts in patients with type-1 diabetes mellitus by refined peritransplant management. J Mol Med. 1999;77:140-3. [pmid: 9930966].
Bunnapradist S, Cho Y W, Cecka J M, et al. Kidney allograft and patient survival in type I diabetic recipients of cadaveric kidney alone versus simultaneous pancreas kidney transplants: a multivariate analysis of the UNOS database. J Am Soc Nephrol. 2003;14(1):208-13. [pmid: 12506153].
Cagliero E. Islet transplant immunosuppressive strategies and clinical results. 1st Islet Transplant Congress, November 13–16, 2003a, Miami, FL
Campbell S. American Diabetes Association islet cell replacement initiative. City of Hope Rachmiel Levine Symposium; 2002 Oct 9–12; Anaheim, CA.
Casey J J, Lakey J R, Ryan E A, et al. Portal venous pressure changes after sequential clinical islet transplantation. Transplantation. 2002;74(7):913-5. [pmid: 12394830].
Cecka JM. The UNOS Scientific Renal Transplant Registry. Clin Transpl 1996; 1–14.
Centers for Disease Control and Prevention. National diabetes fact sheet: general information and national estimates on diabetes in the United States, 2002. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, 2003. Available online at http://www.cdc.gov/diabetes/pubs/factsheet.htm
Chow V C, Pai R P, Chapman J R, et al. Diabetic retinopathy after combined kidney-pancreas transplantation. Clin Transplant. 1999;13(4):356-62. [pmid: 10485379].
Cox D J, Irvine A, Gonder-Frederick L, et al. Fear of hypoglycemia: quantification, validation, and utilization. Diabetes Care. 1987;10(5):617-21. [pmid: 3677982].
Cretin N, Caulfield A, Fournier B, et al. Insulin independence and normalization of oral glucose tolerance test after islet cell allotransplantation. Transpl Int. 2001;14:343-5. [pmid: 11692219].
Davalli A M, Maffi P, Socci C, et al. Insights from a successful case of intrahepatic islet transplantation into a type 1 diabetic patient. J Clin Endocrinol Metab. 2000;85:3847-52. [pmid: 11061548].
Davalli A M, Ogawa Y, Ricordi C, et al. A selective decrease in the beta cell mass of human islets transplanted into diabetic nude mice. Transplantation. 1995;59(6):817-20. [pmid: 7701574].
de Vos P, Hamel A F, Tatarkiewicz K. Considerations for successful transplantation of encapsulated pancreatic islets. Diabetologia. 2002;45:159-73. [pmid: 11935147].
Elliott M D, Kapoor A, Parker M A, et al. Improvement in hypertension in patients with diabetes mellitus after kidney/pancreas transplantation. Circulation. 2001;104:563-9. [pmid: 11479254].
Fanelli C G, Epifano L, Rambotti A M, et al. Meticulous prevention of hypoglycemia normalizes the glycemic thresholds and magnitude of most of neuroendocrine responses to, symptoms of, and cognitive function during hypoglycemia in intensively treated patients with short-term IDDM. Diabetes. 1993;42:1683-9. [pmid: 8405713].
Fernandez L A, Lehmann R, Luzi L, et al. The effects of maintenance doses of FK506 versus cyclosporin A on glucose and lipid metabolism after orthotopic liver transplantation. Transplantation. 1999;68(10):1532-41. [pmid: 10589951].
Fioretto P, Mauer S M, Bilous R W, et al. Effects of pancreas transplantation on glomerular structure in insulin-dependent diabetic patients with their own kidneys. Lancet. 1993;342:1193-6. [pmid: 7901527].
Fioretto P, Steffes M W, Sutherland D E R, et al. Reversal of lesions of diabetic nephropathy after pancreas transplantation. N Engl J Med. 1998;339:69-75. [pmid: 9654536].
Fiorina P, Folli F, Maffi P, et al. Islet transplantation improves vascular diabetic complications in patients with diabetes who underwent kidney transplantation: a comparison between kidney-pancreas and kidney-alone transplantation. Transplantation. 2003;75:1296-1301. [pmid: 12717219].
Fraga D W, Sabek O, Hathaway D K, et al. A comparison of media supplement methods for the extended culture of human islet tissue. Transplantation. 1998;65:1060-6. [pmid: 9583866].
Fraker C A, Alejandro R, Ricordi C. Use of oxygenated perfluorocarbon toward making every pancreas count. Transplantation. 2002;74:1811-2. [pmid: 12499906].
Freise CE, Kang SM, Feng S, et al. Excellent results with steroid free maintenance immunosuppression in simultaneous pancreas-kidney transplantation. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 049.
Froud T, Ferreira J, Hafiz M, et al. Islet after kidney transplantation revisited. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 61.
Froud T, Yrizarry JM, Alejandro R, et al. Use of D-STAT™ to prevent bleeding following percutaneous transhepatic intraportal islet transplantation. Cell Transplant (In press).
Furlong W J, Geeny D H, Torrance G W, et al. The Health Utilities Index (HUI) system for assessing health-related quality of life in clinical studies. Ann Med. 2001;33:375-84. [pmid: 11491197].
Gaber A O, Fraga D W, Callicutt C S, et al. Improved in vivo pancreatic islet function after prolonged in vitro islet culture. Transplantation. 2001;72:1730-6. [pmid: 11740381].
Geiger MC, Caulfield A, Froud JV, et al. Is there a role for infliximab in islet cell transplantation trials? American Transplant Congress; 2002 Apr 25-May 1; Washington DC.
Goral S, Helderman J H. The evolution and future of immunosuppression in renal transplantation. Semin Nephrol. 1997;17(4):364-72. [pmid: 9241720].
Gores P F, Najarian J S, Stephanian E, et al. Insulin independence in type I diabetes after transplantation of unpurified islets from single donor with 15-deoxyspergualin. Lancet. 1993;341(8836):19-21. [pmid: 8093268].
Goss JA, Brunicardi FC, Feliciano S, et al. Achievement of insulin independence via pancreatic islet transplantation using a remote islet isolation center: A first year review. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 011.
Goss J A, Schock A P, Brunicardi F C, et al. Achievement of insulin independence in three consecutive type-1 diabetic patients via pancreatic islet transplantation using islets isolated at a remote islet isolation center. Transplantation. 2002;74(12):1761-6. [pmid: 12499894].
Goss J A, Soltes G, Goodpastor S E, et al. Pancreatic islet transplantation: the radiographic approach. Transplantation. 2003;76(1):199-203. [pmid: 12865810].
Gruessner R W. Tac in pancreas transplantation: a multicenter analysis. Clin Transplant. 1997;11:299-312. [pmid: 9267719].
Gruessner AC, Sutherland DE. Analysis of United States (US) and non-US pancreas transplants as reported to the International Pancreas Transplant Registry (IPTR) and to the United Network for Organ Sharing (UNOS). Clin Transplant 1998; 53–73.
Gruessner AC, Sutherland DE. Pancreas transplant outcomes for United States (US) and non-US cases as reported to the United Network for Organ Sharing (UNOS) and the International Pancreas Transplant Registry (IPTR) as of October 2002. Clin Transplant 2002; :41–77.
Hafiz M, Froud T, Ferreira J, et al. Improvement in islet graft function following removal of tacrolimus from the immunosuppressive regimen in a single islet transplant recipient. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 060.
Harris MI. Diabetes in America, 2nd ed, National Diabetes Data Group, National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. 1995. NIH Publication No. 95–1468. Summary.
Hathaway D K, Hartwig M S, Milstead J, et al. Improvement in quality of life reported by diabetic recipients of kidney-only and pancreas-kidney allografts. Transplant Proc. 1994;26(2):512-4. [pmid: 8171530].
Hering B J, Bretzel R G, Hopt U T, et al. New protocol toward prevention of early human islet allograft failure. Transplant Proc. 1994;26(2):570-1. [pmid: 7998202].
Hering BJ, Kandaswamy R, Ansite JD, et al. Successful single donor islet transplantation in type 1 diabetes. American Transplant Congress (ATC) 2003, Washington, DC, Abstract 567.
Hering BJ, Kandaswamy R, Harmon JV, et al. Transplantation of cultured islets from two-layer preserved pancreases in Type 1 diabetes with anti-Cd3 antibody. Am J Transplant 2004 (In press).
Hering BJ, Kandaswamy R, Parkey J, et al. Graft survival analysis in 20 Type 1 diabetic islet allograft recipients. American Transplant Congress, May 14–19, 2004, Boston, MA. Submitted.
Hering B J, Matsumoto I, Sawada T, et al. Impact of two-layer pancreas preservation on islet isolation and transplantation. Transplantation. 2002;74(12):1813-6. [pmid: 12499907].
Hering BJ. Update on ITN trial and new developments in immunosuppressive regimens for islet transplantation. City of Hope Rachmiel Levine Symposium; 2002 Oct 9–12; Anaheim, CA.
Herold K C, Hagopian W, Auger J A, et al. Anti-CD3 monoclonal antibody in new-onset type 1 diabetes mellitus. N Engl J Med. 2002;346:1692-8. [pmid: 12037148].
Hirshberg B, Rother K I, Digon B J 3rd, et al. Benefits and risks of solitary islet transplantation for type 1 diabetes using steroid-sparing immunosuppression: the National Institutes of Health experience. Diabetes Care. 2003;26(12):3288-95. [pmid: 14633816].
Holohan TV. Simultaneous pancreas-kidney and sequential pancreas-after-kidney transplantation. Health Technol Assess (Rockv) 1995; (4):1–53.
Hricik D E, Phinney M S, Weigel K A, et al. Long-term renal function in Type I diabetics after kidney or kidney-pancreas transplantation. Transplantation. 1997;64(9):1283-8. [pmid: 9371669].
Immune Tolerance Network Clinical Trial Research Summary. Multicenter trial of solitary islet transplantation in type 1 diabetic patients using the Edmonton protocol of steroid-free immunosuppression. Available at: http://www.immunetolerance.org/research/islet/trials/shapiro1.html. Last accessed November 2003.
International Islet Transplant Registry (ITR). ITR Newsletter 2001; 8(1):1–20.
International Pancreas Transplant Registry (IPTR). 2003 Midyear Update. http://www.iptr.umn.edu/ar_midyear2003/03_midyear_update_index.htm. Accessed Dec 9 2003.
Jindal R M, Sidner R A, Milgrom M L. Post-transplant diabetes mellitus. The role of immunosuppression. Drug Safety. 1997;16(4):242-57. [pmid: 9113492].
Johnson JA, Kotovych M, Ryan EA, et al. Reduced fear of hypoglycemia in successful islet transplantation. Diabetes Care [Letter](In press).
Johnson JA. Self-reported health quality of life in islet transplant recipients. Islet Transplantation 2002 and Beyond: 2nd Annual Symposium; 2002 Dec 5–7; Rancho Mirage, CA.
Jordan M L, Chakrabarti P, Luke P, et al. Results of pancreas transplantation after steroid withdrawal under Tac immunosuppression. Transplantation. 2000;69(2):265-71. [pmid: 10670637].
Jordan M L, Shapiro R, Gritsch H A, et al. Long-term results of pancreas transplantation under Tac immunosuppression. Transplantation. 1999;67(2):266-72. [pmid: 10232574].
Kandaswamy R, Asolati M, Gruessner A, et al. A prospective, randomized trial of steroid free maintenance vs. delayed steroid withdrawal using a sirolimus-tacrolimus regimen in simultaneous pancreas-kidney transplants (SPK). 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 051..
Kaufman D B, Baker M S, Chen X, et al. Sequential kidney/islet transplantation using prednisone-free immunosuppression. Am J Transplant. 2002;2(7):674-7. [pmid: 12201371].
Kaufman DB, Leventhal JR, Gallon LG, et al. Pancreas transplantation in the prednisone-free era. American Transplant Congress (ATC) 2003, Washington, DC, Abstract 665.
Kawai T, Sogawa H, Koulmanda M, et al. Long-term islet allograft function in the absence of chronic immunosuppression: a case report of a nonhuman primate previously made tolerant to a renal allograft from the same donor. Transplantation. 2001;72:351-4. [pmid: 11477369].
Kendall D M, Rooney D P, Smets Y F C, et al. Pancreas transplantation restores epinephrine response and symptom recognition during hypoglycemia in patients with long-standing type I diabetes and autonomic neuropathy. Diabetes. 1997;46:249-57. [pmid: 9000702].
Kiebert G M, van Oosterhout E C, van Bronswijk H, et al. Quality of life after combined kidney-pancreas or kidney transplantation in diabetic patients with end-stage renal disease. Clin Transplant. 1994;8(3):239-45. [pmid: 8061362].
Knight R J, Schanzer H, Guy S, et al. Impact of kidney-pancreas transplantation on the progression of peripheral vascular disease in diabetic patients with end-stage renal disease. Transplant Proc. 1998;30(5):1947-9. [pmid: 9723347].
Koznarova R, Saudek F, Sosna T, et al. Beneficial effect of pancreas and kidney transplantation on advanced diabetic retinopathy. Cell Transplant. 2000;9(6):903-8. [pmid: 11202576].
La Rocca E, Fiorina P, Astorri E. Patient survival and cardiovascular events after kidney-pancreas transplantation: comparison with kidney transplantation alone in uremic IDDM patients. Cell Transplant. 2000;9(6):929-32. [pmid: 11202580].
Lakey J R, Kneteman N M, Rajotte R V, et al. Effect of core pancreas temperature during cadaveric procurement on human islet isolation and functional viability. Transplantation. 2002;73:1106-10. [pmid: 12490784].
LaPorte RE, Matsushima M, Chang YF. Diabetes in America, 2nd ed. National Diabetes Data Group, National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. NIH Publication No. 95–1468. 1995. Prevalence and incidence of insulin-dependent diabetes.
Larsen CP. JDRF Center for Islet Transplantation at Emory University. 1st Islet Transplant Congress, November 13–16, 2003, Miami, FL.
Larsen J L, Stratta R J. Pancreas transplantation: A treatment option for insulin-dependent diabetes mellitus. Diabetes Metab. 1996;22(2):139-46. [pmid: 8792094].
Lederer E. Pancreas transplants for diabetic nephropathy: a time for reassessment. Am J Kidney Dis. 2000;35(6):1238-41. [pmid: 10845842].
Lehmann R, Weber M, Zuellig R, et al. Islet graft and kidney function in combined islet-kidney transplantation under a glucocorticoid-free immunosuppression (Edmonton protocol). 63rd Scientific Sessions of the American Diabetes Association (ADA), June 13–17 2003, New Orleans, Abstract 285-OR.
Linetsky E, Bottino R, Lehmann R, et al. Improved human islet isolation using a new enzyme blend, liberase. Diabetes. 1997;46:1120-3. [pmid: 9200645].
Lumelsky N, Blondel O, Laeng P, et al. Differentiation of embryonic stem cells to insulin-secreting structures similar to pancreatic islets. Science. 2001;292:1389-94. [pmid: 11326082].
Maffi P, Bertuzzi F, De Taddeo F, et al. Islet transplantation alone: A review of ten cases. 9th Congress of the International Pancreas and Islet Transplant Association. 8–11 July 2003, Dublin, Ireland, Abstract 063.
Markmann J F, Deng S, Desai N M, et al. The use of non-heart-beating donors for isolated pancreatic islet transplantation. Transplantation. 2003;75(9):1423-9. [pmid: 14702535].
Markmann J F, Deng S, Huang X, et al. Insulin independence following isolated islet transplantation and single islet infusions. Ann Surg. 2003;237(6):741-9. [pmid: 12796569]. [pmcid: 1514687].
Markmann JF, Deng S, Huang X, et al. Reversal of diabetes using islets procured from a single non-heart beating donor. 62nd Scientific Sessions of the American Diabetes Association; 2000 June 14–18; San Francisco.
Markmann J F, Rosen M, Siegelman E S, et al. Magnetic resonance-defined periportal steatosis following intraportal islet transplantation: a functional footprint of islet graft survival?. Diabetes. 2003;52(7):1591-4. [pmid: 12829620].
Matsumoto S, Kandaswamy R, Sutherland D E, et al. Clinical application of the two-layer (University of Wisconsin solution/perfluorochemical plus O2) method of pancreas preservation before transplantation. Transplantation. 2000;70(5):771-4. [pmid: 11003355].
Matsumoto S, Kuroda Y. Perfluorocarbon for organ preservation before transplantation. Transplantation. 2002;74:1804-9. [pmid: 12499904].
McAlister V C, Gao Z, Peltekian K, et al. Sirolimus-tacrolimus combination immunosuppression. Lancet. 2000;355:376-7. [pmid: 10665560].
Meyer C, Hering B J, Grosmann R, et al. Improved glucose counterregulation and autonomic symptoms after intraportal islet transplants alone in patients with long-standing type I diabetes mellitus. Transplantation. 1998;66:233-40. [pmid: 9701271].
Morrison C P, Wemyss-Holden S A, Dennison A R, et al. Islet yield remains a problem in islet autotransplantation. Arch Surg. 2002;137:80-3. [pmid: 11772222].
Morrissey P E, Shaffer D, Madras P N, et al. Progression of peripheral vascular disease after combined kidney-pancreas transplantation in diabetic patients with end-stage renal failure. Transplant Proc. 1997;29(12):662-3. [pmid: 9123467].
Meyer C, Hering B J, Grossmann R, et al. Improved glucose counterregulation and autonomic symptoms after intraportal islet transplants alone in patients with long-standing type I diabetes mellitus. Transplantation. 1998;66(2):233-40. [pmid: 9701271].
Najarian J S. Islet cell transplantation in treatment of diabetes. Hosp Pract. 1977;12:63-9. [pmid: 409659].
Najarian J S, Kaufman D B, Fryd D S, et al. Long-term survival following kidney transplantation in 100 type I diabetic patients. Transplantation. 1989;47:106-13. [pmid: 2643219].
Najarian J S, Sutherland D E, Baumgartner D, et al. Total or near total pancreatectomy and islet autotransplantation for treatment of chronic pancreatitis. Ann Surg. 1980;192(4):526-42. [pmid: 6775603]. [pmcid: 1347000].
Nakache R, Merhav H, Klausner J M. Peripheral vascular disease in pancreas allograft recipients. Transplant Proc. 1999;31(4):1889. [pmid: 10371986].
Nakache R, Tyden G, Groth C G. Long-term quality of life in diabetic patients after combined pancreas-kidney transplantation or kidney transplantation. Transplant Proc. 1994;26(2):510-1. [pmid: 8171529].
Nathan D M, Lachin J, Cleary P, et al. for the Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications (DCCT/EDIC) Research Group. Intensive Diabetes Therapy and Carotid Intima-Media Thickness in Type 1 Diabetes Mellitus. N Engl J Med. 2003;348:2294-303. [pmid: 12788993].
Navarro X, Kennedy W R, Loewenson R B, et al. Influence of pancreas transplantation on cardiorespiratory reflexes, nerve conduction, and mortality in diabetes mellitus. Diabetes. 1990;39:802-6. [pmid: 2354747].
Navarro X, Sutherland D E R, Kennedy W R. Long-term effects of pancreatic transplantation on diabetic neuropathy. Ann Neurol. 1997;42:727-36. [pmid: 9392572].
Nishimura R, LaPorte R E, Dorman J S, et al. Mortality trends in type 1 diabetes. The Allegheny County (Pennsylvania) Registry 1965-1999. Diabetes Care. 2001;24(5):823-7. [pmid: 11347737].
Office of Legislative Policy and Analysis. Legislative updates: 108th Congress. Pending Legislation: Pancreatic Islet Cell Transplantation Act of 2003; H.R. 1068, S. 518, S. Amendment 1023 to S. 1. 2003. Available online at: http://olpa.od.nih.gov/legislation/108/pendinglegislation/pancreatic.asp
Ojo A O, Meier-Kriesche H U, Hanson J A, et al. The impact of simultaneous pancreas-kidney transplantation on long-term patient survival. Transplantation. 2001;71:82-90. [pmid: 11477346].
Organ Procurement and Transplantation Network. Available online at http://www.optn.org/latestData/viewDataReports.asp. Last accessed July 6, 2003.
Organ Procurement and Transplantation Network/United Network for Organ Sharing Kidney and Pancreas Transplantation Committee. Analysis of pancreas disposition and transplantation by region, donor age, donor BMI, and share type, 2000-2002. Prepared for Kidney and Pancreas Transplantation Committee meeting May 15, 2003. Report provided by Dr. Bernhard Hering, December 19, 2003.
Owen R J, Ryan E A, O'Kelly K, et al. Percutaneous transhepatic pancreatic islet cell transplantation in type 1 diabetes mellitus: radiologic aspects. Radiology. 2003;229(1):165-70. [pmid: 12944593].
Panaro F, Testa G, Bogetti D, et al. Auto-islet transplantation after pancreatectomy. Expert Opin Biol Ther. 2003;3(2):207-14. [pmid: 12662136].
Papalois B E, Troppmann C, Gruessner A C, et al. Long-term peritoneal dialysis before transplantation and intra-abdominal infection after simultaneous pancreas-kidney transplantations. Arch Surg. 1996;131(7):761-6. [pmid: 8678779].
Parker D C, Greiner D L, Phillips N E, et al. Survival of mouse pancreatic islet allografts in recipients treated with allogeneic small lymphocytes and antibody to CD40 ligand. Proc Natl Acad Sci USA. 1995;92:9560-4. [pmid: 7568172]. [pmcid: 40841].
Paty B W, Lanz K, Kendall D M, et al. Restored hypoglycemic counterregulation is stable in successful pancreas transplant recipients for up to 19 years after transplantation. Transplantation. 2001;72(6):1103-7. [pmid: 11579308].
Paty B W, Ryan E A, Shapiro A M, et al. Intrahepatic islet transplantation in type 1 diabetic patients does not restore hypoglycemic hormonal counterregulation or symptom recognition after insulin independence. Diabetes. 2002;51(12):3428-34. [pmid: 12453896].
Pelletier R P, Hennessy P K, Adams P W, et al. High incidence of donor-reactive delayed-type hypersensitivity reactivity in transplant patients. Am J Transplant. 2002;2(10):926-33. [pmid: 12482144].
Peripheral Neuropathy Association. Quantitative sensory testing: a consensus report from the Peripheral Neuropathy Association. Neurology. 1993;43:1050-2. [pmid: 8388089].
Piehlmeier W, Bullinger M, Kirchberger I, et al. Prospective study of the quality of life in Type I diabetic patients before and after organ transplantation. Transplant Proc. 1994;26(2):522-3. [pmid: 8171535].
Portuese E, Orchard T. Diabetes in America, 2nd ed. National Diabetes Data Group, National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. NIH Publication No. 95–1468. 1995. Mortality in insulin-dependent diabetes.
Preiksaitis JK, Lakey JR, LeBlanc BA, et al. Cytomegalovirus (CMV) is not transmitted by pancreatic islet transplantation. American Transplant Congress 2002. April 25-May 1, Washington DC.
Recasens M, Ricart M J, Valls-Sole J, et al. Long-term follow-up of diabetic polyneuropathy after simultaneous pancreas and kidney transplantation in type 1 diabetic patients. Transplant Proc. 2002;34(1):200-3. [pmid: 11959247].
Reddy K S, Stablein D, Taranto S, et al. Long-term survival following simultaneous kidney-pancreas transplantation versus kidney transplantation alone in patients with type 1 diabetes mellitus and renal failure. Am J Kidney Dis. 2003;41(2):464-70. [pmid: 12552511].
Renard E. Implantable closed-loop glucose-sensing and insulin delivery: the future for insulin pump therapy. Curr Opin Pharmacol. 2002;2(6):708-16. [pmid: 12482735].
Renard E, Shah R, Miller M, et al. Sustained safety and accuracy of central IV glucose sensors connected to implanted insulin pumps and short-term closed-loop trials in diabetic patients. Abstract 155-OR. American Diabetes Association 63rd Scientific Sessions; 2003 Jun 13–17; New Orleans, LA.
Ricordi C, Fraker C, Szust J, et al. Improved human islet isolation outcome from marginal donors following addition of oxygenated perfluorocarbon to the cold-storage solution. Transplantation. 2003;75(9):1524-7. [pmid: 12792508].
Ricordi C, Fraker J, Szust IH, et al. Successful human islet transplantation from marginal donors. XIX International Congress of the Transplantation Society; 2002 Aug 25–30; Miami, FL.
Ricordi C, Lacy P E, Finke E H, et al. Automated method for isolation of human pancreatic islets. Diabetes. 1988;37:413-20. [pmid: 3288530].
Ricordi C, Tzakis A G, Carroll P B, et al. Human islet isolation and allotransplantation in 22 consecutive cases. Transplantation. 1992;53:407-14. [pmid: 1738936].
Riddell SR. Transplantation-related malignancies. In: Cancer: Principles and Practice of Oncology (6th ed), VT DeVita, Jr, S Hellman SA Rosenberg, eds. Lippincott Williams & Wilkins: Philadelphia, 2001, pp. 2597–2608.
Robertson RP. Multi-center update on recent islet transplantation results. Islet Transplantation 2002 and Beyond: 2^nd^ Annual Symposium; 2002 Dec 5–7; Rancho Mirage, CA.
Robertson R P. Prevention of recurrent hypoglycemia in type 1 diabetes by pancreas transplantation. Acta Diabetol. 1999;36:3-9. [pmid: 10436246].
Robertson R P, Holohan T V, Genuth S. Pancreas transplantation for type I diabetes. J Clin Endocrinol Metab. 1998;83(6):1868-74. [pmid: 9626111].
Robertson R P, Lanz K J, Sutherland D E, et al. Prevention of diabetes for up to 13 years by autoislet transplantation after pancreatectomy for chronic pancreatitis. Diabetes. 2001;50(1):47-50. [pmid: 11147793].
Robertson R P, Sutherland D E, Kendall D M, et al. Metabolic characterization of long-term successful pancreas transplants in Type I diabetes. J Invest Med. 1996;44(9):549-55.
Ryan E A, Lakey J R, Paty B W, et al. Successful islet transplantation: Continued insulin reserve provides long-term glycemic control. Diabetes. 2002;51(7):2148-57. [pmid: 12453896].
Ryan E A, Lakey J R, Rajotte R V, et al. Clinical outcomes and insulin secretion after islet transplantation with the Edmonton protocol. Diabetes. 2001;50(4):710-9. [pmid: 11289033].
Ryan EA, Shandro T, Vantyghem MC, et al. Assessing severity of hypoglycemia and glycemic lability pre and post islet transplant. 63rd Scientific Sessions of the American Diabetes Association (ADA), June 13–17 2003, New Orleans, Abstract 288-OR.
Sacks DB. Tietz Textbook of Clinical Chemistry. 3rdd, Philadelphia: WB Saunders Company; 1999. Chapter 24, Carbohydrates.
Scharp D W, Lacy P E, Santiago J V, et al. Insulin independence after islet transplantation into type I diabetic patient. Diabetes. 1990;39:515-8. [pmid: 2108071].
Secchi A, Taglietti M V, Socci C, et al. Insulin secretory patterns and blood glucose homeostasis after islet allotransplantation in IDDM patients: comparison with segmental- or whole-pancreas transplanted patients through a long term longitudinal study. J Mol Med. 1999;77(1):133-9. [pmid: 9930948].
Shapiro AM. Long-term clinical outcomes: the Edmonton experience. Islet Transplantation 2002 and Beyond: 2nd Annual Symposium; 2002 Dec 5–7; Rancho Mirage, CA.
Shapiro AM. State-of-the-art in clinical islet transplantation. 1st Islet Transplant Congress, November 13–16, 2003, Miami, FL.
Shapiro A M, Gallant H, Hao E, et al. Portal vein immunosuppressant levels and islet graft toxicity. Transplant Proc. 1998;30(2):641. [pmid: 9532212].
Shapiro J, Hering B, Ricordi C, et al. International multicenter trial of islet transplantation using the Edmonton protocol in patients with type 1 diabetes. American Transplant Congress (ATC) 2003, Washington, DC, Abstract 3.
Shapiro J, Lakey J, Paty B, et al. Clinical islet transplantation in Edmonton - 3-year outcomes and new developments. 63rd Scientific Sessions of the American Diabetes Association (ADA), June 13–17 2003, New Orleans, Abstract 284-OR.
Shapiro A M, Ricordi C, Hering B. Edmonton's islet success has indeed been replicated elsewhere [Letter]. Lancet. 2003;362(9391):1242. [pmid: 14568760].
Shapiro A M, Lakey J R T, Ryan E A, et al. Islet transplantation in seven patients with type 1 diabetes mellitus using a glucocorticoid-free immunosuppressive regimen. New Engl J Med. 2000;343(4):230-8. [pmid: 10911004].
Sharp D. Islet encapsulation and immune isolation technologies. City of Hope Rachmiel Levine Symposium; 2002 Oct 9–12; Anaheim, CA.
Shen K, Qin X, Xiao H, et al. Mature insulin production by engineered non-beta cells. Chin Med J (Engl). 2002;115:532-5. [pmid: 12133291].
Smets Y F C, Westendorp F G J, van der Pijl J W, et al. Effect of simultaneous pancreas-kidney transplantation on mortality of patients with type-1 diabetes mellitus and end-stage renal failure. Lancet. 1999;353:1915-9. [pmid: 10371569].
Steinman T I, Becker B N, Frost A E, et al. Guidelines for the referral and management of patients eligible for solid organ transplantation. Transplantation. 2001;71(9):1189-1204. [pmid: 11397947].
Stratta R J. Review of immunosuppressive usage in pancreas transplantation. Clin Transplant. 1999;13:1-12. [pmid: 10617235].
Stratta R J, Shokouh-Amiri M H, Egidi M F, et al. Long-term experience with simultaneous kidney-pancreas transplantation with portal-enteric drainage and tacrolimus/mycophenolate mofetil-based immunosuppression. Clin Transplant. 2003;17(Suppl 9):69-77. [pmid: 12795673].
Stratta R J, Taylor R J, Sindhi R, et al. Analysis of early readmissions after combined pancreas-kidney transplantation. Am J Kidney Dis. 1996;28(6):867-77. [pmid: 8957039].
Stratta R J, Weide L G, Sindhi R, et al. Solitary pancreas transplantation: Experience with 62 consecutive cases. Diabetes Care. 1997;20:362-8. [pmid: 9051388].
Sutherland D E. Present status of pancreas transplantation alone in nonuremic diabetic patients. Transplant Proc. 1994;26(2):379-83. [pmid: 7998258].
Sutherland D E, Goetz F C, Sibley R K. Recurrence of disease in pancreas transplants. Diabetes. 1989;38(Suppl 1):85-7. [pmid: 2642862].
Sutherland D E, Gruessner R W, Dunn D L, et al. Lessons learned from more than 1,000 pancreas transplants at a single institution. Ann Surg. 2001;233(4):463-501. [pmid: 11505060]. [pmcid: 1421277].
Terada I, Hyde C. The SF-36: an instrument for measuring quality of life in ESRD patients. EDTNA ERCA J 2002; 28(2):73–6, 83.
The Diabetes Control and Complications Trial Research Group. The effect of intensive treatment of diabetes on the development and progression of long term complications in insulin-dependent diabetes mellitus. N Engl J Med. 1993;329:977-86. [pmid: 8366922].
Tyden G, Bolinder J, Solders G. Improved survival in patients with insulin-dependent diabetes mellitus and end-stage diabetic nephropathy 10 years after combined pancreas and kidney transplantation. Transplantation. 1999;67(5):645-8. [pmid: 10096516].
Tyden G, Reinholt F P, Sundkvist G, et al. Recurrence of autoimmune diabetes mellitus in recipients of cadaveric pancreatic grafts. N Engl J Med. 1996;335(12):860-3. [pmid: 8778604].
U.S. Food and Drug Administration. October 9–10, 2003 Biological Response Modifiers Advisory Committee meeting notice, draft agenda, draft questions, briefing information, slides, and transcripts. Available at http://www.fda.gov/ohrms/dockets/ac/cber03.html#BiologicalResponseModifiers. Last accessed November 2003.
Valdes-Gonzalez RA, Elliot RB, Dorantes LM, et al. Porcine islet xenografts can survive and function in type 1 diabetic patients in the presence of both pre-existing and elicited anti-pig antibodies. XIX International Congress of the Transplantation Society; 2002 Aug 25–30; Miami, FL.
Venstrom J M, McBride M A, Rother K I, et al. Survival after pancreas transplantation in patients with diabetes and preserved kidney function. JAMA. 2003;290(2):2817-23. [pmid: 14657065].
Vu M D, Qi S, Xu D, et al. Synergistic effects of mycophenolate mofetil and sirolimus in prevention of acute heart, pancreas, and kidney allograft rejection and in reversal of ongoing heart allograft rejection in the rat. Transplantation. 1998;66:1575-80. [pmid: 9884242].
Vu M D, Qi S, Xu D, et al. Tacrolimus (FK506) and sirolimus (rapamycin) in combination are not antagonistic but produce extended graft survival in cardiac transplantation in the rat. Transplantation. 1997;64:1853-6. [pmid: 9422432].
Wahoff D C, Papalois B E, Najarian J S, et al. Autologous islet transplantation to prevent diabetes after pancreatic resection. Ann Surg. 1995;222(4):562-75. [pmid: 7574935]. [pmcid: 1234892].
Wagner K, Herget S, Heemann U. Experimental and clinical experience with the use of Tac (FK506) in kidney transplantation. Clin Nephrol. 1996;45(5):332-5. [pmid: 8738671].
Ware J E Jr, Sherbourne C D. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30:473-83. [pmid: 1593914].
Warnock G L, Kneteman N M, Ryan E A, et al. Long-term follow-up after transplantation of insulin-producing pancreatic islets into patients with type 1 (insulin-dependent) diabetes mellitus. Diabetologia. 1992;35:89-95. [pmid: 1541386].
Weber D J, McFarland R D, Irony I. Selected Food and Drug Administration review issues for regulation of allogeneic islets of Langerhans as somatic cell therapy. Transplantation. 2002;74(11):1-5. [pmid: 12499908].
Weber DJ. Regulation of islets as a biological product: FDA update. City of Hope Rachmiel Levine Symposium; 2002 Oct 9–12; Anaheim, CA.
Wilczek H E, Jaremko G, Tyden G, et al. Evolution of diabetic nephropathy in kidney grafts. Transplantation. 1995;59(1):51-7. [pmid: 7839428].
Winsett R P, Stratta R J, Alloway R, et al. Immunosuppressant side effect profile does not differ between organ transplant types. Clin Transplant. 2001;15(Suppl 6):46-50. [pmid: 11903386].
Writing Team for the Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. Effect of intensive therapy on the microvascular complications of type 1 diabetes mellitus. JAMA. 2002;287(19):2563-9. [pmid: 12020338].
Writing Team for the Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. Sustained effect of intensive treatment of type 1 diabetes mellitus on development and progression of diabetic nephropathy: the Epidemiology of Diabetes Interventions and Complications (EDIC) study. JAMA. 2003;290(16):2159-67. [pmid: 14570951].
Zavala EY, Hanaway M, Peddi, et al. Peri and post operative resource utilization for islet transplantation: the initial transplantation. American Transplant Congress (ATC) 2003, Washington, DC, Abstract 1452.
Zehrer C L, Gross C R. Patient perceptions of benefits and concerns following pancreas transplantation. Diabetes Educ. 1994;20(3):216-20. [pmid: 7851236].
Zehrer C L, Gross C R. Quality of life of pancreas transplant recipients. Diabetologia. 1991;34(Suppl 1):S145-9. [pmid: 1936683].