# Appendix B: Technical Expert Panel (TEP) and Reviewers

## TECHNICAL EXPERT PANEL (TEP)

- Rodolfo Alejandro, M.D.
- Director, Clinical Islet Transplantation
- Diabetes Research Institute
- University of Miami School of Medicine
- Miami, FL

- Michael A. W. Hattwick, M.D.
- Woodburn Internal Medicine Associates, Ltd. and,
- Clinical Assistant Professor
- Georgetown University School of Medicine
- Washington, DC

- Bernhard J. Hering, M.D.
- Director, Islet Transplantation
- Associate Director, Diabetes Institute for Immunology and Transplantation
- University of Minnesota
- Minneapolis, MN

- Frederick G. Hom, M.D.
- Chief of Regional Diabetes
- Kaiser Permanente, Northern California
- Fremont, CA

- James Shapiro M.D., Ph.D., FRCS(Eng), FRCSC
- Clinical Research Chair in Transplantation (CIHR/Wyeth Canada)
- Director, Clinical Islet Transplant Program
- Roberts Centre, University of Alberta
- Edmonton, AB Canada

- Glenn Y. Yokoyama, Pharm.D.
- Director, Pharmacy Clinical Services
- Prescription Solutions
- PacifiCare (Partner organization requesting the evidence report from AHRQ)
- Costa Mesa, CA

## REVIEWERS

- Jeffrey Bluestone, M.D.
- Immune Tolerance Network Nominee
- Director
- Immune Tolerance Network and
- University of California - San Francisco Diabetes Center
- San Francisco, CA

- Bruce F. Bower, M.D.
- American Association of Clinical Endocrinologists Nominee
- Clinical Professor of Medicine
- University of Connecticut School of Medicine
- Farmington, CT

- Sonia Cooper
- Children with Diabetes Foundation Nominee
- President
- Children with Diabetes Foundation
- Boulder, CO

- Judith Fradkin, M.D.
- Director
- Division of Diabetes Endocrinology and Metabolism
- National Institute of Diabetes & Digestive & Kidney Diseases
- National Institutes of Health
- Bethesda, MD

- Robert Goldstein, M.D., Ph.D.
- Juvenile Diabetes Research Foundation Nominee
- Chief Scientific Officer
- Juvenile Diabetes Research Foundation
- New York, NY

- Sam Ho, M.D.
- Senior Vice President, Chief Medical Officer
- PacifiCare (Partner organization requesting the evidence report from AHRQ)
- Cypress, CA

- R. Paul Robertson, M.D.
- Scientific Director
- Pacific Northwest Research Institute
- Seattle, WA

- David E.R. Sutherland, M.D., Ph.D.
- Head, Division of Transplantation
- University of Minnesota Hospital
- Department of Surgery
- Minneapolis, MN
- Darin J. Weber, Ph.D.
- Chief, Cell Therapies Branch
- Office of Cellular, Tissue and Gene Therapies
- Center for Biologics Evaluation and Research
- U.S. Food and Drug Administration
- Rockville, MD