# Appendix A: Exact Search Strings

The MEDLINE database was searched for recently published research articles and for relevant background information. The database was searched initially from 1966 through October 2002; subsequent search updates were performed through October 2003. Additionally, bibliographies of relevant articles were also searched and the project's Technical Expert Panel was queried for any relevant articles omitted from the search results. During the peer review process, reviewers informed the Evidence-based Practice Center (EPC) staff of articles recently published or accepted for publication and in the case of certain imminent publications, provided prepublication manuscripts.

The search strategy selected for review all citations that included any of the following terms:

“Islets of Langerhans Transplantation”[Medical Subject Heading^®^ (MeSH^®^)]

“Islets of Langerhans”[MeSH^®^] AND “transplantation”[MeSH^®^]

islet*[tw] AND transplant*[tw], or

beta cell*[tw] AND transplant*[tw]

The search was limited to studies on human subjects with English-language abstracts. Papers published in foreign languages were reviewed if the English abstract appeared to meet inclusion criteria.