# Acronyms and Abbreviations

AAMI | Age-Associated Memory Impairment
ABID | Agitated Behavior Inventory for Dementia
ABS | Adaptive Behavior Scale
ACES | Agitation-Calmness Evaluation Scale
ACFP | American College of Family Physicians
AChE | Acetycholinesterase
ACP-ASIM | American College of Physicians - American Society of Internal Medicine
ACPT | Auditory Continuous Performance Test
ACTH | Adrenocorticotropic homone
AD | Alzheimer's Disease
ADAS | Alzheimer's Disease Assessment Scale
ADAS-11; ADAS-13 | Alzheimer's Disease Assessment Scale (11 and 13 items)
ADAS-Cog | Alzheimer's Disease Assessment Scale-Cognitive and Non-Cognitive Sections
ADAS-NonCog
ADCS-ADL | Alzheimer's Disease Cooperative Study - Activities of Daily Living
ADCS-CGIC | Alzheimer's Disease Cooperative Study - Clinical Global Impression of Change
ADFACS | Alzheimer's Disease Functional Assessment and Change Scale
ADL; ADLC | Activities of Daily Living (Checklist)
ADL-BDRS | Activities of Daily Living-Blessed Dementia Rating Scale
ADL-PDS | Activities of Daily Living- Progressive Deterioration Scale
ADS | Alzheimer's Deficit Scale
ADSS | Alzheimer's Disease Symptomatology Scale
AFBS | Aversive Feeding Behavior Scale
AGGR | Aggressiveness subscale of the Personality Psychopathology Five (PSY-5) Scales
AGS-E | Assessment of Global Symptomatology-Elderly
AHRQ | Agency for Healthcare Research and Quality
AIDS | Acquired Immune Deficiency Syndrome
AIMS | Abnormal Involuntary Movement Scale
ALCAR | Carnitine
AMED | Allied and Complementary Medicine Database
AMI | Attention Matrices
AMPA | Alpha-amino-3-hydroxy-5-methyl-4-isoxazole proprionic acid
AMTS | Abbreviated Mental Test Score
APOE | Apolipoprotein E gene
BADL | Basic Activities of Daily Living
BARS, BAS | Barnes Akathisia Rating Scale
BCRS | Brief Cognitive Rating Scale
BDI | Beck Depression Inventory
BDRS | Blessed Dementia Rating Scale
BEHAVE - AD | Behavioral Pathology in Alzheimer's Disease Rating Scale
BePU | Berlin rating scale for psychomotoric restlessness
Bf-S | Zerssen Adjective Mood Scale (German test: Befindlichkeitsskala)
BGP | Behavioural Rating Scale for Geriatric Patients
BGP | Behavioural Rating Scale for Geriatric Patients
BI | Barthel Index
bid | Twice a day
BL-A | Blessed A scale
Blessed-D BDRS | Blessed Dementia Rating Scale
BMI | Body Mass Index
BMICT | Blessed Memory Information and Concentration Test
BMY | Nootropic agent; Bristol-Myers Squibb
BNT | Boston Naming Test
BPRS | Brief Psychiatric Rating Scale
BRMS | Bech-Rafaelsen Mania Scale
BRSD | Behavioral Rating Scale for Dementia
BSRT | Babcock Story Recall Test
BSRT | Buschke Selective Reminding Test
BSS | Behavioral Syndromes Scale for Dementia
BTT | Block Tapping Test
CADISIL | Cerebral Autosomal Dominant Ischemia with Subcortical Leukoencephalopathy
CAMCOG | Cognitive section of the Cambridge Examination for Mental Disorders in the Elderly
CAMDEX | Cambridge Examination for Mental Disorders in the Elderly
CAMTOT | CAMCOG Total Score
CANTAB | Cambridge Automated Neuropsychological Test Assessment Battery
CAPE | Clifton Assessment Procedures for the Elderly
CASE | Clifton Assessment Scale for the Elderly
CASI | Cognitive Abilities Screening Instrument
CATS | Caregiver's Activity Time Survey
CAUST | Canadian Utilization of Service Tracking questionnaire
CBC | Complete Blood Count
CBM 36–733 | 2-methyl-alpha-ergokryptine
CCASSS | Computerized Cognitive Assessment System Speed Score
CCT | Controlled Clinical Trial
CDR, CDRS | Clinical Dementia Rating; Clinical Dementia Rating Scale
CDR-NH | Clinical Dementia Rating - Nursing Home Version
CDR-SB | Clinical Dementia Rating - Sum of Boxes
CDT | Clock-Drawing Test
CEB | Clinical Epidemiology and Biostatistics
CERAD | Consortium to Establish a Registry for Alzheimer's Disease
CERE | Cerebrolysin
CETM | Dynamic measure of comprehension process (Spilich)
CGAE | Clinical Global Assessment of Efficacy
CGC+ | Clinical Global Change-Plus
CGI | Clinical Global Impression
cGIC | Caregiver-rated Global Impression of Change
CGIC | Clinical Global Impression of Change
CGI-GI | Global Improvement
CGI-CGC | Clinical Global Impression-Clinical Global Change
CGI-S; CGI-S/C | Clinical Global Impression-Severity/Change
CGRS | Clinicians' Global Rating Score
chisq | Chi-Square Test
chisq _M-H_ | Mantel-Haenszel Chi-Square Test
CI | Confidence interval
CIBI | Clinician's Interview-Based Impression
CIBIC | Clinician's Interview-Based Impression of Change
CIBIC+ | Clinician's Interview Based Impression of Change plus Caregiver
CIBIS+ | Clinician's Interview-Based Impression of Severity with Caregiver Input
CINAHL | Cumulative Index to Nursing & Allied Health Literature ®
CIND | Cognitive Impairment Not yet Diagnosed
CLEX | Clinical Examination
CloND | Cognitive Loss No Dementia
CMAI | Cohen Mansfield Agitation Inventory
CNTB | Computerized Neuropsychological Test Battery
COSTART | Coding Symbols for a Thesaurus of Adverse Reaction Terms
COWAT | Controlled Oral Word Association Test
CPRS | Comprehensive Psychopathological Rating Scale
CPT | Cognitive Performance Test
CSDD | Cornell Scale for Depression in Dementia
CSGDS | Collateral Source Geriatric Depression Scale
CSI | Caregiver Stress Inventory
CSS | Caregiver Stress Scale
CT | Computerized Tomography
CVD | Cerebrovascular Disease
CVLT | California Verbal Learning Test
d | day
d | Effect Size Value - (d) is the average amount of change in standard deviation units achieved by individuals in a treated group versus the change achieved by members of a control/comparison group for a particular study
DAD | Disability Assessment for Dementia
DAT | Dementia Alzheimer's Type
D-B | Delay relative to Baseline
DBDS | Dementia Behavior Disturbance Scale
DCT | Digit Copying Test
DDAVP | Deamino-D-Arginine-Vasopressin
DEK | Dihydroergokryptine
Df | Degrees of Freedom
DMR | Dementia Questionnaire for Mentally Retarded Persons
DMSE | Delayed Matching-to-Sample Exam
D-P | Delay relative to Placebo
DPZ | Donepezil
DRS | Dementia Rating Scale
DSCS | Depressive Symptoms Collateral Source
DSM | Diagnostic and Statistical Manual of Mental Disorders (Edition III, III-R, IV)
DSPT | Digit Span Test
DSS | Depressive Signs Scale
DST; DSST | Digit Symbol (Substitution) Test
DTIC | Discovering Things in Common
e.g., | example
ECG | Electrocardiogram
EEG | Electroencephalography
EFR | Emotional Face Recognition
EIS | Efficacy Index Score
EMBASE | Excerpta Medica Database
EPS | Extrapyramidal Symptoms
ERP | Event-Related Potential
ESRS | Extrapyramidal Symptom Rating Scale
FAST | Functional Assessment Staging
FCCA | Final Comprehensive Consensus Assessment
FCMT | Figure Copy/ Memory Test
FDA | Food and Drug Administration
FDG-PET | Positron Emission Tomography with 18-fluorodeoxyglucoseis
FIGT | Figure Detection Test
FIM | Functional Independence Measure
FRS | Functional Rating Scale test
g | gram
GABA | Gamma-aminobutyric acid
GBS | Gottfries-Bråne-Steen
GBS-SDS | Gottfries-Bråne-Steen - Scale for Dementia Syndromes
GDS | Global Deterioration Scale
GERRI | Geriatric Evaluation by Relative's Rating Instrument
GIS | Global Improvement Scale
GM-1 | Monosialoganglioside
GMS-A | Geriatric Mental State questionnaire
GPI-E | General Psychiatric Impression-Elderly
GS | Gestalt Scale
h | hour
HAM-A; HARS | Hamilton Anxiety Rating Scale
HAM-D; HDRS | Hamilton Depression Rating Scale
HDS-R | Hasegawa Dementia Scale-Revised
HIS | Hachinski Ischemic Score
HIV | Human Immunodeficiency Virus
HMII | Hachinski-Marshall Ischaemic Index
HVLT | Hopkins Verbal Learning Test
IADL | Instrumental Activities of Daily Living
ICC | Item Characteristic Curve analysis
ICD | International Classification of Diseases (Version 9 or 10)
IDDD | Interview for Deterioration in Daily Living Activities in Dementia-complex task
IF | Industry Funded
IM | Intramuscular
I-P | Improvement relative to Placebo
IPSC-E | Raskin's and Crook's Inventory of Psychic and Somatic Complaints for the Elderly
IQCODE | Informant Questionnaire on Cognitive Decline in the Elderly
IS | Industry provided Supplies
ITT | Intention-to-treat
IU | International Units
kg | kilogram
KOLT | Kendrick Object Learning Test
LAS | Luria Alternating Series
lbs | pounds
LFT | Liver Function Test
LMT | Logical Memory Test
LNNB | Luria-Nebraska Neuropsychological Battery
LOCF | Last Observation Carried Forward
LPRS | London Psychogeriatric Rating Scale
LRU | Lipasemic Releasing Units
m | month
M | male
MAACL-R | Multiple Affect Adjective Checklist-Revised
MACF | Microtubule Actin Crosslinking Factor
MADR-S | Montgomery-Asberg Depression Rating Scale
MCI | Mild Cognitive Impairment
MCPT | Modified Continuous Performance Test
MDB | Mental Deterioration Battery
MeSH | Medical Subject Heading
μg | microgram
mg | milligram
MID | Multi Infarct Dementia
Min | Minimal
MITT | Modified Intention-to-treat
ml | milliliter
MMSE (MMSE-CE) | Mini-Mental Status Exam (estimated score)
CMMSE | Cantonese MMSE
MMMSE | Modified MMSE
SMMSE | Standardized MMSE
MNLT | Modified Names Learning Test
Mod | Moderate
Modly Sev | Moderately Severe
MQ | Memory Quotient
MRI | Magnetic Resonance Imaging
MRS | Magnetic Resonance Spectroscopy
MU-EPC | McMaster University Evidence-based Practice Center
MWF | Mattis Word Fluency
MX | Mixed results
n | number included in study
N | No
NA | Not available
NAA | Nuremberg gerontopsychological inventory for Assessing Activities of daily living
NAB | Nurnberger-Alters-Beobachtungs-Skala
NAC | N-Acetylcysteine
NAI | Nuremberg Age Inventory
NART | Nelson Adult Reading Test
NCT | Number Connection Test
NDT | New Dot Test
NI | Non-Industry funding source
NIMCS | Newcastle Memory, Information and Concentration Scale
NINCDS | National Institute of Neurological and Communicative Disorders and Stroke
NINCDS-ADRDA | National Institute of Neurological and Communicative Disorders and Stroke - Alzheimer's Disease and Related Disorders Association
NINDS-AIREN | National Institute of Neurological Disorders and Stroke - Association Internationale pour la Recherche et l'Enseignement en Neurosciences
NLT | Names Learning Test
NMDA | N-methyl-D-aspartate
NMICS | Newcastle Memory, Information and Concentration Scale
NMS | Nowlis Mood Scale
NNI | Number Needed to Intervene
NOSGER | Nurses Observation Scale for Geriatric Patients
NOSGER-IADL | Nurses Observation Scale for Geriatric Patients - Instrumental Activities of Daily Living subscale
NOSIE | Nurses Observation Scale for Inpatients
NPI | Neuropsychiatric Inventory
(NPI-4, NPI-10) | Subscores 4,10
NPI-NH | Neuropsychiatric Inventory - Nursing Home Version
NR | Not Reported
NRSMG | Non-Randomised Studies Methods Group
NS | Not significant
NSL | Neuropsychological Aging Self-Evaluation - List for Age Symptoms
NST | Non-Stress Test
NT | Not tested
OARS - ADL | Older Americans Resource Scale
OAS | Overt Aggression Scale
OC | Observed Cases
OLT | Object Learning Test
OMDR | Oculomotor Delayed Response
OR | Odds Ratio
ORG 2766 | Adrenocorticotropic hormone derivative
OXIR | Oxiracetam
oz | ounce
p | p value
P300 | Electrophysiological potential that is indicator of associative and cognitive processes and latency in decision making processes
PAD | Presenile Alzheimer's Disease
PADL | Performance of Activities of Daily Living
PANSS-EC | Positive and Negative Syndrome Scale-Excited Component
PD | Parkinson's Disease
PDD | Progressive Degenerative Dementia
PDS | Progressive Deterioration Scale
PDSD | Primary Degenerative Senile Dementia
PET | Positron Emission Tomography
PGIR | Patient's Global Improvement Rating
PI | Partially funded by Industry
PICD | Presenile Idiopathic Cognitive Decline
POMS | Profile of Mood States
PRL | Prolactin
PSMS | Physical Self-Maintenance Scale
PSP | Progressive Supranuclear Palsy
PSQI | Pittsburgh Sleep Quality Index
qid | Four times daily
QoL | Quality of Life
R | Correlation Coefficient
RA | Research Assistant
RAGS; RAGS-E | Relative's Assessment of Global Symptomatology (Elderly)
RAPSU | Scale for psychomotoric agitation
R-AVL | Rey auditory-verbal-learning test
RCT | Randomized Controlled Trial
RDS | Rapid Disability Scale
RefMan | Reference Manager Version 10®
RGRS | Relatives' Global Rating Score
RMBPC | Revised Memory and Behavior Problems Checklist
RMT | Rey Memory Test; Randt Memory Test
RMT-A&R | Randt Memory Test - Acquisition and Recall
RMT-DR | Randt Memory Test - Delayed Recall
RMT-MI | Randt Memory Test - Memory Index
RPM | Raven's Progressive Matrices
RPT | Rivermead Behavioural Memory Test-Profile Score
RR | Relative Risk
RT | Reaction Time
RTI | Research Triangle Institute
SADS | Schedule for Affective Disorders and Schizophrenia
SAS | Simpson-Angus Scale
SAS-G | Self Assessment Scale - Geriatric
S-B | Stabilization relative to Baseline
SBI | Spontaneous Behavior Interview
SC | Significant change
SCAG | Sandoz Clinical Assessment - Geriatric
SCB | Screen for Caregiver Burden
SCWIT | Stroop Color Word Interference Test
SD | Standard Deviation
SDAT | Senile Dementia of the Alzheimer's Type
SEM | Standard Error
Sev | Severe
SF-36 | Medical Outcomes Study Short-Form 36-Item Health Survey
SGRS | Stockton Geriatric Rating Scale
SHGRS | Stuard Hospital Geriatric Rating Scale
SIB | Severe Impairment Battery
SIP | Sickness Impact Profile
SKT | Syndrome Kurz test; Syndrome Short Test
SMQ | Squire's Memory Questionnaire
SMST | Sternberg's Memory Scanning Test
SPECT-TcHMPAO | Single Photon Emission Computed Tomography with hexamethylpropyleneamineoxime
SPET | Single Photon Emission Tomography
SRT | Selective Reminding Procedure
SRT-DR | Selective Reminding Procedure-Delayed Recall
SWFT | Semantic Word Fluency Test
TEP | Technical Expert Panel
TESS | Treatment Emergent Symptom Scale
TESS-DOTES | Dosage Record and Treatment Emergent Symptom Scales
tid | Three times daily
TK | Token Test
TOO | Task Order Officer
TP | Toulouse Piéron
TPAT | Toulouse-Pieron Attention Test
TSI | Test for Severe Impairment
UK | United Kingdom
UKU | Side effect rating scale
UPDRS | Unified Parkinson's Disease Rating Scale
US | United States
VaD | Vascular Dementia
VAMS | Visual Analog Mood Scale
VAS | Visual Analogue Scales
VHB | Videorecorder Home-Behavioral assessment
vs. | versus
w | week
WAIS | Wechsler Adult Intelligence Scale
WAIS-DI | Deterioration Index
WAIS-DSPT | Wechsler Adult Intelligence Scale - Digit Span Test
WAIS-DSST | Wechsler Adult Intelligence Scale -Digit Symbol Substitution Test
WAIS-DTIC | Wechsler Adult Intelligence Scale - Discovering Things in Common
WAIS-VOC | Wechsler Adult Intelligence Scale-Vocabulary Subset
WHO | World Health Organization
WLM | Word List Memory test
WMS-MQ | Wechsler Memory Scale-Memory Learning Restoration
WMS-R | Wechsler Memory Scale-Revised
x^2^ | chi-square
y | year
Y | yes
ZVT | Zahlen-Verbindungs Test -Trail Making Test