# Summary Evidence Tables

Summary Table 1. Carnitine

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/ Mood | Quality of Life/ADL | Caregiver Burden | Other
Livingston, 1991 | NS* | MX* | NT | NT | NS* | NT | NT
Rai, 1989 | NT | NS* | NS* | NT | NS* | NT | NT
Sano, 1992 | NS* | NS* | NT | NT | NS* | NT | NT
Spagnoli, 1991 | NT | MX | MX | NS | NT | NT | NT
Thal, 2000a | NS | NT | NS | 2° NS | 2° NS | NT | NT
Thal, 1996a | NS | NT | NS | 2° NS | 2° NS | SUBGROUP | NT
Brooks, 1998

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 2. Donepezil

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Burns, 1999 | SC | NT | SC | NT | SC | NT | NT
Feldman, 2001 | 2° SC | NT | SC | NR | 2° SC | NR | SUBGROUP
Gauthier, 2002
Mohs, 2001 | SC | NT | NT | NT | SC | NT | SC Time to functional decline
Prasher, 2002 | 2° NS* | NT | NS* | 2° MX* | NT | NT | NT
Rogers, 1996 | SC | NT | SC | NT | 2°MX | NT | NT
Rogers, 2000
Neumann, 1999
Rogers, 1998
Rogers, 1998b | SC | NT | SC | NT | 2° NS | NT | NT
Doody, 2001
Sparano, 1998
Rogers, 1998a | SC | NT | SC | NT | 2° SC | NT | NT
Doody, 2001
Steele, 1999
Tariot, 2001 | 2° NS | NT | 2° SC | NS | 2° NS | NT | SUBGROUP
Winblad,2001 | 2° SC | NT | SC | 2° NS | 2° SC | NT | SUBGROUP
Pratt, 2002 | SC | NT | SC | NT | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 3. Galantamine

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/ Mood | Quality of Life/ADL | Caregiver Burden | Other
Erkinjuntti, 2002 | SC* | NT | SC* | 2°SC* | 2°SC* | NT | NT
Raskind, 2000 | SC | NT | SC | NT | 2°NS | NT | NT
Rockwood, 2001 | SC | NT | SC | NS | 2°SC | NT | NT
Tariot, 2000 | SC | NT | SC | SC | SC | NT | NT
Wilcock, 2000 | SC | NT | SC | NT | SC | NT | NT
Wilcock, 2001
Wilkinson, 2001 | MX | NT | 2°NS | NT | 2°NS | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 4. Metrifonate

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL n | Caregiver Burden | Other
Becker, 1996 | SC* | NT | 2°MX* | 2°NS* | 2°NS* | NT | NT
Becker, 1998 | SC* | NT | 2°NS* | 2°NS* | 2°NS* | NT | NT
Cummings, 1997 | SC* | NT | SC* | NT | NT | NT | NT
Cummings, 1998b | SC | NT | SC | NT | 2°NS | NT | NT
Cummings, 1998a
Dubois, 1999 | SC | NT | SC | 2°SC | 2°SC | NT | NT
McKeith, 1998
Jann, 1999 | SC | NT | 2°MX | 2°NS | NT | NT | NT
Morris, 1998 | SC | NT | SC | 2°NS | 2°NS | NT | NT
Pettigrew, 1998 | NR | NT | NR | NR | NT | NT | NT
Raskind, 1999 | SC | NT | MX | MX | NS | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 5. Nicergoline

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/ Mood | Quality of Life/ADL | Caregiver Burden | Other
Herrmann, 1997 | SC | NT | SC | NT | NT | NT | NT
Nappi, 1997 | SC* | NT | SC* | NT | NT | NT | NT
Saletu, 1995 | SC* | NT | MX* | NS* | NT | NT | SUBGROUP
Saletu, 1997
Winblad, 2001a | SC | NT | NS | 2°NS | 2°NS | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 6. Physostigmine

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Van Dyck, 2000 | SC | NT | MX | NT | 2°NS | NT | NT
Moller, 1999 | NR | NT | NS* | NR | NT | NT | NT
Thal, 1996b | SC | NT | SC | NT | 2°NS | NT | NT
Thal, 1999 | SC | NT | SC | NT | 2°NS | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 7. Posatirelin

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/ Mood | Quality of Life/ADL | Caregiver Burden | Other
Ferrari, 1998 | SC | NT | SC | NS | SC | NT | SUBGROUP
Gasbarrini, 1997 | SC | NT | NT | SC | SC | NT | NT
Parnetti, 1995 | NR | NT | NT | NR | NR | NT | NT
Parnetti, 1996 | MX* | NT | NT | NS* | SC* | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 8. Rivastigmine

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Agid, 1998 | NR | SC* | SC* | NS* | NS* | NT | NT
Corey-Bloom, 1998 | SC | NT | SC | NT | SC | NT | NT
Farlow, 2001
Farlow, 2000
Kumar, 2000
Del Ser, 2000
Doraiswamy, 2002
Forette, 1999 | SC* | NT | SC* | NS* | NS* | NT | NT
McKeith, 2000 | SC | NT | NS | MX | NT | NT | NT
Potkin, 2001 | NT | NS* | SC* | NT | NT | NT | NT
Rosler, 1999 | SC | NT | SC | NT | SC | NT | NT
Rosler, 2001
Farlow, 2000
Rosler, 1998
Doraiswamy, 2002

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 9. Tacrine

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Knapp, 1994b | SC | NT | SC | NS | NT | NT | NT
Farlow, 1998
Gracon, 1996
Henke, 1997
Knapp, 1994a
Knopman, 1996
Raskind, 1997
Schneider, 1997
Schneider, 1996
Smith, 1996
Maltby, 1994 | NS* | NS* | NT | NS* | NS* | NS* | NT
Prentice, 1996 | NS* | NT | NT | NS* | NT | NT | NT
Weinstein, 1991 | NS* | NT | NT | NT | NS* | NS* | NT
Gool, 1991
Wong, 1999 | MX | NT | NS | NT | NT | NT | NT
Wood, 1994 | NS | NT | SC | NS | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 10. Velnacrine

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Zemlan, 1996 | SC* | NT | SC* | 2°NS* | 2°NS* | NT | NT
Antuono, 1995 | SC | NT | SC | NT | 2°SC | 2°SC | NT
Huff, 1991 | NT | NS* | MX* | NT | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 11. Various cholinergic neurotransmitter modifying agents

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
CHOLINERGIC NEUROTRANSMITTER MODIFYING AGENTS
Eptastigmine
Imbimbo, 1999 | SC | NT | SC | NT | SC | NT | NT
Canal, 1996 | NS* | NS* | MX* | NT | MX* | NT | NT
Huperzine
Xu, 1995 | SC* | NT | NT | SC* | SC* | NT | NT
Linopirdine
Van Dyck, 1997 | NS* | NT | NS* | NS* | NT | NT | NT
Rockwood, 1997 | SC | 2°NS | NS | 2°NS | 2°NS | NT | NT
Rockwood, 2000
Sabeluzole
Mohr, 1997 | NS* | NS* | NT | NT | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 12. Haloperidol

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver/ Burden | Other
Allain, 2000 | 2° NS | NT | 2° SC | SC | NT | NT | NT
Auchus, 1997 | NT | NT | NT | NS* | NT | 2° NS* | NT
De Deyn, 1999 | NR | NT | NR | SC | NR | NT | NT
Petrie, 1982 | NT | NT | NR | SC* | NT | NT | NT
Teri, 2000 | NS* | NT | NS* | NS* | SC* favors Placebo | NS* | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 13. Memantine

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Orgogozo, 2002 | SC | NT | NS | NT | NT | NT | NT
Wilcock, 2002 | SC | NT | NS | NT | NT | NT | NT
Winblad, 1999 | NT | NT | SC | SC | SC | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 14. Selegeline

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Agnoli, 1992 | MX* | NT | NT | NT | NT | NT | NT
Burke, 1993a | NS* | NT | NS* | NS* | NT | NT | NT
Burke, 1993b
Filip, 1999 | MX* | NT | MX* | NT | NT | NT | SUBGROUP
Freedman, 1998 | 2° NS | 2° NS | 2° NS | NS | NT | NT | NT
Mangoni, 1991 | NR | SC* | SC* | SC* | NT | NT | NT
Smirne, 1993
Sano, 1997 | NT | NT | NT | NT | NT | NT | NS Survival
Sano, 1996 | | | | | | | SUBGROUP

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 15. Various non-cholinergic neurotransmitter/neuropeptide modifying agents

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Perphenazine
Pollock, 2002 | NR | NT | NT | NS | NR | NR | NT
Thioridazine
Barnes, 1982 | NT | NT | NS | NS | NT | NT | NT
Alaproclate
Dehlin, 1985 | NS | NT | NT | NS | SC | NT | NT
Anapsos
Alvarez, 2000 | SC* | NT | NT | NT | NT | NT | SUBGROUPS
Cutler, 1993 | NR* | NT | NS* | NT | NT | NT | NT
Citalopram
Nyth, 1990 | NT | NT | MX* | NS* | NT | NT | NT
Pollock, 2002 | NT | NT | NT | SC | NT | NT | NT
Divalproex Sodium
Tariot, 2001b | 2° NS | NT | 2° SC favors Placebo | NS | NT | NT | NT
Porsteinsson, 2001 | 2° NS* | NT | 2° NS* | NS* | 2° NS* | NT | NT
Fluvoxamine
Olafsson, 1992 | NS* | NS* | NS* | NT | NT | NT | NT
Fluoxetine
Petracca, 2001 | NS | NT | NR | NS | NS | NT | NT
Auchus, 1997 | NT | NT | NT | NS | NT | 2°NS | NT
Imipramine
Reifler, 1989 | NS* | NT | SC* | NS* | NS* | NT | SUBGROUPS
Lisuride
Claus, 1998 | SC* | NS* | NS* | NS* | NT | NT | NT
Lorazepam
Meehan, 2002 | 2° NS* | NT | 2° NS* | NS* | NT | NT | NT
Clark, 2001
Kennedy, 2001
Mintzer, 2001
Street, 2001
Loxapine
Barnes, 1982 | NT | NT | NS | NS | NT | NT | NT
Petrie, 1982 | NT | NT | NR | SC* | NT | NT | NT
LU25
Thal, 2000b | NS | NT | NS | 2° NS | 2° NS | NT | NT
Maprotiline
Fuchs, 1993 | 2° NS* | NT | NS* | NT | NT | NT | NT
Minaprine
Passeri, 1987 | NT | NT | NT | MX | NT | NT | NT
Moclobemide
Roth, 1996 | SC | NT | MX | SC | NT | NT | NT
[underlined: Naftidrofuryl]
Moller, 2001 | SC | NT | SC | NT | NT | NT | NT
Olanzapine
Meehan, 2002 | 2° NS* | NT | 2° NS* | SC* | NT | NT | NT
Street, 2000 | 2° NS | NT | NT | SC | NT | NT | NT
Phosphatidylserine
Amaducci, 1988 | SC* | SC* | SC* | NT | NT | NT | SUBGROUP
SMID Group, 1987
Amaducci, 1986
Crook, 1992a | NT | NT | SC | NT | 2° NS | NT | NT
Risperidone
Katz, 1999 | NT | NT | 2° SC | SC | NT | NT | NT
Jeste, 2000
Pryse-Phillips, 2000
De Deyn, 1999 | NS | NT | SC | MX | NS | NT | NT
Sertraline
Lyketsos, 2000 | 2° NS | NT | SC | 2° MX | 2° SC | NT | NT
Magai, 2000 | NS | NT | NT | NS | NT | NT | NT
Tiapride
Allain, 2000 | NR | NT | NR | 2° SC | NT | NT | NT
Trazodone
Teri, 2000 | NS* | NT | NS* | NS* | SC* | NS* | NT
Xanomeline
Bodick, 1997 | SC | 2° SC | SC | NT | 2° SC | NT | NT
Veroff, 1998
Satlin, 1997

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 16. Cerebrolysin

Author, Year | General Cognitive Function Meausre | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Bae, 2000 | SC | NT | SC | NT | 2°NS | NT | NT
Panisset, 2002 | NS* | NT | SC* | NT | 2°NS* | NT | NT
Ruther, 2001 | SC | NR | SC | 2°SC | NR | NT | NT
Ruther, 2002
Ruther, 1994 | NT | SC | SC | NR | 2°NS | NT | NT
Ruther, 2000
Xiao, 2000 | SC | 2°MX | SC | NT | 2°MX | NT | NT
Xiao, 1999 | SC | 2°SC | NS | 2°NS | 2°NS | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 17. Estrogens

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Asthana, 2001 | NT | SC | 2°NS* | NR | 2°NS* | NT | NT
Henderson, 2000 | NS* | NT | 2°NS* | 2° NS* | 2°NS* | NT | NT
Kyomen, 1999 | NT | NR | NS* | MX* | NS* | NT | NT
Kyomen, 2002
Mulnard, 2000 | 2° NS | 2° MX | NS | 2° NS | 2° NS | NT | NT
Wang, 2000 | NS | NT | NS | 2° NS | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 18. Ginkgo Biloba

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver/Burden | Other
Kanowski, 1996 | NT | SC | SC | NS | NT | NT | NT
Le Bars, 1997 | SC | NT | MX | NT | NT | NT | NT
Le Bars, 2000
Le Bars, 2002
Por, 1998
Maurer, 1997 | 2° NS | SC | 2° NS | NR | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 19. Idebenone

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Bergamasco, 1994 | NT | MX* | SC* | NT | NT | NT | NT
Gutzmann, 1998 | 2° SC | NT | SC | NT | 2° SC | NT | NT
Weyer, 1996
Marigliano, 1992 | SC* | NT | NT | NT | SC* | NT | NT
Weyer, 1997 | 2° SC | NT | SC | 2° SC | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 20. Oxiracetam

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Bottini, 1992 | NT | MX* | NT | NT | SC* | NT | NT
Maina, 1989 | SC* | NT | SC* | SC* | NT | NT | NT
Mangoni, 1988 | NT | SC* | NT | SC* | NT | NT | NT
Rozzini, 1992 | NR | NR | NT | NR | NS* | NT | NT
Rozzini, 1993
Villardita, 1992 | SC* | MX* | NT | NS* | SC* | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 21. Pentoxifylline

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Black, 1992 | 2° NS* | NT | NS* | 2° NS* | NT | NT | SUBGROUP
Ghose, 1987 | MX | 2° NS* | NS* | NT | NT | NT | SUBGROUP
Knezevic, 1996 | 2° NS | NT | NS | 2° NS | 2° NS | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 22. Propentofylline

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Marcusson, 1997 | 2° SC | SC | MX | 2° SC | 2° NS | NT | NT
Mielke, 1998 | NS* | NS* | NT | NT | NT | NT | NT
Mielke, 1996 | NS* | NS* | NT | NT | NT | NT | NT
Saletu, 1990 | SC* | NS* | SC* | NT | NT | NT | NT
Moller, 1994

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 23. Additional pharmacological agents

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
ACTH Neuropeptides
Soininen, 1985 | NT | NT | NS* | NT | NT | NT | NT
Partanen, 1986
Kragh-Sorensen, 1986 | NT | SC* | SC* | NT | NT | NT | NT
Aniracetam
Senin, 1991 | SC* | SC* | SC* | NT | NT | NT | NT
Ateriod
Ban, 1991b | SC* | NT | MX* | NS* | NT | NT | NT
Buflomedil
Cucinotta, 1992 | NT | NR | NR | NR | NT | NT | NT
Choto-san
Shimada, 1994 | NT | NT | MX* | SC* | NT | NT | NT
Terasawa, 1997 | NT | NT | SC* | NS* | NT | NT | NT
Citicoline
Parnetti, 1995 | NR | NT | NT | NR | NR | NT | NT
Cyclandelate
Schellenberg, 1997 | NT | MX | SC | SC | NT | NT | NT
Weyer, 2000 | NS | NT | NS | NT | NS | NT | NT
DDAVP (Deamino-D-arginine-vasopressin)
Peabody, 1986 | NS* | NT | MX* | MX* | NT | NT | NT
Denbufylline
Treves, 1999 | NS* | NS* | NT | NT | NT | NT | NT
Desferrioxamine
Crapper -McLachlan, 1991 | NT | NT | NT | SC* | NT | NT | NT
Diclofenac/misoprostol
Scharf, 1999 | NS | NT | NS | 2° NS | 2° NS | NT | NT
Ergokryptine
Cucinotta, 1996 | 2° SC | 2° SC | MX | NR | NT | NT | NT
Cucinotta, 1998
Danielczyk, 1988 | NS* | NR | SC* | MX* | NS* | NT | NT
Glycosaminoglycan polysulfate
Ban, 1991a | MX* | NT | MX* | SC* | NS* | NT | NT
Guanfacine
Crook, 1992b | NR | SC | SC | NT | NT | NT | NT
Hydergine
Thompson, 1990 | MX* | NT | MX* | NS* | NT | NT | NT
Hydroxchloroquine
Van Gool, 2001 | 2° NS | NT | NT | 2° NS | NS | NT | NT
Aisen, 2002b | NS | NT | NS | NS | NS | NT | NT
Indomethacin
Rogers, 1993 | NS* | MX* | NS | NT | NT | NT | NT
Monosialotetrahexosylgan GM1
Ala, 1990 | NS* | NS* | NS* | NS* | NS* | NT | NT
NAC (N-Acetylcysteine)
Adair, 2001 | NS | 2°NS | NT | NT | NS | NT | NT
Nimodipine
Pantoni, 2000a | NS | NS | NS | NT | NS | NT | NT
Ban, 1990 | SC* | SC* | SC* | SC* | NT | NT | NT
Nizatidine
Carlson, 2002 | NT | NS | NT | NT | NS | NT | NT
Breitner, 1999
Nootropic agent - BMY
Shrotriya, 1996 | SC* | NT | NS* | NT | NT | NT | NT
Piracetam
Croisile, 1993 | NS* | NS* | NS* | NS* | NT | NT | NT
Prednisone
Aisen, 2000b | NS | NT | 2° NS | 2° MX | NT | NT | NT
Aisen, 2000a
Simvastatin
Simons, 2002 | MX* | NT | NT | NT | NT | NT | NT
Thiamine
Nolan, 1991 | SC* | SC* | NT | NT | NT | NT | NT
Vincamine
Fischhof, 1996 | NT | NR | SC* | NT | NR | NT | SUBGROUP
Vitamin E
Sano, 1997 | NT | NT | NT | NT | NT | NT | SC Institutionalization
Sano, 1996 | | | | | | | SUBGROUP
Xantinolnicotinate
Kanowski, 1990 | NT | SC* | SC* | NT | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 24. Drug vs drug studies

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Haloperidol / Tradozone
Teri, 2000 | NS | NT | NS | NR | NR | NR | NT
Olanzepine / Lorazepam
Meehan, 2002 | NR | NT | NT | NT | NT | NT | NT
Haloperidol/Loxapine
Carlyle, 1993 | NT | NT | NT | NS* | NT | NT | NT
Alprazolam / Lorazepam
Ancill, 1991 | NT | NT | NS* | NT | NT | NT | NT
Haloperidol / Oxazepam / Diphenydramine
Coccaro, 1990 | NT | NT | NS* | NS* | NS* | NT | NT
Sulphomucopolysaccharides / CDP-choline
Cucinotta, 1987 | NT | MX* | SC* favors sulphomucopolysaccarides | SC* favors sulphomucopolysaccarides | NT | NT | NT
Citalopram / Mianserin
Karlsson, 2000 | NT | NT | NT | NS* | NT | NT | NT
Citalopram/Perphenazine
Pollock, 2002 | NR | NT | NT | NR | NR | NR | NT
Thoridazine / Loxapine
Barnes, 1982 | NT | NT | NS | NR | NT | NT | NT
Tiapride / Haloperidol
Allain, 2000 | 2° NS | NT | 2° S | NS | NT | NT | NT
Tacrine / Silymarin
Allain, 1998 | NR | NR | NT | NT | NT | NT | NT
Risperidone / Haloperidol
Chan, 2001 | NR | NT | NT | NS* | NR | NT | NT
De Deyn, 1999 | NR | NT | NR | NR | NR | NT | NT
Paroxetine / Imipramine
Katona, 1998 | NT | NT | NS | NS | NT | NT | NT
Fluoxetine / Amitriptyline
Taragano, 1997 | NS* | NT | NT | NS* | NT | NT | NT
Selegiline / Alpha-Tocopherol
Sano, 1997 | NT | NT | NT | NT | NT | NT | NR
Sano, 1996
Meclofenoxate / Antagonic Stress
Popa, 1994 | SC* favors Antagonic Stress | SC* favors Antagonic Stress | SC* favors Antagonic Stress | NT | NT | NT | NT
Posatirelin / Citicoline
Parnetti, 1995 | SC* favors Posatirelin | NT | NT | SC* favors Posatirelin | NR | NT | NT
Pyritinol / Hydergine
Spilich, 1996 | NR | NT | SC* favors Pyritinol | NT | NT | NT | NT
Donepezil / Vitamin E
Thomas, 2001 | SC* favors Donepezil | NT | NT | NR | NT | NT | NT
Sulodexide / Pentoxilylline
Parnetti, 1997 | NR | NT | NT | NR | NR | NT | NT
Haloperidol / Fluoxetine
Auchus, 1997 | NT | NT | NT | NS* | NT | 2° NS* | NT
Melperone / Tiapride
Gutzmann, 1997 | NT | NT | NS | NR | NR | NT | NT
Idebenone/Tacrine
Gutzmann, 2002 | NS | NT | SC favors Idebenone | NR | NT | NT | NT
Nicergoline/Antagonic Stress
Schneider, 1994 | SC* favors Antagonic Stress | NT | SC* favors Antagonic Stress | NT | NT | NT | NT
Tradozone / 5'-MTHF Folate
Passeri, 1993 | NR | NT | NT | NR | NT | NT | NT

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis

Summary Table 25. VaD/MID Studies

Author, Year | General Cognitive Function Measure | Specific Cognitive Function Measure | Global Assessment | Behavior/Mood | Quality of Life/ADL | Caregiver Burden | Other
Ban, 1991b | SC* | NT | MX* | NS* | NT | NT | NT
Ateroid
Subgroup MID
Cucinotta, 1992 | NT | NR | NR | NR | NT | NT | NT
Buflomedil
VaD
Cucinotta, 1987 | NS | SC* | SC* favors | SC* favors | NT | NT | NT
sulphomucopolysaccarides vs CDP-choline | | | sulphomucopolysaccarides | sulphomucopolysaccarides
MID
Xiao, 1999 | SC | 2° SC | NS | 2° NS | 2° NS | NT | NT
Cerebrolysin
VaD
Shimada, 1994 | NT | NT | MX* | SC* | NT | NT | NT
Choto-san
VaD
Terasawa, 1997 | NT | NT | SC* | NS* | NT | NT | NT
Choto-san
VaD
Nyth, 1990 | NT | NT | NS* | NS* | NT | NT | NT
Citalopram
Subgroup VaD
Pratt, 2002 | SC | NT | SC | NT | NT | NT | NT
Donepezil
VaD
Kanowski, 1996 | NT | NR | NR | NR | NT | NT | NT
Ginkgo Biloba
Subgroup MID
Marigliano, 1992 | SC* | NT | NT | NT | SC* | NT | NT
Idebenone
MID
Orgogozo, 2002 | SC | NT | NS | NT | NT | NT | NT
Memantine
VaD
Wilcock, 2002 | SC | NT | NS | NT | NT | NT | NT
Memantine
VaD
Winblad, 1999 | NT | NT | 2° SC* | NT | NT | NT | NT
Memantine
Subgroup HIS>/= 5
Passeri 1987 | NT | NT | NT | MX | NT | NT | NT
Minaprine
Subgroup MID
Herrmann, 1997 | SC | NT | SC | NT | NT | NT | NT
Nicergoline
MID
Saletu1995 | SC* | NT | MX* | NS* | NT | NT | NT
Saletu1997
Nicergoline
Subgroup MID
Pantoni, 2000a | NS | NS | NS | NT | NS | NT | NT
Nimodipine
MID
Maina, 1989 | NT | NR | NR | NR | NT | NT | NT
Oxiracetam
Subgroup MID
Knezevic, 1996 | 2° NS | NT | NS | 2° NS | 2° NS | NT | NT
Pentoxifylline
MID
Black, 1992 | 2° NS* | NT | NS* | 2° NS* | NT | NT | SUBGROUP
Pentoxifylline
Vascular damage or strokes
Parnetti, 1997 | NR | NT | NT | NR | NR | NT | NT
Pentoxifylline vs Sulodexide
VaD
Ghose 1987 | SC* | NS* | NS* | NT | NT | NT | NT
Pentoxyfylline
Subgroup MID
Parnetti, 1996 | MX* | NT | NT | NS* | SC* | NT | NT
Posatirelin
VaD
Ferrari 1998 | NT | NT | NR | NT | NT | NT | NT
Posatirelin
Subgroup VaD
Mielke, 1996 | NS* | NS* | NT | NT | NT | NT | NT
Propentofylline
VaD
Marcusson 1997 | NT | SC | SC | NR | NR | NT | NT
Propentofylline
Subgroup VaD
Passeri 1993 | NT | NR | NT | NR | NT | NT | NT
5′-MTHF vs Tradozone
Subgroup MID
Fischhof, 1996 | NT | NR | SC* | NT | NR | NT | NT
Vincamine
Subgroup MID

MX Mixed results

NT Not tested

2° Secondary outcome

NS Not statistically significant

SC Significant change

* OC analysis