# References

1 Erkinjuntti T, Ostbye T, Steenhuis R, et al. The effect of different diagnostic criteria on the prevalence of dementia. N Engl J Med. Dec 4. 1997;337(23):1667-74. [pmid: 9385127].
2 Jorm A F, Korten A E, Henderson A S. The prevalence of dementia: a quantitative integration of the literature. Acta Psychiatr Scand. Nov. 1987;76(5):465-79. [pmid: 3324647].
3 Brookmeyer R, Gray S, Kawas C. Projections of Alzheimer's disease in the United States and the public health impact of delaying disease onset. Am J Public Health. Sep. 1998;88(9):1337-42. [pmid: 9736873]. [pmcid: 1509089].
4 Canadian Study of Health and Aging Working Group. Canadian study of health and aging: study methods and prevalence of dementia. CMAJ. Mar 15. 1994;150(6):899-913. [pmid: 8131123]. [pmcid: 1486712].
5 Baumgarten M, Hanley J A, Infante-Rivard C, et al. Health of family members caring for elderly persons with dementia. A longitudinal study. Ann Intern Med. Jan 15. 1994;120(2):126-32. [pmid: 8256971].
6 The Canadian Study of Health and Aging Working Group. Patterns of caring for people with dementia in Canada: The Canadian Study of Health and Aging. Can J Aging. 1994;13:470-87.
7 Morris J C, McKeel D W Jr, Fulling K, et al. Validation of clinical diagnostic criteria for Alzheimer's disease. Ann Neurol. Jul. 1988;24(1):17-22. [pmid: 3415196].
8 Tierney M C, Fisher R H, Lewis A J, et al. The NINCDS-ADRDA Work Group criteria for the clinical diagnosis of probable Alzheimer's disease: a clinicopathologic study of 57 cases. Neurology. Mar. 1988;38(3):359-64. [pmid: 3419620].
9 McKhann G, Drachman D, Folstein M, et al. Clinical diagnosis of Alzheimer's disease: Report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer's Disease. Neurology. Jul. 1984;34(7):939-44. [pmid: 6610841].
10 Pohjasvaara T, Mantyla R, Ylikoski R, et al. Comparison of different clinical criteria (DSM-III, ADDTC, ICD-10, NINDS-AIREN, DSM-IV) for the diagnosis of vascular dementia. National Institute of Neurological Disorders and Stroke-Association Internationale pour la Recherche et l'Enseignement en Neurosciences. Stroke. Dec. 2000;31(12):2952-7. [pmid: 11108755].
11 Chui H C, Mack W, Jackson J E, et al. Clinical criteria for the diagnosis of vascular dementia: A multicenter study of comparability and interrater reliability. Arch Neurol. Feb. 2000;57(2):191-6. [pmid: 10681076].
12 Galasko D, Hansen L A, Katzman R, et al. Clinical-neuropathological correlations in Alzheimer's disease and related dementias. Arch Neurol. Sep. 1994;51(9):888-95. [pmid: 8080388].
13 Nolan K A, Lino M M, Seligmann A W, et al. Absence of vascular dementia in an autopsy series from a dementia clinic. J Am Geriatr Soc. May. 1998;46(5):597-604. [pmid: 9588373].
14 Lim A, Tsuang D, Kukull W, et al. Clinico-neuropathological correlation of Alzheimer's disease in a community-based case series. J Am Geriatr Soc. May. 1999;47(5):564-9. [pmid: 10323650].
15 Schroder J, Kratz B, Pantel J, et al. Prevalence of mild cognitive impairment in an elderly community sample. J Neural Transm Suppl. 1998;54:51-9. [pmid: 9850914].
16 Petersen R C, Smith G E, Waring S C, et al. Aging, memory, and mild cognitive impairment. Int Psychogeriatr. 1997;9(Suppl 1):65-9. [pmid: 9447429].
17 Petersen R C. Mild cognitive impairment: transition between aging and Alzheimer's disease. Neurologia. Mar. 2000;15(3):93-101. [pmid: 10846869].
18 Ritchie K, Artero S, Touchon J. Classification criteria for mild cognitive impairment: a population-based validation study. Neurology. Jan 9. 2001;56(1):37-42. [pmid: 11148233].
19 Whitehouse P J, Kittner B, Roessner M, et al. Clinical trial designs for demonstrating disease-course-altering effects in dementia. Alzheimer Dis Assoc Disord. Dec. 1998;12(4):281-94. [pmid: 9876956].
20 Rockwood K, MacKnight C. Assessing the clinical importance of statistically significant improvement in anti-dementia drug trials. Neuroepidemiology. May. 2001;20(2):51-6. [pmid: 11359070].
21 Leber P. Slowing the progression of Alzheimer disease: methodologic issues. Alzheimer Dis Assoc Disord 1997; 11 Suppl 5:S10–21; ; discussion S37–9.:S10–S21
22 Gill S S. Representation and eligibility of real-world subjects with dementia in clinical trials of donepezil. Geriatrics Today: Journal of the Canadian Geriatrics Society. 2003;6(2):67.
23 Leber P. Guidelines for the clinical evaluation of anti-dementia drugs. 1st draft. Rockville,MD: US Food and Drug Administration; 1990
24 Rockwood K, Joffres C. Improving clinical descriptions to understand the effects of dementia treatment: Consensus recommendations. Int J Geriatr Psychiatry. 2002;17(11):1006-11. [pmid: 12404649].
25 European Medicine Evaluation Agency (EMEA). Note for guidance on medicinal products in the treatment of Alzheimer's disease. London: EMEA; 1997
26 Gutzmann H, Kuhl K P, Hadler D, et al. Safety and efficacy of idebenone versus tacrine in patients with Alzheimer's disease: Results of a randomized, double-blind, parallel-group multicenter study. Pharmacopsychiatry. Jan. 2002;35(1):12-8. [pmid: 11819153].
27 Mayeux R, Sano M. Drug therapy: Treatment of Alzheimer's disease. N Engl J Med. 1999;341(22):1670-9. [pmid: 10572156].
28 Rosen W G, Mohs R C, Davis K L. A new rating scale for Alzheimer's disease. Am J Psychiatry. Nov. 1984;141(11):1356-64. [pmid: 6496779].
29 Stern R G, Mohs R C, Davidson M, et al. A longitudinal study of Alzheimer's disease: measurement, rate, and predictors of cognitive deterioration. Am J Psychiatry. Mar. 1994;151(3):390-6. [pmid: 8109647].
30 Demers L, Oremus M, Perrault A, et al. Review of outcome measurement instruments in Alzheimer's disease drug trials: Psychometric properties of functional and quality of life scales. J Geriatr Psychiatry Neurol. 2000;13(4):170-80. [pmid: 11128059].
31 Royall D R, Lauterbach E C, Cummings J L, et al. Executive control function: a review of its promise and challenges for clinical research. A report from the Committee on Research of the American Neuropsychiatric Association. J Neuropsychiatry Clin Neurosci. 2002;14(4):377-405. [pmid: 12426407].
32 Oremus M, Perrault A, Demers L, et al. Review of outcome measurement instruments in Alzheimer's disease drug trials: Psychometric properties of global scales. J Geriatr Psychiatry Neurol. 2000;13(4):197-205. [pmid: 11128059].
33 Demers L, Oremus M, Perrault A, et al. Review of outcome measurement instruments in Alzheimer's disease drug trials: Introduction. J Geriatr Psychiatry Neurol. 2000;13(4):161-9. [pmid: 11128059].
34 Perrault A, Oremus M, Demers L, et al. Review of outcome measurement instruments in Alzheimer's disease drug trials: Psychometric properties of behavior and mood scales. J Geriatr Psychiatry Neurol. 2000;13(4):181-96. [pmid: 11128059].
35 Ioannidis J P, Lau J. Improving safety reporting from randomised trials. Drug Saf. 2002;25(2):77-84. [pmid: 11888350].
36 Lasagna L. Balancing risks versus benefits in drug therapy decisions. Clin Ther. 1998;20(Suppl C):C72-C79. [pmid: 9915092].
37 The Cochrane Non Randomized Studies Method Group: Adverse effects subgroup. Proposed draft addition to Cochrane Handbook: Including adverse effects in Cochrane reviews. Internet. http://www.dsru.org/wwwboard/latestdraft.pdf
38 Fergusson D, Aaron S D, Guyatt G, et al. Post-randomisation exclusions: the intention to treat principle and excluding patients from analysis. BMJ. Sep 21. 2002;325(7365):652-4. [pmid: 12242181]. [pmcid: 1124168].
39 Pocock S J, Abdalla M. The hope and the hazards of using compliance data in randomized controlled trials. Stat Med. Feb 15. 1998;17(3):303-17. [pmid: 9493256].
40 Lefebvre C, Clarke MJ. Identifying randomised trials. In: Egger M, Smith DG, Altman DG, editors. Systematic Reviews in Health Care: Meta-analysis in context, 2nd Edition London: BMJ Books; 2001. p. 69–86. Chapter 4
41 Anonymous. The International classification of diseases, 9th revision, clinical modification: ICD-9-CM. 3rd edition. Washington, DC: US Department of Health and Human Services; 1989
42 World Health Organization. The tenth revision of the International Classification of Diseases and relative health problems (ICD-10). Geneva: WHO; 1992
43 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. Washington, DC: American Psychiatric Association; 1980
44 American Psychiatric Association. Diagnostic and statistical manual of mental disorders (3rd ed. rev.): DSM-III-R. Washington, DC: American Psychiatric Association; 1987
45 American Psychiatric Association. Diagnostic criteria from DSM-IV. 1994
46 Roman G C, Tatemichi T K, Erkinjuntti T, et al. Vascular dementia: diagnostic criteria for research studies. Report of the NINDS-AIREN International Workshop. Neurology. Feb. 1993;43(2):250-60. [pmid: 8094895].
47 Petersen R C, Stevens J C, Ganguli M, et al. Practice parameter: Early detection of dementia: Mild cognitive impairment (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. May. 2001;56(9):1133-42. [pmid: 11342677].
48 Graham J E, Rockwood K, Beattie B L, et al. Prevalence and severity of cognitive impairment with and without dementia in an elderly population. Lancet. Jun 21. 1997;349(9068):1793-6. [pmid: 9269213].
49 Graham J E, Rockwood K, Beattie B L, et al. Standardization of the diagnosis of dementia in the Canadian Study of Health and Aging. Neuroepidemiology. 1996;15(5):246-56. [pmid: 8878077].
50 Folstein M F, Folstein S E, McHugh P R. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. Nov. 1975;12(3):189-98. [pmid: 1202204].
51 Hachinski V C, Iliff L D, Zilhka E, et al. Cerebral blood flow in dementia. Arch Neurol. Sep. 1975;32(9):632-7. [pmid: 1164215].
52 Oremus M, Wolfson C, Perrault A, et al. Interrater reliability of the modified Jadad quality scale for systematic reviews of Alzheimer's disease drug trials. Dement Geriatr Cogn Disord. May. 2001;12(3):232-6. [pmid: 11244218].
53 Harris R P, Helfand M, Woolf S H, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
54 Thal L J, Calvani M, Amato A, et al. A 1-year controlled trial of acetyl-l-carnitine in early-onset AD. Neurology. 2000a;55(6):805-10. [pmid: 10994000].
55 Thal L J, Carta A, Clarke W R, et al. A 1-year multicenter placebo-controlled study of acetyl-L-carnitine in patients with Alzheimer's disease. Neurology. 1996a;47(3):705-11. [pmid: 8797468].
56 Sano M, Bell K, Cote L, et al. Double-blind parallel design pilot study of acetyl levocarnitine in patients with Alzheimer's disease. Arch Neurol. Nov. 1992;49(11):1137-41. [pmid: 1444880].
57 Livingston G A, Sax K B, McClenahan Z, et al. Acetyl-l-carnitine in dementia. Int J Geriatr Psychiatry. 1991;6(12):853-60.
58 Spagnoli A, Lucca U, Menasce G, et al. Long-term acetyl-L-carnitine treatment in Alzheimer's disease. Neurology. Nov. 1991;41(11):1726-32. [pmid: 1944900].
59 Rai G, Wright G, Scott L, et al. Double-blind, placebo-controlled study of acetyl-l-carnitine in patients with Alzheimer's disease. Curr Med Res Opin. 1990;11(10):638-47. [pmid: 2178869].
60 Prasher V P, Huxley A, Haque M S, et al. A 24-week, double-blind, placebo-controlled trial of donepezil in patients with Down syndrome and Alzheimer's disease: Pilot study. Int J Geriatr Psychiatry. Mar. 2002;17(3):270-8. [pmid: 11921156].
61 Mohs R C, Doody R S, Morris J C, et al. A 1-year, placebo-controlled preservation of function survival study of donepezil in AD patients. Neurology. Aug 14. 2001;57(3):481-8. [pmid: 11502917].
62 Winblad B, Engedal K, Soininen H, et al. A 1-year, randomized, placebo-controlled study of donepezil in patients with mild to moderate AD. Neurology. 2001b;57(3):489-95. [pmid: 11502918].
63 Feldman H, Gauthier S, Hecker J, et al. A 24-week, randomized, double-blind study of donepezil in moderate to severe Alzheimer's disease. Neurology. Aug 28. 2001;57(4):613-20. [pmid: 11524468].
64 Tariot P N, Cummings J L, Katz I R, et al. A randomised, double-blind, placebo-controlled study of the efficacy and safety of Donepezil in patients with Alzheimer's disease in the nursing home setting. J Am Geriatr Soc. 2001a;49(12):1590-9. [pmid: 11843990].
65 Burns A, Rossor M, Hecker J, et al. The effects of donepezil in Alzheimer's disease - results from a multinational trial. Dement Geriatr Cogn Disord. May. 1999;10(3):237-44. [pmid: 10325453].
66 Rogers S L, Farlow M R, Doody R S, et al. A 24-week, double-blind, placebo-controlled trial of donepezil in patients with Alzheimer's disease. Neurology. 1998b;50(1):136-45. [pmid: 9443470].
67 Rogers S L, Doody R S, Mohs R C, et al. Donepezil improves cognition and global function in Alzheimer disease: A 15-week, double-blind, placebo-controlled study. Arch Intern Med. 1998a;158(9):1021-31. [pmid: 9588436].
68 Pratt RD, Perdomo CA. Donepezil-treated patients with probable vascular dementia demonstrate cognitive benefits. Ann N Y Acad Sci 2002 Nov;977:513–22.:513–22.
69 Rogers S L, Friedhoff L T. The efficacy and safety of donepezil in patients with Alzheimer's disease: Results of a US Multicentre, Randomized, double-blind, placebo-controlled trial. The Donepezil Study Group. Dementia. Nov. 1996;7(6):293-303. [pmid: 8915035].
70 Thomas A, Iacono D, Bonanni L, et al. Donepezil, rivastigmine, and vitamin E in Alzheimer disease: A combined P300 event-related potentials/neuropsychologic evaluation over 6 months. Clin Neuropharmacol. Jan. 2001;24(1):31-42. [pmid: 11290880].
71 Erkinjuntti T, Kurz A, Gauthier S, et al. Efficacy of galantamine in probable vascular dementia and Alzheimer's disease combined with cerebrovascular disease: A randomised trial. Lancet. Apr 13. 2002;359(9314):1283-90. [pmid: 11965273].
72 Rockwood K, Mintzer J, Truyen L, et al. Effects of a flexible galantamine dose in Alzheimer's disease: a randomised, controlled trial. J Neurol Neurosurg Psychiatry. 2001;71(5):589-95. [pmid: 11606667].
73 Wilkinson D, Murray J. Galantamine: A randomized, double-blind, dose comparison in patients with Alzheimer's disease. Int J Geriatr Psychiatry. Sep. 2001;16(9):852-7. [pmid: 11571763].
74 Tariot P N, Solomon P R, Morris J C, et al. A 5-month, randomized, placebo-controlled trial of galantamine in AD. The Galantamine USA-10 Study Group. Neurology. Jun 27. 2000;54(12):2269-76. [pmid: 10881251].
75 Wilcock G K, Lilienfeld S, Gaens E. Efficacy and safety of galantamine in patients with mild to moderate Alzheimer's disease: Multicentre randomised controlled trial. Galantamine International-1 Study Group. BMJ. Dec 9. 2000;321(7274):1445-9. [pmid: 11110737]. [pmcid: 27547].
76 Raskind M A, Peskind E R, Wessel T, et al. Galantamine in AD: A 6-month randomized, placebo-controlled trial with a 6-month extension. The Galantamine USA-1 Study Group. Neurology. Jun 27. 2000;54(12):2261-8. [pmid: 10881250].
77 Gelinas I, Gauthier L, McIntyre M, et al. Development of a functional measure for persons with Alzheimer's disease: the disability assessment for dementia. Am J Occup Ther. Sep. 1999;53(5):471-81. [pmid: 10500855].
78 Becker R E, Colliver J A, Markwell S J, et al. Double-blind, placebo-controlled study of metrifonate, an acetylcholinesterase inhibitor, for Alzheimer's disease. Alzheimer Dis Assoc Disord. 1996;10(3):124-31. [pmid: 8876775].
79 Becker R E, Colliver J A, Markwell S J, et al. Effects of metrifonate on cognitive decline in Alzheimer's disease: A double-blind, placebo-controlled, 6-month study. Alzheimer Dis Assoc Disord. Mar. 1998;12(1):54-7. [pmid: 9539412].
80 Cummings J, Bieber F, Mas J, et al. Metrifonate in Alzheimer's disease results of a dose finding study. Alzheimers Dis Biol Diagn Ther 1997:665–9.
81 Cummings J L, Cyrus P A, Bieber F, et al. Metrifonate treatment of the cognitive deficits of Alzheimer's disease. Neurology. 1998b;50(5):1214-21. [pmid: 9595966].
82 Dubois B, McKeith I, Orgogozo J M, et al. A multicentre, randomized, double-blind, placebo-controlled study to evaluate the efficacy, tolerability and safety of two doses of metrifonate in patients with mild-to-moderate Alzheimer's disease: The MALT study. Int J Geriatr Psychiatry. Nov. 1999;14(11):973-82. [pmid: 10556869].
83 Jann M W, Cyrus P A, Eisner L S, et al. Efficacy and safety of a loading-dose regimen versus a no-loading-dose regimen of metrifonate in the symptomatic treatment of Alzheimer's disease: A randomized, double-masked, placebo-controlled trial. Clin Ther. 1999;21(1):88-102. [pmid: 10090427].
84 Morris J C, Cyrus P A, Orazem J, et al. Metrifonate benefits cognitive, behavioral, and global function in patients with Alzheimer's disease. Neurology. May. 1998;50(5):1222-30. [pmid: 9595967].
85 Pettigrew L C, Bieber F, Lettieri J, et al. Pharmacokinetics, pharmacodynamics, and safety of metrifonate in patients with Alzheimer's disease. J Clin Pharmacol. Mar. 1998;38(3):236-45. [pmid: 9549662].
86 Raskind M A, Cyrus P A, Ruzicka B B, et al. The effects of metrifonate on the cognitive, behavioral, and functional performance of Alzheimer's disease patients. J Clin Psychiatry. 1999;60(5):318-25. [pmid: 10362441].
87 Nordberg A, Svensson A L. Cholinesterase inhibitors in the treatment of Alzheimer's disease: a comparison of tolerability and pharmacology. Drug Saf. Dec. 1998;19(6):465-80. [pmid: 9880090].
88 Winblad B, Bonura ML, Rossini BM, et al. Nicergoline in the treatment of mild-to-moderate alzheimer's disease: A European multicentre trial. Clin Drug Investig 2001a(9):621–32.
89 Herrmann W M, Stephan K, Gaede K, et al. A multicenter randomized double-blind study on the efficacy and safety of nicergoline in patients with multi-infarct dementia. Dement Geriatr Cogn Disord. Jan. 1997;8(1):9-17. [pmid: 8997547].
90 Nappi G, Bono G, Merlo P, et al. Long-term nicergoline treatment of mild to moderate senile dementia. Results of a multicentre, double-blind, placebo-controlled study. Clin Drug Investig 1997(6):308–16.
91 Saletu B, Paulus E, Linzmayer L, et al. Nicergoline in senile dementia of Alzheimer type and multi-infarct dementia: A double-blind, placebo-controlled, clinical and EEG/ERP mapping study. Psychopharmacologia. Feb. 1995;117(4):385-95.
92 Schneider F, Popa R, Mihalas G, et al. Superiority of antagonic-stress composition versus nicergoline in gerontopsychiatry. Ann N Y Acad Sci. Jun. 1994;717:332-42. [pmid: 8030850].
93 Saletu B, Anderer P, Semlitsch H V. Relations between symptomatology and brain function in dementias: Double-blind, placebo-controlled, clinical and EEG/ERP mapping studies with nicergoline. Dement Geriatr Cogn Disord. 1997;Vol 8(Suppl 1):12-21. [pmid: 9205834].
94 Moller H J, Hampel H, Hegerl U, et al. Double-blind, randomized, placebo-controlled clinical trial on the efficacy and tolerability of a physostigmine patch in patients with senile dementia of the Alzheimer type. Pharmacopsychiatry. May. 1999;32(3):99-106. [pmid: 10463377].
95 Thal L J, Schwartz G, Sano M, et al. A multicenter double-blind study of controlled-release physostigmine for the treatment of symptoms secondary to Alzheimer's disease. Neurology. 1996b;47(6):1389-95. [pmid: 8960716].
96 Thal L J, Ferguson J M, Mintzer J, et al. A 24-week randomized trial of controlled-release physostigmine in patients with Alzheimer's disease. Neurology. Apr 12. 1999;52(6):1146-52. [pmid: 10214735].
97 Van Dyck C H, Newhouse P. Extended-release physostigmine in Alzheimer's disease: A multicenter, double-blind, 12-week study with dose enrichment. Arch Gen Psychiatry. 2000;57(2):157-64. [pmid: 10665618].
98 Ferrari E, Cucinotta D, Albizatti M G, et al. Effectiveness and safety of posatirelin in the treatment of senile dementia: A multicenter, double-blind, placebo-controlled study. Arch Gerontol Geriatr. 1998;27(Suppl 6):163-74.
99 Gasbarrini G, Stefanini G, Addolorato G, et al. Posatirelin for the treatment of degenerative and vascular dementia: Results of explanatory and pragmatic efficacy analyses. Arch Gerontol Geriatr. 1997;26(1):33-47.
100 Parnetti L, Ambrosoli L, Agliati G, et al. Posatirelin in the treatment of vascular dementia: A double-blind multicentre study vs placebo. Acta Neurol Scand. Jun. 1996;93(6):456-63. [pmid: 8836309].
101 Parnetti L, Ambrosoli L, Abate G, et al. Posatirelin for the treatment of late-onset Alzheimer's disease: A double-blind multicentre study vs citicoline and ascorbic acid. Acta Neurol Scand. Aug. 1995;92(2):135-40. [pmid: 7484061].
102 Agid Y, Dubois B, Anand R, et al. Efficacy and tolerability of rivastigmine in patients with dementia of the Alzheimer type. Curr Ther Res Clin Exp. 1998;59(12):837-45.
103 Corey-Bloom J R, Anand J V, Veach J, et al. A randomized trial evaluating the efficacy and safety of ENA 713 (rivastigmine tartrate), a new acetylcholinesterase inhibitor, in patients with mild to moderately severe Alzheimer's disease. Int J Geriatr Psychopharmacol. 1998;1:55-65.
104 Rosler M, Anand R, Cicin-Sain A, et al. Efficacy and safety of rivastigmine in patients with Alzheimer's disease: International randomised controlled trial. BMJ. Mar 6. 1999;318(7184):633-8. [pmid: 10066203]. [pmcid: 27767].
105 Forette F, Anand R, Gharabawi G. A phase II study in patients with Alzheimer's disease to assess the preliminary efficacy and maximum tolerated dose of rivastigmine (Exelon registered ). Eur J Neurol. 1999;6(4):423-9. [pmid: 10362894].
106 McKeith I, Del Ser T, Spano P, et al. Efficacy of rivastigmine in dementia with Lewy bodies: A randomised, double-blind, placebo-controlled international study. Lancet. Dec 16. 2000;356(9247):2031-6. [pmid: 11145488].
107 Potkin S G, Anand R, Fleming K, et al. Brain metabolic and clinical effects of rivastigmine in Alzheimer's disease. Int J Neuropsychopharmacol. Sep. 2001;4(3):223-30. [pmid: 11602028].
108 Knapp M J, Knopman D S, Solomon P R, et al. A 30-week randomized controlled trial of high-dose tacrine in patients with Alzheimer's disease. The Tacrine Study Group. JAMA. 1994b;271(13):985-91. [pmid: 8139083].
109 Maltby N, Broe G A, Creasey H, et al. Efficacy of tacrine and lecithin in mild to moderate Alzheimer's disease: Double blind trial. BMJ. Apr 2. 1994;308(6933):879-83. [pmid: 8173365].
110 Prentice N, Van B M, Dougall N J, et al. A double-blind, placebo-controlled study of tacrine in patients with Alzheimer's disease using SPET. J Psychopharmacol (Oxf). 1996;10(3):175-81.
111 Weinstein H C, Teunisse S, Van Gool W A. Tetrahydroaminoacridine and lecithin in the treatment of Alzheimer's disease. Effect on cognition, functioning in daily life, behavioural disturbances and burden experienced by the carers. J Neurol. Feb. 1991;238(1):34-8. [pmid: 2030370].
112 Wong W J, Liu H C, Fuh J L, et al. A double-blind, placebo-controlled study of tacrine in Chinese patients with Alzheimer's disease. Dement Geriatr Cogn Disord. Jul. 1999;10(4):289-94. [pmid: 10364647].
113 Wood P C, Castleden C M. A double-blind, placebo controlled, multicentre study of tacrine for Alzheimer's disease. Int J Geriatr Psychiatry. 1994;9(8):649-54.
114 Allain H, Schuck S, Lebreton S, et al. Aminotransferase levels and silymarin in de novo tacrine-treated patients with Alzheimer's disease. Dement Geriatr Cogn Disord. May. 1999;10(3):181-5. [pmid: 10325444].
115 Huff F J, Antuono P, Murphy M, et al. Potential clinical use of an adrenergic/cholinergic agent (HP 128) in the treatment of Alzheimer's disease. Ann N Y Acad Sci. 1991;640:263-7. [pmid: 1776748].
116 Antuono P G. Effectiveness and safety of velnacrine for the treatment of Alzheimer's disease. A double-blind, placebo-controlled study. Mentane Study Group. Arch Intern Med. Sep 11. 1995;155(16):1766-72. [pmid: 7654110].
117 Zemlan F P, Folks D G, Goldstein B J, et al. Velnacrine for the treatment of Alzheimer's disease: A double-blind, placebo-controlled trial. J Neural Transm Gen Sect. 1996;103(89):1105-16.
118 Imbimbo B P, Martelli P, Troetel W M, et al. Efficacy and safety of eptastigmine for the treatment of patients with Alzheimer's disease. Neurology. Mar 10. 1999;52(4):700-8. [pmid: 10078713].
119 Canal N, Imbimbo B P. Relationship between pharmacodynamic activity and cognitive effects of eptastigmine in patients with Alzheimer's disease. Clin Pharmacol Ther. 1996;60(2):218-28. [pmid: 8823240].
120 Rockwood K, Beattie B L, Eastwood M R, et al. A randomized, controlled trial of linopirdine in the treatment of Alzheimer's disease. Can J Neurol Sci. May. 1997;24(2):140-5. [pmid: 9164692].
121 Van Dyck C H, Lin C H, Robinson R, et al. The acetylcholine releaser linopirdine increases parietal regional cerebral blood flow in Alzheimer's disease. Psychopharmacologia. Aug. 1997;132(3):217-26.
122 Xu S S, Gao Z X, Weng Z, et al. Efficacy of tablet huperzine-A on memory, cognition, and behavior in Alzheimer's disease. Zhongguo Yao Li Xue Bao/Acta Pharmacologica Sinica. Sep. 1995;16(5):391-5.
123 Mohr E, Nair N P, Sampson M, et al. Treatment of Alzheimer's disease with sabeluzole: Functional and structural correlates. Clin Neuropharmacol. Aug. 1997;20(4):338-45. [pmid: 9260731].
124 Allain H, Dautzenberg P H, Maurer K, et al. Double blind study of tiapride versus haloperidol and placebo in agitation and aggressiveness in elderly patients with cognitive impairment. Psychopharmacologia. Mar. 2000;148(4):361-6.
125 Teri L, Logsdon R G, Peskind E, et al. Treatment of agitation in AD: A randomized, placebo-controlled clinical trial. Neurology. Nov 14. 2000;55(9):1271-8. [pmid: 11087767].
126 Petrie W M, Ban T A, Berney S, et al. Loxapine in psychogeriatrics: A placebo- and standard-controlled clinical investigation. J Clin Psychopharmacol. Apr. 1982;2(2):122-6. [pmid: 7042770].
127 De Deyn P P, Rabheru K. A randomized trial of risperidone, placebo, and haloperidol for behavioral symptoms of dementia. Neurology. Sep 22. 1999;53(5):946-55. [pmid: 10496251].
128 Auchus A P, Bissey-Black C. Pilot study of haloperidol, fluoxetine, and placebo for agitation in Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 1997;9(4):591-3. [pmid: 9447502].
129 Carlyle W, Ancill R J, Sheldon L. Aggression in the demented patient: a double-blind study of loxapine versus haloperidol. Int Clin Psychopharmacol. 1993;8(2):103-8. [pmid: 8345158].
130 Coccaro E F, Kramer E, Zemishlany Z, et al. Pharmacologic treatment of noncognitive behavioral disturbances in elderly demented patients. Am J Psychiatry. Dec. 1990;147(12):1640-5. [pmid: 2244643].
131 Chan W C, Lam L C, Choy C N, et al. A double-blind randomised comparison of risperidone and haloperidol in the treatment of behavioural and psychological symptoms in Chinese dementia patients. Int J Geriatr Psychiatry. Dec. 2001;16(12):1156-62. [pmid: 11748775].
132 Winblad B, Poritis N. Memantine in severe dementia: Results of the 9M-Best Study (Benefit and efficacy in severely demented patients during treatment with memantine). Int J Geriatr Psychiatry. Feb. 1999;14(2):135-46. [pmid: 10885864].
133 Orgogozo J, Rigaud A S, Stoffler A, et al. Efficacy and safety of memantine in patients with mild to moderate vascular dementia. Stroke. 2002;33:1834-9. [pmid: 12105362].
134 Wilcock G, Mobius H J, Stoffler A. A double-blind, placebo-controlled multicentre study of memantine in mild to moderate vascular dementia (MMM500). Int Clin Psychopharmacol. 2002;17(6):297-305. [pmid: 12409683].
135 Sano M, Ernesto C, Thomas R G, et al. A controlled trial of selegiline, alpha-tocopherol, or both as treatment for Alzheimer's disease. The Alzheimer's Disease Cooperative Study. N Engl J Med. 1997;336(17):1216-22. [pmid: 9110909].
136 Mangoni A, Grassi M P, Frattola L, et al. Effects of a MAO-B inhibitor in the treatment of Alzheimer disease. Eur Neurol. 1991;31(2):100-7. [pmid: 1904354].
137 Agnoli A, Fabbrini G, Fioravanti M, et al. CBF and cognitive evaluation of Alzheimer type patients before and after IMAO-B treatment: a pilot study. Eur Neuropsychopharmacol. Mar. 1992;2(1):31-5. [pmid: 1638171].
138 Burke W J, Roccaforte W H, Wengel S P, et al. L-deprenyl in the treatment of mild dementia of the Alzheimer type: Results of a 15-month trial. J Am Geriatr Soc. 1993a;41(11):1219-25. [pmid: 8227897].
139 Filip V, Kolibas E. Selegiline in the treatment of Alzheimer's disease: A long-term randomized placebo-controlled trial. Czech and Slovak Senile Dementia of Alzheimer Type Study Group. J Psychiatry Neurosci. May. 1999;24(3):234-43. [pmid: 10354658]. [pmcid: 1189014].
140 Freedman M, Rewilak D, Xerri T, et al. L-deprenyl in Alzheimer's disease: Cognitive and behavioral effects. Neurology. 1998;50(3):660-8. [pmid: 9521253].
141 Cutler N R, Shrotriya R C, Sramek J J, et al. The use of the Computerized Neuropsychological Test Battery (CNTB) in an efficacy and safety trial of BMY 21,502 in Alzheimer's disease. Ann N Y Acad Sci. 1993;695(Sep 24):332-6. [pmid: 8239308].
142 Alvarez X A, Pichel V, Perez P, et al. Double-blind, randomized, placebo-controlled pilot study with anapsos in senile dementia: Effects on cognition, brain bioelectrical activity and cerebral hemodynamics. Methods & Findings in Experimental & Clinical Pharmacology. Sep. 2000;22(7):585-94. [pmid: 11196347].
143 Olin J T, Fox L S, Pawluczyk S, et al. A pilot randomized trial of carbamazepine for behavioral symptoms in treatment-resistant outpatients with Alzheimer's disease. Am J Geriatr Psychiatry. 2001;9(4):400-5. [pmid: 11739066].
144 Tariot P N, Erb R, Podgorski C A, et al. Efficacy and tolerability of carbamazepine for agitation and aggression in dementia. Am J Psychiatry. Jan. 1998;155(1):54-61. [pmid: 9433339].
145 Pollock B G, Mulsant B H, Rosen J, et al. Comparison of citalopram, perphenazine, and placebo for the acute treatment of psychosis and behavioral disturbances in hospitalized, demented patients. Am J Psychiatry. 2002;159(3):460-5. [pmid: 12202285].
146 Nyth A L, Gottfries C G. The clinical efficacy of citalopram in treatment of emotional disturbances in dementia disorders. A Nordic multicentre study. Br J Psychiatry. Dec. 1990;157:894-901. [pmid: 1705151].
147 Tariot P N, Schneider L S, Mintzer J E, et al. Safety and tolerability of divalproex sodium in the treatment of signs and symptoms of mania in elderly patients with dementia: Results of a double-blind, placebo-controlled trial. Curr Ther Res Clin Exp. 2001b;62(1):51-67.
148 Porsteinsson A P, Tariot P N, Erb R, et al. Placebo-controlled study of divalproex sodium for agitation in dementia. Am J Geriatr Psychiatry. 2001;9(1):58-66. [pmid: 11156753].
149 Petracca G M, Chemerinski E, Starkstein S E. A double-blind, placebo-controlled study of fluoxetine in depressed patients with Alzheimer's disease. Int Psychogeriatr. Jun. 2001;13(2):233-40. [pmid: 11495397].
150 Barnes R, Veith R, Okimoto J. Efficacy of antipsychotic medications in behaviorally disturbed dementia patients. Am J Psychiatry. 1982;139(9):1170-4. [pmid: 7114310].
151 Street J S, Clark W S, Gannon K S, et al. Olanzapine treatment of psychotic and behavioral symptoms in patients with Alzheimer disease in nursing care facilities: A double-blind, randomized, placebo-controlled trial. The HGEU Study Group. Arch Gen Psychiatry. Oct. 2000;57(10):968-76. [pmid: 11015815].
152 Meehan K M, Wang H, David S R, et al. Comparison of rapidly acting intramuscular olanzapine, lorazepam, and placebo: A double-blind, randomized study in acutely agitated patients with dementia. Neuropsychopharmacology. Apr. 2002;26(4):494-504. [pmid: 11927174].
153 Amaducci L. Phosphatidylserine in the treatment of Alzheimer's disease: Results of a multicenter study. Psychopharmacol Bull. 1988;24(1):130-4. [pmid: 3290936].
154 Crook T, Petrie W, Wells C, et al. Effects of phosphatidylserine in Alzheimer's disease. Psychopharmacol Bull. 1992a;28(1):61-6. [pmid: 1609044].
155 Katz I R, Jeste D V, Mintzer J E, et al. Comparison of risperidone and placebo for psychosis and behavioral disturbances associated with dementia: A randomized, double-blind trial. J Clin Psychiatry. 1999;60(2):107-15. [pmid: 10084637].
156 Magai C, Kennedy G, Cohen C I, et al. A controlled clinical trial of sertraline in the treatment of depression in nursing home patients with late-stage Alzheimer's disease. Am J Geriatr Psychiatry. 2000;8(1):66-74. [pmid: 10648297].
157 Lyketsos C G, Sheppard J M, Steele C D, et al. Randomized, placebo-controlled, double-blind clinical trial of sertraline in the treatment of depression complicating Alzheimer's disease: Initial results from the Depression in Alzheimer's Disease study. Am J Psychiatry. Oct. 2000;157(10):1686-9. [pmid: 11007727].
158 Dehlin O, Hedenrud B, Jansson P, et al. A double-blind comparison of alaproclate and placebo in the treatment of patients with senile dementia. Acta Psychiatr Scand. Feb. 1985;71(2):190-6. [pmid: 3883697].
159 Reifler B V, Teri L, Raskind M, et al. Double-blind trial of imipramine in Alzheimer's disease patients with and without depression. Am J Psychiatry. Jan. 1989;146(1):45-9. [pmid: 2643356].
160 Claus J J, de K I, van Harskamp F, et al. Lisuride treatment of Alzheimer's disease. A preliminary placebo-controlled clinical trial of safety and therapeutic efficacy. Clin Neuropharmacol. May. 1998;21(3):190-5. [pmid: 9617511].
161 Passeri M, Cucinotta D, de Mello M, et al. Comparison of minaprine and placebo in the treatment of Alzheimer's disease and multi-infarct dementia. Int J Geriatr Psychiatry. 1987;2(2):97-103.
162 Roth M, Mountjoy C Q, Amrein R. Moclobemide in elderly patients with cognitive decline and depression: An international double-blind, placebo-controlled trial. Br J Psychiatry. Feb. 1996;168(2):149-57. [pmid: 8837903].
163 Moller H J, Hartmann A, Kessler C, et al. Naftidrofuryl in the treatment of vascular dementia. Eur Arch Psychiatry Clin Neurosci. 2001;251(6):247-54. [pmid: 11881837].
164 Bodick N C, Offen W W, Levey A I, et al. Effects of xanomeline, a selective muscarinic receptor agonist, on cognitive function and behavioral symptoms in Alzheimer's disease. Arch Neurol. Apr. 1997;54(4):465-73. [pmid: 9109749].
165 Olafsson K, Jorgensen S, Jensen H V, et al. Fluvoxamine in the treatment of demented elderly patients: A double-blind, placebo-controlled study. Acta Psychiatr Scand. Jun. 1992;85(6):453-6. [pmid: 1642129].
166 Thal L J, Forrest M, Loft H, et al. Lu 25-109, a muscarinic agonist, fails to improve cognition in Alzheimer's disease. Lu25-109 Study Group. Neurology. 2000b;54(2):421-6. [pmid: 10668706].
167 Fuchs A, Hehnke U, Erhart C, et al. Video rating analysis of effect of maprotiline in patients with dementia and depression. Pharmacopsychiatry. Mar. 1993;26(2):37-41. [pmid: 8378411].
168 Ruether E, Husmann R, Kinzler E, et al. A 28-week, double-blind, placebo-controlled study with Cerebrolysin in patients with mild to moderate Alzheimer's disease. Int Clin Psychopharmacol. Sep. 2001;16(5):253-63. [pmid: 11552768].
169 Bae C Y, Cho C Y, Cho K, et al. A double-blind, placebo-controlled, multicenter study of Cerebrolysin for Alzheimer's disease. J Am Geriatr Soc. Dec. 2000;48(12):1566-71. [pmid: 11129744].
170 Xiao S, Yan H, Yao P, et al. Efficacy of FPF 1070 (cerebrolysin) in patients with Alzheimer's disease: A multicentre, randomised, double-blind, placebo-controlled trial. Clin Drug Investig 2000(1):43–53.
171 Xiao S, Yan H, Yao P, et al. The efficacy of cerebrolysin in patients with vascular dementia: Results of a Chinese multicentre, randomised, double-blind, placebo-controlled trial. Hong Kong Journal of Psychiatry 1999(2):13–9.
172 Ruether E, Ritter R, Apecechea M, et al. Efficacy of the peptidergic nootropic drug cerebrolysin in patients with senile dementia of the Alzheimer type (SDAT). Pharmacopsychiatry. Jan. 1994;27(1):32-40. [pmid: 8159781].
173 Panisset M, Gauthier S, Moessler H, et al. Cerebrolysin in Alzheimer's disease: A randomized, double-blind, placebo-controlled trial with a neurotrophic agent. J Neural Transm Gen Sect. 2002;109(78):1089-104.
174 Asthana S, Baker L D, Craft S, et al. High-dose estradiol improves cognition for women with AD: Results of a randomized study. Neurology. Aug 28. 2001;57(4):605-12. [pmid: 11524467].
175 Wang P N, Liao S Q, Liu R S, et al. Effects of estrogen on cognition, mood, and cerebral blood flow in AD: A controlled study. Neurology. Jun 13. 2000;54(11):2061-6. [pmid: 10851363].
176 Henderson V W, Paganini-Hill A, Miller B L, et al. Estrogen for Alzheimer's disease in women: Randomized, double-blind, placebo-controlled trial. Neurology. Jan 25. 2000;54(2):295-301. [pmid: 10668686].
177 Mulnard RA, Cotman CW, Kawas C, et al. Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: A randomized controlled trial. JAMA 2000(8):1007–15.
178 Kyomen H H, Satlin A, Hennen J, et al. Estrogen therapy and aggressive behavior in elderly patients with moderate-to-severe dementia: Results from a short-term, randomized, double-blind trial. Am J Geriatr Psychiatry. 1999;7(4):339-48. [pmid: 10521168].
179 Le Bars PL, Katz MM, Berman N, et al. A placebo-controlled, double-blind, randomized trial of an extract of Ginkgo biloba for dementia. JAMA 1997(16):1327–32.
180 Maurer K, Ihl R, Dierks T, et al. Clinical efficacy of Ginkgo biloba special extract EGb 761 in dementia of the Alzheimer type. J Psychiatr Res. Nov. 1997;31(6):645-55. [pmid: 9447569].
181 Kanowski S, Herrmann W M, Stephan K, et al. Proof of efficacy of the Ginkgo biloba special extract EGb 761 in outpatients suffering from mild to moderate primary degenerative dementia of the Alzheimer type or multi-infarct dementia. Pharmacopsychiatry. Mar. 1996;29(2):47-56. [pmid: 8741021].
182 Bergamasco B, Scarzella L, La Commare P. Idebenone, a new drug in the treatment of cognitive impairment in patients with dementia of the Alzheimer type. Funct Neurol. May. 1994;9(3):161-8. [pmid: 7988944].
183 Gutzmann H, Hadler D. Sustained efficacy and safety of idebenone in the treatment of Alzheimer's disease: Update on a 2-year double-blind multicentre study. J Neural Transm Suppl. 1998;54:301-10. [pmid: 9850939].
184 Marigliano V, Abate G, Barbagallo-Sangiorgi G, et al. Randomized, double-blind, placebo controlled, multicentre study of idebenone in patients suffering from multi-infarct dementia. Arch Gerontol Geriatr. 1992;15(3):239-48. [pmid: 15374363].
185 Weyer G, Babej-Dolle R M, Hadler D, et al. A controlled study of 2 doses of idebenone in the treatment of Alzheimer's disease. Neuropsychobiology. 1997;36(2):73-82. [pmid: 9267856].
186 Bottini G, Vallar G, Cappa S, et al. Oxiracetam in dementia: A double-blind, placebo-controlled study. Acta Neurol Scand. Sep. 1992;86(3):237-41. [pmid: 1414239].
187 Maina G, Fiori L, Torta R, et al. Oxiracetam in the treatment of primary degenerative and multi-infarct dementia: A double-blind, placebo-controlled study. Neuropsychobiology. 1989;21(3):141-5. [pmid: 2693996].
188 Mangoni A, Perin C, Smirne S, et al. A double-blind, placebo-controlled study with oxiracetam in demented patients administered the Luria-Nebraska Neuropsychological Battery. Drug Dev Res. 1988;14(34):217-4.
189 Rozzini R, Zanetti O, Bianchetti A. Effectiveness of oxiracetam therapy in the treatment of cognitive deficiencies secondary to primary degenerative dementia. Acta Neurol (Napoli). Apr. 1992;14(2):117-26. [pmid: 1414555].
190 Villardita C, Grioli S, Lomeo C, et al. Clinical studies with oxiracetam in patients with dementia of Alzheimer type and multi-infarct dementia of mild to moderate degree. Neuropsychobiology. 1992;25(1):24-8. [pmid: 1603291].
191 Knezevic S. European Pentoxifylline Multi-Infarct Dementia Study. Eur Neurol. 1996;36(5):315-21. [pmid: 8864715].
192 Black R S, Barclay L L, Nolan K A, et al. Pentoxifylline in cerebrovascular dementia. J Am Geriatr Soc. Mar. 1992;40(3):237-44. [pmid: 1538042].
193 Ghose K. Oxpentifylline in dementia: A controlled study. Arch Gerontol Geriatr. Apr. 1987;6(1):19-26. [pmid: 3592847].
194 Parnetti L, Mari D, Abate G, et al. Vascular dementia Italian sulodexide study (VA.D.I.S.S.). Clinical and biological results. Thromb Res. Jul 15. 1997;87(2):225-33. [pmid: 9259113].
195 Marcusson J, Rother M, Kittner B, et al. A 12-month, randomized placebo-controlled trial of propentofylline (HWA 285) in patients with dementia according to DSM III-R. Dement Geriatr Cogn Disord. 1997;8(5):320-8. [pmid: 9298634].
196 Mielke R, Kittner B, Ghaemi M, et al. Propentofylline improves regional cerebral glucose metabolism and neuropsychologic performance in vascular dementia. JNS. Sep 15. 1996;141(12):59-2.
197 Mielke R, Ghaemi M, Kessler J, et al. Propentofylline enhances cerebral metabolic response to auditory memory stimulation in Alzheimer's disease. JNS. Jan 21. 1998;154(1):76-82.
198 Saletu B, Moller H J, Grunberger J, et al. Propentofylline in adult-onset cognitive disorders: double-blind, placebo-controlled, clinical, psychometric and brain mapping studies. Neuropsychobiology. Sep. 1990;24(4):173-84. [pmid: 2135708].
199 Terasawa K, Shimada Y, Kita T, et al. Choto-san in the treatment of vascular dementia: A double-blind, placebo-controlled study. Phytomedicine. 1997;4(1):15-22.
200 Shimada Y, Terasawa K, Yamamoto T, et al. A well-controlled study of Choto-san and placebo in the treatment of vascular dementia. J Tradit Med. 1994;11:246-55.
201 Schellenberg R, Todorova A, Wedekind W, et al. Pathophysiology and psychopharmacology of dementia: A new study design. Neuropsychobiology. 1997;35(3):132-42. [pmid: 9170118].
202 Weyer G, Eul A, Milde K, et al. Cyclandelate in the treatment of patients with mild to moderate primary degenerative dementia of the Alzheimer type or vascular dementia: Experience from a placebo controlled multi-center study. Pharmacopsychiatry. May. 2000;33(3):89-97. [pmid: 10855459].
203 Danielczyk W, Simanyi B, Forette F, et al. CBM 36-733 (2-methyl-alpha-ergokryptine) in primary degenerative dementia: Results of a European multicentre trial. Int J Geriatr Psychiatry. 1988;3(2):107-14.
204 Cucinotta D, De L D, Frattola L, et al. Dihydroergokryptine vs. placebo in dementia of Alzheimer type: Interim results of a randomized multicenter study after a 1-year follow-up. Arch Gerontol Geriatr. 1996;22(2):169-80. [pmid: 15374185].
205 Van Gool W A, Weinstein H C, Scheltens P K, et al. Effect of hydroxychloroquine on progression of dementia in early Alzheimer's disease: An 18-month randomised, double-blind, placebo-controlled study. Lancet. Aug 11. 2001;358(9280):455-60. [pmid: 11513909].
206 Aisen P S, Schmeidler J, Pasinetti G M. Randomized pilot study of nimesulide treatment in Alzheimer's disease. Neurology. Apr 9. 2002;58(7):1050-4. [pmid: 11940691].
207 Pantoni L, Bianchi C, Beneke M, et al. The Scandinavian Multi-Infarct Dementia Trial: A double-blind, placebo-controlled trial on nimodipine in multi-infarct dementia. JNS. 2000a;175(2):116-23.
208 Ban T A, Morey L, Aguglia E, et al. Nimodipine in the treatment of old age dementias. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14(4):525-51. [pmid: 2236581].
209 Soininen H, Koskinen T, Helkala E L, et al. Treatment of Alzheimer's disease with a synthetic ACTH 4–9 analog. Neurology. Sep. 1985;35(9):1348-51. [pmid: 2991817].
210 Kragh-Sorensen P, Olsen R B, Lund S, et al. Neuropeptides: ACTH-peptides in dementia. Prog Neuropsychopharmacol Biol Psychiatry. 1986;10(35):479-92. [pmid: 3025927].
211 Ban T A, Morey L C, Santini V. Clinical investigations with ateroid in old-age dementias. Semin Thromb Hemost. 1991b;17(Suppl 2):161-3. [pmid: 1719637].
212 Crapper McLachlan D R, Dalton A J, Kruck T P, et al. Intramuscular desferrioxamine in patients with Alzheimer's disease. Lancet. Jun 1. 1991;337(8753):1304-8. [pmid: 1674295].
213 Ban T A, Morey L C, Aguglia E, et al. Glycosaminoglycan polysulfate in the treatment of old age dementias. Prog Neuropsychopharmacol Biol Psychiatry. 1991a;15(3):323-42. [pmid: 1862217].
214 Crook T, Wilner E, Rothwell A, et al. Noradrenergic intervention in Alzheimer's disease. Psychopharmacol Bull. 1992b;28(1):67-70. [pmid: 1609045].
215 Shrotriya R C, Cutler N R, Sramek J J, et al. Efficacy and safety of BMY 21,502 in Alzheimer's disease. Ann Pharmacother. Dec. 1996;30(12):1376-80. [pmid: 8968446].
216 Nolan K A, Black R S, Sheu K F, et al. A trial of thiamine in Alzheimer's disease. Arch Neurol. Jan. 1991;48(1):81-3. [pmid: 1986730].
217 Fischhof P K, Moslinger-Gehmayr R, Herrmann W M, et al. Therapeutic efficacy of vincamine in dementia. Neuropsychobiology. 1996;34(1):29-35. [pmid: 8884757].
218 Peabody C A, Davies H, Berger P A, et al. Desamino-D-arginine-vasopressin (DDAVP) in Alzheimer's disease. Neurobiol Aging. Jul. 1986;7(4):301-3. [pmid: 3528891].
219 Kanowski S, Fischhof P K, Grobe-Einsler R, et al. Efficacy of xantinolnicotinate in patients with dementia. Pharmacopsychiatry. May. 1990;23(3):118-24. [pmid: 2197635].
220 Cucinotta D, Aveni Casucci M A, Pedrazzi F, et al. Multicentre clinical placebo-controlled study with buflomedil in the treatment of mild dementia of vascular origin. J Int Med Res. Apr. 1992;20(2):136-49. [pmid: 1521670].
221 Treves T A, Korczyn A D. Denbufylline in dementia: a double-blind controlled study. Dement Geriatr Cogn Disord. Nov. 1999;10(6):505-10. [pmid: 10559567].
222 Scharf S, Mander A, Ugoni A, et al. A double-blind, placebo-controlled trial of diclofenac/misoprostol in Alzheimer's disease. Neurology. Jul 13. 1999;53(1):197-201. [pmid: 10408559].
223 Thompson T L, Filley C M, Mitchell W D, et al. Lack of efficacy of hydergine in patients with Alzheimer's disease. N Engl J Med. Aug 16. 1990;323(7):445-8. [pmid: 2082953].
224 Rogers J, Kirby L C, Hempelman S R, et al. Clinical trial of indomethacin in Alzheimer's disease. Neurology. Aug. 1993;43(8):1609-11. [pmid: 8351023].
225 Ala T, Romero S, Knight F, et al. GM-1 treatment of Alzheimer's disease. A pilot study of safety and efficacy. Arch Neurol. Oct. 1990;47(10):1126-30. [pmid: 2222246].
226 Adair J C, Knoefel J E, Morgan N. Controlled trial of N-acetylcysteine for patients with probable Alzheimer's disease. Neurology. Oct 23. 2001;57(8):1515-7. [pmid: 11673605].
227 Carlson M C, Tschanz J T, Norton M C, et al. H2 histamine receptor blockade in the treatment of Alzheimer disease: A randomized, double-blind, placebo-controlled trial of nizatidine. Alzheimer Dis Assoc Disord. Jan. 2002;16(1):24-30. [pmid: 11882746].
228 Croisile B, Trillet M, Fondarai J, et al. Long-term and high-dose piracetam treatment of Alzheimer's disease. Neurology. Feb. 1993;43(2):301-5. [pmid: 8437693].
229 Aisen P S, Davis K L, Berg J D, et al. A randomized controlled trial of prednisone in Alzheimer's disease. Neurology. 2000b;54(3):588-93. [pmid: 10680787].
230 Simons M, Schwarzler F, Lutjohann D, et al. Treatment with simvastatin in normocholesterolemic patients with Alzheimer's disease: A 26-week randomized, placebo-controlled, double-blind trial. Ann Neurol. 2002;52(3):346-50. [pmid: 12205648].
231 Convit A, de Asis J, de Leon M J, et al. Atrophy of the medial occipitotemporal, inferior, and middle temporal gyri in non-demented elderly predict decline to Alzheimer's disease. Neurobiol Aging. Jan. 2000;21(1):19-26. [pmid: 10794844].
232 Rapp S, Brenes G, Marsh A P. Memory enhancement training for older adults with mild cognitive impairment: A preliminary study. Aging Ment Health. Feb. 2002;6(1):5-11. [pmid: 11827617].
233 Johnson S A, Simmon V F. Randomized, double-blind, placebo-controlled international clinical trial of the AMPAKINE CX516 in elderly participants with mild cognitive impairment. A progress report. J Mol Neurosci. 2002;19(12):197-200. [pmid: 12212780].
234 Sherwin B B. Estrogen and cognitive functioning in men with Mild Cognitive Impairment. J Mol Neurosci. 2002;19(12):219-23. [pmid: 12212785].
235 McDermott M P, Hall W J, Oakes D, et al. Design and analysis of two-period studies of potentially disease-modifying treatments. Control Clin Trials. Dec. 2002;23(6):635-49. [pmid: 12505242].
236 Bodick N, Forette F, Hadler D, et al. Protocols to demonstrate slowing of Alzheimer's disease progression: Position paper from the International Working Group on Harmonization of Dementia Drug Guidelines. Alzheimer Dis Assoc Disord. 1997;11(Suppl 3):50-3. [pmid: 9305517].
237 Ancill R J, Carlyle W W, Liang R A, et al. Agitation in the demented elderly: A role for benzodiazepines?. Int Clin Psychopharmacol. 1991;6(3):141-6. [pmid: 1806620].
238 Cucinotta D, Romagnoli S, Godoli G, et al. Comparison of sulfomucopolysaccharides and cytidine diphosphocholine in the treatment of multi-infarct dementia. A randomized double-blind test. Curr Ther Res Clin Exp. 1988;43(1):12-20.
239 Karlsson I, Godderis J, Augusto De Mendonca L C, et al. A randomised, double-blind comparison of the efficacy and safety of citalopram compared to mianserin in elderly, depressed patients with or without mild to moderate dementia. Int J Geriatr Psychiatry. Apr. 2000;15(4):295-305. [pmid: 10767728].
240 Katona C L, Hunter B N, Bray J. A double-blind comparison of the efficacy and safely of paroxetine and imipramine in the treatment of depression with dementia. Int J Geriatr Psychiatry. Feb. 1998;13(2):100-8. [pmid: 9526179].
241 Taragano F E, Lyketsos C G, Mangone C A, et al. A double-blind, randomized, fixed-dose trial of fluoxetine vs. amitriptyline in the treatment of major depression complicating Alzheimer's disease. Psychosomatics. May. 1997;38(3):246-52. [pmid: 9136253].
242 Popa R, Schneider F, Mihalas G, et al. Antagonic-Stress superiority versus meclofenoxate in gerontopsychiatry. Arch Gerontol Geriatr. 1994;18(Suppl 4):197-206. [pmid: 18649860].
243 Spilich GJ, Wannenmacher W, Duarte A, et al. Efficacy of pyritinol versus hydergine upon cognitive performance in patients with senile dementia of the Alzheimer's type: A double-blind multi-center trial. Alzheimers Res 1996(3):79–84.
244 Gutzmann H, Kuhl K P, Kanowski S, et al. Measuring the efficacy of psychopharmacological treatment of psychomotoric restlessness in dementia: clinical evaluation of tiapride. Pharmacopsychiatry. Jan. 1997;30(1):6-11. [pmid: 9065963].
245 Passeri M, Cucinotta D, Abate G, et al. Oral 5'-methyltetrahydrofolic acid in senile organic mental disorders with depression: Results of a double-blind multicenter study. Aging (Milano). Feb. 1993;5(Milano):63-71. [pmid: 8257478].
246 Ruether E, Alvarez XA, Rainer M, et al. Sustained improvement of cognition and global function in patients with moderately severe Alzheimer's disease: A double-blind, placebo-controlled study with the neurotrophic agent Cerebrolysin. J Neural Transm Suppl 2002(62):265–75.
247 Pantoni L, Rossi R, Inzitari D, et al. Efficacy and safety of nimodipine in subcortical vascular dementia: A subgroup analysis of the Scandinavian Multi-Infarct Dementia Trial. JNS. 2000b;175(2):124-34.
248 Dunne M P, Hartley L R. Scopolamine and the control of attention in humans. Psychopharmacologia. 1986;89(1):94-7.
249 Black D W, Monahan P, Wesner R, et al. The effect of fluvoxamine, cognitive therapy, and placebo on abnormal personality traits in 44 patients with panic disorder. J Personal Disord. 1996;10(2):185-94.
250 Dingemanse J, Bury M, Roncari G, et al. Pharmacokinetics and pharmacodynamics of Ro 41-3696, a novel nonbenzodiazepine hypnotic. J Clin Pharmacol. Aug. 1995;35(8):821-9. [pmid: 8522640].
251 Huster W J, Enas G G. A framework establishing clear decision criteria for the assessment of drug efficacy. Stat Med. Aug 15. 1998;17(1516):1829-38. [pmid: 9749450].
252 Ruberg S, Cairns V. Providing evidence of efficacy for a new drug. Stat Med. Aug 15. 1998;17(1516):1813-23. [pmid: 9749449].
253 Boustani M, Peterson B, Hanson L, et al. Screening for dementia in primary care: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Jun 3. 2003;138(11):927-37. [pmid: 12779304].
254 Knopman D S, DeKosky S T, Cummings J L, et al. Practice parameter: diagnosis of dementia (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. May 8. 2001;56(9):1143-53. [pmid: 11342678].
255 Rockwood K, Stolee P. Responsiveness of outcome measures used in an antidementia drug trial. Alzheimer Dis Assoc Disord. Jul. 2000;14(3):182-5. [pmid: 10994660].
256 Beaton D E, Bombardier C, Katz J N, et al. A taxonomy for responsiveness. J Clin Epidemiol. Dec. 2001;54(12):1204-17. [pmid: 11750189].
257 Als-Nielsen B, Chen W, Gluud C, et al. Association of funding and conclusions in randomized drug trials: a reflection of treatment effect or adverse events?. JAMA. Aug 20. 2003;290(7):921-8. [pmid: 12928469].
258 Khan A. Are placebo controls necessary to test new antidepressants and anxiolytics?. Int J Neuropsychopharmacol. 2002;5(3):193-7. [pmid: 12366872].
259 Bowler J V, Eliasziw M, Steenhuis R, et al. Comparative evolution of Alzheimer disease, vascular dementia, and mixed dementia. Arch Neurol. Jun. 1997;54(6):697-703. [pmid: 9193204].
260 Reisberg B, Ferris S H, de Leon M J, et al. The Global Deterioration Scale for assessment of primary degenerative dementia. Am J Psychiatry. Sep. 1982;139(9):1136-9. [pmid: 7114305].
261 Hughes C P, Berg L, Danziger W L, et al. A new clinical scale for the staging of dementia. Br J Psychiatry. Jun. 1982;140:566-72. [pmid: 7104545].
262 Feinstein A R. “Clinical Judgment” revisited: the distraction of quantitative models. Ann Intern Med. May 1. 1994;120(9):799-805. [pmid: 8042827].