# Acknowledgements

The authors of this report would like to thank and acknowledge the assistance of the following people:

- Sarah Tanner-Bouma, Eileen Estrabillo, Connie Freeborn, Naomi Kirshenbaum, Elizabeth Simmons, Rob Stevens, and Hongmei Wu for assistance with data extraction and preparation of data tables;
- Carol Lefebvre for her assistance in developing the search strategies;
- Angela Eady for her assistance in developing the search strategies and editing the final version of the document;
- Bin Zhu, Gary Foster, and Ayaz Hyder for their assistance with the meta-analysis;
- Amy Steep and Tom Flemming of the McMaster University Health Sciences library for helping us with our searches, retrievals, and development of methods to access the library from off-site;
- Dan Ellington from ISI Researchsoft for answering questions regarding the management of our references and citations;
- Roxanne Cheeseman, Laurie Cocking, Susan Hanna, and Jessica Cheeseman for their assistance in the preparation and distribution of the manuscript.