# Discussion

This systematic review was undertaken primarily to evaluate the efficacy of pharmacological agents in the treatment of dementia. The studies were limited to parallel design RCTs with quality scores greater than 3 on the Jadad scale. The interventions were not limited to those currently on label by the FDA; it was of interest to cast a wide net and capture reports of pharmacological agents that are used off-label for the treatment of dementia. Since a variety of agents with different therapeutic effects were evaluated, the outcomes were not restricted to a specific subset of all available outcomes used in the dementia literature. The psychometric properties of some of the most commonly used outcomes have been critically appraised and found to be limited. Moreover, there is no current consensus as to which domains, and the outcomes within these, that best reflect clinically important change.

## Strength of the Evidence

The studies eligible for review in this dementia report represent the highest form of evidence. This strongly suggests that these trials are more likely to be “well-designed, well conducted studies in representative populations that assess the effects of health outcomes”. ^53^ The high quality scores also indicate that the studies evaluated in this systematic review have a relatively high level of internal validity. The characteristics of the population and the interventions were detailed to assist the reader in evaluating the degree of external validity. Similarly, attempts were made to highlight “consistency” in the evidence as well as the quantity of evidence and the magnitude of the reported changes.

Although, there is greater understanding on evaluating the evidence for the “benefits” of therapies, there is less clarity on determining the potential for harms from pharmacological interventions for treating dementia. With respect to adverse events and the potential for serious harms, greater variability in systematic collection and reporting of these were observed in the dementia pharmacological literature. Evaluation of the potential for harm is considered with three main points: 1) the most frequently reported adverse events across studies for a specific drug, 2) the overall withdrawal rate due to adverse events for both the control and treatment groups, and 3) the range of frequencies reported for a subset of symptoms (nausea, diarrhea, dizziness, agitation, eating disorder) selected a priori and evaluated for all pharmacological interventions.

At present there is no coherent framework that captures the disease processes present in dementia patients for the range of outcomes evaluated in this systematic review. This report details the highest evidence from both a design and internal validity perspective. It is our view that determining the clinical relevance (external validity) of such high-quality evidence must ultimately be reached by consensus amongst multidisciplinary experts within the decision-making body that will use this evidence for such purposes as developing practice guidelines.

## Question 1: Does pharmacotherapy for dementia syndromes improve cognitive symptoms and outcomes?

### Summary of the Systematic Review Results

A total of 97 interventions in 186 studies were eligible for evaluation in this systematic review and were distributed as follows:

- A total of 16 different cholinergic neurotransmitter modifying pharmacological agents in 72 studies.
- A total of 35 non-cholinergic neurotransmitter/neuropeptide modifying agents in 61 studies.
- A total of 46 other pharmacological agents in 76 studies^*^.
  * there are more than 186 studies here because some studies compared a drug from one class with a drug from another, so that study would be in both categories and therefore counted twice.
- two studies compared two NCNMAs with an OTHER.
- two studies compared a CNMA with an OTHER.
- one study compared a CNMA with two OTHERS.
- two studies compared an NCNMA with an OTHER.

The evidence for all these pharmacological agents was presented in great detail in Chapter 3 and in Evidence Tables of Key Study Characteristics, Tables of Study Results, and Tables of Study Adverse Events contained in Appendix C. Conclusions regarding those pharmacological agents that had a minimum of three trials are summarized here. The summary of the pharmacological agents that had fewer than three trials can be found in Chapter 3.

### Summary of Cholinergic Neurotransmitter Modifying Agents

Carnitine. Six trials evaluated carnitine in 925 subjects with mild to moderate severity, recruited predominately from the community at doses of 2 to 3 g for either 24 or 52 weeks. Evidence of benefit is conflicting for the domains of cognition. Most studies were not statistically significant and the lack of sufficient power may have been an important factor. Similarly, no significant differences were found in the domains of global assessment, behavior/mood, and quality of life/ADL; power could not be evaluated for the majority of these outcomes.

Four of the six studies scored 3 for quality on reporting adverse events. Withdrawal rates due to adverse events varied from 0 – 3% (excluding results from one outlier trial ^248^ ), and gastrointestinal symptoms were the most frequently reported types of adverse events. The percent of subjects reporting the a priori symptoms of interest across all studies were as follows: 1) nausea (placebo = 6 – 14%, all doses carnitine = 28%), and 2) agitation (placebo = 6%, all doses carnitine = 7%). Dizziness, diarrhea, or eating disorder were not reported by any study. No serious adverse events requiring hospitalization and associated with carnitine were reported.

Donepezil. Ten trials in 3239 subjects evaluated the efficacy of donepezil compared to placebo, and one trial compared donepezil to a group given vitamin E. The majority of studies (n = 8) evaluated AD patients, for which half were recruited from the community (other studies did not specify). The subjects had predominately mild to moderate disease and doses of 5 or 10 mg were used with varying duration from 12 to 56 weeks.

There is consistent evidence of benefit in the domains of general cognitive function and global assessment. The combined effect sizes for the ADAS-cog and the CIBIC were estimated. Evidence is inconsistent for a dose response in these domains based on the three studies that evaluated two different doses (5 and 10 mg); the benefit was of similar magnitude for both dose groups for global assessment outcomes. Similarly, two of the three studies that evaluated behavior/mood outcomes (NPI) showed no statistically significant changes relative to placebo; these trials lacked sufficient power to detect a difference. There is some evidence of benefit in ADL outcomes, although this outcome domain was evaluated with a variety of instruments. Caregiver burden outcomes was evaluated in a single study that did not report the findings for this domain.

Adverse events quality scores were 3 or greater for the majority of studies (n=7). Four trials provided evidence of a dose response for adverse events. One study showed a statistical difference for balance-related problems and asthenia (neurological fatigue) between placebo and treatment groups. Withdrawal due to adverse events ranged from 0 – 18% for treatment groups and 0 – 11% for placebo. Four out of six studies testing differences between groups were statistically significant for diarrhea (placebo = 3 – 21%, all doses donepezil = 0 – 38%), nausea and vomiting (placebo = 4 – 9%, all doses donepezil = 4 – 25%). The other a priori symptom reported was agitation and frequencies for placebo varied from 0 – 8% and for all doses from 3 – 19%; but these were not shown to be statistically different.

Galantamine. Six trials in 3530 subjects evaluated the efficacy of galantamine compared to placebo. Doses of 24 and 32 mg were evaluated in half of these studies. Five studies evaluated AD patients and there was limited information regarding whether the subjects were from the general community or institutional settings. All studies recruited subjects with mild to moderate disease and the drug was administered with varying duration of 3 or 6 months.

Evidence of benefit is consistent in the domains of general cognitive function, global assessment, quality of life/ADL. Two of the three studies that evaluated, behavior/mood found statistically significant differences. A small dose effect was evident in the ADL domain when comparing the pooled estimates of the DAD; no dose effect was observed for outcomes in the global assessment domain, and dose effect could not be evaluated for the general cognition domain. The caregiver burden domain was not evaluated in any trials.

Five of the six trials scored 3 out of 5 on our quality scale for rating adverse events. Withdrawal rates due to adverse events ranged from 4 – 9% for placebo and 8 – 27% for the treatment group. One study showed a dose response for adverse events. Although, most trials did not report testing for differences between groups, two trials reported a statistically significant difference in weight loss with the treatment group having more than the placebo group. The most common types of adverse events reported were gastrointestinal symptoms (nausea and vomiting, diarrhea), eating disorders/weight loss, and dizziness. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea and vomiting (placebo = 3 – 13%, all doses = 6 – 44%), 2) dizziness (placebo = 3 – 11%, all doses = 4 – 19%), 3) diarrhea (placebo = 2 – 10%, all doses = 4 – 19%), 4) agitation (placebo = 1 – 9%, all doses = 6 – 15%), and 5) eating disorder (placebo = 0 – 6%, all doses = 4 – 20%).

Metrifonate. Nine studies compared metrifonate to placebo in 2759 subjects with mild to moderate AD (likely from community settings as the majority of studies did not specify this). Metrifonate dosages evaluated varied from 50 to 80 mg, and study duration ranged from 21 days to 26 weeks duration.

All but one study showed metrifonate to have a consistent positive effect on measures of general cognitive function; none of the studies evaluated any specific cognitive function measures. The effects on global assessment were less consistent, but suggested a positive effect in four of the eight studies that reported this outcome. Evidence for effect in the domains of behavior/mood and quality of life/ADL were not significant in the majority of studies that evaluated these domains, however these were primarily evaluated as secondary outcomes and likely lacked sufficient power.

With the exception of a single study, quality scores for reporting adverse events were greater than 3. However, only one trial ^83^ tested for differences between groups and found nausea and vomiting, diarrhea, and muscle and joint disorder to be significantly different. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea and vomiting (placebo = 3 – 14%, all doses = 2 – 50%), 2) dizziness (placebo = 1%, all doses = 3 – 4%), 3) diarrhea (placebo = 4 – 14%, all doses = 11 – 19%), 4) agitation (placebo = 2 – 14%, all doses = 8 – 33%), and none reported eating disorder as an adverse event. Withdrawal due to adverse events varied from 0 – 9% for placebo and 0 – 12% for the treatment group. Overall, it was difficult to determine which types of adverse events reported had the potential to cause serious harm. This is noteworthy as metrifonate has been withdrawn from use in North America, and Bayer has suspended Phase III trials, ^87^ because some patients in clinical trials have experienced serious muscle weakness . This decision was based on the results of an experimental study showing risk of respiratory paralysis with the use of metrifonate. Other adverse events of concern included severe leg cramps, dyspepsia, and bradycardia. None of the studies we reviewed indicated that if present, these events differed significantly between groups. It is not clear if this inconsistency is a function of the methods used to collect and report adverse events or a limitation of RCTs as a source of detecting serious adverse events when incidence is low.

Nicergoline. Four trials in 705 subjects compared nicergoline to placebo and one trial compared it to antagonic-stress in mixed populations that included AD, MID, PDD, VaD, mixed dementia, and SDAT, which were classified as mild to moderate in severity.

All placebo-controlled trials found a positive effect for general cognitive outcomes, but half the results were based on OC analyses. The evidence was mixed for benefit in the domain of global assessments. No significant differences were found for behavior/mood, and quality of life/ADL outcomes, but these were evaluated in few studies and as secondary outcomes (suggesting that sufficient power was an issue).

Quality scores for reporting adverse events varied from 2 to 5 for these four trials, and none tested for differences between groups. Withdrawal due to adverse events varied from 0 – 8% for placebo and 0 – 9% for the treatment group. With the exception of headache, which was reported in all four trials, it was difficult to determine which types of adverse events most characterized exposure to this pharmacological agent. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all doses = 3%), 2) dizziness (placebo = 1–2%, all doses = 0% or not reported), 3) diarrhea (placebo = 2 – 6%, all doses = 2 – 4%), 4) agitation (placebo = 5%, all doses = not reported), and none reported eating disorder as an adverse event.

Physostigmine. Four studies of 1198 subjects with mild to moderate AD evaluated physostigmine administered in patch and oral form (30 to 60 mg dose) for study duration varying from 6 to 24 weeks. All subjects were recruited from the community.

There is evidence that physostigmine has a statistically significant effect on general cognitive function, as three of the four studies showed improvement. Evidence for an effect on global function was mixed with no consistent benefit. Similarly, for quality of life/ADL outcomes, all three studies that evaluated this domain were not statistically significant but these were secondary outcomes and may reflect a lack of power. Behavior/mood and caregiver burden were not tested in these trials.

The quality scores for reporting adverse events were generally low, scoring 1 or 2 out of 5. Withdrawal rates due to adverse events varied from 1 – 5% for placebo and 12 – 55% in the treatment group, with one study not reporting rates. The high withdrawal rates were in studies with sample sizes that varied from181 to 475 subjects. A single study tested for differences between groups, and found that dizziness, tremor, weight loss, asthenia, confusion, delirium, and respiratory problems were significantly different. The cluster of reported types of adverse events suggests that gastrointestinal problems (abdominal pain, diarrhea) (placebo = 1 – 9%, all doses = 13 – 28%), nausea and vomiting (placebo = 1 – 9%, all doses = 9 – 75%) and eating disorder (placebo = 2 – 6%, all doses = 5 – 16%) were most frequently reported. Dizziness (placebo = 4 – 13%, all doses = 11 – 38%) and agitation (placebo = 6 – 16%, all doses = 4 – 8%) were also reported.

Posatirelin. Four trials evaluated posatirelin in 931 subjects in a variety of mild to moderate dementia populations (AD, PDD, VaD) using a dose of 10 mg per day over 3 months duration.

Three of the four trials showed statistical significance for general cognitive function and quality of life/ADL (as measured by GBS subscales for these domains). The evidence remains inconsistent for benefit in global assessment (evaluated in only one trial) and behavior/mood (mixed results). Caregiver burden and specific cognitive function were not evaluated in any trial.

Quality scores for reporting adverse events varied from 2 to 4. Withdrawal rates due to adverse events ranged from 0 – 3% in placebo and 0 – 4% in the treatment group. None of the studies tested for significant differences between groups. All studies reported the presence of agitation, and at least three studies reported arrhythmia, nausea/vomiting, headache, rash/skin disorder, and sleep disorder. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all doses = 1 – 4%), 2) dizziness (placebo = not reported, all doses = 1%), 3) diarrhea (placebo = 2%, all doses = 2%), 4) agitation (placebo = 1 – 5%, all doses = 1 – 5%), and none reported eating disorder as an adverse event.

Rivastigmine. Six studies evaluated 2071 subjects and three of these studies were limited to AD patients only. Doses for rivastigmine varied from 1 to 12 mg, and treatment ranged from 14 to 26 weeks and only one study specified a community sample.

The evidence shows that general cognitive function improves with rivastigmine at a dose of 12 mg, but there is mixed results for efficacy at lower doses. Two trials also evaluated specific cognitive function but the results were not consistent within studies (between general and specific measures) and between studies for these domains. There is consistent evidence of benefit for the outcome of global assessment but the dosage at which this is significant varies highly between studies. In the domains of behavior/mood and quality of life/ADL, the findings were not statistically significant nor consistent; most of these analyses were not based on intention to treat analysis and lack of sufficient power cannot be ruled out. Caregiver burden outcomes were not evaluated by any trial.

Quality scores for reporting adverse events varied from 2 to 5. Withdrawal rates due to adverse events ranged from 4 – 11% in the placebo and 11 – 27% in the treatment group. Two trials demonstrated a dose response; however, one of these trials showed significant differences for nausea and vomiting only, and the other trial showed significant difference for all the adverse events reported. The majority of studies reported dizziness, nausea and vomiting, eating disorder/weight loss, and headache. It should be noted that one study allowed intentional prescribed anti-emetic drugs to increase the tolerance of subjects taking rivastigmine. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3 – 10%, all doses = 8 – 58%), 2) dizziness (placebo = 0 – 7%, all doses = 6 – 20 %), 3) diarrhea (placebo = 2 – 9%, all doses = 7 – 17%), 4) eating disorder (placebo = 4 – 8%, all doses = 4 – 19%), and 5) agitation was not reported.

Tacrine. Six studies ^108,^ ^109,^ ^110,^ ^111,^ ^112,^ ^113^ evaluated tacrine in 994 subjects predominately with mild to moderate AD at doses of 80 to 160 mg lasting either 12 – 13 or 3 – 36 weeks in duration. Two other studies ^114,^ ^26^ involving 425 patients were non-placebo controlled studies.

A single trial ^108^ was found to show benefit for general cognitive function with a small effect and this was based on a series of related publications. The five trials showing no benefit for general cognitive function comprised small sample sizes and much shorter study duration. Overall, the evidence for benefit for general cognitive function is limited to this single trial. There is evidence for benefit in global function from two of the three trials that evaluated this domain. Changes in behavior/mood, quality of life/ADL domains, specific cognitive function, and caregiver burden were all not significant, but lack of sufficient power cannot be ruled out.

The quality scores for reporting adverse events varied from 1 to 3. The proportion of subjects withdrawing due to adverse events ranged from 0 – 12% for placebo and 0 – 55% in the treatment group. The higher rates of withdrawal were associated with higher doses. Elevated alanine transaminase (ALT) or hepatic abnormality (placebo = 4 – 13%, all doses tacrine = 7 – 67%) was reported in six studies, raising concerns for the potential for serious liver damage. None of these trials tested for differences between treatment and placebo with respect to adverse events. Five of the studies reported nausea and vomiting (placebo = 0 – 9%, all doses = 9 – 37%); gastrointestinal problems; dizziness (placebo = 0 – 16%, all doses = 4 – 14%) was also noted in several studies. Frequencies of other a priori symptoms of interest are as follows: 1) agitation (placebo = 5 – 12%, all doses = 5 – 9%), and 2) diarrhea (placebo = 0 – 13%, all doses = 4 – 18%). There is evidence for the potential for serious adverse events associated with liver function in six trials.

Velnacrine. Three studies evaluated the effects of velnacrine in 774 AD patients with a diagnosis of AD. The doses that were shown to effect significant changes were 75 mg twice daily and 225 mg daily in studies with a 15 and 24 week duration. Location of recruitment was not specified.

Statistically significant effects were observed for general cognitive function, and global assessment in the two studies with sample sizes over 300 subjects. Behavior/mood and caregiver burden showed some benefit in one trial ^116^ at the highest dose only. Quality of life/ADL was tested as a secondary outcome and showed mixed findings.

Quality scores for reporting adverse events were 3 for all studies. Withdrawal rates varied from 0 – 22% for the placebo group and 5 – 33% for the treatment group. None of the studies reported a dose response. None of the studies tested for statistical differences between the placebo and treatment groups. Two studies reported aberrant hematology and hepatic abnormality; ^116,^ ^117^ for these two studies the rates of occurrence were 2 – 21% for placebo, and 32 – 40% for all doses. All studies reported diarrhea and nausea and vomiting. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 0 – 4%, all doses = 3 – 8%), 2) dizziness (placebo = 3%, all doses = 0 – 8%), 3) diarrhea (placebo = 3%, all doses = 2 – 33%), 4) agitation (placebo = 4%, all doses = 1 – 4%), and 5) eating disorder (placebo = 1%, all doses 2 – 4%). The potential for serious liver effects was not well specified in these trials.

### Summary of Non-cholinergic Neurotransmitter/Neuropeptide Modifying Agents

Haloperidol. Five studies evaluated the effect of haloperidol relative to placebo in a total of 622 subjects with mild to moderate disease and included AD patients ^124,^ ^125,^ ^128^ and mixed populations (MID/VaD/ PDD). ^126,^ ^127^ One trial ^128^ had only 15 patients, and one trial ^124^ lasted only three weeks. Two studies recruited subjects from institutions; one from the community and two did not specify.

Mixed results were observed for improvement in global assessment. In three of the trials there was benefit in the domain of behavior/mood which reached statistical significance. Two trials evaluated caregiver burden and found no statistically significant differences but lack of sufficient power cannot be ruled out. Few studies evaluated outcomes in quality of life/ADL. Haloperidol did not affect general cognitive function in two trials and was not evaluated in the other studies.

The quality scores for reporting adverse events varied from 1 to 5 and only three of five studies reported withdrawal rates; the proportion of subjects withdrawing due to adverse events ranged from 5% to 17% for placebo and 17 – 33% in the treatment group. One trial ^124^ showed a dose-response effect but the study only lasted for three weeks. Three trials tested for differences between treatment and placebo with respect to extra pyramidal symptoms (placebo = 17 – 32%, all does = 34 – 97%), and two found statistically significant differences. ^124,^ ^125^ One study ^125^ found significant differences between groups for balance-related problems. Although reported by only two trials, the range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all doses = not reported, and 2) dizziness (placebo = 24%, all doses = 21%). No frequencies were reported for agitation, diarrhea, or eating disorder.

Memantine. Three trials evaluated memantine in 1066 patients, primarily with VaD, with 10 or 20 mg doses lasting 12 or 28 weeks. Disease severity was moderate to severe in a single study ^132^ and mild to moderate in the remaining two studies ^133,^ ^134^ . One study included patients that were institutionalized, one from the community and the third did not specify.

There is consistent evidence of benefit for general cognitive function in the two studies that evaluated this domain. The findings for global assessment are mixed. The sole trial that evaluated mixed dementia populations (including some VaD) with moderate to severe dementia found significant differences for global function, behavior/mood, and quality of life/ADL outcomes, but did not evaluate general cognitive function. It should be noted that this trial with mixed populations used half the dose of memantine for half the study duration in patients with greater disease severity, and had approximately half the sample size of the other two trials evaluated in this systematic review. Despite a lower dose, a smaller number of more severely affected patients, and a shorter duration, a statistically significant difference was found.

The quality scores for reporting adverse events varied from 3 to 4. Only two of three studies reported withdrawal rates; the proportion of subjects withdrawing due to adverse events ranged from 7% to 13% for placebo and 9 – 12% in the treatment group. A single trial tested for differences between treatment and placebo, and none of the comparisons were significant. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all doses = 5%), 2) dizziness (placebo = 3 – 8%, all doses = 6 – 11%), 3) diarrhea (placebo = 4%, all doses = 4%), 4) agitation (placebo = 7 – 8%, all doses = 4 – 5%), and none reported eating disorder as an adverse event.

Selegiline. Six trials ^135,^ ^136,^ ^249,^ ^138,^ ^139,^ ^140^ evaluated selegiline in 733 patients with AD, PDD, and DAT with 10 mg per day and a study duration of 60 days or 2 years. Only one study reported that patients were from institutional settings.

All but one trial that evaluated general cognition showed no statistically significant changes. A single trial found statistical improvements in specific cognitive tests (Sternberg Memory tests); this trial also showed statistically significant improvements in global assessment and behavior/mood. Only this trial, which had the highest quality score (7), showed consistently positive findings across domains tested. Three of the five trials that evaluated part or all of these domains had very small sample sizes and were likely underpowered, possibly accounting for the inconsistent findings. There is some evidence that selegiline and selegiline combined with vitamin E, increases the time to important functional decline milestones; this is based on a single study.

The quality scores for reporting adverse events varied from 0 to 3. The proportion of subjects withdrawing due to adverse events ranged from 0 – 4% for placebo and 0 – 9% in the treatment group. Only one trial ^135^ tested for differences between the treatment and placebo groups and showed that balance and falls were significantly different (worse) between groups (22% for the group with selegiline combined with vitamin E versus 5% in the placebo). When adjusted for multiple comparisons, these were no longer significant. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 2%, all doses = 0%), 2) dizziness (placebo = 2 – 20%, all doses = 0 – 30%), and 3) agitation (placebo = 4 – 16%, all doses = 4 – 23%); no trial reported diarrhea or eating disorder as an adverse event.

### Summary of Other Pharmacological Agents

Cerebrolysin. Six studies evaluated the effect of cerebrolysin in a total of 819 subjects. All but one of the trials ^171^ included only AD patients with mild to moderate disease. All of the studies used the same dose of cerebrolysin, 30 ml per day for 5 days per week for 4 to 24 weeks. Location of recruitment was not specified.

Cerebrolysin showed a statistically significant effect on cognition in four out of five studies. Although, a pooled estimate for the ADAS-cog was calculated, the model was positive for heterogeneity and the overall estimate was not significant. The results for specific cognitive tests for the three trials that evaluated this domain were inconsistent. Global assessment measures showed a significant effect in five of the trials. This model was also positive for heterogeneity but significant for an overall effect. Two out of three studies showed an effect for behavior/mood, and none of the six studies showed an effect on quality of life/ADL. No study measured caregiver burden.

Two of the six trials scored 5 out of 5 on our quality scale for rating adverse events, yet they did not report any adverse events. Two studies scored 4, and the other two trials scored 3 and 2. All the studies with scores equals to 4 or less tested for statistical differences in adverse events between placebo and treatment groups. Withdrawals due to adverse events were not reported in one study ^170^ and were 1% in two studies ^173,^ ^168^ and none withdrew in three studies. ^169,^ ^172,^ ^173^ One study reported significant differences between treatment and control group ^173^ for weight change, anxiety, and headache. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 10 – 24%, all doses = 3 – 21%), 2) dizziness (placebo = 0 – 12, all doses = 1 – 8%), and 3) agitation (placebo = 1%, all doses = 0%), and none reported diarrhea or eating disorder as an adverse event.

Estrogen. Five studies evaluated estrogens for dementia in 247 patients with primarily mild to moderate AD, with the exception of one study ^178^ that included moderate to severe dementia patients who were all institutionalized. One of the studies with AD patients provided 0.10 mg per day ^174^ by skin patch for 8 weeks and the others used 1.25 mg per day for 12 to 52 weeks. ^177^ The study including severe subjects used 2.5 mg per day for 4 weeks. ^178^

Three trials evaluated general cognitive function and all showed non-significant findings; two of these trials lacked sufficient power for the ADAS-cog. Similarly, two trials evaluated specific cognitive function but results were mixed. Most of the outcomes evaluated in the domains of global assessment, behavior/mood, and quality of life/ADL were secondary outcomes and none showed significance; lack of power could be a factor in these trials.

One of the five trials scored 5 out of 5 on our quality scale for rating adverse events, and surprisingly, this same trial did not report any adverse event. Withdrawal rates due to adverse events ranged from 0 – 5% for placebo and 0 –14% for the treatment group. The most frequently reported adverse event was vaginal bleeding and a single trial reported a significant difference between placebo and treatment group for this symptom. It was not clear from the descriptions provided in the study if they had ascertained whether vaginal bleeding was present prior to the trial commencement. Nausea was the single a priori symptom of interest that was reported and by a single trial; frequencies varied from 0% for the placebo group and 4% for the treatment group.

Ginkgo biloba. Three trials evaluated Ginkgo biloba, 120 to 240 mg per day for 3 to 12 months, in a total of 563 subjects with mixed dementias of mild to moderate severity.

The largest trial ^179^ had the longest treatment interval but the lowest daily dosage and reported a significant effect for general cognitive function but had mixed findings for global assessment. A second large trial ^181^ found positive changes for neuropsychological tests, global assessment, and behavior outcomes with double the dosage of the previously described trial and half the treatment interval. In this same RCT, clinical efficacy was assessed by using a responder analysis, with therapy response being defined as response in at least two of the three variables: CGI (global function), SKT (special cognitive function), and NAB (ADL). A single trial evaluated behavior/mood and was not significant. No trial evaluated caregiver burden or quality of life/ADL.

All three trials scored 3 or greater on the quality scale for rating adverse events. Two studies had no withdrawals due to adverse events, and one trial had a withdrawal rate of 6% for both placebo and treatment groups. Two studies did not report any adverse event. One study reported a statistically significant difference between the treatment and the placebo group for skin disorders. The same study reported gastrointestinal and headache adverse effects, but did not test for statistical differences between the placebo and the treatment group. None of the trials reported the presence of the a priori symptoms of interest.

Idebenone. Four studies ^185,^ ^183,^ ^182,^ ^184^ evaluated the drug idebenone in 1153 subjects of mixed dementia populations of mild to moderate severity; one of these trials ^26^ evaluated idebenone relative to tacrine. Doses varied from 30 mg per day to 360 mg per day, and the treatment interval ranged from 90 days to 60 weeks.

There was evidence of benefit for general cognitive function and global assessment. Several studies evaluated behavior/mood and quality of life/ADL and these outcomes were found to be significantly different. None of the trials evaluated caregiver burden.

Quality scores for reporting adverse events varied from 1 to 5. Rates of withdrawal due to adverse events varied from 0 – 5% for the placebo group and 0 – 5% in the treatment group; a single trial ^183^ did not report withdrawal rates. Two trials ^183,^ ^185^ tested for statistical differences between groups and found no differences. Although no clear pattern emerges, three studies identified at least one balance-related adverse event most consistently reported across studies. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 2%, all doses = 2 – 11%), 2) dizziness (placebo = not reported, all doses = 2%), and 3) not reported for diarrhea, agitation, or eating disorder as an adverse event.

Oxiracetam. Five studies ^186,^ ^187,^ ^188,^ ^189,^ ^190^ evaluated oxiracetam in 554 subjects with different dementia syndromes of mild to moderate severity. All analyses were observed cases and not ITT. All studies used 1600 mg daily, with one exception ^189^ where the dose ranged between 1600 – 2400 mg per day. The treatment interval ranged from 90 days to 26 weeks.

All outcomes shown to be positive for this drug were based on observed case evaluation. The two trials that evaluate general cognitive function showed benefit. The findings for specific cognitive function were mixed. A single trial evaluated global assessment and showed statistically significant change. Behavior/mood, and quality of life/ADL outcomes showed mixed results. No study evaluated caregiver burden.

The quality scores for reporting adverse events varied from 2 to 5. The proportion of withdrawals due to adverse events varied form 0 – 9% for the placebo group and 0 – 6% for the treatment group. No clear pattern for adverse events is evident, but three of the five studies reported gastrointestinal related problems, primarily associated with abdominal pain. Although, only single trials evaluated the range of frequencies of the a priori symptoms of interest are as follows: 1) dizziness (placebo = not reported, all doses = 11%), and 2) agitation (placebo = 1%, all doses = not reported); no trial reported nausea, eating disorder, or diarrhea as an adverse event.

Pentoxifylline. Three placebo-controlled studies ^193,^ ^192,^ ^191^ evaluated pentoxifylline and one study ^194^ compared pentoxifylline to sulodexide, with a total of 482 subjects with predominately MID. The total dose administered in all studies was 1200 mg per day but varied from 400 mg three times per day to 1200 mg once per day. The treatment intervals ranged from 12 to 36 weeks.

All three placebo trials showed non-significant findings for any primary outcome evaluated on all subjects in the study. It should be noted that two of these trials had very small sample sizes (n = 38, n =28) that were evaluated in the OC analyses; this suggests that the trials lacked sufficient power to evaluate multiple outcomes. The remaining trial had a large sample size (n = 289) and employed an ITT analysis; all primary outcomes evaluated were not significant.

The quality scores for reporting adverse events were generally low, varying from 1 to 3. Withdrawal rates due to adverse events varied from 0 – 25% in the placebo group and 0 – 22% in the treatment group. The two studies that reported adverse events indicated the presence of gastrointestinal disturbances, including abdominal pain or nausea and vomiting (placebo = 7% and all doses = 14%). None of the trials reported dizziness, agitation, eating disorder or diarrhea.

Propentofylline. Four trials ^197,^ ^196,^ ^250,^ ^198^ using propentofylline in 510 patients with AD and VaD were included. A dose of 900 mg per day was consistent across all studies, and the treatment duration ranged from 3 to 12 months.

The two studies with small sample sizes (n = 30) showed no significant results for any outcome evaluated but lack of power cannot be ruled out. There were two trials that found benefit in general cognitive function based on the MMSE. The results for specific cognitive function as measured by the DSST were mixed, as were those for global assessment. Behavior/ mood outcomes were evaluated by a single trial ^195^ and shown to be significant; this same trial evaluated quality of life/ADL and showed no significant difference. No trial evaluated caregiver burden.

The quality scores for reporting adverse events varied from 1 to 4. The percentage of withdrawals varied from 0 – 13% for the placebo group and 0 – 12% for the treatment group. None of the trials tested for differences between groups. Three of the trials ^195,^ ^197,^ ^198^ reported gastrointestinal events that included abdominal pain, constipation, and nausea and vomiting (placebo = 2%, all doses = 7%). Dizziness (placebo = 3 – 5%, all doses = 1 – 6%) was the only other a priori symptom of interest.

### Methodological Issues and Limitations in Assessing Efficacy of Dementia Agents

Definition of clinically significant or meaningful difference. The stance undertaken in this review has been cautious with regards to interpreting “clinically significant” differences within and across studies. This systematic review has highlighted some of the concerns expressed in the literature on pharmacological efficacy research in dementia. Ultimately, clinical significance is a complex issue, and its definition can vary across individuals and groups of individuals. Wherever possible, attempts were made to identify the magnitude of differences in the studies and the limitations of the data from some of these primary studies.

In drug development programs, an ordered series of trials are undertaken: dose tolerance (phase I), dose finding (phase II), dose efficacy (Phase III), and post-marketing (phase IV). However, due to the pressures on pharmaceutical companies to develop drugs quickly and cost-efficiently, a drug may move into the next phase of development before evidence of the previous phase is known. ^251^ Even when phase III trials are carried out in an adequate manner, the interpretation of the efficacy results is hampered by multiple p-values, disagreement over the need for multiplicity corrections, and the potential for conflicting evidence from trials of different sizes. ^251^ Some of these difficulties can be minimized by measuring a single primary efficacy variable at one point in time and using a p-value of less than 0.025 (one-tailed, as the aim is for the statistical test to determine if the drug performs better than the placebo or low dose). ^252^ This presumes that good dose-response data exist, identifying a single dose level as the best candidate for further evaluation. Lastly, interpreting differences on the basis of statistical significance has long been recognized as problematic. Clinically meaningful change reflects a different level of “significance” and often requires consensus among experts within the field for these criteria.

Issues of diagnosis and severity. Three methodological issues related to population classifications have limited the inferences that can be garnered from this systematic review. The first issue concerns the classification models used for diagnosing dementia; they are not interchangeable among the various types of dementia and the “pre-clinical” forms of slight cognitive impairment. Moreover, there are still concerns about the accuracy of these criteria. For example, in the American Academy of Neurology's (AAN) recent evidence-based review of dementia case definitions, none met the AAN's highest evidence standard. A clinical diagnosis of AD is only 28% specific after age 79 years. Similarly, no dementia screening measure is accurate enough to be recommended by the American Society of Internal Medicine. ^253^ The AAN specifically faulted the emphasis on memory function in dementia case definitions. ^254^ Yet tests like the ADAS-cog emphasize memory loss at the expense of other cognitive domains, especially executive control function, ^31^ and many anti-dementia treatment strategies target neurotransmitters and structures (like acetylcholine and the hippocampus), which mediate memory test performance.

A second consideration in defining populations of dementia patients concerns determination of severity level. The MMSE, although frequently used, may not best capture severity. Many studies were observed to define the severity (mild, moderate, severe) of dementia populations based on the MMSE. For example, a range from 10 to 26 has been used to define a mild to moderate severity level. ^50^ Given that the maximum and minimum instrument scores are 0 and 30, this suggests that the extreme ends of the spectrum, particularly the “severe” end (i.e. <10), represent a very narrow proportion of patients. These two broad categories (mild to moderate and severe) may not actually reflect the cognitive and functional differences in a clinically meaningful manner. The MMSE does not address issues of executive control function (as required by the DSM-IV dementia case definition), which is known to be a good predictor of functional status. From a research perspective, a better classification reflecting disease severity may be an important factor for stratification and determining the efficacy of pharmacological interventions.

Outcome issues. The studies evaluated in our review used 181 different outcomes across seven domains. This raises the issue of which of these outcomes are considered by clinicians to be most “clinically relevant”. Let us assume that the most clinically relevant outcomes for all the drug interventions for dementia are the ADAS-cog and the MMSE because they are very commonly reported in studies.

In this dementia review, numerous studies did not measure outcomes evaluating cognition, as the intended effect of the drug was not always in the domain of cognition (e.g. neuroleptics for behavior control). Moreover, a large number of the studies that used important clinical cognition outcomes, such as the MMSE, did so only to establish baseline severity, or they used it as a secondary outcome. This presents us with some difficulty in the consistency of reporting on this limited set of “clinically relevant” outcomes. There is also the issue of which domain (i.e. cognitive function versus ADL versus behavior) is the most clinically relevant. The FDA guidelines suggest cognition and global assessment; the EMEA guidelines suggest the addition of an ADL or quality of life/ADL measure as being most clinically relevant. Thus, some consensus work needs to be done among experts in the field to determine the most clinically relevant outcomes and domains. For example, the choice of most clinically relevant outcome may depend upon type and stage of dementia (e.g. for mild AD, neuropsychological outcomes may be are the most important domain while for severe AD, behavior may be the most relevant outcome), which may challenge the achievement of consensus.

To our knowledge, no specific set of outcomes that define “clinical relevance” applies to all the drug interventions we evaluated. The FDA has recommended that “dual efficacy” of dementia drug interventions be established by significant change in both a psychological measure and a global change measure. The outcomes measuring these attributes within these two domains were not specified. However, there was a general trend for using the outcomes ADAS-cog and CIBIC+ to capture these two attributes when evaluating drugs for AD populations.

Ideally, all outcomes should have demonstrated acceptable psychometric properties, such as reliability, validity (construct), and responsiveness. We did not a priori evaluate the properties of outcomes reported in the eligible studies. In some cases, these outcomes were developed in non-English languages but the original study was reported in English. In considering the psychometric properties of some of the outcome instruments used, the attribute of responsiveness is critical, and some have suggested that this has not been adequately evaluated in many outcome measures. ^33,^ ^30,^ ^255^

We might envision a clinically relevant pharmacological treatment as one that has made a real difference, where the change is both relevant and important to the patient or to clinicians. This fundamentally shows the difference between clinically significant (relevant and important) versus statistically significant (associated with probabilities), where the latter determines that the results are not due to chance. Moreover, a clinically important change will vary depending on whether importance is defined from the patient or clinician perspective.

Five different levels of responsiveness (ability to detect change) of outcome measures have been defined: ^256^ 1) Minimal change potentially detectable (essentially an attribute of the scoring method of the outcome), 2) Minimal change actually detectable beyond measurement error of the instrument (also defined as Minimum Detectable Change (MDI) or Reliability Change Index (RCI), which includes the Standard Error of the Measurement (SEM)), 3) Observed change (often reported as the standardized response mean (SRM) or effect size (ES). 4) Observed change in those estimated to have improved; the key to understanding change in this instance is that an external standard is used to determine whom has improved (often reported as comparison between groups that have improved versus those who have not; the improved group can be defined by either patient and/or clinician or a combination), and 5) Observed change in those estimated to have important improvement (often reported as the minimal clinically important difference and can be determined by the patient or clinician, or a combination of both).

Consider the ADAS-cog and the CIBIC+: The minimal change detectable is 1/70 = 0.0143 for the ADAS-cog and 1/7 = 0.143 for the CIBIC+, suggesting that the ADAS-cog can detect smaller increments of change relative to the CIBIC+. Thus different instruments have differing sensitivities to detecting change. There is scant literature on the responsiveness of outcome measures as defined in number 4 above, observed change in those that have improved, or as in number 5 above, observed change in those estimated to have important improvement. Thus, we have identified a significant gap in the literature with regard to estimating clinically important changes. Much greater consideration of issues of responsiveness should be given in future research in efficacy trials of pharmacological agents. Greater understanding of clinically important change suggests that some of our current judgments of efficacy are limited as these important differences need to be established.

Analysis issues. The inability to estimate the power of a study to detect a difference presented significant limitations in interpreting those studies that showed no significant differences. Similarly, the lack of sufficient data for estimating effect size limited the ability to show the magnitude of the change. It is recommended that future trials evaluating the efficacy of pharmacological agents adhere to the CONSORT guidelines in order to provide sufficient data to estimate power and effect size for all relevant outcomes.

Although the difficulty of maintaining adherence to long-term drug interventions among dementia patients is acknowledged, the ITT analysis should continue to be the analysis of choice in trials. Ideally, both ITT and OC analyses should be presented. If both suggested the same conclusion, confidence in the study results would be increased.

Problems with funding/ sponsorship exclusively from drug companies. The sponsorship of studies by for-profit organizations has led to bias towards the publishing of positive results. ^257^ These findings suggest that there are powerful disincentives for pharmaceutical companies to publish negative trials. This is contrary to what academic-based, non-industry funded trials show, where the publication of negative trials are more likely.

A recent evaluation of FDA databases for antidepressant drugs ^258^ in the US, suggested that less than half of antidepressant trials were negative, which does not correspond to the published literature. In this systematic review, no attempts were made to contact industry for unpublished trials, which introduces the possibility of a bias associated with not reporting negative trials. Additionally, we did not contact authors who did not specify funding sources for their studies. Future research on the efficacy of pharmacological agents to treat dementia should indicate all sources of funding and who undertook the study analyses.

Adverse events. In this systematic review, the type and frequency of adverse events associated with the use of a drug intervention were scrutinized and reported to a greater extent than previous reviews of anti-dementia drugs. Attempts were made to weigh the potential for harm against the benefits when determining the efficacy of pharmacological interventions. Empirical evidence across diverse medical fields indicates that reporting of safety information (including milder adverse events) receives much less attention than the positive efficacy outcomes. ^35^ Thus, it was recognized that an evaluation of the benefits of anti-dementia pharmacological agents alone may present a biased view of the efficacy of the intervention.

The ability to capture and evaluate adverse events proved to be difficult for several reasons. For example, although metrifonate had good evidence of positive effects on cognitive function, it was banned from use due to the risk of respiratory paralysis. The description of serious adverse events in the trials we evaluated did not capture this type of event, nor did different studies identify “serious events” in a consistent manner. This points to several fundamental limitations. The first of these relates to the limitation associated with the RCT design itself, which is less likely than the longitudinal cohort study designs to capture serious adverse events that are rare. Secondly, many trials were of relatively short duration and captured “idealized” dementia populations. Many of these trials were from pre-marketing studies contracted by pharmaceutical companies in carefully controlled research settings. Dementia patients seen in practice may have more complex medical illnesses and are at greater risk for potential side effects. In addition, drugs used in “polypharmacy” have even greater potential for pharmacological interactions. Furthermore, practitioners may prescribe these pharmacological agents for wider indications than originally intended, or may not refrain from withholding the drug from certain high-risk subgroups, leading to increased risk of adverse events. Thus, published rates of adverse events in well-controlled trials may underestimate true rates seen in practice.

Thirdly, by their nature, some adverse events are not easily anticipated, and therefore are not screened for in some trials. Adverse events may be hard to predict or anticipate but can be captured only if a trial protocol was designed to measure these events. This problem is compounded by the lack of consistency in what constitutes “serious” events or how the severity of the typical events is rated. A limited number of standardized instruments exist to capture these events reliably, but the overwhelming majority of studies in this systematic review did not use these instruments. Furthermore, capturing information from individuals with cognitive decline can create problems; the validity of the self-report instrument, even if completed by the caregiver, can be problematic. More research on the reliable collection of adverse events in dementia populations (with compromised cognition) may be required.

A fourth consideration concerns the issue of off-label use of pharmacological agents. Given that only four drugs are currently approved by the FDA for the treatment of dementia, the other 97 interventions evaluated in this review are classified as “off label use” but many are not approved by the FDA and not, therefore, available. For some of these off-label medications the potential mechanism of action on the disease process has not been fully established (if even considered), yet they have been applied to dementia populations. This off-label use of pharmacological agents may present further difficulties in evaluating adverse events.

## Question 2: Does pharmacotherapy delay cognitive deterioration or delay disease onset of dementia syndromes?

### Summary of Systematic Review Results

Few studies evaluated delay of onset or delay in disease progression. A definite gap for evaluating disease onset (as defined by the selection of populations at risk such as MCI populations) has been identified in this review.

Conversely, the need for good evaluation of disease progression in trials was also identified. In general, few studies evaluated subjects in more severe state of the disease. This suggests that a bias exists towards evaluating mild to moderate disease in the trials eligible in this systematic review. This in turn reflects the underlying assumption that the less severe groups are most likely to benefit from drug trials. Since so few studies have evaluated the more severe groups, this assumption may require some empirical justification in future research. Those studies that evaluated severe patients showed some potential for benefit. Future research in this area may require some consensus regarding the classification of severity levels.

Three studies evaluating cerebrolysin, ^168^ selegiline and vitamin E, ^135^ and donepezil ^61^ have shown significant effects in delaying disease progress in mild to moderate ^61,^ ^168^ and moderately severe disease in patients with AD. This delay in progress was expressed in terms of delay in days to primary event ^135,^ ^61^ or statistical differences between placebo at a specified time interval. ^168^ Although these two trials coincidentally evaluated dementia patients over the longest time interval, it did not withdraw the drug at the end of the study. Theoretically, conclusive evidence of disease delay would be demonstrated if the treatment groups did not return to the level of the placebo. Thus, distinguishing between symptomatic and disease modifying effects is not possible unless the drug is withdrawn and the treatment group(s) are observed for these changes.

When studies attempted to evaluate disease progression, long-term (1 year or greater) trials continued in an “open-label fashion”, where blinding was no longer maintained. This limits the confidence that bias did not affect the subsequent changes in the outcomes. It was observed that increasing levels of dropout (for a variety of reasons) also plagued these open-label phases of evaluation. From a practical perspective, maintaining adherence in longer-term trials in dementia patients are challenging, ^19^ particularly for those in the placebo arm or for those interventions that have a high proportion of adverse events.

A number of trial designs have been proposed to capture delay in disease progression versus symptomatic treatment. Some of these trial designs include withdrawal of treatment, active-extension, randomized withdrawal, randomized start, and staggered start designs. ^235,^ ^236,^ ^19,^ ^21^ One important aspect of these designs is the selection of an adequate washout period or an adequate follow-up period. In addition, longer evaluation with survival analyses may be a good strategy to evaluate delay in disease progress for some drugs. One advantage of this design is the selection of clinically relevant milestones (functional changes over time), which was utilized in two studies ^63,^ ^136^ ; the selection of such events may merit greater consideration in future trials evaluating delay. A more critical analysis of the staggered/start/stagger withdrawal design in comparison to the survival analysis would be helpful. Also, one could provide a more extensive analysis of the data on propentofylline and vitamin E, ^136^ which represent the most extensive efforts to use the stagger/start/stagger withdrawal and survivor analysis approaches, respectively. Future research seeking to establish efficacy should clearly specify if symptomatic treatment or delay in progression is the therapeutic aim. This is important for determining specifically if efficacy is considered with respect to these two aims. Accordingly, a design that can establish this aim should be selected.

### Methodological Issues

Determining symptomatic treatment versus affecting delay in disease progress. Figure 31 depicts hypothetical responses of dementia patients to two similar pharmacological interventions relative to placebo. In this example, the placebo group changes over time were modeled according to the natural history of AD as described by Stern et al. (1994) ^29^ ; the progressive decline of the AD subjects may not be representative of all dementia types. For simplicity's sake, the decline is assumed to be linear, although the literature has suggested the rate of decline varies between the different types of dementia and within each of these groups as a function of the disease severity. ^21,^ ^259^ The two drugs depicted in Figure 31 are similar in that they have the identical titration (approximately 8 weeks) and washout periods. In this hypothetical scenario, the drugs are both withdrawn at 6 months (DW) and the washout periods have ended at 8 months. Within the active treatment period (first 6 months), the response to Drug I depicts the maintenance or stabilization of cognition function relative to the placebo, whereas the response to Drug II suggests improvement (or restoration) of cognition for a short period. However, the rapid decline of cognition scores within the two treatment groups to the level of placebo at 8 months (end of the washout period (EW)) suggests that the treatment effect was symptomatic relief. Upon withdrawal for subjects exposed to either Drug I (maintenance or stabilization) or Drug II (improvement relative to baseline and placebo), the cognition scores declined to the same rate of placebo, and thus no delays in disease progression were demonstrated.

Figure 31. Delay of symptomatic treatment effects

In contrast, Figure 32 shows a delayed rate of decline relative to placebo after the withdrawal of the pharmacological interventions. The response depicted for the treatment group exposed to Drug I shows that cognitive function is maintained until the drug is withdrawn (DW) and then the rate of decline is slower relative to the placebo (different slope of change) following the washout period. The response of the treatment group exposed to Drug II would suggest that cognition is improved for an interval (relative to baseline and placebo); when the drug is withdrawn, the rate of decline in cognitive function approximates that of the placebo group but is offset by approximately 6 months. Comparison of the slopes of the decline of cognition (Figure 32) would indicate a greater rate of decline for Drug II relative to Drug I, but both exemplify delay in progression of the disease effects. Theoretically, the treatment group rates of decline will never meet the decline rate of the placebo group when true disease modification has been effected by the pharmacological agent.

Figure 32. Dealy in disease progression treatment effects

In these two Figures (31, 32), the responses depicted have been idealized to clearly show the differences between symptomatic treatments versus disease modifying treatments. Additionally, two examples of the rate of decline as a characteristic of delay in disease progress have been explicated. However, in practical terms the most effective time interval for bringing about meaningful change in cognition (or other important outcomes), and the best time period to observe whether or not the effect is maintained (or lost), is not known. The difficulty in estimating these ideal time intervals is further compounded when the uncertainty of the rate of cognitive change (or decline) is considered. ^21^ It is likely that treatment effects may not be equal across all stages of the disease (mild, moderate, severe) or between the various types of dementia diagnoses.

The evidence provided in dementia trials to demonstrate the three broad therapeutic aims of pharmacological interventions has been expressed in a variety of comparisons. Ideally the changes due to the pharmacological intervention would be expressed in terms of differences between the treatment and placebo groups. Surprisingly, many trials have reported statistical significance between baseline and endpoint of the treatment group(s) as evidence of a therapeutic effect. Change has been described as “improvement” relative to the baseline for either of the treatment or control groups. Although, it is unlikely that AD subjects would ever improve spontaneously relative to baseline, it may be possible in some dementias. Additionally, the magnitude of the “improvement” is dependent on the time interval for which the differences were estimated. Consider Drug II in Figure 31 at the 4- and 6-month intervals; clearly, the magnitude of the difference is greatest at 4 months. Similarly, the evidence for “stabilization” or estimates for “delay in progression” was dependent on the interval used for evaluation.

## Question 3: Are certain drugs, including alternative medicines (including non-pharmaceutical) more effective than others?

### Summary of Systematic Review Results

What may be most relevant to clinicians are head to head comparisons of the cholinergic modifying neurotransmitter pharmacological agents, particularly those currently approved for the treatment of dementia (tacrine, rivastigmine, galantamine, donepezil) in the United States. The evidence for each of these drugs has been extensively detailed, and the relative merits and handicaps of each were outlined in chapter 3. Relative effectiveness as demonstrated by effect sizes for the ADAS-cog and the CIBIC were also shown in chapter 3. Although, the psychometric properties of these two outcomes are well accepted, comparison across the populations in these pooled estimates may not lend themselves to direct comparison across these four different specific drugs. Thus, inferences about the relative effectiveness of these four medications specific for the treatment of dementia should be made cautiously as head to head comparisons were not undertaken.

### Relative efficacy must be evaluated in direct comparison trials

From a methodological perspective, addressing the question of being “more effective” requires head to head comparisons of pharmacological interventions.

An evaluation of the trials that undertook direct head to head comparison of two distinct pharmacological agents was limited because only seven trials were identified. Although, these trials may have shown some relative benefit of one drug versus another, the clinical relevance of these particular agents is limited as none of the drugs currently approved by the FDA specifically for the treatment of dementia is represented in these eligible studies. Moreover, these studies are essentially limited to single trials and are not sufficiently strong to base recommendations on the relative effectiveness of drugs. Head to head comparison studies are beginning to appear in abstract form only and a significant gap in the literature has been identified.

## Question 4: Do certain patient populations benefit more from pharmacotherapy than others?

### Summary of Systematic Review Results

In general, very few trials examined the efficacy of dementia drugs across different populations or population characteristics. From the 13 studies that reported stratified analyses, eight different variables were identified, which included age, gender, APOE genotype, disease type, disease severity (as determined by MMSE/ ADAS-cog threshold levels), treatment center, care dependence, and presence of depression. Additionally, three trials were identified that evaluated efficacy in 1) patients with Down's syndrome and dementia, 2) different ethnicities as a function of treatment center in a multicenter trial, and 3) depressed patients. Given the relatively small number of trials evaluating these variables within different populations and different pharmacological interventions, the findings of this review are limited with respect to these patient variables. These reflect merely what has been reported in the literature rather than variables of importance with respect to efficacy of pharmacological therapies. A significant gap in the literature has been identified.

### Representativeness of populations in the drug trials

The study population characteristics were detailed for the trials evaluated. A recent study, ^22^ suggests that many “real world” dementia patients in Ontario would not have met the eligibility criteria for participation in several of the cholinesterase inhibitor studies. This study highlights an important limitation of the pharmacological literature in that dementia patients recruited are not representative of the general dementia population. Additionally, clinicians and researchers should note that when a when a drug is approved for use, it is for a specific indication and a specific patient population. Evidence for one type of patient population may not necessarily be applied to another population. This is critical information to have when establishing clinical practice guidelines.

## Question 5: What is the evidence-base for the treatment of vascular dementia?

### Summary of Systematic Review Results

A total of 20 pharmacological interventions in 29 studies ^211,^ ^220,^ ^238,^ ^171,^ ^200,^ ^199,^ ^146,^ ^68,^ ^181,^ ^184,^ ^133,^ ^134,^ ^132,^ ^161,^ ^89,^ ^91,^ ^93,^ ^247,^ ^187,^ ^191,^ ^192,^ ^194,^ ^193,^ ^100,^ ^98,^ ^196,^ ^195,^ ^245,^ ^217^ were applied specifically to VaD classified dementias. The majority of these pharmacological interventions (n = 14) were represented by single trials, these interventions included ateroid, buflomedil, cerebrolysin, sulphomucopolysaccharides (CDP choline), citalopram, donepezil, Ginkgo biloba, idebenone, minaprine, nimodipine, oxiracetam, 5-THF (trazodone), vincamine, and xantinolnicotinate. Six interventions had more than a single trial, and these included Choto-san (n = 2), memantine (n = 3), nicergoline(n = 2), pentoxifylline (n = 4), posatirelin (n = 2), and propentofylline (n = 2). In general, when the drug interventions were shown to be effective, it was in the domains of cognitive function (both general and specific) and global assessment. Other domains were less frequently evaluated. Several trials attempted to test for differences between VaD groups and other dementia types.

### Diagnosis Classification of VaD

Erkinjuntti et al (1997) ^1^ compared six commonly used classification schemes (DSM-III, DSM-III-R, DSM-IV, ICD-9, ICD-10 and the CAMDEX) and demonstrated that the prevalence of dementia can differ by a factor of 10 depending on the diagnostic criteria used. Two other studies have demonstrated that the prevalence of VaD varies with the classification system; therefore these criteria for diagnosis are not interchangeable. ^10,^ ^11^

There is controversy about the validity of the clinical classification of VaD, as autopsy confirmation often does not substantiate the clinical diagnosis. ^12,^ ^13^ The majority of dementias were actually AD with co-existing VaD and PDD lesions. ^14^ In contrast, the clinical accuracy of AD diagnosis is relatively high. ^7^ Future research in vascular dementia should attempt to better distinguish this subgroup.

## Determining Clinical Relevance

With rare exceptions, dementias are inevitably progressive and eventually lead to severe cognitive deficits, functional impairment, and often behavioral problems, unless death supervenes from intercurrent disease. The trajectories, sequence of clinical features, and burden on caregivers vary depending upon the type of dementia. For example, cognitive decline typically precedes functional impairment and behavioral disturbances in AD, while behavior and/or language problems typically announce the onset of frontotemporal degeneration.

Physicians and other health care practitioners have numerous roles in the management of individuals with dementia. These include identification, assessment and staging, classification, and prognostication, in addition to treatment of the individual and caregiver and planning for future disabilities (e.g. arranging alternatives to driving, assigning power of attorney and compiling living wills/advance directives).

Given these multiple tasks, how is the treating physician to interpret the results of therapeutic trials, which mostly deal with the pharmacological treatment of individuals with predominantly one type of dementia (AD) in the mild to moderate stages?

The traditional view of most physicians is that treatment success is measured by reversal of a disease, which is not a realistic goal in dementia. (While the older literature suggested that as many as 15 to 30% of dementias were “reversible,” more recent studies indicate that at most a few percent of dementias presenting to physicians are potentially reversible.)

Thus, the treating practitioner must begin by setting a realistic goal for therapeutic intervention. Symptom relief, alleviation of caregiver burden, prevention of complications (such as injury prevention or avoidance of aspiration pneumonia), and delay in progression of disease might be potential treatment targets. From this list, only symptom relief and delay in progression could be inferred from the studies examined in this systematic evidence review.

Outside the specialty clinic or clinical trial setting, most physicians have limited time and resources to expend on their patients with dementia. Few will have access to psychometrists or other individuals capable of administering extensive assessment instruments such as those used in clinical trials (e.g. ADAS-cog). Thus the typical practitioner must be able to complete a brief assessment, which provides sufficient information to determine whether a treatment is 1) indicated and 2) effective.

Deciding if a treatment is indicated depends upon the correct diagnosis (does this person have a dementia, and if so what type?), potential contraindications to the treatment (e.g. active peptic ulcer or heart block in the case of cholinesterase inhibitors), and the severity of disease. Determination of severity of dementia has given rise to several global scores such as the Global Deterioration Scale (GDS) ^260^ and the Clinical Dementia Rating (CDR) ^261^ In practice, the Mini-Mental State Examination (MMSE) ^50^ (a short, 30-item, cognitive screening test) is frequently used as a measure of severity. Not only is it part of the usual diagnostic protocol for suspected dementia, but it also has the advantage of being included in the entry criteria of many of the RCTs of anti-dementia medications. It is therefore useful for determining whether a patient fulfils the appropriate severity criterion for therapeutic intervention.

With regard to deciding whether a treatment is effective, much has been written about the relative importance of statistically significant and clinically significant changes in measures of cognition, function, and behavior in dementia. A distinction must be drawn between clinically detectable change and clinically meaningful change. While psychometric measures (standardized instruments, which are highly reliable and relatively free from the influence of judgment) may detect changes too small to be appreciated by the clinician, clinometric tools (measures that are based on a clinical judgment about an individual patient ^262^ ) may be considered more relevant to practice. Results expressed as a change from baseline measured by clinometric instruments such as the Clinicians Interview Based Impression of Change (CIBIC) or its derivative the CIBIC plus, which incorporates observations of the caregiver, mimic clinical practice more closely than most psychometric tools. The CIBIC aims to cover multiple domains relevant to the clinician (i.e. cognitive, functional, and behavioral). Clinicians may therefore interpret statistically significant changes on the CIBIC or similar scales with more confidence than changes on the many psychometric scales used in therapeutic trials. However, if an effect size of ~0.5 or greater is included in the analysis of psychometric outcomes, one can be reasonably confident of a robust response to the treatment under investigation.

Another measure of efficacy is the response rate—the percentage of study participants who experience an improvement (defined as a change of a specific magnitude on one or more scales.) This figure is useful for the clinician who may then indicate to the individual with dementia the chances of a positive outcome from the planned treatment.

Clinicians are faced with a bewildering array of results from clinical trials. Convergence of results (different studies of the same medication showing similar results) or studies of drugs in the same class showing similar results may help to reassure clinicians that the results are genuine. Conversely, when trials show differing results, clinicians should be especially vigilant in accepting only the results of the more positive trials.

As always, the translation of clinical trial evidence into practice demands careful scrutiny by the practitioner. Attention to external validity (is my patient sufficiently similar to those in the clinical trial that I can expect the same result from treatment?), interpretation of the outcome measures (clinically as well as statistically significant benefit), and weighing potential risks against potential benefits remain the responsibility of the treating practitioner.

## Limitations of the McMaster AHRQ Review

A systematic review that has evaluated 91 pharmacological interventions in 186 RCTs with high internal validity has several limitations. The studies selected for this review are English-language trials. Based on our search results, we estimate that we could have potentially retrieved 1385 foreign-language articles (after de-duplication 1213) distributed among databases as follows: 346 from Cochrane Central, 444 from EMBASE, 559 from MEDLINE/PreMedline® 36 from other databases before review for title and abstract. If we assumed the same rate of potentially eligible studies for these non-English studies, an additional 16 non-English studies may have been eligible for review. It is possible that agents, such as Ginkgo biloba, may have had important trials published in non-English languages. The budget and timelines available, however, were a limiting factor to obtaining, translating, and abstracting non-English trials.

Secondly, no contact with authors of the eligible trials was undertaken to collect additional unpublished studies or provide results/data that were not presented in the published article. Although contact with the original authors of the trials (to supplement the missing information from the included studies) could have compensated for many of the reporting challenges we encountered, this strategy was not feasible given the timeline of this systematic review. Our experience at the McMaster EPC suggests that the majority of authors do not respond in a timely fashion if at all. Additionally, efforts were not made to contact industry for unpublished trials. It is likely that industry sponsors of trials that are not published in the public domain are under no obligation to share trials (particularly negative trials). Not contacting authors of eligible trials for additional data and not attempting to locate unpublished trials (either by other authors/ experts or by industry) may introduce publication bias in this systematic review.

Thirdly, we employed two eligibility criteria that may account for some differences in acceptance of well-known studies. The first of these was a minimum threshold for quality score as determined by the modified Jadad scale. Despite the fact that this scale has excellent reliability and content validity, some may argue that the threshold score of 3 is arbitrary and may have unnecessarily eliminated studies of historical importance. It is our view that given the amount of literature available, all efforts should be aimed at selecting only the trials with the highest internal validity rather than selecting the largest number of eligible trials.

The second eligibility criteria concerned the exclusion of crossover trials. Although crossover trials are suitable for chronic diseases, they may be prone to period effects or period-by-treatment interactions. Period effects are systematic changes in the outcome that apply to all patients due to temporal changes in the disease or to the measurement instrument. Period-by-treatment interactions occur when the efficacy of the intervention varies by period. This is a significant concern for studies that attempt to show disease modification and are carried out over a longer period of time. Additionally, a carry-over effect may occur if the washout period is not adequate. In addition to the weaknesses of this design, some limitations arise when considering the potential for meta-analytic analyses. Traditionally, first period data from a crossover trial are abstracted and can be potentially combined with parallel trials for analyses of a pooled estimate; the reporting of the study results (positive or negative) would also be based on this first period data. In a preliminary phase of the review, several crossover trials were examined. It was noted that many did not report first period data, which precludes any potential for combining with parallel trials; many trials also did not undertake statistical tests during the first experience, thus making it difficult to report the direction of the findings, even if the trial could be combined. Finally, the TEP considered the fact that this systematic review was evaluating a variety of drug interventions administered over differing time intervals, and so period effects might be an important source of bias. For all these reasons, the TEP made the decision to exclude crossover trials from this systematic review. Thus, this review is limited to evidence based on high-quality parallel trials only.

A final limitation to our study was the use of a checklist developed to address the issue of quality of reporting adverse events. The Jadad scale was not designed to evaluate the quality of reporting adverse events. Thus, when determining the “harms” or risks associated with an intervention, the quality or “internal validity” of collecting and reporting these adverse events needed to be evaluated. Although our checklist has face validity, it has not undergone formal psychometric testing.

## Future Research Recommendations

The findings of this report suggest several important areas for future research on pharmacological treatments for dementia. These include:

Analytic Framework of the intended aim of the therapy on the disease

- Better conceptualization and research design to capture “delay in progression”.
- Clearer consensus on defining efficacy (benefits and clinically important change).
- Longer term studies (> 12 months).

Potential for bias

- Clarification of the role of industry sponsorship; one recommendation should be that all studies are required to disclose such information in future, including who analyzed the results.
- More concerted effort to incorporate unpublished studies and negative trials in future reviews.

Population

- Inclusion of the spectrum of severity in the patient populations (there is nothing to suggest that severe patients may not benefit from pharmacotherapy aimed at cognitive function improvement).
- The need for validation of trials and testing processes within cultures other than the traditional white population.
- Examining the efficacy of interventions in different sub-populations (age, disease severity levels, etc.).
- Better measurement and reporting of important patient characteristics (including baseline cognition scores, co-morbid conditions, the use of other medications, etc.).
- Inclusion of MCI type groups of subjects to evaluate “delay of onset”.

Outcomes

- Expansion of outcomes collected to include more than just cognitive function, and especially include caregiver burden and quality of life/ADL.
- Clear operational definitions for determining critical outcomes (delay to onset, delay to progression, important effect size, etc).
- Better understanding of how outcomes perform cross-culturally.
- Production of other diagnostic instruments to detect both onset and responses to therapies across varied cultural groups.
- Improvement in the reporting of adverse events to evaluate harm.

Analysis

- Appropriate analytical strategies that take into account intention to treat (ITT)/ last observation carried forward (LOCF) analyses; where possible both observed case and ITT/LOCF analyses should be presented.
- Sufficient data to estimate effect size, taking into account variability in both treated and control populations on the primary measures.
- Reporting the power of the study when findings are non-significant.

Intervention

- Undertake more studies with direct comparison of drugs to determine the relative efficacy of agents.
- Improved description of the titration process.
- Improved collection of adverse events undertaken in a systematic fashion with standardized instruments.