# Results

In this chapter, the presentations of the main results of the systematic review are organized according to the five questions that were addressed. The first question, concerning efficacy of the pharmacological interventions, contains results from all eligible studies. Subsets of trials were then selected from this larger set to address the remaining four questions (see Chapter 2 Methods).

## Eligible Studies

Figure 2 shows the final yield of eligible studies for evaluation, and the inclusion/exclusion criteria are listed in Chapter 2. Approximately 10.5% of identified studies met the eligibility criteria in the title and abstract phase. Similarly, 14.7% of the full text screened citations were eligible for full data abstraction. Several trials were identified as “companion papers”, indicating that results for these related studies were based on the same study subjects. These related studies were evaluated and a main publication was selected (usually the first chronological publication), and the remaining trials were searched for any additional data for abstraction; the “companion papers” were not considered as unique studies. English-language reports only were included in this review. ^53^ Although this is acknowledged as a possible source of bias, the overall proportion of potentially eligible non-English studies for review in title and abstract was small (7%).

Figure 2. Flow diagram showing the final number of studies meeting the eligibility criteria

Figure 3 indicates the distribution of eligible studies as a function of publication year grouped into approximately 5-year intervals. The largest proportion of studies (83%) was published within the last 11 years, with the greatest number from 1997 forward. This may have some implications for future systematic reviews with respect to the years searched.

Figure 3. Proportion of studies as a function of year of publication

This systematic review yielded a total of 97 pharmacological agents used in the treatment of dementia from 186 unique studies. These 97 interventions have been classified according to three broad categories: 1) cholinergic neurotransmitter modifying agents, 2) non-cholinergic neurotransmitter/ neuropeptide modifying agents, and 3) other agents.

## Question 1: Does pharmacotherapy for dementia syndromes improve cognitive symptoms and outcomes?

The largest number of eligible citations evaluated was cholinergic neurotransmitter modifying agents (n = 72). The remaining citations were distributed amongst the non-cholinergic neurotransmitter/neuropeptide modifying agents (n = 61) and other agents (n = 76) categories. Some studies evaluated agents in more than one category. The results for all pharmacological agents are presented in this chapter in summary format with descriptive text and an overall summary table (OST) for each drug located at the end of this chapter. The specific details abstracted from each individual study are presented within Appendix C (guide to the results tables) and organized into these same three therapeutic effect classification groups and by pharmacological agent. These Evidence Tables are available on-line at http://www.ahrq.gov/clinic/epcindex.htm.

Appendix C contains three sets of tables with key study descriptors as follows:

Key characteristics. Summarizes the following aspects of each study: features (author, year published, funding source, modified Jadad scale quality score, number randomized, number completing the trial, subgroup analysis), population characteristics (diagnosis, criteria for diagnosis, disease severity, percent male, age, dwelling, and differentiating demographics), intervention (doses, titration scheme, and intervention period), and a complete list of outcomes administered in the study protocol.

Study results. Details the changes observed (the magnitude of theses changes, the comparison groups analyzed, and the findings of any statistical testing) for those outcomes for which appropriate data was reported (for up to three time periods if available). When reported in studies, baseline measures, particularly MMSE score, were also detailed in these tables.

Study adverse events. Lists the specific types of adverse events (side effects, adverse reactions, and serious events) reported, any statistically significant differences between groups, the proportion of withdrawals due to adverse events, and the quality rating score (based on a checklist devised at the McMaster EPC and on the work of Ioannidis and Lau (2002) ^35^ ) specific to the collection and reporting of these adverse events.

### Interpretation of the Results in the Overall Summary Tables (OST) for Individual Studies

To facilitate the presentation of information within the OST (found at the end of this chapter), the outcomes reported in eligible studies were classified into seven domains: 1) general cognition scales, 2) specific cognition tests (neuropsychological tests evaluating specific attributes of cognition, such as short- and long-term memory, word fluency, etc.), 3) global assessment, 4) behavior/mood, 5) quality of life/ADL, 6) caregiver burden, and 7) other. The EPC research team reached consensus on the classification of the various outcome measures within these seven domains. For example, the ADAS-cog and MMSE were classified as “general cognition scales”, and the BEHAVE-AD and NOSGER were placed in the “behavior and mood” domain (see Appendix C guide to the results tables). The complete list of outcomes that were reported in the studies evaluated in this review and the domains that they were classified within is found in Appendix E. Table 9 in the report presents a guide to the overall summary tables by domain.

Table 9. Guide to Overall Summary Tables - Outcome Measures Classified by Domain

General cognitive function measure | Specific cognitive function measure | | Global Assessment | Behavior/Mood | Quality of Life/ADL/Function | Caregiver Burden | Other
ADAS-Cog (also ADAS-11) | ACPT | R-AVL | ADAS | ABID | ABS | CATS | CAUST
AMTS | Babcock Story recall | RM | ADCS-CGIC | ABSR | ADCS-ADL | CSS | SAS
BCRS | Barbizet Visuospatial | RPM | ADS | ACES | ADFACS | CSI | AIMS
CamCOG | BLM | Rey Memory Test | AGS-E | ADAS-Non-cog | ADL | SCB | BARS/ BAS
CASI | BNT | Set test | Bf-S | AFBS | ADL-C | | ERP
CETM | BSRT | Snodgrass Picture Naming Task | BGP | BDI | ADL-PDS | | ESRS
IQCODE | BSV | SRT-DR | Blessed-D/ BDRS | BEHAVE-AD | BI | | Finger Tapping
MCPT | BVR | SWFIT | CAPE | BPRS | Dependency Scale | | Test
MMSE | CCASSS | SWFT | CDR-NH | BRMS | DAD | | SAS
MMMSE | Category Fluency | SKT | CDR-SB | BRDS | FAST | | UPDR
SMMSE | CDT | TK | CGAE | CERAD-BRSD | FIM
CMMSE | CNTB | TMT | CGI | CMAI | IADL
MQ | Controlled Challenge Word Association | WMS (MQ) | CGIC | CS or CSDD | IDDD
RMT | COWAT | WMS-RR | CGRS | DSCS | NAA
RVM | CVLT | ZVT | CIBIC | DSS | NAI
SIB | Digit Span Test | | CICIC+ | Facial Behavior | OARS-ADL
SMQ | DSST | | DBDS | GS | PDS
SMST | EFR | | DMR | HAM-A | PSMS
TP, TPAT | FCMT | | DRS | HAM-D | PSQI
WAIS | FIGT | | EIS | HDRS | QoL
| FOM | | FCCA | HDS-R | QoL-P
| GAGS | | FRS | IPSC-E | QoL-C
| Grooved Pegboard Test | | GERRI | LPRS | SF-36
| Letter Cancellation | | GBS | MAACL-R | SIP
| Letter Fluency | | GDS | MADRS | Time to functional decline
| LMT | | GIS | MOSES
| LNNB | | GPI-E | NAB
| MAE | | HDS | NMS
| MEMT | | HIS | NOSGER-IADL
| MNLT | | MAC-F | NPI-NH
| NCT | | NOSGER | NSL
| NDT | | NOSIE | OAS
| NLT | | NPI (NPI-4, NPI10) | PANSS-EC
| NMIC | | PDRS | POMS
| NST | | PGIR | RMBPC
| OLT | | Plutchik CGS | RPT
| OMDR | | RAGS | SBI
| | | RGRS | SHGRT
| | | SCAG | SRT
| | | Stockton GRS | VHB
| | | TSI
| | | VRGI

For each of the outcomes reported by a study, four interpretations of the results were possible. The four options for interpretation are as follows:

SC = significant change. Demonstrated by statistical significance (p ≤ 0.05) for the primary outcomes from an ITT analysis comparing treatment and placebo groups, or comparing differences among dose groups.

NS = not significant. The corollary of SC indicating no statistical significance.

MX = mixed results. Primary outcomes within the same domain show opposite or inconclusive statistical significance; for example, in the general cognition domain, half the studies show significant change and the other half show no significance).

NR = not reported. Outcome was collected but not statistically evaluated or not reported in the publication.

NT = not tested. No outcomes in this domain were tested.

Secondary outcome results were reported in the absence of any primary outcome data (for the domain of interest) and were demarcated with a (2°) in the OST. Similarly, analyses other than ITT were denoted with an asterisk (*) in the OST. If the report describes my subgroup analyses, the word SUBGROUP appears in the “other” column.

Adverse events were not always clearly described in many studies. A priori, we selected 5 generic symptoms (nausea, dizziness, agitation, eating disorder, and diarrhea) and selected to detail the ranges amongst studies for both placebo and treatment groups for these symptoms. The percent of withdrawals for both groups due to adverse events was reported. Adverse events reported to be statistically significant are highlighted for the reader. The details in addition to the quality score rating will assist the reader in evaluating the potential for harm.

### Statistical Analysis

Power Analyses and Measures of Effect for combined studies. Power analyses (PW) were for individual trials for select pharmacological interventions (donepezil, galantamine, tacrine, rivastigmine, memantine, estrogen, carnitine, ginkgo biloba, selegiline) for all primary outcomes. In addition, if the trial reported the outcomes of the MMSE, ADAS-cog, or CIBIC+, power was also estimated (for individual trials of pharmacological interventions that had a minimum of three trials with a common outcome). Quantitative meta-analyses were undertaken in interventions that had a minimum of three trials using the same outcome scales and which provided sufficient data to permit calculation of effect sizes (as an Odds Ratio (OR), Relative Risk (RR) and Weighted mean difference (WMD)). The random-effects model results are presented to the reader.

### Quantitative and Descriptive Analyses

### Results of cholinergic neurotransmitter modifying agents (CNMA)

A total of 70 studies evaluating 16 cholinergic neurotransmitter modifying agents were eligible for review (Table 2). Six studies directly compared different drugs, and these trials are considered separately in the section that addresses question three. Overall results for each of the trials for each of the interventions are detailed in the OST located at the end of this chapter and organized by drug. All other study details are available in Evidence Tables 1 through 93 in Appendix C.

Table 2. List of Cholinergic neurotransmitter modifying agents and the number of studies vs. placebo for each of these. Asterisk (*) indicates report of a drug vs. drug trial [comparator drug(s) in brackets]

Drug | Number of studies vs. placebo
Antagonic Stress *[Meclofenoxate] *[Nicergoline] | 0**
Carnitine | 6
Donepezil *[Vitamin E] | 10*
Eptastigmine | 2
Galantamine | 6
Huperzine-A *[Tablet Capsule] | 1*
Linopirdine | 2
Mexofenoxate *[Antagonic stress] | 0*
Metrifonate | 9
Nicergoline*[Antagonic Stress] | 4*
Physostigmine | 4
Posatirelin *[Citicoline] | 4*
Rivastigmine | 6
Sabeluzole | 1
Tacrine *[Idebenone] *[Silymarin] | 6**
Velnacrine | 3

Carnitine (also known as acetyl-L-carnitine, gamma-trimethyl-β-acetylbutyrobetaine (Alcar). See Evidence Tables 1 through 8 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. A total of six studies ^54,^ ^55,^ ^56,^ ^57,^ ^58,^ ^59^ evaluating carnitine were included in this review. Four of the reports were published from 1990 to 1992 ^56,^ ^57,^ ^58,^ ^59^ while the remaining two, both by same authors, were published in 1996 and 2000. ^55,^ ^54^

Design/methodology. A total of 925 subjects were evaluated in these six studies comparing carnitine and placebo. The range of study sample sizes was from 30 to 431 subjects. Quality scores (out of 8 points) ranged from moderate ^57^ (5) to high ^58,^ ^59^ (7), and all of the studies were partially or totally funded by industry.

Populations. All trials were conducted on AD patients, and all but one study used the NINCDS criteria for diagnosis. None of the trials reported including patients with severe dementia; all were classified as mild to moderate.

One trial ^58^ had a mix of community and institutional patients, and one study reported using a community sample. ^56^ The mean age of the samples ranged from 59 ^54^ to 79 years, ^59^ with the majority reporting mean age greater than 70 years. One study ^56^ did not report mean age. Three studies specified the baseline MMSE ^54,^ ^55,^ ^57^ (range 16.1 to 20.6) and one trial specified the modified MMSE ^56^ (mean 35) demonstrating no differences between placebo and treatment groups.

Intervention. The dose varied from 2 to 3 grams per day, and treatment duration was either 24 weeks ^56,^ ^57,^ ^59^ or 52 weeks. ^54,^ ^55,^ ^58^ One study ^57^ did not report the dose used. No titration period was used for this drug in any of the studies.

Primary outcomes. All of the studies measured cognition as a main outcome; half of the trials also measured outcomes in the behavior/mood domain. ^58,^ ^54,^ ^55^ All but one of the studies ^58^ used a quality of life/ADL or functional status measure. Only one study ^55^ evaluated caregiver burden. Of the four studies ^59,^ ^58,^ ^54,^ ^55^ reporting the findings from a global measure, only one ^55^ used the Caregiver-rated Global Impression of Change (CGIC).

Analysis. Half of the studies reported ITT analyses ^58,^ ^54,^ ^55^ and the remaining trials reported OC results. ^57,^ ^59,^ ^56^ The ability to combine results was limited with only three studies having the common outcomes of ADAS-cog, modified MMSE (mMMSE), and Clinical Dementia Rating (CDR).

Results and interpretation. See Summary Table 1. The four studies that evaluated “general cognitive function” did not find statistically significant differences in this domain. For those trials that provided sufficient data to estimate power, three trials ^54,^ ^55,^ ^56^ were underpowered for the MMSE (PW = 0.15 to 0.19), and two trials ^54,^ ^55^ for the ADAS-cog (PW = 0.08 to 0.09) and the CDR (PW = 0.06 to 0.11). Meta-analysis was undertaken for the MMSE scores; although favoring a treatment effect, the pooled effect size (WMD = 0.55) was modest and zero was contained within the confidence interval (Figure 4) for the random effects models. The pooled estimate favoring treatment may suggest some potential for benefit in general cognitive function, but this must be verified in future research.

Figure 4. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the MMSE comparing carnitine versus placebo

For “specific cognitive tests”, two out of four studies did not detect statistical differences relative to placebo, and the remaining two showed mixed results (see Summary Table 1). No significant differences were found in the domains of global assessment, behavior/mood, and quality of life/ADL; power could not be evaluated for the majority of these outcomes in the trials (insufficient data reported to permit calculation).

Four ^57,^ ^59,^ ^56,^ ^58^ of the six trials scored 3 out of 5 on our quality scale for rating adverse events. Two trials ^55,^ ^54^ did not adequately report adverse events (score = 1), but tested for statistical differences between groups. Withdrawal rates due to adverse events ranged from 0 – 3% in all studies, with the exception of a single trial ^59^ where the percentage was 22% (placebo) and 44% (treatment). The high rates in this trial are likely related to the small sample size (n = 36). This same trial ^59^ was also the sole study reporting dizziness and anxiety (confusion, depression). In general, gastrointestinal symptoms (Evidence Table 8) were the most frequently reported adverse events, but most studies did not test for statistical differences in the rates between the groups. The percent of subjects reporting of a priori selected symptoms across all studies are as follows: 1) nausea (placebo = 6 – 14%, all doses carnitine = 28%), 2) dizziness (not reported as an event for either placebo or treatment group), 3) agitation (placebo = 6%, all doses carnitine = 7%), 4) diarrhea (not reported as an event for either placebo or treatment group), and 4) eating disorder (not reported as an event for either placebo or treatment group).

Donepezil. See Evidence Tables 9 through 21 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. A total of 11 studies ^60,^ ^61,^ ^62,^ ^63,^ ^64,^ ^65,^ ^66,^ ^67,^ ^68,^ ^69,^ ^70^ evaluating donepezil were eligible for this systematic review. One study ^70^ compared donepezil to vitamin E rather than placebo. All were published within the last 6 years (n = 1, 1996), (n = 2, 1998), (n = 1, 1999), (n = 5, 2001), (n = 2, 2002). Three of these studies ^66,^ ^67,^ ^69^ were undertaken by the same research group at different time periods and had unrelated cohorts of patients.

Design/methodology. A total of 3239 subjects (range of study sample size, 30 – 893) were included in these trials. The modified Jadad scale quality scores ranged from 5 ^61^ to 8. ^63,^ ^64^ All studies were funded by industry sponsors with the exception of a single trial ^70^ that did not specify their source of support.

Populations. All but one study ^60^ used the NINCDS criteria to diagnose dementia. Eight studies included only AD patients, one study included only VaD, ^68^ and the remaining two included Parkinson's disease dementia (PDD ^65^ ) and AD patients with cardiovascular disease. ^64^ A single trial included subjects with Down's syndrome and AD. ^60^ The severity of the dementia patients was described as mild to moderate in five studies, ^65,^ ^66,^ ^60,^ ^62,^ ^70^ mild to moderately severe in two studies, ^69,^ ^67^ probable in two studies, ^61,^ ^68^ and moderate to severe in two studies. ^63,^ ^64^

Some studies specified that the dementia patients were recruited from the community, ^68,^ ^63,^ ^60^ one study from institutional setting, ^64^ and the remaining did not specify the living arrangements. Mean ages of the study subjects ranged from 54 to 85.7 years with most studies representing ages in the upper to mid 70s.

Six studies ^61,^ ^62,^ ^65,^ ^66,^ ^67,^ ^69^ specified the race of the subjects, and of these, the overwhelming sample was Caucasian (range from 92 – 100%). All but one study ^68^ specified the proportion of men recruited, the range being from 18 – 46%. Four of these studies presented some results stratified by gender, ^62^ age, ^64^ APOE genotype, ^62^ baseline MMSE, ^63,^ ^64^ patients with Down's syndrome, ^60^ and the use of psychoactive drugs. ^63^ Three studies specified the baseline MMSE ^61,^ ^64,^ ^70^ demonstrating no differences between placebo and treatment group, and the mean values varied from 14 to 16.

Intervention. Five studies evaluated a 10 mg dose given once daily, ^60,^ ^61,^ ^62,^ ^63,^ ^66^ two studies 5 mg daily, ^64,^ ^69^ and four studies compared 5 mg and 10 mg dose groups. ^65,^ ^68,^ ^67,^ ^70^ Titration periods observed included 7 days ^65,^ ^67^ and 4 weeks, ^70,^ ^68^ these were not specified in the remaining studies. The total duration of the drug (including titration) varied from 12, ^65^ 15, ^67^ 23/24, ^60,^ ^63,^ ^64,^ ^65,^ ^66,^ ^68^ and 54/56 ^61,^ ^62^ weeks.

Primary outcomes. Specific cognitive tests and caregiver burden were not evaluated in these studies. Nine studies used the MMSE, and six studies the ADAS-cog.

Analysis. All but one of the studies ^60^ comparing donepezil to placebo used ITT analysis. The study using OC analysis showed no statistical difference between treatments. It had the smallest sample size of 30 subjects and was underpowered (PW = 0.16) for the behavioral measure used, NPI.

Results and interpretation. See Summary Table 2. For the 10 trials ^60,^ ^61,^ ^62,^ ^63,^ ^64,^ ^65,^ ^66,^ ^67,^ ^69,^ ^68^ comparing donepezil to placebo, two studies ^60,^ ^64^ did not show a positive effect for the domain of general cognition. However, both of these studies evaluated the outcomes in this domain as secondary outcomes, with one trial ^64^ lacking sufficient power for the MMSE (PW = 0.69); for the other trial, power could not be evaluated. For the eight trials ^61,^ ^62,^ ^63,^ ^64,^ ^66,^ ^69,^ ^67,^ ^68^ showing a positive effect on general cognition, all but one trial used the MMSE as an outcome, which allowed for a pooled effect size estimate (Figure 5); we assumed that the VaD patients in one trial ^65^ could be combined with the other dementia populations. Figure 5 shows a consistent treatment effect for improvement in general cognitive function as measured by the MMSE, and the overall effect was statistically significant. Figure 6 shows the four trials ^65,^ ^66,^ ^67,^ ^68^ that used the ADAS-cog to measure general cognitive function change. A consistent effect favoring treatment was evident, and the test for overall effect was statistically significant. It should be noted that some of the values used in the pooled estimates for the MMSE and the ADAS-cog were derived from figures showing means and confidence intervals in the trial reports, thus introducing some imprecision into these estimates.

Figure 5. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the MMSE comparing donepezil and placebo

Figure 6. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing donepezil versus placebo

Ten studies ^60,^ ^62,^ ^63,^ ^64,^ ^70,^ ^65,^ ^66,^ ^67,^ ^69,^ ^68^ evaluated global assessment, and with the exception of three trials, ^60,^ ^69,^ ^70^ all studies showed a statistically significant difference in this domain. The overall effect for the CIBIC (Figure 7), and the CIBIC + (Figure 8, expressed as a proportion of improved versus not improved) were estimated for the 5 mg dose of donepezil. Figure 9 shows the summary estimate for the three studies ^65,^ ^66,^ ^68^ that evaluated the 10 mg dose of donepezil; heterogeneity was significant (p = 0.007) in this meta-analysis, but the overall effect was significant (p = 0.002). Similarly, Figure 10 shows the summary estimate for the Clinical Dementia Rating (CDR) global assessment measure. A radial plot of these three studies was undertaken and suggests that one trial ^64^ could be an important source of the heterogeneity. Summary estimate was also calculated for the Neuropsychiatric Inventory (NPI), which was classified in the behavior domain. It was noted that two of the three studies that evaluated this outcome were lacking sufficient power ^60,^ ^64^ (PW = 0.11, PW = 0.16). The test for heterogeneity was significant but the test for overall effect was not. Thus, the results of the summary estimates for the NPI outcome are problematic. Two global assessment outcomes, the CIBIC+ and the CDR, show a consistent effect favoring the drug treatment at 5 mg; the evidence is inconsistent for the 10 mg dose.

Figure 7. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the CIBC+ (continuous data) comparing donepezil versus placebo

Figure 8. Relative Risk (RR) from the Random Effects Model (Random) for the CIBIC+ (dichotomous data probability of improving) for a 5 mg dose of donepezil

Figure 9. Relative Risk (RR) from the Fixed Effect Model (fixed) for the CIBIC+ (dichotomous data [improved versus not]) for a 10 mg dose of donepezil

Figure 10. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the Clinical Dementia Rating (CDR) comparing donepezil versus placebo

Five of the eight studies ^60,^ ^61,^ ^63,^ ^64,^ ^65,^ ^66,^ ^67,^ ^69^ measuring Activities of Daily Living (ADL) found a significant difference in the various outcomes used to assess ADL, but none of these could be combined into a summary estimate. It should be noted that the majority of trials selected these ADL variables as secondary outcomes. Behavior outcomes were not significant or showed mixed results for the three studies that evaluated this domain but these lacked sufficient power. Only one study collected caregiver stress and health service utilization outcomes ^63^ but did not report these data.

Quality scores for reporting adverse events varied from 1 to 4 but the majority of trials scored 3 or greater (n=7). One recently published study ^68^ scored 1, with no events detailed. Withdrawal due to adverse events ranged from 0 – 18% for treatment groups and 0 – 11% for placebo (see Evidence Table 21). Four studies ^65,^ ^68,^ ^67,^ ^66^ were able to demonstrate a dose effect, with increasing frequency of events as dosage increased. One study ^62^ reported significant differences between treatment and placebo for balance problems and asthenia (neurological fatigue). Fatigue was shown to be significant in two other studies. ^61,^ ^66^ Four ^65,^ ^61,^ ^66,^ ^67^ out of six studies testing differences between groups were statistically significant for diarrhea (placebo = 3 – 21%, all doses donepezil = 0 – 38%), nausea and vomiting (placebo = 4 – 9%, all doses donepezil = 4 – 25%). The other a priori symptom reported was agitation and frequencies for placebo varied from 0 – 8% and for all doses from 3 – 19%; but these were not shown to be statistically different. No serious adverse events requiring hospitalization were reported or shown to differ statistically between groups.

Galantamine. See Evidence Tables 22 through 29 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Six studies of galantamine ^71,^ ^72,^ ^73,^ ^74,^ ^75,^ ^76^ were included in this review. All compared galantamine with placebo and were published between 2000 and 2002 (from six different authors).

Design/methodology. The sample sizes for subjects ranged from 285 ^73^ to 978 ^74^ with 3530 subjects evaluated in total. All quality scores were high, with either 7 or 8 on the Jadad scale. Funding sources for these studies varied; one study did not report funding source, ^74^ one was funded by a non-industry source, ^75^ one was partially funded by industry, ^71^ and three were funded by industry. ^72,^ ^73^

Populations. All but one of the studies ^71^ included AD patients only, and this single study mixed VaD and AD patients. All subjects in these studies were classified as mild to moderate.

One study specified that the subjects were from the community. ^73^ All studies included from 36 – 53% male subjects, and the mean age ranged from 72.2 to 76.8 years. Three studies ^71,^ ^74,^ ^76^ specified race, and with the largest proportions being white (range from 91.5 – 99.9%). Two studies evaluated subgroups, based on baseline MMSE ^75^ and APOE genotype. ^75,^ ^76^

Intervention. All studies had a titration period, starting at 4 mg per day ^71,^ ^73^ or 8 mg per day. ^72,^ ^74,^ ^75,^ ^76^ Four studies increased the dose weekly, ^71,^ ^72,^ ^75,^ ^76^ and one study increased every 2 to 3 days. ^73^ All studies had a treatment dose of 24 mg per day. Three studies ^73,^ ^75,^ ^76^ included other doses ranging from 16 mg per day to 36 mg per day. Trials were undertaken for a minimum of 3 and maximum of 6 months.

Primary outcomes. All domains were measured except for specific cognitive tests and caregiver burden. All studies used the ADAS-cog and CIBIC or CGIC measures as primary outcomes. None reported baseline mean MMSE values.

Analysis. All but one ^71^ of the studies reported ITT analysis, and the results of this study did not differ from the others.

Results and interpretation. See Summary Table 3. Five of the six trials ^71,^ ^72,^ ^73,^ ^74,^ ^75,^ ^76^ that evaluated general cognitive function showed a significant effect. One trial ^73^ showed mixed effects with the ADAS-cog showing some improvement at the 24 mg but not the 32 mg dose level . Figures 11 and 12 show the pooled estimate for the ADAS-cog for five studies for 24 and 32 mg doses; one trial ^71^ was excluded from the pooled estimate as the population of this study was thought to be a source of heterogeneity. However, the test for heterogeneity for the 24 mg dose (Figure 11) was significant (p = 0.001) despite omitting this study, but the overall effect was significant (p = 0.0005); this estimate should be interpreted with caution. The pooled estimate for the 32 mg dose (Figure 12) showed a consistent effect favoring treatment and was significant (p < 0.00001).

Figure 11. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing galantamine at 24 mg dose versus placebo

Figure 12. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing galantamine at 32 mg dose versus placebo

All studies evaluated global assessment with the CIBIC+ with one exception. ^73^ All studies with the exception of this study showed a significant difference between placebo and treatment for both the 24 and 32 mg doses. Figures 13 and 14 show the pooled estimates for the CIBIC+ for these two dosages and suggest an overall effect size of equivalent magnitude for either dose. Similarly, all studies evaluated quality of life/ADL with a variety of different outcome measures; four studies ^71,^ ^72,^ ^74,^ ^75^ showed statistically significant differences between groups, and two studies did not. ^76,^ ^73^ Figures 15 and 16 shows the results of pooling the estimates for the Disability Assessment for Dementia (DAD) ^77^ outcome in those studies that provided sufficient data. In this instance, we included the trial with mixed dementia populations ^71^ to have a minimum of three studies required for a pooled estimate. A consistent, statistically significant effect favoring treatment is evident; the higher dose of 32 mg shows a slightly larger effect size relative to 24 mg. Two of the three studies that reported on behavior/mood outcomes showed statistically significant differences (Summary Table 3).

Figure 13. Relative Risk (RR) from the Random Effects Model (Random) for the CIBIC comparing galantamine at 24 mg dose versus placebo

Figure 14. Relative Risk (RR) from the Fixed Effects Mode Fixed l for CIBIC comparing galantamine at 32 mg dose versus placebo

Figure 15. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the DAD comparing galantamine at 24 mg dose versus placebo

FIgure 16. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the DAD comparing galantamine at 32 mg dose versus placebo

Five ^71,^ ^73,^ ^74,^ ^75,^ ^76^ of the six trials scored 3 out of 5 on our quality scale for rating adverse events. One trial ^72^ scored 4. Withdrawal rates due to adverse events ranged from 4 – 9% for placebo and 8 – 27% for the treatment group. One study ^73^ showed a dose response for adverse events. Although, most trials did not report testing for differences between groups, two trials ^76,^ ^75^ reported a statistical significant difference in weight loss between the placebo and treatment group. Statistical differences for aberrant hematology were not significant in any of the five studies that evaluated this (Evidence Table 29). The most common types of adverse events reported were gastrointestinal symptoms (nausea and vomiting, diarrhea), eating disorders/weight loss, and dizziness (four studies, see Evidence Table 29). The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea and vomiting (placebo = 3 – 13%, all doses = 6 – 44%), 2) dizziness (placebo = 3 – 11%, all doses = 4 – 19%), 3) diarrhea (placebo = 2 – 10%, all doses = 4 – 19%), 4) agitation (placebo = 1 – 9%, all doses = 6 – 15%), and 5) eating disorder (placebo = 0 – 6%, all doses = 4 – 20%).

Metrifonate. See Evidence Tables 30 through 40 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Nine studies ^78,^ ^79,^ ^80,^ ^81,^ ^82,^ ^83,^ ^84,^ ^85,^ ^86^ were eligible for this systematic review. Studies were published from 1996 to 1999, and all studies compared metrifonate to placebo.

Design/methodology. Overall, 2759 subjects were evaluated. Sample sizes randomized ranged from 27 to 605 subjects. Quality of the studies ranged from 5 ^80^ to 8, ^81^ with the majority of studies earning 6 points. ^82,^ ^83,^ ^79,^ ^85,^ ^78^ Two studies were non-industry-funded ^78,^ ^79^ and one did not specify the source of funding, ^80^ while the other six studies were partially or wholly funded by industry.

Populations. The subjects in all included trials were classified as having mild to moderate AD. Not all trials specified the source of recruitment or the racial composition of subjects. Three studies specified a community sample, ^86,^ ^79,^ ^85^ and three trials reported the racial composition l, ^83,^ ^86,^ ^84^ which was greater than 90% white in all cases. Mean age for all of the studies ranged from 71.4 to 75.0 years, with one study not reporting the mean age. ^80^

Intervention. All but one study ^86^ reported the loading dose, which varied from 0.5 mg per kg to 5.0 mg per kg. Following this initial loading period, the maintenance dose varied from 0.65 mg per kg to 4 mg per kg and 50 mg per day. The duration of the study treatments varied from 21 days to 26 weeks.

Primary outcomes. All outcome domains were evaluated with the exception of caregiver burden. ADAS-cog, CIBIC+, and MMSE were most frequently used as outcomes.

Analysis. Four trials reported OC analyses ^78,^ ^79,^ ^80,^ ^85^ and the remaining reported ITT analyses.

Results and interpretation. See Summary Table 4. A consistent positive change in cognitive function was found in all studies that reported this outcome (n = 8). One study ^85^ tested cognitive function, global assessment, and behavioral outcomes and reported the baseline endpoint scores but did not test for differences between treatment and placebo groups. Four of the eight studies reporting global assessment outcomes showed statistically significant differences between groups, and two ^83,^ ^86^ showed mixed results. The remaining two trials showed no significant results for global assessment, but they were secondary rather than primary outcomes. All studies that evaluated behavior/mood and quality of life/ADL outcomes (with the exception of one trial ^86^ ) showed no significant findings or mixed findings; it should be noted that all were secondary outcomes. There were not enough similar outcomes reported to complete a pooled analysis for metrifonate.

With the exception of a single study, quality scores for reporting adverse events were greater than 3 and generally well reported. However, only one trial ^83^ tested for differences between groups and found nausea and vomiting, diarrhea, and muscle and joint disorder to be significantly different. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea and vomiting (placebo = 3 – 14%, all doses = 2 – 50%), 2) dizziness (placebo = 1%, all doses = 3 – 4%), 3) diarrhea (placebo = 4 – 14%, all doses = 11–19%), 4) agitation (placebo = 2 – 14%, all doses = 8 – 33%), and none reported eating disorder as an adverse event. Withdrawal rates due to adverse outcomes varied from 0 – 9% for placebo and 0 – 12% for treatment groups. Some studies indicated arrhythmia ^80,^ ^82,^ ^83,^ ^85^ and hypotension ^82,^ ^85^ and hematological abnormality ^82^ but did not test for differences between groups. The majority of studies reported that laboratory tests including liver function and hematology were within normal limits. Overall, it was difficult to determine which types of adverse events reported had the potential to cause serious harm. This is some concern as metrifonate is no longer used as a therapy for dementia due to its potential for serious adverse events that include: respiratory paralysis, bradychardia, severe leg cramps and dyspepsia. ^87^

Nicergoline. See Evidence Tables 41 through 47 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Four studies ^88,^ ^89,^ ^90,^ ^91^ compared the effect of nicergoline to placebo, and one study, ^92^ published in 1994, compared nicergoline to antagonic-stress. The four placebo comparison studies were published in 1995, ^91^ 1997, ^89,^ ^90^ and 2001. ^88^

Design/methodology. Sample sizes in the controlled studies varied from 108 to 346, with the total number of subjects included totaling 705. The drug versus drug study had only 62 subjects. The placebo trials all had quality scores of 6 points, while the non-placebo trial had a quality score of 5. Funding sources were reported only in two studies, ^88,^ ^90^ and both were industry-funded.

Populations. These studies had a very mixed population of dementia patients. Two included AD only, ^88,^ ^92^ one trial MID only, ^89^ one trial included both senile dementia of Alzheimer type (SDAT) and MID, ^91^ and one trial included PDD, VaD, and mixed dementia. ^90^ All subjects had mild to moderate dementia. Studies included 38 – 55% male subjects; one study ^91^ did not report the gender proportions. Mean age of subjects ranged from 69.3 to 73.7 years with one study not reporting ^91^ this value. One study ^91^ compared SDAT patients to MID patients.

Intervention. All trials versus placebo used 60 mg per day, but duration varied from 2 months, ^91^ 6 months, ^88,^ ^89,^ ^92^ and 12 months. ^90^

Primary outcomes. Caregiver burden was the only domain not evaluated by at least one of the studies. Three trials ^89,^ ^90,^ ^91^ specified baseline MMSE, and this varied from 20 to 22.

Analysis. Two of the trials reported OC analyses ^90,^ ^91^ and two reported ITT analyses ^89,^ ^88^ ; the trial comparing nicergoline to antagonic-stress presented OC analysis only.

Results and interpretation. See Summary Table 5. There was a consistent positive effect for improvement in general cognitive function as all four studies showed a statistically significant difference. The evidence for benefit in the global assessment domain is inconclusive as only two of the trials ^89,^ ^90^ found significant differences and two trials ^88,^ ^93^ had mixed results (see Summary Table 5). Two trials ^91,^ ^88^ measured behavior/mood and found no significant difference. A single trial ^88^ evaluated quality of life/ADL; although two outcomes in this domain were used (both as secondary measures), none was significant relative to placebo. There were not enough similar outcomes reported to complete a pooled analysis for nicergoline.

Quality scores for reporting adverse events varied from 2 to 5 for these four trials, and none tested for differences between groups. Withdrawal due to adverse events varied from 0 – 8% for placebo and 0 to 9% for the treatment group. The trial with the lowest quality reporting score ^89^ reported the most number of different events (up to 23 event types). With the exception of headache, which was reported in all four trials, it was difficult to determine which types of adverse events most characterized exposure to this pharmacological agent. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all doses = 3%), 2) dizziness (placebo = 1 – 2%, all doses = 0% or not reported), 3) diarrhea (placebo = 2 – 6%, all doses = 2 – 4%, 4) agitation (placebo = 5%, all doses = not reported), and none reported eating disorder as an adverse event.

Physostigmine. See Evidence Tables 48 through 53 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Four studies were eligible for our review, ^94,^ ^95,^ ^96,^ ^97^ all comparing physostigmine to placebo only. The studies were from 1996, 1999, and 2000 with two of the studies being by the same author. ^95,^ ^96^

Design/methodology. Sample size ranged from 176 ^97^ to 475 ^96^ with an overall total of 1198 subjects. Quality scores were 5, ^96^ 6, ^94,^ ^95^ and 7 ^97^ out of 8 possible points. Two studies were industry-funded, ^97,^ ^96^ one was partially funded by industry, ^95^ and one did not report funding source. ^94^

Populations. All subjects had a diagnosis of mild to moderate or probable AD. Only one study ^96^ reported that all subjects were drawn from the community. Mean age ranged from 68.6 to 73.4 years, and the proportion of male subjects varied from 39.8 – 63%.

Intervention. Treatment schedules varied across the studies. One study ^94^ used a patch (30 and 60 mg), one trial used 30 mg (15 mg twice daily), ^97^ one trial had a washout and titration every 3 weeks to 30 or 36 mg per day, ^96^ and another trial titrated weekly to 15 mg twice daily. ^95^ Duration of treatment ranged from 6 weeks ^95^ to 24 weeks. ^94,^ ^96^

Primary outcomes. All studies used the ADAS-cog as a primary outcome, and none reported caregiver burden or behavior/mood measures. No studies reported baseline MMSE scores.

Analysis. All but one trial ^94^ used ITT analysis.

Results and interpretation. See Summary Table 6. Although all four trials measured general cognitive function, only three reported the results. All of these were statistically significant (see Summary Table 6) for the ADAS-cog, with change scores varying from 0.95 to 2.9 (change from baseline). Two trials ^95,^ ^96^ found significant change for global assessment outcomes; the remaining two showed mixed results ^97^ and non-significance. ^94^ Behavior/mood was only measured in one trial, ^94^ and the effect was not reported. Three of the trials included measures of quality of life/ADL as secondary outcomes ^95,^ ^96,^ ^97^ and all found no significant difference from placebo but these were secondary outcomes and may reflect a lack of power. There were not enough similar outcomes reported to complete a pooled analysis for physostigmine.

The quality scores for reporting adverse events were generally low, scoring 1 or 2 out of 5. Withdrawal rates due to adverse events varied from 1 – 5% for placebo and 12 – 55%in the treatment group, with one study ^97^ not reporting rates. The high withdrawal rates were in studies with sample sizes that varied from181 to 475 subjects. A single study ^97^ tested for differences between groups, and found that dizziness, tremor, weight loss, asthenia (varying from 6 – 22% for all doses), confusion, delirium, and respiratory problems were significantly different. The cluster of reported types of adverse events suggests that gastrointestinal problems (abdominal pain, diarrhea) (placebo = 1 – 9%, all doses = 13 – 28%), nausea and vomiting (placebo = 1 – 9%, all doses = 9 – 75%) and eating disorder (placebo = 2 – 6%, all doses = 5 – 16%) were most frequently reported. Dizziness (placebo = 4 – 13%, all doses = 11 – 38%) and agitation (placebo = 6 – 16%, all doses = 4 – 8%) were also reported. No events deemed serious enough for hospitalization were reported.

Posatirelin. See Evidence Tables 54 through 59 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Four studies ^98,^ ^99,^ ^100,^ ^101^ compared posatirelin to placebo, and one of these ^101^ also compared it to citicoline. One study was published in each of the years from 1995 to 1998, and all studies were conducted in Italy. Two studies were by the same author. ^100,^ ^101^

Design/methodology. Populations randomized in the studies varied from 136 ^100^ to 360 ^99^ with a total of 931 in all trials. Quality scores ranged from 5 ^98^ to 7 ^100^ out of a possible 8 points. Three of the four studies did not report the source of their funding, but one trial ^100^ reported partial funding by industry.

Populations. No two studies included exactly the same populations; one trial had only AD, ^101^ one trial had only VaD, ^100^ one trial had mixed AD and VaD, ^99^ and another trial had mixed AD, VaD, and PDD. ^98^ This latter trial ^98^ compared populations in a subgroup analysis of AD versus VaD. All studies evaluated populations with mild to moderate disease.

The mean age of the subjects ranged from 69.4 ^100^ to 78.8 ^98^ with the percentage of male subjects varying from 34 ^101^ to 66%. ^100^ One study ^100^ included a dementia population who also had hypertension.

Intervention. A dose of 10 mg per day was used in all studies, and treatment interval varied from 3 to 4 months.

Primary outcomes. General cognitive function was evaluated in all studies using the intellectual impairment Gottfries-Bråne-Steen (GBS) subscale and the MMSE was used in one trial. ^101^ Specific cognitive function was evaluated in one trial. ^100^ Quality of life/ADL was evaluated with the ADL subscale of the GBS, and behavior/mood was evaluated with the emotional impairment subscale of the GBS. GBS total score was assumed to be a measure of quality of life/ADL rather than global assessment. None of the trials reported baseline MMSE scores.

Analysis. Two of the studies ^100,^ ^101^ used OC analysis to report outcomes.

Results and interpretation. See Summary Table 7. All four studies evaluated general cognitive function, and three of these trials ^100,^ ^99,^ ^98^ reported significant differences using the intellectual impairment subscale of the GBS as a measure of this attribute. One study ^100^ measured this same outcome and the MMSE, but did not report results for the latter outcome. One study ^101^ measured reported changes within a treatment relative to baseline and not relative to placebo; this study demonstrated superiority for posatirelin relative to citicoline (a third comparison group), but did not test for differences between the placebo group. Showing non-inferiority of citicoline in this trial does not establish efficacy with respect to placebo. Statistically significant changes were also shown for the domain of quality of life/ADL as measured by the GBS total score or GBS ADL (FactorII) subscales in three of the studies. ^98,^ ^99,^ ^100^ A single trial ^100^ evaluated global assessment using the TP Global scale in VaD subjects. There were not enough similar outcomes reported to complete a pooled analysis for posatirelin.

Quality scores for reporting adverse events varied from 2 to 4. Withdrawal rates due to adverse events ranged from 0 – 3%in placebo and 0 – 4%in the treatment group. One trial ^100^ did not report the rate of withdrawal. None of the studies tested for significant differences between groups. All studies reported the presence of agitation, and at least three studies reported arrhythmia, nausea/vomiting, headache, rash/skin disorder, and sleep disorder; there is no evidence to suggest that these differed between placebo and treatment group. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all doses = 1 – 4%), 2) dizziness (placebo = not reported, all doses = 1%), 3) diarrhea (placebo = 2%, all doses = 2%), 4) agitation (placebo = 1 – 5%, all doses = 1 – 5%), and none reported eating disorder as an adverse event. No serious adverse events were reported.

Rivastigmine. See Evidence Tables 60 through 67 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Six studies were eligible for this review, all comparing rivastigmine to placebo. Studies were published in 1998, ^102,^ ^103^ 1999, ^104,^ ^105^ 2000, ^106^ and 2001. ^107^

Design/methodology. Six studies evaluated 2071 subjects in total, with studies ranging from 27 ^107^ to 725 ^104^ subjects. The quality of studies varied from 5 to 8, with three studies ^106,^ ^104,^ ^103^ scoring 8 points and one ^107^ earning 5 points. All studies were funded by industry sponsors.

Populations. Four studies were evaluated in AD patients, ^107,^ ^105,^ ^104,^ ^103^ one trial ^102^ dementia of the Alzheimer's type (DAT), and one study ^106^ Lewy body dementia subjects for mild to moderately severe subjects. One study ^103^ reported a subgroup analysis by vascular risk. One study reported a community sample in their trial. ^104^ Mean age for the studies ranged from 69.4 ^102^ to 75.9 years. ^107^ Two studies ^107,^ ^105^ did not report the ratio of male subjects in their study, and the other four varied from 39 – 56%. One trial ^104^ reported co-morbidity of diabetes, hypertension and arthritis; one trial ^103^ reported concurrent medication use for cardiovascular, gastrointestinal and analgesic aids.

Intervention. Doses for rivastigmine varied from 1 mg ^103^ to 12 mg, ^106,^ ^105,^ ^104^ and treatment duration varied from 14 ^104^ to 26 ^107,^ ^103^ weeks. All studies titrated the dose of drug over a period ranging from 2 weeks ^106^ to 12 weeks. ^107^

Primary outcomes. The ADAS-cog and CIBIC+ were evaluated in half the studies. Baseline MMSE was reported in two trials, ^103,^ ^106^ and the mean scores varied from 18 to 20. Specific cognitive function, behavior/mood, and quality of life/ADL were infrequently evaluated, and caregiver burden was not evaluated in the trials.

Analysis. Trials were evenly divided between ITT analyses ^106,^ ^104,^ ^103^ and OC. ^107,^ ^105,^ ^102^

Results and interpretation. See Summary Table 8. Although, general cognitive function was evaluated in five studies, only four reported findings, which were all statistically significant; one of these was borderline significant (p = 0.054) (see Summary Table 8). Two of these studies ^104,^ ^103^ represented two sites (North American and European) of the same protocol. Although the same protocol was used, one study ^103^ found significance for both high (6 – 12 mg) and lower (1 – 4 mg) dosages, but the other trial did not show significance for the lower dose, likely due to lack of power for this outcome (PW = 0.67). Interestingly, at the 12-week midpoint, the low dose groups in both these studies appeared to be worse than placebo for all primary outcome measures, but then migrated to improvement at the 26-week endpoint. For those studies ^105,^ ^104,^ ^103^ that reported ADAS-cog change scores from baseline for the treatment group, mean change values varied from -2.75 to 0.26. Figure 17 shows the pooled estimate for those trials that provided sufficient data and represents the 12 mg dose. However, the test for homogeneity was significant suggesting that the pooled estimate should be interpreted with caution (albeit a significant overall effect). For those studies that reported MMSE change scores from baseline for the treatment group, mean values varied from 0.0 to 0.6; a single trial ^103^ showed a decline of 7.9 points relative to baseline for the placebo after 26 weeks (other trials reporting MMSE scores did not report such marked change).

Figure 17. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing rivastigmine versus placebo

Two trials evaluated specific cognitive tests; one trial ^106^ showed statistical significance for the CCASSS but not for the MMSE (general cognitive test). Similarly, another trial ^105^ found the Weschler Logical memory (instant recall) to be significant but the ADAS-cog (general cognitive outcome) was borderline significant.

With respect to global changes, five of six studies showed significant changes, and from these, three studies ^104,^ ^103,^ ^102^ were for the high dose only. One of these studies ^102^ defined the high dose as 6 mg per day, which was the minimum dose level for the other two studies. One study ^107^ showed a statistical difference for the two deterioration categories (5 – 7) in the CIBIC+, but not in the improvement categories when comparing treatment and placebo groups. Figure 18 shows the pooled estimate for the CIBIC+ in those studies that provided sufficient information. A consistent effect favoring treatment is shown, but the two smaller trials display large confidence intervals (Figure 18). There was no clear trend in the domains of behavior/mood and quality of life/ADL as not all studies evaluated these domains.

Figure 18. Relative Risk (RR) from the Random Effects Model (Random) for the CIBIC+ comparing rivastigmine versus placebo

Quality scores for reporting adverse events varied from 2 to 5. Withdrawal rates due to adverse events ranged from 4 – 11% in the placebo and 11 – 27% in the treatment group. One trial ^107^ did not report the withdrawal rates or the types of adverse events observed. Two trials ^103,^ ^104^ demonstrated a dose response; however, one of these trials ^104^ showed significant differences for nausea and vomiting only, and the other trial ^103^ showed significant for all the adverse events reported. With respect to the types of adverse events, the majority of studies reported dizziness, nausea and vomiting, eating disorder/weight loss, and headache. It should be noted that one study ^105^ allowed intentional prescribed anti-emetic drugs to increase the tolerance of subjects taking rivastigmine. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3 – 10%, all doses = 8 – 58%), 2) dizziness (placebo = 0 – 7%, all doses = 6 – 20 %), 3) diarrhea (placebo = 2 – 9%, all doses = 7 – 17%), 4) eating disorder (placebo = 4 – 8%, all doses = 4 – 19%), and 5) agitation was not reported. No serious adverse events were reported.

Tacrine. See Evidence Tables 68 through 77 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Eight studies evaluating tacrine were eligible for this review; tacrine was compared to placebo in six trials ^108,^ ^109,^ ^110,^ ^111,^ ^112,^ ^113^ (lecithin was assumed to be like placebo) and to other drugs in two trials. ^114,^ ^26^ One study ^114^ compared two arms with tacrine, one with silymarin added and one placebo arm. The other non-placebo controlled trial compared tacrine with idebenone. ^26^ These drug versus drug trials were published in 1999 and 2002. The placebo controlled trials were published 1991, ^111^ 1994, ^108,^ ^109,^ ^113^ 1996, ^110^ and 1999. ^112^

Design/methodology. The placebo studies evaluated 994 patients in total with a range of 13 ^111^ to 663 ^108^ subjects per study. Quality scores out of 8 points were evenly distributed with two studies each having scores of 5, 6 and 7. Both drug versus drug trials had scores of 7. One study ^109^ was not funded by industry, and one trial ^114^ did not report its source of funding; the other six studies had at least partial, if not full, industry support.

Populations. All studies included AD subjects; one trial ^26^ also included PDD patients. Subjects in all studies had mild to moderate or probable disease. Five of the studies ^113,^ ^109,^ ^111,^ ^114,^ ^26^ reported that their sample was from the community. The mean age ranged from 68 ^110^ to 75 years, ^113^ and the percentage of male subjects in the studies varied from 13 ^110^ – 54%. ^113^ One study reported race with 100% white subjects. ^26^

Intervention. See Summary Table 9. All placebo-controlled trials used a titration period to get to maximum dose, from 11 days ^113^ to 18 weeks. ^112,^ ^108^ Treatment doses varied from 80 mg per day ^110^ to 160 mg per day. ^108^ Treatment duration was either 12/13 weeks, ^110,^ ^113,^ ^111^ or 30/36 weeks ^112,^ ^108,^ ^109^ for all placebo-controlled studies. The trial versus Idebenone ^26^ was for 60 weeks and the trial with silymarin ^114^ was for 15 weeks.

Primary outcomes. All six of our identified domains were evaluated by at least one trial. All trials measured cognition; however, sufficient data to permit pooled analyses could not be adequately abstracted from all these studies that had similar outcomes. Baseline MMSE varied from 14 to 18 in the fours trials ^112,^ ^110,^ ^109,^ ^114^ that reported this.

Analysis. Five studies ^108,^ ^112,^ ^113,^ ^114,^ ^26^ reported ITT analysis and three did not. ^109,^ ^111,^ ^110^

Results and interpretation. Of the six placebo-controlled studies, only one trial ^108^ showed statistical significance for general cognitive function as measured by the ADAS-cog (ES = -0.268). Three doses (80 mg,120 mg,160 mg) were compared in this trial, and the 120 and 160 mg per day were shown to be statistically significant (approximately a mean change of 2 points on the ADAS-cog). One trial ^112^ showed mixed results for the two outcomes used (CASI and MMSE) to evaluate general cognitive function; this trial was underpowered for both these outcomes (PW = 0.22 and 0.26, respectively). Three trials ^109,^ ^110,^ ^111^ found no statistical differences between treatment and placebo but had small sample sizes, ranging from 12 to 32 subjects, and were likely underpowered (insufficient reporting to estimate power). A fourth trial ^113^ also found no statistical difference (p = 0.55) for general cognitive function, but the study duration was 12 weeks. It should be noted that this study used an 80 mg dose, which was shown to have no benefit relative to higher doses of 120 and 160 mg. ^108^ A single trial ^109^ of small sample size evaluated specific cognitive tests and did not show statistical differences.

Three studies evaluated global assessment, and two ^113,^ ^108^ found statistical significance; the trial showing no benefit ^112^ also showed inconclusive findings for general cognitive function as well (PW = 0.05 for the CGIC). Four trials ^108,^ ^109,^ ^110,^ ^113^ evaluated behavior/mood and showed no difference between groups. Two trials ^109,^ ^111^ with small sample sizes measured quality of life/ADL and showed no significant changes; lack of sufficient power cannot be ruled out. There were not enough similar outcomes reported to complete a pooled analysis for tacrine.

The quality scores for reporting adverse events varied from 1 to 3. The proportion of subjects withdrawing due to adverse events ranged from 0 – 12% for placebo and 0 – 55% in the treatment group. The higher rates of withdrawal were associated with higher doses. Elevated alanine transaminase (ALT) or hepatic abnormality (placebo = 4 – 13%, all doses = 7 – 67%) was reported in six studies, suggesting the potential for serious liver damage. None of these trials tested for differences between treatment and placebo with respect to adverse events. Five of the studies reported nausea and vomiting (placebo = 0 – 9%, all doses = 9 – 37%); gastrointestinal problems and dizziness (placebo = 0 – 16%, all doses = 4 – 14%) was also noted in several studies. Frequencies of other a priori symptoms of interest are as follows: 1) agitation (placebo = 5 – 12%, all doses = 5 – 9%), and 2) diarrhea (placebo = 0 – 13%, all doses = 4 – 18%).

Velnacrine. See Evidence Tables 78 through 82 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Three studies evaluated velnacrine versus placebo, and these were published in 1991, ^115^ 1995, ^116^ and 1996. ^117^

Design/methodology. A total of 774 subjects were studied with sample sizes ranging from 16 ^115^ to 449. ^116^ Quality scores out of a possible 8 points varied from scores of 6 ^117,^ ^115^ or 7. ^116^ All studies were sponsored by industry.

Populations. The characteristics of the populations all included probable AD subjects. The mean age of the participants ranged from 70.5 to 72.8 years and the percentage of male subjects ranged from 31 – 41%. Location of recruitment was not specified.

Intervention. The doses given for this drug overlapped between the studies, but they were on different schedules (once, twice, or three times per day). None of the studies had a titration period. One study ^117^ compared four doses (three daily doses of 10 mg, 25 mg, 50 mg, and 75 mg). One study ^116^ compared doses of 150 mg or 225 mg per day. The other study used a dose of 100 mg twice daily and had the smallest sample size.

Primary outcomes. General cognitive function was evaluated in all studies with the ADAS-cog, and none specified baseline MMSE values. A variety of outcomes were used to evaluate global assessment. At least one of these trials evaluated the other outcomes domains

Analysis. Only one of the trials ^116^ used an ITT analysis.

Results and interpretation. See Summary Table 10. One ^115^ trial was of very small sample size (n = 16) and of a 2 weeks duration, compared to the other two studies ^117,^ ^116^ with 15 or 24 weeks. Similarly, this trial evaluated two outcomes (specific cognitive function and global assessment) and showed mixed or non-significant results, likely a function of being underpowered. The two remaining studies ^117,^ ^116^ had sample sizes over 300 subjects and showed statistical significance for the domain of general cognitive function using the ADAS-cog. The magnitude of the change reported varied from -2.0 at 12 weeks and then -1.0 ^116^ at 24 weeks for the 225 mg dose group only; a mean change of 2.15 ^117^ for the 75 mg (three times daily) as observed at the study endpoint of 15 weeks (no other dosage group was reported for this study). The trial ^116^ evaluating doses of 150 and 225 given once daily showed significant changes for 225 mg per day but not for 150 mg per day at endpoint (24 weeks), whereas, the trial with 75 mg twice daily did show significant change for general cognitive function.

All studies included assessment of global functioning, for which two ^117,^ ^116^ found significant differences, and one ^115^ had mixed results. Behavior/mood was evaluated in only one study ^117^ as a secondary outcome with an OC analysis, and no significant effect was found. Similarly, quality of life/ADL was measured in two studies as secondary outcomes, which produced opposite results (not significant ^117^ and significant ^116^ ). One of the trials ^116^ measured effects on caregiver burden as a secondary outcome and found a significant effect. There were not enough similar outcomes reported to complete a pooled analysis for velnacrine.

Quality scores for reporting adverse events were 3 for all studies. Withdrawal rates varied from 0 – 22% for the placebo group and 5 – 33% for the treatment group. None of the studies reported a dose response. None of the studies tested for statistical differences between the placebo and treatment groups. Two studies reported aberrant hematology and hepatic abnormality ^116,^ ^117^ ; for these two studies the rate of occurrence were 2 – 21% for placebo, and 32 – 40% for all doses. All studies reported diarrhea and nausea and vomiting. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 0 – 4%, all doses = 3 – 8%), 2) dizziness (placebo = 3%, all doses = 0 – 8%), 3) diarrhea (placebo = 3%, all doses = 2 – 33%), 4) agitation (placebo = 4%, all doses = 1 – 4%), and 5) eating disorder (placebo = 1%, all doses 2 – 4%).

Various cholinergic neurotransmitter modifying agents. See Evidence Tables 83 through 93 at http://www.ahrq.gov/clinic/epcindex.htm. See Summary Table 11.

The remaining agents classified as cholinergic neurotransmitter modifying agents were grouped according to the number of studies for the purposes of presentation:

Cholinergic pharmacological agents that had two trials eligible for this review and were compared to placebo.

Eptastigmine (Evidence Tables 83, 84, 85, 93). Two trials ^118,^ ^119^ evaluated eptastigmine in patients with mild to moderate AD (103 patients for 4 weeks and in 491 patients for 24 weeks). Both trials were industry-funded. The trial that used an ITT analysis ^118^ and had the longer duration (24 weeks) showed significant change in the three domains: general cognitive function, global assessment, and quality of life/ADL. The OC analysis ^119^ of the patients treated for 4 weeks showed no significant effect. One trial used the ADAS-cog as a primary outcome ^118^ and showed a small increase of 1.05 and 0.41 for the 15 and 20 mg thrice daily doses, respectively, relative to the placebo group (which increased by 2.6 points). The CIBIC+ was significant for the higher dose group only in this same trial. The evidence of benefit for eptastigmine remains inconclusive given the lack of consistency between studies.

Linopirdine (Evidence Tables 83, 87, 88, 93). Two 1997 trials ^120,^ ^121^ evaluated linopirdine in patients with mild to moderate AD patients for 4 or 6 weeks at 40 or 30 mg thrice daily. Both were at least partially industry-funded. One trial ^120^ included 382 patients on 30 mg dose during a 6 month trial and used an ITT analysis; this study showed statistically significant findings for general cognitive function alone as measured with the ADAS-cog (mean change 2.0 points); global assessment, quality of life/ADL, and behavior/mood were not significant. All outcomes evaluated in the second trial ^121^ were not significant, even though OC analysis was used.

Cholinergic pharmacological agents with only one trial eligible for this systematic review.

Huperzine-A (Evidence Tables 83, 92, 93). This study ^122^ showed a statistically significant benefit relative to placebo in an OC analysis of all domains that were evaluated: general cognitive function, behavior/mood, and quality of life/ADL. The study population was 103 Asian patients with mild to moderate AD, who were treated for 8 weeks.

Sabeluzole (Evidence Tables 83, 89, 93). This study ^123^ included 39 patients with mild to moderate AD and lasted 48 weeks. General cognitive function as measured by the ADAS-cog showed approximately a 5 point increase compared to a 7 point increase for placebo. The OC analysis showed no significant difference from placebo in general cognition.

### Results of non-cholinergic neurotransmitter/neuropeptide modifying agents (NCNMA)

A total of 35 drugs in 50 studies were classified as non-cholinergic neurotransmitter/neuropeptide modifying agents. These pharmacological agents can be seen in Table 3. Sixteen of these studies involved direct comparisons to other drugs and these are considered separately in the section addressing Question Three. Overall results for each of the trials each intervention are detailed in OST located at the end of this chapter and organized by drug. All other study details are available in Evidence Tables 95 through 161 in the Appendices.

Table 3. List of Non-cholinergic neurotransmitter/neuropeptide modifying agents and the number of studies vs. placebo for each of these. Asterisk (*) indicates report of a drug vs. drug trial [comparator drug(s) in brackets]

Drug | Number of studies vs. placebo
Alaproclate | 1
Alprazolam *[Lorazepam] | 0*
Anapsos | 1
BMY (Nootropic) | 1
Carbamazepine | 2
Citalopram *[Mianserin] *[Perphenazine] | 2**
Diphenhydramine *[Haloperidol, Oxazepam] | 0*
Divalproex | 2
Fluoxetine *[Haloperidol] *[Amitriptyline] | 2**
Fluvoxamine | 1
Haloperidol **[Risperidone] *[Loxapine] *[ Diphenhydramine Oxazepam ] *[Fluoxetine] *[ Tiapride] *[ Trazodone] | 4*******
Imipramine *[Paroxetine] | 1*
Lisuride | 1
Lorazepam *[Alprazolam] *[Olanzapine] | 1**
Loxapine *[Haloperidol] *[Thioridazine] | 1**
Lu25-109 | 1
Maprotiline | 1
Melperone *[Tiapride] | 0*
Memantine | 3
Mianserin *[Citalopram] | 0*
Minaprine | 1
Moclobemide | 1
Naftidrofuryl | 1
Olanzapine *[Lorazepam] | 2*
Oxazepam *[Diphenhydramine Haloperidol] | 0*
Paroxetine *[Imipramine] | 0*
Perphenazine *[Citalopram] | 1*
Phosphatidylserine | 2
Risperidone **[Haloperidol] | 1**
Selegiline *[Vitamin E] | 7*
Sertraline | 2
Thioridazine *[Loxapine] | 1*
Tiapride *[Haloperidol] *[Melperone] | 1**
Trazodone *[Haloperidol] *[5′-MTHF] | 1**
Xanomeline | 1

Haloperidol. See Evidence Tables 94 through 103 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Five studies ^124,^ ^125,^ ^126,^ ^127,^ ^128^ evaluating haloperidol relative to placebo as well as another drug were included in this review. Three additional trials ^129,^ ^130,^ ^131^ (from 1990, 1993, and 2001) compared haloperidol to another drug and did not include a placebo group (these are detailed in question 3). One study was published in each of 1982, 1997, and 1999; two were from 2000.

Design/methodology. Sample sizes for the placebo-controlled studies were generally small with samples of 15, ^128^ 64, ^126^ 149, ^125^ 344, ^127^ and 306 ^124^ for an overall total sample size of 622 subjects. All but one of the studies had a quality score of 6 out of a possible 8 points; the other study ^127^ had a score of 7 points. One study ^124^ did not indicate a funding source, three studies ^125,^ ^126,^ ^127^ indicated some industry funding, although none showed total industry funding, and one study ^128^ had no industry funding.

Populations. Populations evaluated in the studies included three with only mild to moderate or probable AD, ^124,^ ^125,^ ^128^ one with PDD and MID, ^126^ and one with PDD, VaD, and mixed dementia ^127^ (which reported subgroup information about VaD versus all subjects). Two placebo studies ^126^ reported the presence of subjects with severe disease. Two trials ^126,^ ^127^ studied institutionalized patients while one ^128^ looked at community subjects. Ages in the studies ranged from a mean of 72.7 to 81.0 years, and 33 – 49% of subjects were male.

Intervention. Haloperidol doses ranged from 3 mg to 20 mg per day for a treatment period of 3 weeks, ^124^ 6 weeks, ^128^ 10 weeks, ^126^ 12 weeks ^127^ or 16 weeks. ^125^ The other drugs that haloperidol was compared to included fluoxetine, ^128^ loxapine, ^126^ risperidone, ^127^ tiapride, ^124^ trazodone & BMT ^125^ in the placebo controlled studies; loxapine, ^129^ risperidone, ^131^ oxazepam & diphenhydramine ^130^ were evaluated in the head to head comparisons.

Primary outcomes. All studies evaluated behavioral outcomes, and at least one study evaluated the effect of haloperidol in each of the other domains included in this review with the exception of specific cognitive function. None of the studies reported baseline MMSE values.

Analysis. Two studies ^124,^ ^127^ reported ITT analysis and three ^128,^ ^126,^ ^125^ did not.

Results and interpretation. See Summary Table 12. Of the five studies that had a placebo group, only three trials evaluated general cognitive function. One trial ^127^ did not report the results for this domain and two showed no significant difference. ^124,^ ^125^ Three trials ^124,^ ^126,^ ^127^ found statistical differences for outcomes in the behavior/mood domain, and two trials ^128,^ ^125^ showed no change. One of these non-significant trials ^128^ evaluating behavior had a very small sample size (n = 12) and was likely underpowered. Four trials evaluated global function, and the two studies ^124,^ ^125^ that reported findings based on the CGIC and CGI showed both improvement and no benefit, suggesting inconsistent evidence for this domain; it should be noted that one of these trials lasted for only 3 weeks. ^124^ One trial evaluated quality of life using the IADL and showed statistical difference in favor of the placebo. Two trials ^125,^ ^128^ evaluated caregiver burden and showed no effect; one of these studies ^128^ had very small sample size and was likely underpowered. There were not enough similar outcomes reported to complete a pooled analysis for haloperidol.

The quality scores for reporting adverse events varied from 1 to 5. Only three of five studies reported withdrawal rates; the proportion of subjects withdrawing due to adverse events ranged from 5 – 17% for placebo and 17 – 33% in the treatment group. One trial ^124^ showed a dose response effect, but the study only lasted for 3 weeks. Three trials tested for differences between treatment and placebo with respect to extrapyramidal symptoms (placebo = 17 – 32%, all doses = 34 – 97%), and two ^124,^ ^125^ found significant differences. One study ^125^ found significant differences between groups for balance-related problems. Although reported by only two trials, the range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all doses = not reported), and 2) dizziness (placebo = 24%, all doses = 21%), 3) no frequencies were reported for agitation, diarrhea, or eating disorder.

Memantine. See Evidence Tables 104 through 108 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Three studies comparing memantine to placebo were eligible for review. One study was published in 1999 ^132^ and the other two ^133,^ ^134^ in 2002.

Design/methodology. Sample sizes ranged from 166 to 579 for a total population evaluated of 1066 subjects. Two studies ^132,^ ^133^ earned 6 points out of 8 for the quality score while the other ^134^ earned 7 points. One report ^132^ did not indicate the source of funding, and the other two had industry support or funding.

Populations. Two studies ^133,^ ^134^ included VaD patients only, one of which ^134^ analyzed subgroups based on MMSE, type of VaD, and gender. The other study ^132^ included VaD, DAT and PDD patients and did subgroup analysis comparing VaD to DAT and grouping for care dependence. One trial ^132^ included patients with severe disease and was the only study to report that all of their subjects were institutionalized. One study ^134^ included only community subjects and the other study ^133^ did not report source of patients. Study subjects had a mean age of 71.2, ^132^ 76.4, ^133^ and 77.4 ^134^ years, and 42 – 53% were male.

Intervention. Two studies ^133,^ ^134^ had a 4 week titration period with a final dose of 20 mg per day for the remaining 24 week study duration. The third study used a 2-week titration period with a final dose of 10 mg per day for the remaining 10 weeks of the study.

Primary outcomes. All studies evaluated global function. The ADAS-cog was evaluated in two studies ^134,^ ^133^ and showed smaller changes of decline relative to placebo by approximately 1.5 points. All studies measured global function with the CGI-C but did not provide variance data to permit the calculation of the pooled estimates. Although, all trials measured MMSE, none reported baseline values for this outcome. Only one trial ^132^ evaluated behavior/mood and quality of life/ADL. No study evaluated specific cognitive function or caregiver burden.

Analysis. All studies performed ITT analysis.

Results and interpretation. See Summary Table 13. Two studies ^134,^ ^133^ in subjects with mild to moderate VaD showed significant findings for general cognitive function but not global assessment. The power could be estimated for one of these trials ^133^ and was found to be below acceptable levels (PW= 0.60). The third memantine trial ^132^ in this review evaluated mixed dementia populations (including some VaD) with moderate to severe dementia and found significant differences for global function, behavior/mood, and quality of life/ADL, but did not evaluate general cognitive function. It should be noted that this trial ^132^ used half the dose of memantine for half the study duration in patients with greater disease severity, and had approximately half the sample size of the other two trials evaluated in this systematic review. There were not enough similar outcomes reported to complete a pooled analysis for Memantine.

The quality scores for reporting adverse events varied from 3 to 4. Only two of three studies reported withdrawal rates; the proportion of subjects withdrawing due to adverse events ranged from 7 – 13% for placebo and 9 – 12% in the treatment group. One trial ^133^ tested for differences between treatment and placebo, and none of the comparisons were significant. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 3%, all does = 5%), 2) dizziness (placebo = 3 – 8%, all doses = 6 – 11%), 3) diarrhea (placebo = 4%, all doses = 4%), 4) agitation (placebo = 7 – 8%, all doses = 4 – 5%), and none reported eating disorder as an adverse event.

Selegiline. See Evidence Tables 109 through 116 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Six studies evaluated the effect of selegiline compared to placebo. ^135,^ ^136,^ ^137,^ ^138,^ ^139,^ ^140^ A single study ^135^ compared selegiline to vitamin E, placebo and the combination of selegiline plus vitamin E . The studies were published in 1991, ^136^ 1992, ^137^ 1993, ^138^ 1997, ^135^ 1998, ^140^ and 1999. ^139^

Design/methodology. Sample sizes ranged from 10 ^137^ to 341 ^135^ with a total population evaluated of 733 subjects. Study quality scores were 5, ^140,^ ^135,^ ^137^ 6, ^139,^ ^138^ and 7. ^136^ Three trials ^139,^ ^137,^ ^136^ did not report the source of funding, and the other three ^140,^ ^135,^ ^138^ had some industry support.

Populations. Studies included patients with mild to moderate PDD, DAT, and AD. Two subgroup analyses based on the results of the clock drawing test ^139^ and the GDS result ^136^ were reported. One study reported that the included patients were institutionalized. ^139^ Mean age of the subjects in the trials ranged from 68.6 to 83.0 years and all had male subjects (29 – 74%).

Intervention. All trials used the same dose, 10 mg per day, with three of the trials ^135,^ ^138,^ ^137^ giving the drug in two 5 mg doses. One trial ^140^ reported a titration period of 7 days. The duration of the trials varied with treatment times of 2 months, ^137^ 3 months, ^136^ 6 months, ^139,^ ^140^ 15 months, ^138^ and 24 months. ^135^

Primary outcomes. Quality of life/ADL and caregiver burden were not evaluated in any of the studies.

Analysis. Two studies ^135,^ ^140^ carried out ITT analysis.

Results and interpretation. See Summary Table 14. Five of the six trials evaluated general cognitive function, and of these, only four reported their findings. Two of the trials ^138,^ ^140^ showed non-significant findings, but these had very small sample sizes (10 and 41 subjects) and were likely underpowered. Two trials ^137,^ ^139^ showed mixed results, and one of these was likely underpowered. ^137^ One trial ^136^ found significant changes for specific cognitive tests (Sternberg Memory tests). Similarly, this same trial showed significant differences for global assessment and behavior/mood. This is the only trial that showed consistently positive findings across domains tested, and it also had the highest quality score (7). However, the other studies evaluating specific cognitive functions, global assessment, and behavior/mood did not show consistent results (non-significant or mixed findings). There were not enough similar outcomes reported to complete a pooled analysis for selegiline.

There is some evidence that shows that selegiline and selegiline combined with vitamin E, increases the time to important functional decline milestones ^135^ using time to event in the survival analysis. The results of this study showed that the vitamin E, selegiline, and combined groups were statistically different (i.e., declined less) from the placebo group in analyses that included baseline MMSE score as a covariate (not significant when excluded). The median survival was 230 days (vitamin E), 215 days (selegiline), and 145 days (combined group). Moreover, the vitamin E group showed a statistically significant difference for the endpoint of institutionalization, and the other treatment groups did not. Thus, the findings of this study suggest that selegiline and vitamin E may delay clinically important deterioration in patients with moderately severe AD; this delay varied from 20 to 32 weeks. It should be noted that this study evaluated subjects over a 2 year period, the longest of any dementia trial; moreover, the population was moderate to severe with respect to severity.

The quality scores for reporting adverse events varied from 0 to 3. The proportion of subjects withdrawing due to adverse events ranged from 0 – 4% for placebo and 0 – 9% in the treatment group. Two trials ^137,^ ^138^ did not report any adverse events. Only one trial ^135^ tested for differences between the treatment and placebo groups and showed that balance (worse) and falls were significantly different between groups (particularly the group with selegiline combined with vitamin E (22%) versus placebo (5%)). However, when adjusted for multiple comparisons, these were no longer significant. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 2%, all doses = 0%), 2) dizziness (placebo = 2 – 20%, all doses = 0 – 30%), and 3) agitation (placebo = 4 – 16%, all doses = 4 – 23%); no trial diarrhea or reported eating disorder as an adverse event.

Various non-cholinergic neurotransmitter/neuropeptide modifying agents. See Evidence Tables 117 through 160 at http://www.ahrq.gov/clinic/epcindex.htm. See Summary Table 15.

Ten non-cholinergic neurotransmitter neuropeptide modifying agents versus placebo were studied in only two included trials:

Anapsos (Evidence Tables 117, 119, 120, 160). Anapsos versus placebo was reported for a total of 114 patients with AD or VaD in reports published 1993 ^141^ and 2000. ^142^ Both studies were partially funded by industry, and varied in the drug dose and duration; one trial ^142^ used 360 mg per day or 720 mg per day for 4 weeks, and the other trial ^141^ used 300 mg three times a day for 12 weeks. They each reported only one domain, and showed a significant change for general cognitive function ^142^ and no significant results for global assessment. ^141^

Carbamazepine (Evidence Tables 117, 121, 122, 160). Two trials ^143,^ ^144^ evaluated carbamazepine in a total of 72 patients. The 1998 study ^144^ included a mixed severity population of institutionalized patients with non-industry-funding but also some financial support from industry. Both studies titrated up from 100 mg per day to 300 mg per day for 6 weeks. They evaluated all domains except caregiver burden. The trial using OC ^143^ population showed no significant effect for all outcomes tested but was likely underpowered (n = 16). The trial using ITT ^144^ showed a significant change in global assessment and behavior/mood. The evidence for benefit remains inconclusive given the lack of consistency between trials.

Citalopram (Evidence Tables 117, 123, 124, 160). Citalopram was evaluated in a total of 183 patients with mixed dementias including AD, VaD, mixed, MID, PDD. One trial ^145^ was non-industry-funded and the other ^146^ did not report funding source. Treatment was 20 mg per day for two weeks in both trials, with one continuing for 2 more weeks with 30 mg per day. One trial ^146^ measured the global effect and had mixed results. Both studies measured behavior/mood: one ^145^ showing significant change and the other ^146^ showing no significant change.

Divalproex sodium (Evidence Tables 117, 125, 126, 160). Divalproex sodium was evaluated in 229 subjects with mixed populations of VaD and AD who were treated for 6 weeks with increasing dosages until 20 mg per kg daily ^147^ or until side effects appeared. ^148^ These trials were both industry-supported or funded and included 56 or 173 institutionalized patients with probable or possible disease. Both trials showed no significant change in cognition and behavior/mood, while only one study ^148^ measured quality of life/ADL and found no significant difference. Both trials did a global assessment; one study found no significant difference, ^148^ and the other ^147^ found a significant change in favor of placebo.

Fluoxetine (Evidence Tables 117, 140, 141, 160). Fluoxetine was studied in a total of 56 AD patients using 3 or 20 mg per day ^128^ or a titration from 10 to 40 mg per day ^149^ for 6 weeks. All patients included in one study ^149^ also had major or minor depression. One study ^128^ was not industry-funded, and the other ^149^ did not indicate the funding source. Overall, the two studies evaluated general cognition, behavior/mood, quality of life/ADL, and caregiver burden; no significant differences between the drug and placebo were found.

Loxapine (Evidence Tables 117, 147, 159, 160). Loxapine was evaluated in two trials ^150,^ ^126^ from 1982 and included a total of 124 patients with MID and PDD. One trial ^126^ reported moderate to severe disease. The mean age in the other trial ^150^ was 83.0 years compared to 72.7 years in the trial with severe patients. Both studies were partially funded by industry and lasted 8 or 10 weeks. Only two domains were evaluated: global assessment and behavior /mood. No significant difference was shown in one trial, ^150^ while the other trial ^126^ showed a significant difference for behavior/mood.

Olanzapine (Evidence Tables 117, 135, 146, 160). Olanzapine was evaluated by two industry-funded trials in a total of 478 institutionalized patients with AD, VaD, and mixed dementia. One study ^151^ used 10 or 15 mg per day for 6 weeks and the other ^152^ used 12.5 mg maximum for one day. Both studies showed no significant change in general cognition. Both showed a significant change in measures of behavior/mood. One study ^152^ evaluated global assessment and found no significant differences.

Phosphatidylserine (Evidence Tables 117, 136, 137, 160). Two industry-funded trials studied a total of 193 patients with AD or PDD. One study ^153^ included institutionalized patients with mild to severe AD and a mean age of 62.1 years, and the other ^154^ included community patients with mild to moderate AD or PDD and a mean age of 71.0 years. Both studies did subgroup analysis based on severity of illness. The study of institutionalized patients ^153^ found significant change in the domain of general cognition and global assessment. The study with community patients found significant change in a global assessment but no significant change in a measure of quality of life/ADL.

Risperidone (Evidence Tables 117, 142, 144, 160). Two studies evaluated risperidone for 12 weeks in 625 AD, VaD, or mixed dementia patients with moderate to severe disease ^155^ and in 344 PDD, VaD, or mixed dementia patients with severe disease. ^127^ The studies were industry-funded or supported, and both did subgroup analysis: one by disease and the other by gender, age, race, and diagnosis. Both trials showed a significant change in a global assessment. One study ^155^ found a significant change in behavior/mood, and the other study ^127^ had mixed results for that domain. There was no significant change in cognition or quality of life/ADL according to one of the trials. ^127^

Sertraline (Evidence Tables 117, 138, 139, 160). Sertraline was evaluated in two studies: one trial ^156^ for 8 weeks in 31 late-stage institutionalized AD patients with major depression (mean age 89.0 years), and the other trial ^157^ for 13 weeks in a community sample of 22 patients with mild to moderate AD and depression (mean age 77.0 years). Both studies found no significant differences in cognition. The trial ^156^ in subjects with severe disease found no significant difference in behavior/mood; the second trial ^157^ had mixed results for this same domain. The study in patients with mild to moderate disease showed significant change for a global assessment and no significance for quality of life/ADL.

Non-cholinergic neurotransmitter/neuropeptide modifying interventions (NCNMA). Fifteen drugs in this drug grouping were compared to placebo in only one included trial. Eight of these trials showed a significant difference from placebo (See Evidence Tables 117, 120, 128, 129, 133, 134, 143, 145, 149, 160 at http://www.ahrq.gov/clinic/epcindex.htm): Alaproclate ^158^ for 4 weeks in 43 institutionalized patients with mild to severe PDD, MID and mixed dementia was better for quality of life/ADL. Imipramine ^159^ for 8 weeks in a community sample of 61 PDD and AD patients with depression was better for global assessment. Lisuride ^160^ for 8 weeks in 22 patients with mild to moderately severe AD was better for cognition. Minaprine ^161^ for 12 weeks in an institutionalized sample of MID or SDAT patients showed mixed results for behavior. Moclobemide ^162^ for 6 weeks in 511 patients with mild to moderate AD who were from both the community and institutions was better for cognition and behavior/mood. Naftidrofuryl ^163^ for 6 months in 378 patients with mild to severe VaD or mixed dementia was better for cognition and global assessment. Tiapride ^124^ for 3 weeks in 306 institutionalized AD patients with aggressiveness or irritability was better for behavior/mood. Trazodone ^125^ for 16 weeks in 149 AD patients from the community was better for quality of life/ADL. Xanomeline ^164^ in 343 community AD patients for 6 months was better for cognition, global assessment, and quality of life/ADL.

Seven trials (See Evidence Tables 119, 127, 130, 131, 132, 146, 147, 148, 160 at http://www.ahrq.gov/clinic/epcindex.htm) found no significant differences from placebo when evaluating perphenazine, ^145^ thoridazine, ^150^ fluvoxamine, ^165^ lorazepam, ^152^ LU25, ^166^ maprotiline, ^167^ and minaprine ^161^ .

### Results of other agents

A total of 72 studies representing 46 different other agents were eligible for this review and these can be seen in Table 4. Twenty-two of these interventions were evaluated in a single trial and only briefly summarized in this chapter; greater detail is provided in Evidence Tables 161 through 249.

Table 4. List of Other pharmacological agents and the number of studies vs. placebo for each of these. Asterisk (*) indicates report of a drug vs. drug trial [comparator drug(s) in brackets]

Drug | Number of studies vs. placebo
Aniracetam | 1
5′-MTHF *[Trazodone] | 0*
Amitriptyline *[Fluoxetine] | 0*
Ateroid | 1
Buflomedil | 1
Cerebrolysin | 6
Choro-San | 1
Choto-San | 1
Citicoline *[Posatirelin] *[Sulphomucopolysaccharides] | 0**
Cyclandelate | 2
Denbufylline | 1
Desferrioxamine | 1
Diclofenac | 1
Ergokryptine (CMB 36-733) | 1
Ergokryptine (Dek) | 1
Estrogens | 5
Ginkgo Biloba | 3
Glycosaminoglycan Polysulfate | 1
Guanfacine | 1
Hydergine *[Pyritinol] | 1*
Hydroxychloroquine | 1
Idebenone *[Tacrine] | 4*
Indomethacin | 1
Misoprostol *[Diclofenac] | 0*
Monosialotetrahexosylganglioside (GM-1) | 1
N-Acetylcysteine | 1
Nimesulide | 1
Nimodipine | 2
Nizatidine | 1
Nootropic | 1
ORG 2766 | 2
Oxiracetam | 5
Pentoxifylline *[Sulodexide] | 3*
Piracetam | 1
Prednisone | 1
Propentofylline | 4
Pyritinol *[Hydergine] | 0*
Silymarin + Tacrine *[Placebo + Tacrine] | 0*
Simvastatin | 1
Sulphomucopolysaccharides *[Citicoline] | 0*
Sulodexide *[Pentoxifylline] | 0*
Thiamine | 1
Vasopressin (DDAVP) | 1
Vincamine | 1
Vitamin E *[Donepezil] *[Selegiline] | 1**
Xantinolnicotinate | 1

Cerebrolysin. See Evidence Tables 161 through 168 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Six included studies ^168,^ ^169,^ ^170,^ ^171,^ ^172,^ ^173^ compared cerebrolysin to placebo. One report was from 1994, ^172^ one from 1999, ^171^ two from 2000, ^169,^ ^170^ one from 2001, ^168^ and one from 2002. ^173^

Design/methodology. The sample size in the studies ranged from 53 ^169^ to 192 ^173^ with a total of 819 subjects. The quality of studies varied from scoring 6 ^171^ to 8 ^168,^ ^173^ points out of a possible 8 points. One study ^172^ did not indicate the source of funding, one trial had non-industry funding, ^173^ and the four remaining trials were funded by industry. ^168,^ ^169,^ ^170,^ ^171^

Populations. All but one of the six studies included AD patients; one study ^171^ evaluated patients who had mild to moderate VaD. Mean ages of the subjects in the studies ranged from 69.7 ^171^ to 74.1 years. ^173^ The proportion of males in the trials varied from 34 – 69%, and only one trial ^173^ specified the proportion of Caucasians.

Intervention. All of the studies used the same dose of cerebrolysin, 30 ml per day, for 5 days per week. One trial ^172^ was for 28 days, four studies ^169,^ ^170,^ ^171^ lasted 4 weeks, one trial ^168^ lasted 16 weeks, and one trial ^173^ lasted 24 weeks.

Primary outcomes. Most studies evaluated general cognitive function and three trials ^168,^ ^169,^ ^173^ used the ADAS-cog. Baseline MMSE was reported in a single trial ^173^ with a score of 21. All studies evaluated global function, and at least two studies evaluated one outcome in each of the remaining domains with the exception of caregiver burden.

Analysis. All but one ^173^ of the studies used ITT analysis.

Results and interpretation. See Summary Table 16. Four of the five studies that evaluated general cognitive function showed significant differences. ^169,^ ^168,^ ^170,^ ^171^ Figure 19 displays the pooled estimate for those studies for which the appropriate data could be extracted for the ADAS-cog. Although a summary estimate was calculated, the test for heterogeneity was positive, suggesting the estimate should be interpreted with caution. Moreover, the overall estimate was not significant. One study ^173^ showed no significant difference in MMSE or ADAS-cog. This was the only study to report non-industry funding and coincidentally the only study to use OC population analysis. Three studies used specific cognitive measures, two of which ^172,^ ^171^ found significant differences and one of which ^170^ showed mixed results.

Figure 19. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing cerebrolysin versus placebo

All trials evaluated global assessment, and all except one trial ^171^ reported a significant difference. Figure 20 shows the pooled estimate for the CGI. The pooled estimate was calculated, the test for heterogeneity was positive, suggesting the estimate should be interpreted with caution. However, the overall estimate is significant. Three trials reported results for a measure of behavior/mood, one showing significant effects ^168^ and the other two ^171^ showing none. All trials carried out evaluations of quality of life/ADL measures; one did not report the effect, ^168^ one had mixed results ^170^ and the other four showed no significant difference. ^169,^ ^173,^ ^172,^ ^171^ No study measured caregiver burden.

Figure 20. Odd Ratio (OR) from the Random Effects Model (Random) for the CGI comparing cerebrolysin versus placebo

Two ^169,^ ^172^ of the six trials scored 5 out of 5 on our quality scale for rating adverse events, yet they did not report any adverse events. Two studies ^173,^ ^168^ scored 4, and the other two trials scored 3 ^171^ and 2. ^170^ All the studies with scores equals to 4 or less tested for statistical differences in adverse events between placebo and treatment groups. Withdrawals due to adverse events were not reported in one study, ^170^ and were 1% in two studies. ^173,^ ^168^ Three studies ^169,^ ^172,^ ^171^ reported no withdrawals. A significant difference between treatment and control group was reported in one study ^173^ for weight change, anxiety, and headache. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 10 – 24%, all doses = 3 – 21%), 2) dizziness (placebo = 0 – 12, all doses = 1 – 8%), and 3) agitation (placebo = 1%, all doses = 0%), and none reported diarrhea or eating disorder as an adverse event.

Estrogens. See Evidence Tables 169 through 175 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Five studies ^174,^ ^175,^ ^176,^ ^177,^ ^178^ evaluated estrogens for dementia patients: one published in 1999, ^178^ three in 2000, ^176,^ ^177,^ ^175^ and one in 2001. ^174^ None compared estrogens to another drug.

Design/methodology. The number of subjects included in the studies ranged from 15 ^178^ to 120 subjects ^177^ with a total of 247 patients. Quality of the studies ranged from 5 ^174^ to 8 ^178^ points out of a possible 8 points. All studies were partially or fully funded by industry.

Populations. Four of the studies ^176,^ ^177,^ ^175,^ ^174^ included patients with mild to moderate AD, and one study ^178^ included moderate to severe dementia patients who were all institutionalized. Only one of the studies ^178^ included male subjects. Mean age ranged from 71.8 ^175^ to 80.0 years ^174^ in the AD studies, and it was 83.8 in the dementia study. ^178^

Intervention. One of the studies with AD patients used 0.10 mg per day ^174^ for 8 weeks, and the others used 1.25 mg per day for 12 weeks, ^175^ 16 weeks, ^176^ and 52 weeks. ^177^ The study ^178^ including subjects with severe disease used 2.5 mg per day for 4 weeks.

Primary outcomes. At least one study evaluated each of the included domains with the exception of caregiver burden.

Analysis. Two of the studies ^177,^ ^175^ performed ITT analysis and the other three used OC analysis.

Results and interpretation. See Summary Table 17. Three ^176,^ ^177,^ ^175^ trials evaluated general cognitive function and all showed non-significant findings; two trials ^176,^ ^177^ lacked sufficient power (PW = 0.10, PW = 0.44) for the ADAS-cog. Attempts were made to combine the ADAS-cog, but the random-effects model was positive for heterogeneity and the overall effect was not significant. Two trials ^174,^ ^177^ evaluated specific cognitive function, and only one of these, using the Stroop Color Word Interference Test (SCWIT) measure, showed significant differences. ^174^ Global assessment was undertaken in all trials and found to be not significant in any of these trials. For those trials where power could be estimated, ^176,^ ^177,^ ^175^ there was insufficient power for the CGIC, CDR, and CIBIC+ outcomes. For the outcomes of behavior/mood and quality of life/ADL, none of the trials reported significant differences; power for the outcomes used in the trials could not be estimated. Overall, the evidence that estrogen affected general and specific cognitive function, global assessment, behavior/mood, and quality of life/ADL is inconclusive. There were not enough similar outcomes reported to complete a pooled analysis for estrogens.

One ^178^ of the five trials scored 5 out of 5 on our quality scale for rating adverse events, and surprisingly, this same trial did not report any adverse event. Two trials ^176,^ ^177^ scored 3; one trial ^175^ scored 2, and one ^174^ scored 1. This latter study reported adverse events, but did not test for significant differences between groups. Withdrawal rates due to adverse events ranged from 0 – 5% for placebo and 0 –14% for the treatment group. The most frequently reported adverse event was vaginal bleeding, ^175,^ ^177,^ ^176^ and a single trial ^175^ reported a significant difference between placebo and treatment group for vaginal bleeding. It was not clear from the descriptions provided in the study if they had ascertained whether vaginal bleeding was present prior to the trial commencement. Nausea was the single a priori symptom of interest that was reported and by a single trial; frequencies varied from 0% for the placebo group and 4% for the treatment group.

Ginkgo biloba. See Evidence Tables 176 through 180 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Three studies ^179,^ ^180,^ ^181^ evaluating Ginkgo biloba were eligible to be included in this review. All of the studies compared the drug to placebo only. One of the studies was reported in 1996 ^181^ and two were reported in 1997. ^179,^ ^180^

Design/methodology. The studies included evaluated 20 subjects, ^180^ 216 subjects, ^181^ and 327 subjects ^179^ (totaling 563 subjects). Two of the reports ^179,^ ^181^ scored 8 quality points out of a possible 8 points, and the other ^180^ earned 6 points. One study did not indicate the funding source, ^180^ and the other two had industry funding.

Populations. All of the studies included a mix of dementia diagnoses as follows: 1) mild to moderately severe AD and MID, ^179^ 2) mild to moderate DAT and PDD ^180^ , and 3) mild to moderate DAT and MID ^181^ in community dwelling patients. Two of the studies reported subgroup analysis, one comparing diagnoses and comparing effects based on baseline MMSE score ^179^ and the other based on diagnosis. ^181^ The patients in these trials had mean ages of 64.6, ^180^ 69.0, ^179^ and 69.6 years. ^181^

Intervention. Two of the trials gave 240 mg per day for 3 months ^180^ and 6 months, ^181^ and the other trial ^179^ gave 40 mg three times daily for 12 months.

Primary outcomes. None of the studies reported on quality of life/ADL or caregiver burden.

Analysis. All of the trials used an ITT analysis.

Results and interpretation. See Summary Table 18. Two of the three trials evaluated general cognitive function, and only one of these showed significant results. ^179^ Two studies ^181,^ ^180^ showed positive results with specific cognitive function. The results for global assessment are inconsistent as only one trial had positive findings, ^181^ one study had mixed results, ^179^ and one trial ^180^ showed non-significant results. This latter study had a very small sample size and lacked sufficient power for some outcomes. Only one trial ^181^ reported behavior/mood outcomes and found no difference between groups. None of the studies evaluated quality of life/ADL and caregiver burden. There were not enough similar outcomes reported to complete a pooled analysis for ginkgo biloba.

One ^180^ of the three trials scored 5 out of 5 on our quality scale for rating adverse events. One study ^181^ scored 4, and one trial ^179^ scored 3. Two studies ^181,^ ^180^ had no withdrawals due to adverse events, and one trial ^179^ had a withdrawal rate of 6% for both placebo and treatment groups. Two studies ^179,^ ^180^ did not report any adverse event. One study ^181^ reported a statistically significant difference between the treatment and the placebo group for skin disorders. The same study reported gastrointestinal and headache adverse effects, but did not test for statistical differences between the placebo and the treatment group. None of the trials reported any of the a priori symptoms of interest.

Idebenone. See Evidence Tables 181 through 187 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Four studies ^182,^ ^183,^ ^184,^ ^185^ were included in this review that evaluated idebenone versus placebo, and one study ^26^ compared idebenone to tacrine but not to placebo. The placebo trials were published in 1992, ^184^ 1994, ^182^ 1997, ^185^ and 1998, ^183^ the tacrine trial was published in 2002 by the same author as a previous placebo trial. ^183^

Design/methodology. Sample sizes in the studies ranged from 92 ^182^ to 450 subjects ^183^ with a total of 950 patients in the placebo-controlled studies. The study comparing idebenone with tacrine included 203 subjects, but a large number withdrew, and only 44 completed the trial. One of the trials ^185^ earned 5 points out of a possible 8 points on the quality scale, two of the trials earned 6 points, ^182,^ ^183^ and one earned 7 points. ^184^ None of the placebo studies reported their funding source. The tacrine study earned 7 points on the quality scale and was partially funded by industry.

Populations. The studies included patients with AD, MID, PDD, and DAT. Two of the trials ^182,^ ^183^ reported that the subjects had mild to moderately severe disease and the remainder reported mild to moderate disease. Two of the studies reported subgroup analysis based on disease severity. ^185,^ ^183^ Mean ages in the studies ranged from 69.9 ^183^ to 73.6 years. ^184^

Intervention. Dosing schemes were 30 or 90 mg per day for 6 months, ^185^ 30 mg three times per day for 3 months, ^182^ 45 mg twice daily for 4 months, ^184^ and 120 mg three times per day for 12 months. ^183^ The tacrine trial used 360 mg per day for 14 months.

Primary outcomes. Caregiver burden was the only domain in this review that was not evaluated in at least one of the studies.

Analysis. Two of the studies ^183,^ ^185^ used ITT analysis while the other two used OC analysis. The tacrine trial used ITT analysis.

Results and interpretation. See Summary Table 19. Three trials ^183,^ ^184,^ ^185^ found significant differences for general cognitive function. Two trials ^185,^ ^183^ used the ADAS-cog and reported changes that varied from -4.5 to -4.9 for placebo versus -4.4 to -8.8 for the treatment group. The doses varied in these two trials from 90 to 360 mg per day. A single trial ^182^ evaluated specific cognitive function and showed inconsistent findings. Three trials ^182,^ ^183,^ ^185^ evaluated global assessment and all found significant differences relative to placebo. A single trial ^185^ evaluated behavior/mood and was statistically significant, even though it was a secondary outcome. Two trials ^183,^ ^184^ evaluated quality of life/ADL and were both statistically significant. No study evaluated caregiver burden. These findings suggest some evidence of benefit for general cognitive function, global assessment, and quality of life/ADL. There were not enough similar outcomes reported to complete a pooled analysis for idebenone.

Quality scores for reporting adverse events varied from 1 to 5. Rates of withdrawal due to adverse events varied from 0 – 5% for the placebo group and 0 – 5% in the treatment group; a single trial ^183^ did not report withdrawal rates. Two trials ^183,^ ^185^ tested for statistical differences between groups and found no differences. Although no clear pattern emerges, three studies identified at least one balance-related adverse event across studies. The range of frequencies of the a priori symptoms of interest are as follows: 1) nausea (placebo = 2%, all doses = 2 – 11%), 2) dizziness (placebo = not reported, all doses = 2%), and 3) not reported for diarrhea, agitation, or eating disorder as an adverse event.

Oxiracetam. See Evidence Tables 188 through 194 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Five trials ^186,^ ^187,^ ^188,^ ^189,^ ^190^ included in this review evaluated oxiracetam versus placebo. The studies were published in 1988, ^188^ 1989, ^187^ and 1992. ^190,^ ^189,^ ^186^

Design/methodology. A total of 554 patients were included in the studies, ranging from 30 patients ^188^ to 289 patients. ^187^ Four of the studies earned 6 points out of a possible 8 points on the quality scale, and the other study ^189^ earned 4 points. Two of the studies ^189,^ ^187^ did not report the source of their funding, and the other three trials had partial industry funding.

Populations. The trials included a mixture of diagnoses, including AD, PDD, mixed dementia, and MID, and none of the studies reported severe disease. One of the studies ^187^ performed subgroup analysis based on diagnosis, comparing MID to PDD. The mean age of the subjects included in the trials ranged from 62.0 ^188^ to 73.8 years. ^189^

Intervention. All of the trials used a dose of 800 mg twice daily, for a duration of 12 ^186,^ ^187^ to 26 weeks. ^189^

Primary outcomes. At least one trial evaluating oxiracetam evaluated one of the outcome domains examined in this review with the exception of caregiver burden. A single trial ^189^ reported baseline MMSE at 22 for both placebo and treatment groups.

Analysis. None of the trials used ITT analysis.

Results and interpretation. See Summary Table 20. Three trials ^187,^ ^190,^ ^189^ out of the five studies tested for outcomes on general cognitive function. Only two of these trials ^187,^ ^190^ reported the findings, which were both significant, even though the NMIC and MMSE were used to measure this attribute. Three trials ^186,^ ^188,^ ^190^ evaluated specific cognitive function and showed mixed results. A single large trial ^187^ evaluated global assessment and found significant differences between groups using the Blessed Dementia Scale (Italian version). Three trials ^187,^ ^188,^ ^190^ evaluated behavior/mood with the IPSC-E, and of these, a single trial ^190^ did not show significant differences. One trial ^189^ reported on Beck Depression Inventory (BDI) but did not show statistical comparisons. Similarly, three trials ^186,^ ^189,^ ^190^ evaluated quality of life/ADL, and a single trial ^189^ showed no significant findings. No study evaluated caregiver burden. There were not enough similar outcomes reported to complete a pooled analysis for oxiracetam.

The quality scores for reporting adverse events varied from 2 to 5. The proportion of withdrawals due to adverse events varied form 0 – 9% for the placebo group and 0 – 6% for the treatment group. No clear pattern for adverse events is evident, but three of the five studies reported gastrointestinal related problems, primarily associated with abdominal pain. Although, only single trials evaluated the range of frequencies of the a priori symptoms of interest are as follows: 1) dizziness (placebo = not reported, all doses = 11%), and 2) agitation (placebo = 1%, all doses = not reported); no trial reported nausea, eating disorder, or diarrhea as an adverse event.

Pentoxifylline. See Evidence Tables 195 through 200 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Three trials ^191,^ ^192,^ ^193^ in this review evaluated pentoxifylline versus placebo. One trial, ^194^ published in 1997, compared pentoxifylline to sulodexide rather than placebo. The placebo trials were published in 1987, ^193^ 1992, ^192^ and 1996. ^191^

Design/methodology. The studies included 36 patients, ^193^ 64 patients ^192^ and 289 patients. ^191^ The sulodexide trial included 93 patients. All placebo trials had 6 points out of a possible 8 points on the quality scale and had partial or full industry funding. The sulodexide trial earned 5 points on the quality scale and did not report the source of funding.

Populations. The three placebo-controlled trials included patients with mild to moderate MID, and one trial ^193^ also included PDD patients. The sulodexide trial had only patients with mild to moderate VaD. Subgroup analysis was performed in two trials, looking at MID versus PDD diagnosis ^193^ and grouping by vascular change versus discrete stroke. ^192^ The mean age of the studies ranged from 69.7 ^191^ to 77.0 years. ^193^

Intervention. All of the studies gave 1200 mg per day of pentoxifylline; one study gave the drug once a day for 9 months, ^191^ one study gave 400 mg three times per day for 9 months, ^192^ and one gave 400 mg three times per day for 3 months. ^193^ The sulodexide study gave the drug once a day for 6 months.

Primary outcomes. At least one trial evaluated one of the outcome domains examined in this review with the exception of caregiver burden.

Analysis. A single ^191^ trial used an ITT analysis.

Results and interpretation. See Summary Table 21. All three placebo trials showed non-significant findings for any primary outcome evaluated on all subjects in the study. It should be noted that two of these trials ^192,^ ^193^ had very small sample sizes (n = 38, n =28) that were evaluated in the OC analyses; this suggests that the trials lacked sufficient power to evaluate multiple outcomes. Knezevic et al. ^191^ had a large sample size (n = 289) and employed an ITT analysis; all primary outcomes evaluated were not significant. The evidence for all outcomes considered in this review are inconclusive for pentoxifylline. There were not enough similar outcomes reported to complete a pooled analysis for pentoxifylline.

The quality scores for reporting adverse events were generally low, varying from 1 to 3. Withdrawal rates due to adverse events varied from 0 – 25% in the placebo group and 0 – 22% in the treatment group. The two studies that reported adverse events indicated the presence of gastrointestinal disturbances, including abdominal pain or nausea and vomiting (placebo = 7% and all doses = 14%). None of the trials reported dizziness, agitation, eating disorder or diarrhea.

Propentofylline. See Evidence Tables 201 through 206 at http://www.ahrq.gov/clinic/epcindex.htm.

Number of studies. Four studies ^195,^ ^196,^ ^197,^ ^198^ in this review evaluated propentofylline versus placebo. The first trial was published in 1990. ^198^ Two, by the same author, were published in 1996 ^196^ and 1998. ^197^ One was published in 1997. ^195^

Design/methodology. The number of subjects in the studies ranged from 30 subjects ^197,^ ^196^ to 260 subjects, ^195^ with a total of 510 subjects. Three of the studies ^197,^ ^195,^ ^196^ earned 5 points out of a possible 8 points on the quality scale, and the other study ^198^ earned 6 points. Only one study indicated the source of funding for the trial, ^196^ and it was industry-supported.

Populations. The trials included subjects with mild to moderate AD only, ^197^ VaD only, ^196^ mild dementia only, ^198^ and mild to moderate combined AD and VaD. ^195^ Two trials presented subgroup analysis: one for AD versus VaD, ^195^ and one based on MMSE baseline score. The mean age in the studies ranged from 64.8 ^197^ to 72.4 years. ^195^

Intervention. All four studies gave 300 mg three times a day for 3 months with the exception of one trial ^195^ which had a duration of 12 months.

Primary outcomes. At least one trial evaluated one outcome in each of the domains examined in this review with the exception of caregiver burden. Baseline MMSE was reported in two trials ^197,^ ^198^ and varied from 20 and 21 for both placebo and treatment groups.

Analysis. One of the studies ^195^ used an ITT analysis.

Results and interpretation. See Summary Table 22. All four trials evaluated general cognitive function and the pooled estimate can be seen in Figure 21. Two of the trials ^197,^ ^196^ had small sample sizes and these trials had the widest confidence intervals. The test for heterogeneity did not exceed our threshold of 0.10 for significance; the overall summary effect was significant. Figure 22 shows the pooled estimate for the DSST, a measure of specific cognitive function; this pooled estimate should be interpreted with caution as the test for heterogeneity was significant and the overall effect was not significant. Thus, there is some evidence of benefit for general cognitive function, and inconclusive evidence for specific cognitive function as measured by the DSST. Similarly, there is inconclusive evidence for global assessment. Behavior/mood outcomes (using the NAB) were evaluated by a single trial ^195^ and shown to be significantly different; this same trial evaluated quality of life/ADL (using the NAA) and showed no significant difference.

Figure 21. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the MMSE change score comparing propentofylline versus placebo

Figure 22. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the DSST change score comparing propentofylline versus placebo

The quality scores for reporting adverse events varied from 1 to 4. The percentage of withdrawals varied from 0 – 13% for the placebo group and 0 – 12% for the treatment group. None of the trials tested for differences between groups. Three of the trials ^195,^ ^197,^ ^198^ reported gastrointestinal events that included abdominal pain, constipation, and nausea and vomiting (placebo = 2%, all doses = 7%). Dizziness (placebo = 3 – 5%, all doses = 1 – 6%) was the only other a priori symptom of interest.

Various other agents. See Evidence Tables 207 through 249 at http://www.ahrq.gov/clinic/epcindex.htm. See Summary Table 23.

Interventions with two studies included for review. Six other agents were compared with placebo in only two included trials:

Choto-san (Evidence Tables 207, 213, 214, 249) Two studies compared Choto-San with placebo in patients with VaD. Both studies included all Asian subjects and co-morbid disorders were present in both studies. Each study lasted 12 week, with doses of drug at 7.5 g three times a day ^199^ and 2.5 g three times a day. ^200^ The studies were published in 1994 ^200^ and 1997 ^199^ and both had a quality score of 5 out of 8 points. Both studies measured global assessment and behavior/mood and disagreed on both results. One study ^199^ showed a significant change in global assessment and no significant difference in behavior/mood while the other ^200^ showed mixed results for global assessment and a significant difference for behavior/mood.

Cyclandelate (Evidence Tables 207, 215, 216, 249). Cyclandelate was evaluated in two studies: one ^201^ in 139 AD patients and another ^202^ in 196 PDD, VaD, and mixed dementia patients. The mixed population study ^202^ had a subgroup analysis based on the MMSE, ADAS-cog, and treatment center. The AD patients received 400 mg four times per day for 16 weeks and the mixed population study used 800 mg twice a day for 24 weeks. Only caregiver burden was not evaluated by either study and only global assessment was evaluated by both studies. The study with AD patients ^201^ showed a significant change in global assessment and in behavior/mood and mixed results in the specific cognitive function measures. The study with the mixed population ^202^ showed no significant difference in global assessment or general cognitive measures or quality of life/ADL or function.

Ergokryptine (Evidence Tables 207, 212, 218, 249). Two trials, which were not similar, evaluated ergokryptine. One trial ^203^ that did not indicate the source of funding included 125 PDD patients and treated them with a dose titrated up to 2 mg per day for 8 weeks. The other trial, ^204^ which was industry funded, treated 215 AD patients with a dose titrated up to 20 mg twice a day for one year. Neither study reported caregiver burden, but both reported general cognitive function and global assessment. They differed on the results of both of those domains: one study ^204^ showed significant change in cognition and mixed results in global assessment, and the other study ^203^ showing no significant difference and significant change, respectively. Significant change was demonstrated in specific cognitive measures in the study with AD patients. ^204^ Mixed results were shown for behavior/mood outcomes, and no significant difference was seen for quality of life/ADL in the study with PDD patients. ^203^

Hydroxychloroquine/Nimesulide (Evidence Tables 207, 226, 229, 249). No significant difference from placebo was seen in either of two studies ^205,^ ^206^ for cognition, behavior/mood, or quality of life/ADL. Global assessment was evaluated in one of the studies ^206^ and there was no significant difference found. One trial ^205^ included minimal to mild AD patients and the other ^206^ included mild to moderate AD patients One study ^205^ treated patients for 18 months with a dose of 400 or 200 mg per day based on weight. The other study treated for 3 months with 100 mg twice a day. Both studies had non-industry funding, and one study ^205^ also had industry support.

Nimodipine (Evidence Tables 207, 230, 231, 249). Nimodipine was evaluated in one study ^207^ with 259 mild to moderate MID patients receiving 30 mg twice a day for 26 weeks. The other study ^208^ evaluated 178 patients with mild to moderately severe MID and PDD receiving 90 mg per day for 12 weeks. The trials received industry funding or support and were published ten years apart, in 1990 ^208^ and in 2000. ^207^ The trial using ITT analysis ^207^ showed no significant difference in the domains of general cognitive function measures, specific cognitive measures, global assessment, and quality of life/ADL. The trial using OC ^208^ analysis found significant differences in the domains of general cognitive function measures, specific cognitive measures, global assessment, and behavior/mood.

ORG2766 (ACTH peptides) (Evidence Tables 207, 233, 234, 249) Org2766 versus placebo was reported for a total of 233 patients with AD or primary degenerative senile dementia (PDSD) in reports from 1985 ^209^ and 1986. ^210,^ ^209^ One study ^209^ was industry-supported and used 20 mg twice daily for 6 months, and the other was non-industry-funded ^210^ and used 80 mg twice daily for 1 month. One study ^210^ found a statistical difference between drug and placebo in the domains of specific cognitive function measures and in global assessment, and the other study ^209^ found no significant difference in the domains they evaluated: global assessment and behavior.

Interventions with only one trial included for review. Twenty-two drugs in this drug grouping were compared to placebo in only one included trial. Eleven of these trials showed a significant difference from placebo and are summarized briefly here. See Evidence Tables 207 to 240, 244, 248 and 249 for greater detail concerning the trials.

Drugs compared to placebo in one trial only (Evidence Tables 207, 208, 209, 210, 217, 220, 222, 224, 237, 238, 240, 248, 249) Aniracetam was better for cognition and global assessment in 109 community patients for 6 months, Ateroid ^211^ in 155 PDD, MID or SDAT patients for 12 weeks was better for general cognition. Desferrioxamine ^212^ in 48 probable AD patients for 2 years was better for behavior/mood. Glycosaminoglycan polysulfate ^213^ in 155 moderate to severe PDD or MID patients for 12 weeks was better for behavior/mood. Guanfacine ^214^ in 29 mild to moderate AD or PDD patients for 13 weeks was better for specific cognitive measures and global assessment. Nootropic agent BMY ^215^ in 69 mild to moderate AD patients for 12 weeks was better for general cognitive measures. Thiamine ^216^ in 15 mild to moderate AD patients for 12 months was better for general and specific cognitive function measures. Vincamine ^217^ for 12 weeks in 152 institutionalized patients with mild to moderate PDD or VaD was better for global assessment. Vitamin E ^135^ in 341 moderate AD patients for 2 years was better for delaying institutionalization. Deamino-D-arginine-vasopressin ^218^ in 14 PDD patients was better for behavior and had mixed results for global assessment. Xantinolnicotinate ^219^ in 313 mild to moderate AD or MID patients for 12 weeks was better for specific cognitive function measures and global assessment.

Twelve trials (Evidence Tables 207, 211, 219, 221, 223, 225, 227, 228, 232, 235, 236, 239, 244, 249) found no significant differences from placebo or mixed results when evaluating buflomedil, ^220^ citicoline, ^101^ denbufylline, ^221^ diclofenac and misoprostol, ^222^ hydergine, ^223^ indomethacin, ^224^ monosialotetrahexosylgan, ^225^ N-acetylcysteine, ^226^ nizatidine, ^227^ piracetam, ^228^ prednisone, ^229^ and simvastatin. ^230^

## Question 2: Does pharmacotherapy delay cognitive deterioration or delay disease onset of dementia syndromes?

### Delay of Onset of Dementia

The concept of “delay onset” was operationalized to imply delay in conversion from a cognitive disturbance state, classified as MCI, CLOND or CIND, to a true dementia state. No studies with this population met the final eligibility criteria, although four trials ^231,^ ^232,^ ^233,^ ^234^ advanced to the full text screening stage. The lack of studies eligible for evaluation in this systematic review points to a gap in the literature for pharmacological interventions (attempting to demonstrate a delay in disease onset) in MCI-type populations.

### Delay of Progression

In general, very few studies evaluated patients who were classified as “severe”. Five studies ^126,^ ^208,^ ^129,^ ^178,^ ^132^ had moderate to severe groups of dementia patients, and only one trial reported all three levels ^163^ of the disease spectrum. The interventions evaluated in these trials were estrogen, haloperidol, glycosaminoglycan polysulfate, memantine, and naftidrofuryl. This suggests that there is a bias in the trials eligible in this systematic review towards evaluating mild to moderate disease; this in turn reflects the underlying assumption that the less severe groups are most likely to benefit from drug trials. Since so few studies have evaluated the more severe groups, this assumption may require some empirical justification. Therefore, delay in progression has not been considered in severe patients.

The selected studies used two approaches for showing “delaying disease progression”. The first method for evaluating the potential for a drug to delay disease progression used longer-term follow-up; survival analyses (time to a relevant event) were then used to show differences between the two groups. The second design approach used withdrawal from treatment for a period and continued monitoring of the treatment and placebo groups (to demonstrate a deviation of the treatment group from the natural history as represented by the placebo group). Such designs have been termed withdrawal, active-extension, randomized withdrawal, randomized start, and staggered start. ^235,^ ^236,^ ^19,^ ^21^ From our 186 included studies, we then further selected a subgroup of papers that had the potential to demonstrate delay in disease progression through the use of one of these two designs. Therefore, any eligible trial that employed a survival analysis or a two-period approach, where the pharmacological agent was withdrawn during one of the periods, was selected for further evaluation to answer this question.

### Survival Analyses

Two studies ^135,^ ^61^ using survival analyses were identified. In a 2-year study ^135^ that compared placebo to three other groups (selegiline, selegiline with vitamin E, and vitamin E), time to the development of significant dementia milestones (death, institutionalization, loss of ability to perform ADL, or score on scale indicating severe dementia) was used as the time to event in the survival analysis. The results of this study showed that the vitamin E, selegiline, and combined groups were statistically different (i.e. declined less) from the placebo group in analyses that included baseline MMSE score as a covariate (not significant when excluded). The median survival was 230 days (vitamin E), 215 days (selegiline), and 145 days (combined group). Moreover, the vitamin E group showed a statistically significant difference for the endpoint of institutionalization, and the other treatment groups did not. There were no statistical differences between groups with respect to adverse events. Thus, the findings of this study suggest that selegiline and vitamin E may delay clinically important deterioration in patients with moderately severe AD; this delay varied from 20 to 32 weeks. The second study ^61^ used survival analyses to evaluated the time to the development of severe functional impairments in a comparison of placebo and donepezil with a follow-up of 54 weeks. The results of the Kaplan-Meier analysis showed a mean number of days to significant functional decline of 252 days for placebo and 357 days for the donepezil group (mean difference of 100 days). The treatment group was 38% less likely to decline over a 1-year period. Both these studies demonstrated some delay in disease progress varying from 100 to 230 days for these three different pharmacological agents.

### Staggered Withdrawal

Delay in disease progression can also be evaluated using a “time to return to baseline” following withdrawal of treatment. Similarly, staggering the start of the treatment parallels the staggered withdrawal and can be used to evaluate disease progression. In this design approach, the time to return to baseline is compared to the placebo group, which represents the natural course of the disease. Of the studies that were eligible for this research question used a classic withdrawal design (withdrawal in period II after the intervention was administered); none of these studies were able to maintain double blinding after the withdrawal of the intervention. Justification for the selection of the length of the washout or follow-up period was not consistently provided (which possibly reflects the lack of a priori aim to show delay in progression).

Tables 5 and 6 detail any study that attempted to withdraw the drug in the treatment group and then continue observations over time. All studies that reported outcomes after the drug trial endpoint subsequently interrupted protocol and switched to “open-label” circumstances. In open-label conditions, blinding was broken and greater proportions of patients withdrew from the study as the follow-up increased. From a methodological perspective, these data were considered to be biased and would not meet our review eligibility criteria. However, we summarize in these Tables the same observations that were reported in all the studies eligible for this systematic review.

Table 5. Studies that withdrew the treatment agent but maintained at least single blinding

Study | Drug | Schedule | Result
Ruether 2001 | Cerebrolysin | 4w drug + 8w washout + 4w drug + 12w washout | All patients:
| | | ADAS-noncog, maintained difference from placebo
| | | NAI returned to baseline
| | | Subgroup MMSE<20:
| | | ADAS Noncog, CGI, ADAS-cog, SKT maintained difference from placebo
Nyth 1990 | Citalopram | 4w drug + 8 w open drug + 4w new random drug | NR
Rogers 1996 | Donepezil | 12w drug + 2w SB Pl washout | 5 mg maintained effect, 3 mg no maintenance of effect for ADAS-cog (NS)
Rogers 1998b | Donepezil | 24w drug + 6w SB and placebo washout | Return to placebo levels for ADAS-cog, MMSE, CIBIC (all NS)
Wilcock 2002 | Memantine | 2w SB and placebo + 28w drug + 2w SB placebo washout | NR
McKeith 2000 | Rivastigmine | 20w drug + 3w rest | Return to placebo levels for NPI and computerized cognitive assessment (NS)
Antuono 1995 | Velnacrine | 2w SB placebo + 24w drug + 6w SB placebo washout | Return to placebo levels for the ADAS-cog but SC for CGIC remained for washout
Bodick 1997 | Xanomeline | 24w drug + 4 w SB placebo | SC at week 24 with CNTB
| | | No differences vs. placebo at w4 of washout

Table 6. Studies that withdrew treatment and did not specify if blinding for washout or extension was maintained

Study | Drug | Schedule | Result
Dehlin 1985 | Alaproclate | 2w placebo + 4w drug + 2w placebo | SC for GBS intellectual subscale at w4 of treatment
| | | No significant difference at w2 of washout
Cutler 1993 | BMY 21,502 | 12w drug + 4w placebo washout | Treatment showed no significant change and follow-up showed no change
Amaducci 1988 | Phosphatidylserine | 3m drug + 21 m follow-up | SC remained for severe disease patients, not moderate
Raskind 1997 | Metrifonate | 26w drug + 8w follow-up | NR
Parnetti 1995 | Posatirelin | 90d IM + 30d follow-up placebo | “Maintained positive effect” but specific numbers not reported
Agid 1998 | Rivastigmine | 10w drug + 2w placebo washout | NR

In Table 5, single blinding was maintained in a placebo-controlled trial of cerebrolysin, which had an 8- and 12-week follow-up and showed continuing statistical differences after drug withdrawal. The remaining drug interventions listed in Table 5 suggest that the treatment provided predominately symptomatic relief lasting 2 to 6 weeks and then returning to placebo levels. Similarly, the pharmacological agents in Table 6 suggest that treatment provided only symptomatic relief.

## Question 3: Are certain drugs, including alternative medicines (non-pharmaceutical), more effective than others?

From a methodological perspective, addressing the question of being “more effective” requires head to head comparisons of pharmacological interventions. If one intervention (Drug A) has been shown to be effective relative to placebo of a specified effect size, and a second intervention (Drug B) has been shown to be effective at a lower magnitude relative to placebo, it does not necessarily follow that Drug A is more effective than Drug B. Comparisons of the relative effectiveness of certain drugs can only be evaluated in the context of head to head evaluation within the same trial. Those studies undertaken as direct comparisons are summarized below.

### Head to Head Comparisons

A total of 26 ^125,^ ^152,^ ^129,^ ^237,^ ^130,^ ^238,^ ^239,^ ^145,^ ^150,^ ^124,^ ^114,^ ^131,^ ^127,^ ^240,^ ^241,^ ^135,^ ^242,^ ^101,^ ^243,^ ^70,^ ^194,^ ^128,^ ^244,^ ^26,^ ^92,^ ^245^ studies compared efficacy of two or more pharmacological agents relative to each other. In general, few drugs showed statistically significant differences relative to each other. Those that did include the following (drug performing better is listed first):

1. Sulphomucopolysaccharides versus CDP-choline ^238^ - Significant differences were seen in favor of sulphomucopolysaccharides in measures of behavior and global assessment in 30 institutionalized patients with mild to moderate MID.
2. Donepezil and vitamin E ^70^ - Significant differences were seen in favor of donepezil in general cognitive function in 54 patients with mild AD.
3. Antagonic stress versus nicergoline ^92^ - Significant differences were seen in favor of antagonic stress in cognition as well as a global assessments in 62 subjects with mild to moderate AD.
4. Antagonic stress versus meclofenate ^242^ - Significant differences were seen in favor of antagonic stress in measures of cognition and global assessment in 63 patients with mild to moderate AD.
5. Posatirelin versus citicoline ^101^ - Significant differences were seen in favor of posatirelin in general cognitive measure and mood in 222 community living patients with mild to moderate AD.
6. Pyritinol versus hydergine ^243^ - A significant difference was found in favor of pyritinol in a global assessment measure in 102 Hispanic patients with mild to moderate AD.
7. Idebenone ^26^ versus tacrine-Mixed results were observed; the Efficacy Index Score showing a significant benefit over tacrine, while the global assessment showed no difference in 203 AD patients, 44 of whom completed the study.

Relative comparisons of FDA approved drugs for the treatment of dementia. Although no head to head trials compared drugs that are likely to be used in current practice in the United States, it was recognized that an assessment of the relative effectiveness of those drugs approved for the treatment of dementia would be of interest to clinicians. Four drug interventions that are currently approved for the treatment of dementia include donepezil, galantamine, rivastigmine, and tacrine. We caution the reader that inferences drawn from the following figures are limited because these FDA-approved drugs were not compared within the same study. The evidence for benefits and harms has been previously discussed in this report. The pooled estimates (WMD and RR) of two outcomes (ADAS-cog, CIBIC) frequently used in clinical practice have been presented together to illustrate the relative benefit of these approved drugs (Figures 23 to 30). For the purposes of this relative comparison, the pooled estimate reflecting the largest effect size (i.e. the dose showing the greatest magnitude) was selected. Several relevant details should be noted before comparing these estimates as follows: 1) the 5 mg dose of donepezil was selected because the magnitude of the pooled estimate was largest, 2) the 32 mg dose of galantamine had the largest pooled estimate, 3) the rivastigmine pooled estimate for the ADAS-cog was significant for heterogeneity, so the pooled estimate should be considered with great caution, and 4) none of the studies that evaluated tacrine and measured the CIBIC reported sufficient data to estimate an effect size; hence the effect size of the CGIC was substituted for comparison.

Figure 24. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing galantamine versus placebo

Figure 25. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing rivastigmine versus placebo

Figure 26. Weighted Mean Difference (WMD) from the Fixed Effects Model (Fixed) for the ADAS-cog comparing tacrine versus placebo

Figure 27. Relative Risk (RR) from the Random Effects Model (Random) for the CIBIC comparing donepezil versus placebo

Figure 28. Relative Risk (RR) from the Random Effects Model (Random) for the CIBIC comparing galantamine versus placebo

Figure 29. Relative comparison of effect sizes for studies using the CIBIC rivastigmine versus placebo

Figure 23. Weighted Mean Difference (WMD) from the Random Effects Model (Random) for the ADAS-cog comparing donepezil versus placebo

Figure 30. Relative comparison of effect sizes for studies using the CIBIC comparing tacrine versus placebo

## Question 4: Do certain patient populations benefit more from pharmacotherapy than others?

The following studies contained stratified analyses of outcomes for different clinical populations. A total of 22 ^245,^ ^211,^ ^146,^ ^179,^ ^181,^ ^132,^ ^134,^ ^142,^ ^183,^ ^185,^ ^56,^ ^168,^ ^201,^ ^63,^ ^64,^ ^55,^ ^173,^ ^62,^ ^76,^ ^75,^ ^60,^ ^159^ studies addressed this question. During data abstraction, these trials were identified if the methods sections (including analyses) stated that stratified analyses were undertaken. Eight different variables were identified for which stratified analyses were reported. These included: age, gender, APOE genotype, disease type, disease severity (as determined by MMSE/ ADAS-cog threshold levels), treatment center, care dependence, and presence of depression. Of these 22 studies, seven trials ^245,^ ^211,^ ^146,^ ^179,^ ^181,^ ^132,^ ^134^ evaluated disease type (AD, PDD, SDAT, MID, VaD). They will be discussed in Question 5 (see below).

Table 7 details the 15 ^142,^ ^26,^ ^185,^ ^56,^ ^246,^ ^201,^ ^63,^ ^64,^ ^55,^ ^173,^ ^62,^ ^76,^ ^75,^ ^60,^ ^159^ studies that provided stratified analyses other than for disease type. For disease severity, no clear pattern emerges. For APOE, no significant difference was noted between groups ^173,^ ^62,^ ^76,^ ^75^ for the three interventions that included cerebrolysin, donepezil, and galantamine. For age, Thal et al. ^55^ conducted a post-hoc analysis to assess the effect of age on the rate of decline. Patients were categorized according to age (< 65 years, 65 years and older). The results of the study indicate that a subgroup of patients, aged 65 years or younger, may benefit more from carnitine as compared to older subjects. Specifically, in the younger population, the significant difference between the treatment and the placebo group was observed for ADAS-cog but not for CDR.

Table 7. Studies with stratified analyses

CITATION | DRUG | SUBGROUP | DRUG EFFECT
Alvarez 2000 | Anapsos | Disease severity | SC in ADAS-cog in patients with mild cognitive deterioration and with AD
| | | NS in patients with VD
Gutzmann 1998 | Idebenone | Disease severity | NR
Weyer 1997 | Idebenone | Disease severity | SC for ADAS Total
| | ADAS total score ≥ 20
Sano 1992 | Carnitine | MMSE | Low mMMSE group SC on the SRT and CSF levels of drug
| | | High mMMSE group NS neuropsychological test scores, CGI ratings and CSF levels of drug
Ruether 2001 | Cerebrolysin | MMSE | Subgroup MMSE < 20: SC in CGI, ADAS-cog, NAI and ADAS-Noncog. Suggests it's because this group had reduced placebo response.
Schellenberg 1997 | Cyclandelate | MMSE, ADAS-cog, Treatment center | NR
Feldman 2001 | Donepezil | MMSE Psychoactive drug use | NR
Tariot 2001a | Donepezil | MMSE (10–26) Age | MMSE group: SC greater differences than for the whole group for MMSE, GDR
| | | Older patients group: SC for MMSE, CDR
Thal 1996a | Carnitine | Age | SC age-by-treatment interaction on the ADAS-cog ITT population
| | | Patients ≤ 65 years significant difference in decline for ADAS-cog favoring Carnitine but not for CDR
| | | Patients > 65 years NS
Panisset 2002 | Cerebrolysin | APOE genotype | NS association of the APOE e4 status and response to study drug
Winblad 2001b | Donepezil | APOE genotype Gender | NS difference for the subgroups
Raskind 2000 | Galantamine | APOE genotype | NS
Wilcock 2000 | Galantamine | APOE genotype | NS for APOE group
| | MMSE | SC for MMSE < 18
Prasher 2002 | Donepezil | Down syndrome ONLY in trial | NR
Reifler 1989 | Imipramine | Depression | Depressed patients SC higher HAM-D scale score. For MMSE patients with AD + depression had higher scores initially and improved significantly more over time

SC = Significant change

NS = Not statistically significant

NR = Not reported

In general, very few studies examined the efficacy of drugs with respect to dementia by population characteristics. Three additional studies attempted to evaluate unique populations or population characteristics. Prasher et al. ^60^ evaluated subjects who had Down's Syndrome with dementia and were treated with donepezil, and found none of the outcomes to be significant; this study had a sample size of 30 subjects and was underpowered. Ban et al. ^213^ conducted a multicenter, placebo-controlled, double-blind study with Hispanic and Italian populations. This study was not designed to specifically evaluate the efficacy of glycosaminoglycan polysulfate by ethnicity. However, the study included centers from Mexico, Panama, Naples, and Trieste. This study examined whether the changes encountered in the different outcome measures could be related to center effect, but no statistically significant center effect was found. While this study suggests that ethnicity may have minimal impact, future studies should specifically assess the impact of racial composition on the efficacy of drugs.

## Question 5: What is the evidence for the treatment of VaD?

Summary Table 25 details the results of studies in which patients had VaD, or stratified data were presented with respect to VaD subgroups identified as VaD or MID. The trial details for all these studies are provided in evidence tables of key study characteristics, evidence tables of study results, and evidence tables of adverse events found in Appendix C; summary results of trials were also discussed in the results sections of Question 1.

A total of 20 pharmacological interventions in 29 studies ^211,^ ^220,^ ^238,^ ^171,^ ^200,^ ^199,^ ^146,^ ^68,^ ^181,^ ^184,^ ^133,^ ^134,^ ^132,^ ^161,^ ^89,^ ^91,^ ^93,^ ^247,^ ^187,^ ^191,^ ^192,^ ^194,^ ^193,^ ^100,^ ^98,^ ^196,^ ^195,^ ^245,^ ^217^ were applied specifically to dementias classified as VaD. Sixteen studies evaluated populations entirely composed of patients with VaD (or MID), and the remaining 13 trials had VaD as a subgroup. The majority of these pharmacological interventions (n = 14) were represented by a single trial, limiting the extent of the evidence; these included ateroid, buflomedil, cerebrolysin, sulphomucopolysaccharides (CDP choline), citalopram, donepezil, Ginkgo biloba, idebenone, minaprine, nimodipine, nicergoline, oxiracetam, 5-THF (trazodone), vincamine, and xantinolnicotinate. Surprisingly, four of these trials did not report any results relative to placebo, and these included buflomedil, Ginkgo biloba, oxiracetam, and 5-THF (trazodone); all but one of these trials ^220^ evaluated subgroups of VaD patients and likely did not posses sufficient power to evaluate differences. Six interventions had more than a single trial, and these included Choto-san (n = 2), memantine (n = 3), nicergoline (n = 2), pentoxifylline (n = 4), posatirelin (n = 2), and propentofylline (n = 2).

Several of the trials with sample sizes greater than 100 subjects showed significant differences in general cognitive function: ateroid, cerebrolysin, donepezil, idebenone, and nicergoline. Similarly, these larger sample studies showed statistical differences for global assessment: Choto-san, donepezil, memantine, nicergoline, propentofylline, vincamine, and xantinolnicotinate. Findings for other outcome domains were inconclusive, as these were rarely evaluated (see Summary Table 25).

Table 8 below lists the studies that undertook comparisons between VaD populations and other dementia types. Although, not consistent across all trials, three of the studies suggests possible differences between 1) MID and AD for 5′-MTHF-trazodone, ^245^ 2) AD/SDAT and VaD for citalopram, ^146^ and 3) DAT and MID for Ginkgo biloba. ^181^

Table 8. Studies evaluating vascular dementia patients relative to other dementias

CITATION | DRUG | SUBGROUP | DRUG EFFECT
Passeri 1993 | 5′-MTHF Trazodone (TRZ) | AD vs. MID | Equivalence study
| | | When patients with AD were analyzed separately the same pattern of response to MTHF and TRZ was found in the HDRS and RVM as when they were analyzed together with patients with MID.
| | | MID as separate group: HDRS was significantly reduced vs. baseline after 8 weeks of treatment in the TRZ group and only at the end of the follow-up period in the MTHF group. RVM remained unchanged in MID pts in both treatment groups.
Ban 1991b | Ateroid | PDD vs. MID | NR
Nyth 1990 | Citalopram | AD/SDAT vs. VaD | A period:
| | | No improvement in the VaD group
| | | SC in the AD/SDAT group in emotional bluntness, confusion, irritability, anxiety, fear-panic, depressed mood, and restlessness. MADRS scores significantly reduced
| | | B period:
| | | AD/SDAT group SC in emotional bluntness at week 8. NS at week 4 and 12.
| | | NS for the VaD group.
LeBars 1997 | Ginkgo biloba | AD vs. MID+AD MMSE | AD subgroup: SC for ADAS-cog and GERRI
Kanowski 1996 | Ginkgo biloba | DAT vs. MID | Improvements at 24 weeks of treatment in comparison to baseline values were consistently slightly greater in the DAT group than in the MID group. Calculation of descriptive p-values seemed inappropriate due to the very small number of patients with MID in the sample.
Winblad 1999 | Memantine | AD/VaD Care dependence | NR for differences between dementia types
| | | Care dependence: Patients with < 20 points on the CGI and BGP
| | | Care dependence subscore shows slightly higher response rates than those with >20 points in the memantine group.
Wilcock 2002 | Minaprine | SDAT vs. MID | The largest treatment effect occurred in patients with baseline MMSE score < 15 (p = 0.04) and in those without cerebrovascular macro-lesions (p = 0.002)

SC = Significant change

NS = Not statistically significant

NR = Not reported