# Methods

## The Research Team

A multidisciplinary local research team representing geriatric and dementia epidemiology/ systematic review methods (P. Raina, PhD), pharmaco-epidemiology (M. Levine, MD, PhD), geriatric medicine/ dementia (D. Cowan, MD; C. Patterson, MD), rehabilitation/ systematic review methods (P. Santaguida, PT, PhD), and neuropsychology (A. Unsal, PhD) was assembled. The core research team, including experienced staff at the McMaster Evidence-based Practice Center (EPC) (F. Baldassarre, MSc; L. Booker, BA; M. Gauld, BA) participated in regular meetings and reached consensus on key methodological issues. An international Technical Expert Panel (TEP) was assembled to provide high-level content expertise in dementia and participated in conference calls on an as-needed basis. Participants in this panel were: Larry W. Chambers, PhD. Ottawa, ON, Canada; Thomas Cook, MD. (ACP appointee) Colorado Springs, CO, USA; Rachelle Doody, MD, PhD. Houston, TX, USA; John Feightner, MSc, MD. London, ON, Canada; Rodney Hornbake, MD. (ACP appointee) Hadlyme, CT, USA; David Hogan, MD. Calgary, AB, Canada; Roy Jones, MD. Bath, UK; and Holly Tuokko, PhD. Victoria, BC, Canada.

## Topic Assessment and Refinement

### Refinement of Questions

The first step during the topic assessment and refinement process was to organize a teleconference with the partner organization, the Task Order Officer (TOO), invited topic experts, and the McMaster team in order to define the magnitude of the topic addressed and to refine/clarify the preliminary research questions for this evidence report. It was agreed that this evidence report would focus on addressing the efficacy of pharmacotherapies for dementia syndromes. Regular teleconferences were held with the TOO, the partner, and technical experts throughout the data refinement and extraction phase.

### Search Strategy

Search strategies were developed and undertaken in the electronic databases listed in Table 1 for the time periods specified. The order of the databases in Table 1 also represents the sequence that the databases were searched. Appendix A details the search terms for all databases.

Table 1. Databases searched for relevant RCTs

Database searched | Search date | Period searched
Cochrane Central | February 3, 2003 | 1st Quarter 2003
MEDLINE® & PreMedline® | February 4, 2003 | 1998 to 2003 week 4
EMBASE | February 6, 2003 | 1998 to 2003 week 5
AMED | March 4, 2003 | 1985 to 2003 February
CINAHL® | March 5, 2003 | 1982 to February 2003 week 3
Ageline | March 6, 2003 | 1978 to 2002 December
PsycINFO | March 7, 2003 | 1967 to 2002 December

Expert opinion was sought on the most efficient search strategies to minimize noise in the collection of citations. Some of the medical subject headings (MeSH) used to select RCTs yielded a large number of non-RCT literature due to misclassification of the study design terms. For example, in previous indexing, terms like “longitudinal study” or “comparative study” were applied to RCTs; conversely, the MeSH terms “random” or “randomized” in the title or abstract were not consistently used. However, some recent methodological work has suggested that more specific search term approaches can be used, which increases the sensitivity and specificity of the search results. ^40^ The Cochrane Central Trial Registry contains correctly re-classified RCT/Controlled Clinical Trial (CCT) trials that were misclassified in MEDLINE® and EMBASE from 1966 to 1998. All published RCTs to 1998 are contained within this database. Hence we commenced our search with the Cochrane Central Trial Registry database. For this reason, MEDLINE® and EMBASE were searched from 1998 forward for relevant studies, and all the other databases from their inception.

Specific drug names and manufacturer brands were considered as potential search terms. However, the local research team was in agreement that listing specific drug names would bias the yield to include only those pharmacological agents searched and would not capture newer drug therapies. Thus the recommendation was to not restrict the search to known pharmacological agents but to include whatever agents were in the literature.

In addition to the electronic databases, the bibliographies of retrieved papers were retrieved. Any citations recommended by the local research team, the TEP, or the peer reviewers were retrieved and screened.

### Eligibility Criteria

Inclusion. Studies were included that contained the following criteria:

1. Age: Studies involving dementia patients who were 18 years or older in age
2. Diagnostic model used to determine dementia: The diagnosis of dementia using any of these criteria:
  i. ICD 9 or 10. ^41,^ ^42^
  ii. DSM III, III-R, and IV. ^43,^ ^44,^ ^45^
  iii. NINCDS. ^9^
  iv. NINCDS-ADRDA ^9^ or NINCDS-AIREN. ^46^
3. Diagnostic criteria used to determine cognitive impairment (pre-dementia): In the case of not yet diagnosed dementia, specific diagnostic categories were accepted for the following:
  i. mild cognitive impairment (MCI).. ^47^
  ii. cognitive impairment not dementia (CIND). ^48^
  iii. cognitive loss no dementia (CLoND). ^49^
4. Disease classifications for dementia: These included AD, senile dementia of the Alzheimer's type (SDAT), Lewy body disease, VaD, multi-infarct dementia (MID), AIDS/HIV dementia, Parkinson's disease dementia (PDD), progressive supranuclear palsy (PSP), mixed diagnosis dementia, encephalopathy, Mesulam syndrome, progressive non-fluent aphasia, Binswanger disease, subcortical leukoencephalopathy, circumscribed lobar brain atrophy, Pick disease, amyloid beta-protein (not Down's syndrome or trisomy), cerebral amyloid angiopathy, neurofibrillary tangles, threads, senile plaques, corticobasil ganglionic degeneration, cerebral autosomal dominant ischemia with subcortical leukoencephalopathy (CADISIL), Huntington's disease with dementia, hydrocephalus (for additional terms used in the search strategy, see Appendix A).
5. Severity classification: This was accepted in whichever classification system the studies specified. The majority of studies specified threshold criteria using the MMSE as follows: mild > 22, moderate 14 – 21, and 10 – 14 as severe. Many studies used the definition of mild to moderate as a range from 10 to 26 based on criteria established by Folstein et al. ^50^ Some studies specified a category (i.e. mild to moderate) but did not report the baseline MMSE values for the groups compared.

Some studies specified two categories (mild to moderate) and (moderate to severe) based on the DSM-III-R criteria. Cambridge Examination for Mental Disorders in the Elderly (CAMDEX) specifies levels of severity (minimal, mild, moderate, severe). Similarly, some studies reported a category of severity without stating which method was used. In these instances, the category of severity specified was accepted as reported by the study authors.

Exclusion. Studies that had populations with any of the characteristics listed below were excluded.

1. Dementia disease classification: i) alcohol caused dementia/ Korsakoff's syndrome, ii) Creutzfeldt-Jakob syndrome, c) spongiform encephalopathy, iii) hypothyroidism, iv) vitamin B12 deficiency, v) neurosyphilis.
2. Dementia diagnosed using only Lowb, Hachinski (specific for VaD) criteria. ^51^
3. All organically caused dementias which includes “Delirium, Dementia, Amnesic Disorders, and Cognitive Disorder Otherwise Specified. The predominant disturbance is a clinically significant deficit in cognition that represents a significant change from a previous level of functioning. For each disorder in this section, the etiology is either a general medical condition (although the specific general medical condition may not be identifiable) or a substance (i.e., a drug of abuse, medication, or toxin), or a combination of these factors.” ^43^
4. Temporary dementia (e.g. side effect of anesthesia) classified as follows: Delirium: a delirium is characterized by a disturbance of consciousness and a change in cognition that develop over a short period of time. The disorders included in the “Delirium” section are listed according to presumed etiology: delirium due to a general medical condition, substance-induced delirium (i.e. due to a drug of abuse, a medication, or toxin exposure), delirium due to multiple etiologies, or delirium not otherwise specified (if the etiology is indeterminate).
5. Normal or healthy volunteers: studies that deal with healthy people (i.e. prevention is limited to people who have any form of the above); volunteer study population
6. General population of elderly persons.
7. Study subjects selected for depression (some patients may have dementia but not all) and where there is no stratified analysis by disease subgroup (i.e. the dementia subjects).

Study Design. Eligible studies included parallel design RCTs only. Although crossover trials are suitable for chronic diseases, they may be prone to period effects or period by treatment interactions. Period effects are systematic changes in the outcome that apply to all patients due to temporal changes in the disease or to the measurement instrument. Period by treatment interactions occur when the efficacy of the intervention varies by period. Additionally, a carry-over effect may occur if there is not an adequate washout period. Apart from the weaknesses of this design, some limitations arise when considering the potential for meta-analytic analyses. Traditionally, first period data from a crossover trial are abstracted and can be potentially combined with parallel trials for analyses of a pooled estimate; the reporting of the study results (positive or negative) would also be based on this first period data. In a preliminary phase of the review, several crossover trials were examined. Many did not report first period data, which precluded any potential for combining with parallel trials; many trials also did not undertake statistical tests during the first experience, thus making it difficult to report the direction and significance of the first period findings. Finally, because this systematic review was considering a variety of drug interventions administered over differing time intervals, period effects might be an important source of bias. For all these reasons, the decision was made to exclude crossover trials from this systematic review.

Language of Publication. Studies published in the English language were eligible. The scope and resources of this review did not permit translation of studies published in other languages.

Sample Size. No sample size restrictions were applied.

Treatment Interventions. Drug interventions were eligible in the following manner:

1. Pharmacological agents: all types of pharmacological treatment were considered in this review, including food supplements (as defined by the FDA). Government approval was not a requirement, and as such, off-label use of drugs (i.e. drugs approved for other conditions but used in the treatment of dementia) were eligible for this review.
2. Dose: all doses and dosing schedules and any mode of administration (oral, subdermal, transdermal, intravenous, suppository, or intra-muscular injection) were considered.
3. Treatment period: the period of treatment must equal or exceed 1 day.
4. Follow-up length: Any duration of follow-up was eligible. Different drugs require different time periods to show an effect. For example, antidepressant and anti-psychotic medications may take a month or more to be effective. Some dementia drugs take a minimum of 2 months. For interventions such as vitamin E or Ginkgo biloba, the time to effect is not well established. Thus, an absolute limit to the minimum number of months of follow-up could not be applied to all potential interventions. It was anticipated that many studies with some of the most recent pharmacological agents (i.e. donepezil) would have a minimum follow-up of 24 weeks.

Study Outcomes. No specific set of commonly accepted outcomes that define efficacy or “clinical relevance” were applicable to all the pharmacological interventions that have been used to treat dementia. The literature evaluating outcome measures in dementia trials would suggest that most instruments have significant limitations or at least more data are required to establish the required properties for acceptability of the scales. Since none of the outcomes used in dementia trials have been accepted as standards (no consensus), the selection of the most appropriate or clinically relevant outcome is purely arbitrary. Similarly, establishing a rationale to exclude studies based on the specific type of outcome measure would be arbitrary. For this reason, no exclusion criteria based on outcome measures were used as eligibility criteria for this study; rather the domains of interest for inclusion have been identified.

Studies with the following outcomes were included:

- General cognitive function (e.g., ADAS-cog).
- Specific cognitive function (e.g., Weschler Memory Tests).
- Global clinical assessment (e.g., CIBIC).
- Behavior/mood (disturbances characterized by agitation, wandering, sleep cycle disturbance, depression, obsessive compulsive activities) (e.g., Behavioral Pathology in Alzheimer's Disease Rating Scale (BEHAVE_AD)).
- Quality of life/ADL (e.g., Instrumental Activities of Daily Living (IADL)).
- Effects on primary caregiver (also referred to as caregiver burden).
- Safety as measured by the incidence of adverse effects (e.g., particularly serious adverse events).
- Acceptability of treatment as measured by withdrawal rate from trial due to side effects of the medication. (e.g., dropouts due to adverse events).
- Mortality.
- Dependency or Rate of Institutionalization/ or continued residence in own home.
- Use of services.

Studies with the following outcomes were excluded as follows:

- Studies which reported only biological/ physiological outcomes, such as plasma levels, changes on functional imaging, or electroencephalography (EEG) activity, were noted but not assessed as efficacy measures.
- Outcomes reported in the trials should reflect changes in the person with dementia. If the study population did not all have dementia, only data subgrouped for dementia was examined.

Minimum quality threshold score for eligibility.

Exclusion part I: Pre-Jadad score. Studies were also screened to determine a minimum threshold for quality, sometimes described as “fatal flaws” in the trial design. Specifically, all studies had to include at least some mention of the term “randomization” or “withdrawal(s)” in the text of the paper. Trials that did not at least mention these components were excluded, as they possessed a fatal flaw.

Exclusion part II: Post-Jadad score. The methodological quality of the primary studies was assessed using the modified Jadad scale for RCTs ^52^ (Appendix B). The reliability of this modified scale was shown to be high, as measured by the intraclass correlation coefficient (ICC = 0.90). ^52^ Each study was evaluated by two reviewers, and the level of agreement was determined statistically. The first three items on the scale rate elements that have been shown to bias meta-analytic results. These include randomization, blinding, and withdrawal. If these items alone are considered, the maximum score is 5. Any study that did not score 3 or more on the scale was excluded from the review. Therefore, this review abstracts detailed data only from studies that achieved moderate to high ratings on the quality scale.

Evaluating the methodological quality of studies and rating the strength of the evidence.

Quality of the RCT. The methodological quality of the primary studies was assessed using the modified Jadad scale for RCTs. ^52^

Quality of reporting adverse events. The potential for risk, or adverse events, was an important component to consider with respect to efficacy. The Jadad scale for quality does not take into account factors associated with adequate collection and reporting of adverse events as detailed by Ioannidis and Lau (2002). ^35^ Therefore, a summary checklist was developed to determine the potential quality in the collection and reporting of adverse events (Appendix B). This score was used to evaluate the relative quality of the adverse events reported.

### Data Collection and Reliability of Study Selection

During the identification phase, two independent reviewers evaluated the title and abstract for eligibility; those meeting the criteria were retrieved as well as those that reported insufficient information to determine eligibility. Two independent reviewers examined the full text of these articles (passing from the title and abstract phase). All studies meeting eligibility criteria were reviewed to assess quality and abstracted according to predetermined criteria. The articles were grouped according to the pharmacological agent used in the intervention.

A team of study assistants was trained in the eligibility criteria for the purposes of this systematic review. Standardized forms and a guide explaining the criteria were developed from previous templates (Appendix B). Two reviewers were used for the identification, selection, validity, and abstraction phases of the systematic review. Disagreements were resolved by consensus. The reviewers were experienced EPC staff with post-graduate training in research methods. The reviewers and abstractors would consult with more senior members of the TEP for content expertise or methods-related issues.

### Summarizing Results: Descriptive and Analytic Approaches

It was expected that studies of the pharmacological agents used in the management of dementia would be quite diverse with respect to the intended therapeutic effect. For these studies, evidence and summary tables (Appendix C) were constructed to describe the more salient characteristics of the included studies.

### Meta-analysis

Statistical meta-analysis was not appropriate for all outcomes or interventions. Before calculating a pooled effect measure, the reasonableness of pooling was assessed on clinical and biological grounds, in terms of clinical homogeneity. Tabular summaries of key characteristics, participants, interventions, and outcomes were considered. A priori, it was decided that pooled estimates would be undertaken for studies with the same pharmacological intervention and the same outcome measure and that a minimum of three studies was necessary for pooling for a specific outcome^*^. Consideration was given to the similarity of study populations when selecting studies to be included in the pooled estimates. Although many studies evaluated multiple outcomes, data necessary for meta-analysis were not provided in all eligible trials. When sufficient data were provided to estimate the weighted mean difference (WMD), then a meta-analysis was undertaken. WMD was selected as the pooled estimate (versus the standardized mean difference) because the outcome measures did not differ between studies eligible for pooled estimates. For WMD, the difference between the treated and control groups are weighted by the inverse of the variance.

* A priori it was decided that a minimum of three studies would be required for undertaking pooled estimates. It was assumed that if two studies were meta-analyzed, theoretically the estimates could be in opposite directions leading to un-interpretable estimates. In this same situation, a third study would allow for interpretation of the direction of the effect.

Analysis was undertaken in RevMan 4.2 (Review Manager, Cochrane Collaboration, 2003), and the random-effects model was used to conduct our analyses. In cases where heterogeneity existed, the results of the random-effects model only were considered for interpretation of the results of the pooled estimate. RevMan 4.2 automatically tests the homogeneity of the results of the individual studies for each comparison of dichotomous or continuous data. Tests of homogeneity are formal statistical analyses for examining whether the observed variation in study results is compatible with the variation expected by chance alone. The more significant the results of the test (the smaller the p-value), the more likely that the observed differences were due to unknown factors likely not controlled for in the study. Sensitivity analysis or meta-regression was not undertaken to assess the extent to which the methodological quality of studies, population characteristics, dose, etc., accounted for variation in the primary outcome.

### Power Analyses

Power analyses were conducted for select pharmacological interventions reporting non-significant findings for all primary outcomes reported in the paper. In addition, if the trial reported the outcomes of MMSE, ADAS-cog, or the CIBIC+, the power for these was also estimated. It was assumed that the desired level of significance was set to alpha equal to 0.05. Adequate power was defined as at least 80% power.

### Peer Review Process

A list of potential peer reviewers was created at the outset of the study. During the course of the project, additional names were added to this list by the McMaster Center and Agency for Healthcare Research and Quality (AHRQ). In May 2003, the individuals on the list were approached by the McMaster team and asked if they would act as peer reviewers of this evidence report. A total of 26 experts agreed and received a copy of the draft report and a copy of the “Structured Format for Referee's Comments” (Appendix D). A list of the reviewers' names and their affiliation is provided in Appendix D. In addition, a criticism editor, Dr. Patricia Huston, who is external to the McMaster EPC, was asked to review the draft report and synthesize the peer review comments. The report from the criticism editor was then used to prioritize the incorporation of peer review comments into the final version of this evidence report.