# Introduction

This review focuses on the pharmacological treatment of dementia. Dementia is a syndrome of acquired cognitive defects sufficient to interfere with social or occupational functioning, which results from various central neurodegenerative and ischemic processes. Dementia has become a major public health problem due to its increasing prevalence, long duration, caregiver burden, and high financial cost of care. The prevalence of dementia varies as a function of the defining criteria as shown by Erkinjuntti et al. (1997), ^1^ who showed a range from 3.1% using the International Classification of Diseases, Tenth Revision (ICD-10) criteria, up to 29.1% using the Diagnostic and Statistical Manual, Third Edition (DSM-III) criteria. Jorm et al. (1987) ^2^ conducted a meta-analysis based on 22 international studies and found that the actual prevalence rates differed significantly from study to study. However, this meta-analysis demonstrated that the prevalence increased exponentially with age. The prevalence ranged from 0.7% for 60 – 64 year olds to 24% for people over the age of 85 years. In the United States, the prevalence of Alzheimer's disease (AD) is projected to quadruple to one in 45 Americans in the next 50 years ^3^ across all ages. The Canadian Study of Health & Aging (CSHA) ^4^ estimated the prevalence of dementia in Canada at 8% (approximately 252,600 cases) in 1991 among seniors over the age of 65 years. The prevalence of dementia increases to 34% among those aged 85 years or more. ^4^ The age-standardized incidence of dementia in Canada has been estimated at 21.8 per thousand for females and 19.1 per thousand for males. ^5^ The prevalence is expected to double to half a million cases in Canada by 2013. ^6^ Because the world's population is progressively aging, especially in the developed nations, more people are falling into age groups where the prevalence of dementia is highest. From a clinical perspective, dementia predominately affects 1) cognition, 2) behavior/mood, 3) physical functions and activities of daily living, and 4) caregiver burden. Therapeutic interventions for dementia aim to affect these four primary domains.

Pharmacotherapy is often the primary intervention used to improve symptoms or delay the progression of dementia syndromes. The pharmacological agents used vary significantly with respect to their therapeutic actions. The most common pharmacological agents used in North America modify the activity of cholinesterases—enzymes, which degrade acetylcholine, a neurotransmitter that is critical to the neurons involved in cognition (e.g. memory, thought, and judgment). Other approaches include the use of anti-oxidants, which work by minimizing the effects of free radicals that are released through normal oxidative metabolism. These free radicals may cause neuronal damage and play a role in the development of dementia. Similarly, it is believed that inflammation contributes to nerve cell damage and dementia; hence anti-inflammatory drugs may act by decreasing inflammation, potentially reducing nerve degeneration, which may in turn slow or even prevent dementia illnesses.

Other pharmacological interventions that have been studied include cholesterol-lowering agents, anti-hypertensives, folic acid, hormones (e.g. estrogen), behavior and mood altering drugs, anti-amyloid strategies (e.g. immunization, aggregation inhibitors, and secretase inhibitors), transition metal chelators, nerve growth factors, and agents that target neurotransmitters other than acetylcholine and its receptors. The various pharmacotherapeutic agents available to treat problems associated with dementia have varying levels of evidence to support their efficacy. This report is a systematic evaluation of the evidence for pharmacological interventions in the treatment of dementia in the domains of cognition, global function, behavior/mood, quality of life/ADL, and caregiver burden.

## Diagnosis of Dementia

Determination of disease onset presents considerable difficulty, as dementia, by definition, has an insidious and gradual progression. A number of diagnostic models have been used to classify dementia. In 1988 the National Institute of Neurological and Communicative Disorders and Stroke - Alzheimer's Disease and Related Disorders Association (NINCDS/ADRDA) research on diagnostic criteria were published for AD, which served to increase the validity and reliability of the clinical diagnosis. ^7,^ ^8^ Trials published prior to this time may reflect mixed populations other than AD. Other models used to diagnose dementia include: the International Classification of Diseases (ICD) version 9 or 10, the Diagnostic and Statistical Manual of Mental Disorders (DSM) III, III-R, and IV (American Psychiatric Association), and the NINCDS/ADRDA. ^9^ The difficulty with these different diagnostic criteria for dementia is that they are not interchangeable. Erkinjuntti et al. (1997) ^1^ compared six commonly used classification schemes (DSM-III, DSM-III-R, DSM-IV, ICD-9, ICD-10, and the Cambridge Examination for Mental Disorders in the Elderly (CAMDEX)). They showed that the prevalence of dementia can differ by a factor of 10 depending on the diagnostic criteria used. Two other studies have demonstrated that the prevalence of vascular dementia (VaD) varies with the classification system and therefore these criteria for diagnosis are not interchangeable. ^10,^ ^11^ Furthermore, there is controversy about the validity of the clinical classification of VaD, as autopsy confirmation often does not substantiate the clinical diagnosis. ^12,^ ^13^ The majority of dementias were actually AD with co-existing vascular and Parkinson's disease lesions. ^14^ In contrast, the clinical accuracy of AD diagnosis is relatively high. ^7^ The discovery that a long pre-clinical period precedes AD has led to the establishment of early diagnostic indices of dementia. This border zone between normality and dementia has been given numerous names and definitions, which include: benign senescent forgetfulness (BSF), age associated memory impairment (AAMI), age-consistent memory impairment (ACMI), age-associated cognitive decline (AACD), mild cognitive impairment (MCI), cognitive loss no dementia (CLOND), and cognitive impairment but not dementia (CIND). The prevalence for this pre-clinical or mild form of cognitive decline varies with the classification system used. ^15^ Unfortunately, the classifications used to diagnose early mild cognitive decline are not interchangeable. MCI ^16^ is emerging as the preferred term for this condition ^17^ using the criteria of Petersen et al. ^16^ Ritchie et al. ^18^ (2001) estimated the prevalence of MCI to be 3.2% with an 11.1% conversion rate to dementia within a 3 year period.

## Analytic Framework: Understanding Therapeutic Aims of Pharmacological Treatment

Dementia is a chronic progressive disease for which no known cure exists. Pharmacological interventions used to treat dementia are intended to achieve at least one of the following broad therapeutic aims:

Prevention of onset of the disease. In the context of this review, this applies to those at greatest risk (such as those with the clinical diagnosis of MCI) of conversion to a dementia syndrome.

Symptomatic treatment of the disease. Symptomatic benefit can be described as maintenance (or stabilization) or improvement of the current cognitive, behavioral, functional, or caregiver status only while on active treatment with the pharmacological intervention. Withdrawal of the pharmacological therapy results in a decline towards baseline or placebo levels of relevant outcomes.

Delay in the progression of the disease. A therapeutic intervention that brings about delay in the progression of the disease can be described as either 1) one that maintains (or stabilizes) or improves current cognitive, behavioral, functional, or caregiver status, which is sustained, or 2) one that can be shown to alter the rate of decline of the disease progression, even when the drug is withdrawn.

Figure 1 details the analytic framework for the progression of dementia and shows when various pharmacological interventions would ideally be administered for the intended therapeutic benefit within this pathway. The scope of this review did not include the evaluation of normal healthy aging populations. Rather, pharmacological agents intended for populations at increased risk of conversion to dementia syndromes, such as MCI, were eligible for evaluation in this systematic review.

Figure 1. Pathway for the progression of dementia and the ideal application of drug interventions within this framework

## Understanding Efficacy of Pharmacological Interventions in Dementia Trials

It has been suggested that dementia does not have uniformly accepted criteria for disease progression or consensus regarding the magnitude of clinically important changes. ^19,^ ^20^ With respect to the therapeutic aim, the practical consequences of these unresolved issues are that the same efficacy variables have been used to both show evidence of symptomatic benefit and demonstrate the effects on disease progression. Thus, the design of a clinical trial (rather than the outcome) is critical to demonstrating which of these two therapeutic outcomes (symptomatic benefit or delay in progression) is being achieved with the pharmacological agent. ^21^

Irrespective of which therapeutic aim is being achieved by the pharmacological agent, the lack of consensus on these two issues has even more important implications when considering the definition of “efficacy” for either treatment goal. A change in a relevant outcome measure that is due to factors other than chance is deemed statistically significant. The criteria to determine efficacy solely on statistical significance have long been recognized as problematic from an interpretation perspective. Clinically meaningful change reflects a different level of “significance” and often requires consensus among experts within the field to establish what magnitude of change is important. ^20^

## Efficacy as Measured by Clinical versus Statistical Significance

The dementia literature is not consistent in the criteria used for establishing efficacy, and there is no consensus on the meaning of clinical significance in the changes observed. ^20,^ ^22^ In general, attempts are made to select an outcome measuring an important dementia attribute (such as cognition) and an additional outcome evaluating global change as observed by a clinician (with or without input from the caregiver). The outcomes selected to reflect these two domains vary, as do the number of attributes that are selected for evaluation.

The United States Food and Drug Administration (FDA) has established criteria for efficacy of dementia (specifically AD) drug interventions, ^23^ which require the following: 1) a double blind, placebo-controlled trial, 2) subjects who meet established criteria for AD, 3) sufficient length of follow-up to appreciate a meaningful effect of the drug on cognition, and 4) a clinical change of sufficient magnitude to be recognized by a clinician. In establishing these criteria, it was assumed that the outcome measuring cognition was the primary change of interest, and that the global clinical evaluation would mirror the changes in the primary variable. ^24^ In 1997, the European Medicine Evaluation Agency (EMEA) issued new guidelines that incorporated two new concepts for the treatment of AD. ^25^ Firstly, the EMEA guidelines suggested a preference for a measure of functional abilities in addition to a global measure, and noted that behavioral outcomes were important from a clinical perspective. Secondly, a definition of “responders” should be included in all trials, such that the degree of improvement in their cognition (or stabilization) was pre-specified. However, the magnitude of the change reflecting a clinically meaningful change was not specifically stated in either of these two guidelines. Sufficient magnitude of the change would reflect a clinically important difference, and this would vary with the type of outcome selected.

Several authors have attempted to define “clinically” relevant change. Gutzmann et al. (2002) ^26^ developed an Efficacy Index Score (EIS), which is a checklist that combines dropout as well as the relevant improvements individually across the three levels of assessment (cognitive function, activities of daily living and global function). Although, this summary score has not been validated relative to other traditional outcomes, it does present a unique example of determining efficacy in the context of anti-dementia drug interventions. Mayeux and Sano (1999) ^27^ in reviewing drug interventions for dementia, evaluated efficacy as a percent of the change in the treatment group relative to baseline (corrected for any change in the placebo group) and contrasted this with the percent of dropouts related to adverse events. Disease progression was considered with respect to the outcomes of 1) time until death, 2) nursing home placement, 3) loss of ability to perform Activities of Daily Living (ADL), or 4) severe dementia. In the context of clinical trials seeking to establish efficacy of pharmacological interventions, the latter outcomes may be problematic to ascertain.

Evaluation of the natural history of AD established some threshold values for expected decline or progression of the disease. Using the Alzheimer's Disease Assessment Scale-Cognitive Section (ADAS-cog), ^28^ Rosen demonstrated that a decline of 1.28 points occurred within 12 weeks, a decline of 3.5 points within 6 months, and Stern et al. (1994) ^29^ showed a decline of 9 – 11 points by 1 year. Clinical experience would also suggest that the decline is not linear, with less deterioration in the early and later stages and the greatest acceleration in the middle severity category. The characteristics of the natural history of AD and other dementia types are best derived from longitudinal studies. Although, more details on the natural history of dementia are being reported, the fundamental difficulty still remains concerning the diversity of the outcome measures used to describe these changes. The picture of cognitive, behavioral, and functional decline will therefore vary with the outcome measure selected to describe it. Additionally, the diversity has a negative impact on comparisons of drug efficacy that can be made across trials. ^30^

## Efficacy and Outcome Measures Used in Pharmacological Intervention Trials

No specific set of commonly accepted outcomes that define efficacy or “clinical relevance” applies to all the pharmacological interventions that have been used to treat dementia. More than 175 outcome measures are listed in Appendix E. EMEA guidelines acknowledge that no single test encompasses the broad range of disease characteristics associated with AD; nor has there been convincing evidence that an ideal (or reference) instrument exists to capture cognitive, behavioral, functional, or caregiver status. ^25^ The FDA has recommended that “dual efficacy” of dementia drug interventions be established by significant change in both a psychological measure and a global change measure. The outcomes used to measure these attributes within these two domains were not specified. In practice, there has been a general trend in North America toward using the outcomes ADAS-cog, the Mini-Mental State Examination (MMSE), and the Clinicians' Interview-Based Impression of Change-Plus (CIBIC+) to capture the two domains when evaluating drugs for AD populations. However, these frequently used outcome measures may not be the best choice with respect to capturing “clinically relevant change”. The psychometric instrument properties must also be taken into consideration. For example, it has been suggested that the ADAS-cog is weighted predominately to evaluate memory loss at the expense of other cognitive domains (especially executive control functions), ^31^ which suggests that the face validity of this instrument may be in question. The generalizability of these results may be limited to dementia in which memory impairment is a key feature as the instrument is less sensitive to personality and executive dysfunction changes seen in a less typical dementia, such as frontotemporal dementia. The responsiveness (ability to detect change) of the CIBIC+ has not been well established. ^32^ This suggests that some of the most established outcomes used to evaluate efficacy of pharmacological interventions are far from ideal.

Demers et al. (2000) ^33^ critically appraised some of the most commonly used scales evaluating global assessment, ^32^ quality of life/ADL, ^30^ and behavior/mood ^34^ with respect to the quality of their psychometric properties. Several important limitations were identified in these reviews for the measures they evaluated, and these include 1) a lack of responsiveness data, 2) diversity in the content of the scales (capturing various aspects of a domain, for example, behavior), and 3) limited studies on reliability and validity (which are sample specific). The literature evaluating outcome measures used in dementia trials would suggest that most instruments have significant limitations, or at least more data are required to establish the required properties for acceptability of the scales.

Given the current state of development of research on outcome measures used in dementia trials for determining efficacy, a dilemma is clearly at hand. Ideally, all outcomes used to evaluate efficacy should have demonstrated acceptable psychometric properties, such as reliability, validity (construct), and responsiveness. However, since none of these outcomes have been accepted as standards, the selection of the most appropriate outcome is purely arbitrary. Similarly, establishing a rationale to exclude studies based on the specific type of outcome measure would be arbitrary. For this reason, no exclusion criteria based on outcome measures were used as eligibility criteria for this study.

## Efficacy and Potential Risk of Adverse Events

Increasing attention has been given to the potential for harm, and not just benefits, when considering the efficacy of drug interventions. Empirical evidence across diverse medical fields indicates that reporting of safety information, including milder adverse events, receives much less attention than the positive efficacy outcomes. ^35^ Thus, an evaluation of the benefits of anti-dementia pharmacological agents alone may present a biased view of the overall benefit of the intervention. In the context of this systematic review, the type and frequency of adverse events associated with the use of a drug intervention will be scrutinized to a greater extent than previous reviews of anti-dementia drugs.

Capturing and evaluating adverse events is problematic. Typical randomized controlled trial (RCT) dose finding studies should consist of the comparison of several doses of a drug versus placebo; efficacy is demonstrated relative to a placebo group or relative to a different dose group. Ideally, the goal of early phase trials is to estimate the minimum effective dose or the maximum safe dose (or both). However, it is misleading to assume that drugs shown to be safe and effective in trials are safe and effective in all other circumstances. ^36^ The nature of pre-market clinical trials makes it difficult to evaluate the benefits of drugs for the universe of potential users, as criteria restricting entry into the trial do not necessarily reflect dementia patients in general. By their nature, some adverse events are not easily anticipated, and therefore are not screened for in some trials. The implementation of pharmaco-vigilance systems attests to the need for further capture of potential adverse events not captured in trials. Adverse events may be hard to predict or anticipate and are captured only if a trial protocol was designed to measure these events. A limited number of standardized instruments exist to capture these events reliably. Unique to individuals with cognitive decline is the potential problem of validity of the self-report instrument, even if completed by the caregiver. Furthermore, many trials may be underpowered to detect adverse events with an incidence of 1/1000. ^37^ Despite these limitations, quality criteria for the collection and reporting of adverse events have been identified. ^35,^ ^37^ An instrument to evaluate the quality of reporting adverse events has been developed and used in this report to determine the strength of the evidence for adverse events in the context of determining efficacy.

## Efficacy and Intention to Treat Analysis

Determining efficacy in dementia trials evaluating pharmacological interventions may vary depending on the selection of the analysis type. In general, the types of analyses of primary data in trials fall into two main categories: 1) intention to treat analyses (ITT) or last observation carried forward (LOCF), and 2) observed case (OC) or completed trial (CT). The advantages of ITT over OC analyses have been well explicated. ^38^ It is recognized that non-compliance is not a random event; thus, ITT analyses should be used to base principal conclusions of efficacy. ^39^ In the context of some anti-dementia drug therapies, where dropout rates due to adverse events and other non-compliance reasons may be high, the ITT analysis minimizes bias and the potential for type I errors when considering treatment efficacy. However, the ITT analysis, while less biased, does tend to reduce treatment effects to the extent that there are dropouts and crossover patients. The optimal analysis, when there is a large loss to follow-up, is to conduct the analysis both ways and look for consistency.

## Primary Objectives and Scope of Systematic Review

A large number of pharmacological interventions have been studied in dementia patients. These agents can be classified into three broad categories: 1) cholinergic neurotransmitter modifying agents, such as acetylcholinesterase inhibitors, 2) non-cholinergic neurotransmitter/ neuropeptide modifying agents, and 3) other pharmacological agents. Although only four agents have been approved by the FDA for the treatment of dementia, many other pharmacological agents are being evaluated in trials in off-label use. In both these circumstances, there was a need to determine the evidence to support claims of efficacy and to describe adverse events.

### The Questions

Given the range of pharmacological agents that have been used to treat dementia, evaluation of all of these interventions in a systematic review (which afforded a consistent methodology) should serve as a meaningful contribution in this area. The purpose of this systematic review is to answer the following questions:

1. Does pharmacotherapy for dementia syndromes improve cognitive symptoms and outcomes?
2. Does pharmacotherapy delay cognitive deterioration or delay disease onset of dementia syndromes?
3. Are certain drugs, including alternative medicines (non-pharmaceutical), more effective than others?
4. Do certain patient populations benefit more from pharmacotherapy than others?
5. What is the evidence base for the treatment of VaD?

This review considers different dementia populations (not just AD) and subjects from both community and institutional settings. The interventions were limited to pharmacological agents (including nutriceuticals), and these were not restricted to those that have received official approval in North America. The studies eligible in this systematic review were restricted to parallel RCTs, but the study outcomes were not limited to specific types.

The review will serve to evaluate the quality of the evidence and identify important gaps in the literature. Future recommendations will serve the dementia research community specifically. This evidence report will support the American College of Physicians (ACP) and the American Academy of Family Physicians (AAFP) in developing “best practices” and practice guidelines for the evidence-based treatment of dementia for providers, patients and the public.