# Appendix F. List of excluded studies

Aarsland D, Larsen J P, Lim N G, et al. Olanzapine for psychosis in patients with Parkinson's disease with and without dementia. J Neuropsychiatry Clin Neurosci. 1999;11(3):392-4. [pmid: 10440017].
Status: Not included because dementia population not randomized to treatment
Aarsland D, Laake K, Larsen J P, et al. Donepezil for cognitive impairment in Parkinson's disease: A randomised controlled study. J Neurol Neurosurg Psychiatry. 2002;72(6):708-12. [pmid: 12023410].
Status: Cross-over trial;
Aarsland D. Erratum: Donepezil for cognitive impairment in Parkinson's disease. A randomised controlled study. J Neurol Neurosurg Psychiatry. 2002;73(3):354. [pmid: 12023410].
Status: Not included because not a full article
Abalan F, Manciet G, Dartigues J F, et al. Nutrition and SDAT. Biol Psychiatry. Jan 1. 1992;31(1):103-5. [pmid: 1543795].
Status: Not included because not a full article
Abuzzahab F S Sr, Merwin G E, Zimmermann R L, et al. A double-blind investigation of piracetam (nootropil) versus placebo in the memory of geriatric inpatients. Psychopharmacol Bull. Jan. 1978;14(1):23-5. [pmid: 343146].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Abyad A. Prevalence of vitamin B12 deficiency among demented patients and cognitive recovery with cobalamin replacement. J Nutr Health Aging. 2002;6(4):254-60. [pmid: 12486445].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Adler L A, Peselow E, Rosenthal M, et al. A controlled comparison of the effects of propranolol, benztropine, and placebo on akathisia: An interim analysis. Psychopharmacol Bull. 1993;29(2):283-6. [pmid: 8290678].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Aerssens J, Raeymaekers P, Lilienfeld S, et al. APOE genotype: no influence on galantamine treatment efficacy nor on rate of decline in Alzheimer's disease. Dement Geriatr Cogn Disord. Mar. 2001;12(2):69-77. [pmid: 11173877].
Status: Not included because does not meet criteria for treatment for dementia patients
Agnoli A, Martucci N, Manna V, et al. Effect of cholinergic and anticholinergic drugs on short-term memory in Alzheimer's dementia: a neuropsychological and computerized electroencephalographic study. Clin Neuropharmacol. 1983;6(4):311-23. [pmid: 6661730].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Agnoli A, Martucci N, Manna V. Quantitative EEG as a tool in neuropharmacological studies: The effect of naftidrofuryl in chronic cerebrovascular diseases (C.C.V.D). Curr Ther Res Clin Exp. 1985;37(3):387-97.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Agnoli A, Manna V, Martucci N, et al. Randomized double-blind study of flunarizine versus placebo in patients with chronic cerebrovascular disorders. Int J Clin Pharmacol Res. 1988;8(3):189-97. [pmid: 3042644].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Aguglia E, Caraceni T, Genitrini S, et al. Comparison of teniloxazine and piracetam in Alzheimer-type or vascular dementia. Curr Ther Res Clin Exp. 1995;56(3):250-7.
Status: Not included because Jadad Quality Scale score less than three
Ahlin A, Nyback H, Junthe T, et al. THA in Alzheimer's dementia clinical biochemical and pharmacokinetic findings. Alzheimer's disease basic mechanisms diagnosis and therapeutic strategies 1990; 621–5.
Status: Not included because not a full article
Ahlin A, Nyback H, Junthe T, et al. Tetrahydroaminoacridine in Alzheimer's dementia: Clinical and biochemical results of a double-blind crossover trial. Hum Psychopharmacol 1991; (2):109–18.
Status: Cross-over trial;
Ahlin A, Hassan M, Junthe T, et al. Tacrine in Alzheimer's disease: Pharmacokinetic and clinical comparison of oral and rectal administration. Int Clin Psychopharmacol. 1994;9(4):263-70. [pmid: 7868848].
Status: Cross-over trial;
Aisen P S, Marin D, Davis K L. Anti-inflammatory drug studies in Alzheimer's disease. Biol Psychiatry. 1996;39(7):563.
Status: Not included because not a full article
Aisen P S, Marin D B, Brickman A M, et al. Pilot tolerability studies of hydroxychloroquine and colchicine in Alzheimer disease. Alzheimer Dis Assoc Disord. Apr. 2001;15(2):96-101. [pmid: 11403336].
Status: Not included because dementia population not randomized to treatment
Aisen P S, Berg J D, Craft S, et al. Steroid-induced elevation of glucose in Alzheimer's disease: Relationship to gender, apolipoprotein E genotype and cognition. Psychoneuroendocrinology. 2003;28(1):113-20. [pmid: 12445840].
Status: Not included because dementia population not randomized to treatment
Alafuzoff I, Helisalmi S, Heinonen E H, et al. Selegiline treatment and the extent of degenerative changes in brain tissue of patients with Alzheimer's disease. Eur J Clin Pharmacol. Feb. 2000;55(1112):815-12. [pmid: 10805059].
Status: Not included because no extractable data relevant to review
Albizzati M G, Bassi S, Calloni E, et al. Cyclandelate versus flunarizine. A double-blind study in a selected group of patients with dementia. Drugs. 1987;33(Suppl 2):90-6. [pmid: 3304956].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Aldenkamp A P, van Wieringen A, Alpherts W C, et al. Double-blind placebo-controlled, neuropsychological and neurophysiological investigations with oxiracetam (CGP 21690E) in memory-impaired patients with epilepsy. Neuropsychobiology. Sep. 1990;24(2):90-101. [pmid: 2134116].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Alexopoulos G S, Meyers B S, Young R C, et al. Executive dysfunction and long-term outcomes of geriatric depression. Arch Gen Psychiatry. Mar. 2000;57(3):285-90. [pmid: 10711915].
Status: Not included because does not meet criteria for treatment for dementia patients
Allain H, Denmat J, Bentue-Ferrer D, et al. Randomized, double-blind trial of exifone versus cognitive problems in Parkinson's disease. Fundam Clin Pharmacol. 1988;2(1):1-12. [pmid: 3286439].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Allain H, Raoul P, Lieury A, et al. Effect of two doses of Gingko biloba extract (EGb 761) on the dual-coding test in elderly subjects. Clin Ther. 1993;15(3):549-58. [pmid: 8364946].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Allain H, Neuman E, Malbezin M, et al. Bridging study of S12024 in 53 in-patients with Alzheimer's disease. J Am Geriatr Soc. 1997;45(1):125-6. [pmid: 8994509].
Status: Not included because not a full article
Almkvist O, Jelic V, Amberla K, et al. Responder characteristics to a single oral dose of cholinesterase inhibitor: A double-blind placebo-controlled study with tacrine in Alzheimer patients. Dement Geriatr Cogn Disord. Jan. 2001;12(1):22-32. [pmid: 11125238].
Status: Cross-over trial;
Altman H, Mehta D, Evenson R C, et al. Behavioral effects of drug therapy on psychogeriatric inpatients. II. Multivitamin supplement. J Am Geriatr Soc. Jun. 1973;21(6):249-52. [pmid: 4575803].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Altman H, Mehta D, Evenson R C, et al. Behavioral effects of drug therapy on psychogeriatric inpatients. I. Chlorpromazine and thioridazine. J Am Geriatr Soc. Jun. 1973;21(6):241-8. [pmid: 4575803].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Alvarez X A, Laredo M, Corzo D, et al. Citicoline improves memory performance in elderly subjects. Methods & Findings in Experimental & Clinical Pharmacology. Apr. 1997;19(3):201-10. [pmid: 9203170].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Alvarez X A, Mouzo R, Pichel V, et al. Double-blind placebo-controlled study with citicoline in APOE genotyped Alzheimer's disease patients. Effects on cognitive performance, brain bioelectrical activity and cerebral perfusion. Methods & Findings in Experimental & Clinical Pharmacology. Nov. 1999;21(9):633-44. [pmid: 10669911].
Status: Not included because Jadad Quality Scale score less than three
Amaducci L, Maurer K, Winblad B, et al. A long-term, double-blind, placebo-controlled efficacy and safety study of nicergoline in patients with mild to moderate Alzheimer's disease. J Eur Coll Neuropsychopharmacol 1999; (Suppl 5):S323.
Status: Not included because not a full article
Amar K, Wilcock G K, Scot M, et al. The presence of leuko-araiosis in patients with Alzheimer's disease predicts poor tolerance to tacrine, but does not discriminate responders from non-responders. Age Ageing. Jan. 1997;26(1):25-9. [pmid: 9143434].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ambrozi L, Danielczyk W. Treatment of impaired cerebral function in psychogeriatric patients with memantine: Results of a phase II double-blind study. Pharmacopsychiatry. May. 1988;21(3):144-6. [pmid: 3406051].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anand R, Gharabawi G, Enz A. Efficacy and safety results of the early phase studies with Exelon(tm) (ENA-713) in Alzheimer's disease: An overview. J Drug Dev Clin Pract 1996; 1–8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ananth JV, Deutsch M, Ban TA. Senilex in the treatment of geriatric patients. Curr Ther Res Clin Exp; 13(5):316–21.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ancoli-Israel S, Martin J L, Kripke D F, et al. Effect of light treatment on sleep and circadian rhythms in demented nursing home patients. J Am Geriatr Soc. 2002;50(2):282-9. [pmid: 12028210].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anderer P, Barbanoj M J, Saletu B, et al. Restriction to a limited set of EEG-target variables may lead to misinterpretation of pharmaco-EEG results. Neuropsychobiology. 1993;27(2):112-6. [pmid: 8515827].
Status: Not included because no extractable data relevant to review
Anderson J, Arens K, Johnson R, et al. Spaced retrieval vs. memory tape therapy in memory rehabilitation for dementia of the Alzheimer's type. Clin Gerontol 2001; (1–2):123–39.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Darvon and Darvon-N. Med Lett Drugs Ther 1972 May; 14(11):37–8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Severely demented patients beyond help of drugs. Modern Geriatrics 1976; (10):36.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Double-blind, placebo-controlled evaluation of cinromide in patients with the Lennox-Gastaut Syndrome. The Group for the Evaluation of Cinromide in the Lennox-Gastaut Syndrome. Epilepsia 1989 Jul; 30(4):422–9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Safety and tolerability of the antioxidant OPC-14117 in HIV-associated cognitive impairment. The Dana Consortium on the Therapy of HIV Dementia and Related Cognitive Disorders. Neurology 1997 Jul; 49(1):142–6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Study suggests antioxidants slow decline in Alzheimer's disease. Am J Health Syst Pharm 1997; 54(13):1478.
Status: Not included because not a full article
Anonymous. Selegiline hydrochloride: Antiparkinsonian cognition enhancer. Drugs of the Future 1998; 23(2):240–1.
Status: Not included because not a full article
Anonymous. Benefits of new Alzheimer disease therapies. J Pharm Technol 1998; 14(3):125.
Status: Not included because not a full article
Anonymous. Eptastigmine tartrate: Cognition enhancer acetylcholinesterase inhibitor. Drugs of the Future 1998; 23(2):217–8.
Status: Not included because not a full article
Anonymous. Phosphatidylserine. Altern Med Rev 1999; 4(2):115–7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. The alternative to tube-feeding patients with advanced dementia. Volunt Leader 1999; 40(4):13–4.
Status: Not included because not a full article
Anonymous. Tacrine and Alzheimer disease. WHO Drug Information 1999; 13(1):7–8.
Status: Not included because not a full article
Anonymous. New hope for early Alzheimer's disease. Harv Womens Health Watch 2000 Apr; 7(8):7
Status: Not included because not a full article
Anonymous. Rivastigmine for Alzheimer's disease. Drug Ther Bull 2000; 38(2):15–6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Erratum: Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: A randomized controlled trial (Journal of the American Medical Association (February 23,2000) 283 (1007–1015)). JAMA 2000; 284(20):2597
Status: Not included because not a full article
Anonymous. Lead success for Nuerogen. Manuf Chem 2001; 72(4):11
Status: Not included because not a full article
Anonymous. New Alzheimer's drug is first therapy to show efficacy in vascular dementia. Hosp Formul 2001; 36(8):569.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous Idebenone. Altern Med Rev 2001; 6(1):83–6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Double-blind trial will compare two anti-Alzheimer's drugs. Journal of Dementia Care 2001; 9(5):6
Status: Not included because not a full article
Anonymous. Colostrinin. Journal of Dementia Care 2001; 9(6):37.
Status: Not included because not a full article
Anonymous. Erratum: A 24-week, randomized, double-blind study of donepezil in moderate to severe alzheimer's disease (Neurology (2001) 57 (613–620)). Neurology 2001; 57(11):2153.
Status: Not included because not a full article
Anonymous. Galantamine (Reminyl) for Alzheimer's disease. Med Lett Drugs Ther 2001; 43(1107):53–4.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Caregiver experience relates to clinical trial involvement: research looks at how caregivers of Alzheimer's patients make decisions regarding care. Caremanagement 2001 Jun; 7(3):55.
Status: Not included because not a full article
Anonymous. Aromatherapy trial. Journal of Dementia Care 2001; 9(6):38.
Status: Not included because not a full article
Anonymous. Galantamine: New preparation. The fourth cholinesterase inhibitor for Alzheimer's disease. Prescrire Int 2001 Dec; 10(56):180–1.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Galantamine effective in treating dementia in patients with cerebrovascular disease. Pharm J 2001; 266(7153):842.
Status: Not included because not a full article
Anonymous. Trial of new immunotherapeutic agent for Alzheimer's suspended. Pharm J 2002; 268(7187):279
Status: Not included because not a full article
Anonymous. Drug that modulates glutamate levels promising for Alzheimer's disease. Pharm J 2002; 269(7209):152.
Status: Not included because not a full article
Anonymous. Drugs to treat dementia and psychosis: Management of Parkinson's disease. Mov Disord 2002; 17(Suppl 4):S120–S127.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. NSAID use could reduce Alzheimer's risk. Pharm J 2002; 269(7217):428.
Status: Not included because not a full article
Anonymous. Memantine launched for treatment of Alzheimer's. Pharm J 2002; 269(7219):516.
Status: Not included because not a full article
Anonymous. Greater satisfaction, ease of use reported with donepezil versus galantamine. Hosp Formul 2002; 37(8):383–4.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Anonymous. Reminyl of benefit in vascular dementia. Pharm J 2002; 268(7194):526.
Status: Not included because not a full article
Anonymous. Perindopril protects against dementia. Pharm J 2002; 268(7204):899.
Status: Not included because not a full article
Anonymous. NSAIDs: Protection against Alzheimer's? Med Today 2002; 3(2):9.
Status: Not included because not a full article
Arendt G, von Giesen H J, Hefter H, et al. Therapeutic effects of nucleoside analogues on psychomotor slowing in HIV infection. AIDS. Mar 9. 2001;15(4):493-500. [pmid: 11242146].
Status: Not included because dementia population not randomized to treatment
Arkin SM. Alzheimer memory training: Quizzes beat repetition, especially with more impaired. Am J Alzheimers Dis 1997; (4):147–58.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Arkin S M. Alzheimer memory training: Students replicate learning successes. Am J Alzheimers Dis. May. 2000;15(3):152-62.
Status: Not included because dementia population not randomized to treatment
Arrigo A, Moglia A, Borsotti L. A double-blind, placebo-controlled, crossover trial with nicergoline in patients with senile dementia. Int J Clin Pharmacol Res. 1982;2(4 Suppl 1):33-41.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Arrigo A, Casale R, Giorgi I, et al. Effects of intravenous high dose c-dergocrine mesylate (‘Hydergine’ (R)) in elderly patients with severe multi-infarct dementia: A double-blind, placebo-controlled trial. Curr Med Res Opin. 1989;11(8):491-500. [pmid: 2680286].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ashford J W, Soldinger S, Schaeffer J, et al. Physostigmine and its effect on six patients with dementia. Am J Psychiatry. 1981;138(6):829-30. [pmid: 7246817].
Status: Not included because dementia population not randomized to treatment
Asthana S, Raffaele K C, Berardi A, et al. Treatment of Alzheimer's disease by continuous intravenous infusion of physostigmine. Alzheimer Dis Assoc Disord. 1995;9(4):223-32. [pmid: 8749612].
Status: Cross-over trial;
Asthana S, Greig N H, Holloway H W, et al. Clinical pharmacokinetics of arecoline in subjects with Alzheimer's disease. Clin Pharmacol Ther. Sep. 1996;60(3):276-82. [pmid: 8841150].
Status: Not included because no extractable data relevant to review
Asthana S, Raffaele K C, Greig N H, et al. Neuroendocrine responses to intravenous infusion of physostigmine in patients with Alzheimer's disease. Alzheimer Dis Assoc Disord. Apr. 1999;13(2):102-8. [pmid: 10372954].
Status: Cross-over trial;
Asthana S, Craft S, Baker L D, et al. Cognitive and neuroendocrine response to transdermal estrogen in postmenopausal women with Alzheimer's disease: Results of a placebo-controlled, double-blind, pilot study. Psychoneuroendocrinology. Aug. 1999;24(6):657-77. [pmid: 10399774].
Status: Not included because Jadad Quality Scale score less than three
Ather S A, Shaw S H, Stoker M J. A comparison of chlormethiazole and thioridazine in agitated confusional states of the elderly. Acta Psychiatr Scand. 1986;73(Suppl 329):81-91.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Auer SR, Monteiro IM, Reisberg B. Behavioral symptoms in dementia: community-based research. Int Psychogeriatr 1996; 8(Suppl 3):363–6, 381, 382.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Avorn J, Soumerai S B, Everitt D E, et al. A randomized trial of a program to reduce the use of psychoactive drugs in nursing homes. N Engl J Med. Jul 16. 1992;327(3):168-73. [pmid: 1608408].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Avorn J, Benner J, Ford I, et al. Measuring the cost-effectiveness of lipid-lowering drugs in the elderly: The outcomes research and economic analysis components of the PROSPER trial. Control Clin Trials. 2002;23(6):757-73. [pmid: 12505250].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Azuma T, Nagai Y, Saito T, et al. The effect of dehydroepiandrosterone sulfate administration to patients with multi-infarct dementia. JNS. Jan 1. 1999;162(1):69-73.
Status: Not included because dementia population not randomized to treatment
Bach D, Bach M, Bohmer F, et al. Reactivating occupational therapy: A method to improve cognitive performance in geriatric patients. Age Ageing. May. 1995;24(3):222-6. [pmid: 7645443].
Status: Not included because does not meet criteria for treatment for dementia patients
Bachynsky J, McCracken P, Lier D, et al. Propentofylline treatment for Alzheimer disease and vascular dementia: An economic evaluation based on functional abilities. Alzheimer Dis Assoc Disord. Apr. 2000;14(2):102-11. [pmid: 10850749].
Status: Not included because Jadad Quality Scale score less than three
Backonja M, Beydoun A, Edwards K R, et al. Gabapentin for the symptomatic treatment of painful neuropathy in patients with diabetes mellitus: A randomized controlled trial. JAMA. Dec 2. 1998;280(21):1831-6. [pmid: 9846777].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Baines S, Saxby P, Ehlert K. Reality orientation and reminescence therapy. A controlled cross-over study of elderly confused people. Br J Psychiatry. 1987;Vol 151:222-31. [pmid: 3318991].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Baker R, Dowling Z, Wareing LA, et al. Snoezelen: Its long-term and short-term effects on older people with dementia. Br J Occup Ther 1997; (5):213–9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Baker R, Bell S, Baker E, et al. A randomized controlled trial of the effects of multi-sensory stimulation (MSS) for people with dementia. Br J Clin Psychol. Mar. 2001;40(Pt 1):1-96. [pmid: 11317951].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Baladi J F, Bailey P A, Black S, et al. Rivastigmine for Alzheimer's disease: Canadian interpretation of intermediate outcome measures and cost implications. Clin Ther. Dec. 2000;22(12):1549-61. [pmid: 11192146].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Baldereschi M, Di Carlo A, Lepore V, et al. Estrogen-replacement therapy and Alzheimer's disease in the Italian Longitudinal Study on Aging. Neurology. Apr. 1998;50(4):996-1002. [pmid: 9566385].
Status: Not included because dementia population not randomized to treatment
Balestreri R, Bompani R, Cerrato G. Comparative study of suloctidil and dihydroergotoxine in chronic cerebrovascular insufficiency. Results of a double blind double dummy multicentric trial. Acta Ther. 1984;10(2):163-75.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Balestreri R, Fontana L, Astengo F. A double-blind placebo controlled evaluation of the safety and efficacy of vinpocetine in the treatment of patients with chronic vascular senile cerebral dysfunction. J Am Geriatr Soc. May. 1987;35(5):425-30. [pmid: 3553281].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ball J A, Taylor A R. Effect of cyclandelate on mental function and cerebral blood flow in elderly patients. BMJ. Aug 26. 1967;3(564):525-8. [pmid: 6038318]. [pmcid: 1842910].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ballard C, O'Brien J, James I, et al. Quality of life for people with dementia living in residential and nursing home care: The impact of performance on activities of daily living, behavioral and psychological symptoms, language skills, and psychotropic drugs. Int Psychogeriatr. Mar. 2001;13(1):93-106. [pmid: 11352339].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ballard C, Powell I, James I, et al. Can psychiatric liaison reduce neuroleptic use and reduce health service utilization for dementia patients residing in care facilities?. Int J Geriatr Psychiatry. Feb. 2002;17(2):140-5. [pmid: 11813276].
Status: Not included because dementia population not randomized to treatment
Ballard C G, O'Brien J T, Reichelt K, et al. Aromatherapy as a safe and effective treatment for the management of agitation in severe dementia: The results of a double-blind, placebo-controlled trial with Melissa. J Clin Psychiatry. 2002;63(7):553-8. [pmid: 12143909].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Balldin J, Gottries C G, Karlson I, et al. Relationship between DST and the serotonergic system. Results from treatments with two 5-HT reuptake blockers in dementia disorders. Int J Geriatr Psychiatry. 1988;3(1):17-26.
Status: Not included because no extractable data relevant to review
Bambasova E, Bilkova J, Budinska K. Papaverin in the treatment of geriatric patients. Act Nerv Super (Praha). Aug. 1974;16(3):192-3. [pmid: 4609360].
Status: Not included because dementia population not randomized to treatment
Ban T A, Modafferi A, Morey L. Global changes with glycosaminoglycan polysulfate in primary degenerative and multi-infarct dementia. Curr Ther Res Clin Exp. 1987;41(5):631-6.
Status: Not included because Jadad Quality Scale score less than three
Ban T A, Morey L C, Fjetland O K, et al. Early manifestations of dementing illness: Treatment with glycosaminoglycan polysulfate. Prog Neuropsychopharmacol Biol Psychiatry. Sep. 1992;16(5):661-76. [pmid: 1379739].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Banerjee S. Randomized controlled trials. Int Rev Psychiatry. 1998;10(4):291-303.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Barak Y, Levine J, Glasman A, et al. Inositol treatment of Alzheimer's disease: A double blind, cross-over placebo controlled trial. Prog Neuropsychopharmacol Biol Psychiatry. May. 1996;20(4):729-35. [pmid: 8843494].
Status: Cross-over trial;
Baro F, Malfroid M, Waegemans T, et al. Double-blind trial of suloctidil versus placebo in moderate to severe mental deterioration. Pharmatherapeutica. 1985;4(6):399-404. [pmid: 3001778].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bass D M, McClendon M J, Brennan P F, et al. The buffering effect of a computer support network on caregiver strain. J Aging Health. 1998;10(1):20-43. [pmid: 10182416].
Status: Not included because does not meet criteria for treatment for dementia patients
Bassi S, Albizzati M G, Corsini G U, et al. Therapeutic experience with transdihydrolisuride in Huntington's disease. Neurology. 1986;36(7):984-6. [pmid: 2940475].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Battaglia A, Bruni G, Ardia A, et al. Nicergoline in mild to moderate dementia. A multicenter, double-blind, placebo-controlled study. J Am Geriatr Soc. Apr. 1989;37(4):295-302. [pmid: 2646350].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Battaglia A, Bruni G, Sacchetti G, et al. A double-blind randomized study of two ergot derivatives in mild to moderate dementia. Curr Ther Res Clin Exp. 1990;48(4):597-612.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Battistin L, Pizzolato G, Dam M, et al. Effects of acetyl-L-carnitine (ALC) treatment in dementia: A multicentric, randomized, double-blind study. New Trends in Clinical Neuropharmacology 1989; (2):131–2.
Status: Not included because Jadad Quality Scale score less than three
Bavazzano A, Guarducci R, Gestri G, et al. Clinical trial with amantadine and hydergine in elderly patients. J Clin Exp Gerontol 1980; (4):289–99.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bazo A J. An ergot alkaloid preparation (Hydergine) versus papaverine in treating common complaints of the aged: Double-blind study. J Am Geriatr Soc. Feb. 1973;21(2):63-71. [pmid: 4631704].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Beck C, Heacock P, Mercer S O, et al. Improving dressing behavior in cognitively impaired nursing home residents. Nurs Res. May. 1997;46(3):126-32. [pmid: 9176501].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Beck C K, Vogelpohl T S, Rasin J H, et al. Effects of behavioral interventions on disruptive behavior and affect in demented nursing home residents. Nurs Res. 2002;51(4):219-28. [pmid: 12131234].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Beck C, Heacock P, Mercer S, et al. The impact of cognitive skills remediation training on persons with Alzheimer's disease or mixed dementia. J Geriatr Psychiatry. 1988;21(1):73-88. [pmid: 3171111].
Status: Not included because dementia population not randomized to treatment
Beckers T, Wagemans J, Boucart M, et al. Different effects of lorazepam and diazepam on perceptual integration. Vision Res. Aug. 2001;41(17):2297-303. [pmid: 11448721].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bedard M, Molloy D W, Standish T, et al. Clinical trials in cognitively impaired older adults: Home versus clinic assessments. J Am Geriatr Soc. Oct. 1995;43(10):1127-30. [pmid: 7560704].
Status: Not included because does not meet criteria for treatment for dementia patients
Bedard M A, Pillon B, Dubois B, et al. Acute and long-term administration of anticholinergics in Parkinson's disease: Specific effects on the subcortico-frontal syndrome. Brain Cogn. Jul. 1999;40(2):289-313. [pmid: 10413563].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Belanoff J K, Jurik J, Schatzberg L D, et al. Slowing the progression of cognitive decline in Alzheimer's disease using mifepristone. J Mol Neurosci. 2002;19(12):201-6. [pmid: 12212781].
Status: Not included because no extractable data relevant to review
Belfiore G, Di Maio L, Napolitano G, et al. Long-term effect of a single dose of flunarizine in Huntington's disease. Eur J Neurol. 1998;5(3):249-53. [pmid: 10210839].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bell I R, Edman J S, Morrow F D, et al. Brief communication. Vitamin B1, B2, and B6 augmentation of tricyclic antidepressant treatment in geriatric depression with cognitive dysfunction. J Am Coll Nutr. Apr. 1992;11(2):159-63. [pmid: 1578091].
Status: Not included because does not meet criteria for treatment for dementia patients
Beller S A, Overall J E, Swann A C. Efficacy of oral physostigmine in primary degenerative dementia. A double-blind study of response to different dose level. Psychopharmacologia. 1985;87(2):147-51.
Status: Cross-over trial;
Bellus S B, Vergo J G, Kost P P, et al. Behavioral rehabilitation and the reduction of aggressive and self-injurious behaviors with cognitively impaired, chronic psychiatric inpatients. Psychiatr Q. 1999;70(1):27-37. [pmid: 9924730].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ben Shlomo Y, Churchyard A, Head J, et al. Investigation by Parkinson's Disease Research Group of United Kingdom into excess mortality seen with combined levodopa and selegiline treatment in patients with early, mild Parkinson's disease: Further results of randomised trial and confidential inquiry. BMJ. Apr 18. 1998;316(7139):1191-6. [pmid: 9583926]. [pmcid: 28519].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Benedict R H, Shapiro A, Priore R, et al. Neuropsychological counseling improves social behavior in cognitively-impaired multiple sclerosis patients. Mult Scler. Dec. 2000;6(6):391-6. [pmid: 11212135].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bentham P W. A double-blind placebo-controlled trial of L-tryptophan to assess the degree of cognitive and behavioural improvement in patients with Alzheimer-type dementia and to compare differential response in clinical sub-groups. Int Clin Psychopharmacol. 1990;5(4):261-72. [pmid: 2081897].
Status: Not included because Jadad Quality Scale score less than three
Bergamasco B, Villardita C, Coppi R. Idebenone in the treatment of multi-infarct dementia: A randomised, double-blind, placebo controlled multicentre trial. Arch Gerontol Geriatr. 1992;15(3):271-8. [pmid: 15374367].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bergamasco B, Villardita C, Coppi R. Effects of idebenone in elderly subjects with cognitive decline. Results of a multicentre clinical trial. Arch Gerontol Geriatr. 1992;15(3):279-86. [pmid: 15374367].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bernardi F, Lanzone A, Cento R M, et al. Allopregnanolone and dehydroepiandrosterone response to corticotropin-releasing factor in patients suffering from Alzheimer's disease and vascular dementia. Eur J Endocrinol. 2000;142(5):466-71. [pmid: 10802523].
Status: Not included because does not meet criteria for treatment for dementia patients
Besson J A O, Palin A N, Ebmeier K P, et al. Calcium antagonists and multi-infarct dementia: A trial involving sequential NMR and psychometric assessment. Int J Geriatr Psychiatry. 1988;3(2):99-105.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bierer L M, Aisen P S, Davidson M, et al. A pilot study of oral physostigmine plus yohimbine in patients with Alzheimer disease. Alzheimer Dis Assoc Disord. 1993;7(2):98-104. [pmid: 8347333].
Status: Not included because dementia population not randomized to treatment
Bierer L M, Aisen P S, Davidson M, et al. A pilot study of clonidine plus physostigmine in Alzheimer's disease. Dementia. Sep. 1994;5(5):243-6. [pmid: 7951680].
Status: Not included because Jadad Quality Scale score less than three
Binder E F, Schechtman K B, Birge S J, et al. Effects of hormone replacement therapy on cognitive performance in elderly women. Maturitas. Apr. 2001;38(2):137-46. [pmid: 11306202].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Birge S J. The role of estrogen in the treatment of Alzheimer's disease. Neurology. 1997;48(5 Suppl 7):S36-S41. [pmid: 9153165].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Birkett D P, Boltuch B. Chlorpromazine in geriatric psychiatry. J Am Geriatr Soc. Aug. 1972;20(8):403-6. [pmid: 5053460].
Status: Not included because no extractable data relevant to review
Bjorkman T, Hansson L, Sandlund M. Outcome of case management based on the strengths model compared to standard care. A randomised controlled trial. Soc Psychiatry Psychiatr Epidemiol. Apr. 2002;37(4):147-52. [pmid: 12027240].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Blaha L, Erzigkeit H, Adamczyk A, et al. Clinical evidence of the effectiveness of vinpocetine in the treatment of organic psychosyndrome. Hum Psychopharmacol 1989; (2):103–11.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Blass J P, Gleason P, Brush D, et al. Thiamine and Alzheimer's disease. A pilot study. Arch Neurol. Aug. 1988;45(8):833-5. [pmid: 2969232].
Status: Cross-over trial;
Blass J P, Cyrus P A, Bieber F, et al. Randomized, double-blind, placebo-controlled, multicenter study to evaluate the safety and tolerability of metrifonate in patients with probable Alzheimer's disease. Alzheimer Dis Assoc Disord. 2000;14(1):39-45. [pmid: 10718203].
Status: Not included because no extractable data relevant to review
Blazer D G, Landerman L R, Hays J C, et al. Symptoms of depression among community-dwelling elderly African-American and white older adults. Psychol Med. Nov. 1998;28(6):1311-20. [pmid: 9854272].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Blin J, Piercey M F, Giuffra M E, et al. Metabolic effects of scopolamine and physostigmine in human brain measured by positron emission tomography. JNS. May. 1994;123(12):44-2.
Status: Not included because does not meet criteria for treatment for dementia patients
Blin J, Ivanoiu A, Coppens A, et al. Cholinergic neurotransmission has different effects on cerebral glucose consumption and blood flow in young normals, aged normals, and Alzheimer's disease patients. Neuroimage. Nov. 1997;6(4):335-43. [pmid: 9417975].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Blin J, Ivanoiu A, De Volder A, et al. Physostigmine results in an increased decrement in brain glucose consumption in Alzheimer's disease. Psychopharmacologia. Apr. 1998;136(3):256-63.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Block R I, DeVoe M, Stanley B, et al. Memory performance in individuals with primary degenerative dementia: Its similarity to diazepam-induced impairments. Exp Aging Res. 1985;11(34):151-4. [pmid: 4076305].
Status: Not included because does not meet criteria for treatment for dementia patients
Blume J, Ruhlmann K U, de la Haye R, et al. Treatment of chronic cerebrovascular disease in elderly patients with pentoxifylline. J Med. 1992;23(6):417-32. [pmid: 1293252].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bodick N C, Offen W W, Shannon H E, et al. The selective muscarinic agonist xanomeline improves both the cognitive deficits and behavioral symptoms of Alzheimer's disease. Alzheimer Dis Assoc Disord. 1997;11(Suppl 4):S16-S22. [pmid: 9339268].
Status: Not included because Jadad Quality Scale score less than three
Boelhouwer C, Henry C E, Glueck B C Jr. Positive spiking: A double-blind control study on its significance in behavior disorders, both diagnostically and therapeutically. Am J Psychiatry. Oct. 1968;125(4):473-81. [pmid: 4886101].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bollen E L E M, Gaw A, Buckley B M, et al. Statin therapy and the prevention of dementia. Arch Neurol. 2001;58(6):1023-4. [pmid: 11405825].
Status: Not included because not a full article
Bompani R, Scali G. Fipexide, an effective cognition activator in the elderly: A placebo-controlled, double-blind clinical trial. Curr Med Res Opin. 1986;10(2):99-106. [pmid: 3519097].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bonavita E. Study of the efficacy and tolerability of L-acetylcarnitine therapy in the senile brain. Int J Clin Pharmacol Ther Toxicol; 24(9):511–6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bonura ML, Grigoletto F. A 6-month, multicentre, double-blind trial of nicergoline in the treatment of mild to moderate Alzheimer's disease and its 12-month follow-up: Preliminary results. J Neural Transm Gen Sect 2000; XVIII.
Status: Not included because not a full article
Boon A J, Tans J T, Delwel E J, et al. Does CSF outflow resistance predict the response to shunting in patients with normal pressure hydrocephalus?. Acta Neurochir Suppl. 1998;71:331-3. [pmid: 9779222].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Borjesson A, Karlsson T, Adolfsson R, et al. Linopirdine (DUP 996): Cholinergic treatment of older adults using successive and non-successive tests. Neuropsychobiology. 1999;40(2):78-85. [pmid: 10474062].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Borromei A, Gaggi R, Giancola L C. Involutional dementias: New perspectives. Ital J Neurol Sci. 1985;6(2):167-71. [pmid: 4030301].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Borroni B, Colciaghi F, Pastorino L, et al. Amyloid precursor protein in platelets of patients with Alzheimer's disease: Effect of acetylcholinesterase inhibitor treatment. Arch Neurol. 2001;58(3):442-6. [pmid: 11255448].
Status: Not included because dementia population not randomized to treatment
Bottiglieri T, Godfrey P, Flynn T, et al. Cerebrospinal fluid S-adenosylmethionine in depression and dementia: Effects of treatment with parenteral and oral S-adenosylmethionine. J Neurol Neurosurg Psychiatry. 1990;53(12):1096-8. [pmid: 2292704].
Status: Not included because dementia population not randomized to treatment
Bourgeois M S, Burgio L D, Schulz R, et al. Modifying repetitive verbalizations of community-dwelling patients with AD. Gerontologist. Feb. 1997;37(1):30-9. [pmid: 9046703].
Status: Not included because does not meet criteria for treatment for dementia patients
Bourgeois M S, Dijkstra K, Burgio L, et al. Memory aids as an augmentative and alternative communication strategy for nursing home residents with dementia. Aac: Augmentative & Alternative Communication. Sep. 2001;17(3):196-210.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bower H M, McDonald C. A controlled trial of A.N.P. 235 (“Lucidril”) in senile dementia. Med J Aust. Aug 6. 1966;2(6):270-1. [pmid: 4380322].
Status: Not included because dementia population not randomized to treatment
Bowles E J, Griffiths D M, Quirk L, et al. Effects of essential oils and touch on resistance to nursing care procedures and other dementia-related behaviours in a residential care facility. Int J Aromather. 2002;12(1):22-9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bowling A, Formby J, Grant K, et al. A randomized controlled trial of nursing home and long-stay geriatric ward care for elderly people. Age Ageing. Sep. 1991;20(5):316-24. [pmid: 1755386].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Branconnier R J, Cole J O. A memory assessment technique for use in geriatric psychopharmacology: Drug efficacy trial with naftidrofuryl. J Am Geriatr Soc. Apr. 1977;25(4):186-8. [pmid: 903545].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Branconnier R J, Cole J O. The impairment index as a symptom-independent parameter of drug efficacy in geriatric psychopharmacology. J Gerontol. Mar. 1978;33(2):217-23. [pmid: 342594].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Branconnier R J, Cole J O, Gardos G. ACTH 4–10 in the amelioration of neuropsychological symptomatology associated with senile organic brain syndrome. Psychopharmacologia. Mar. 1979;61(2):161-5.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Branconnier R J, Cole J O, Ghazvinian S, et al. Treating the depressed elderly patient: The comparative behavioral pharmacology of mianserin and amitriptyline. Adv Biochem Psychopharmacol. 1982;Vol 32:195-212. [pmid: 7046364].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Branconnier R J, Cole J O, Dessain E C, et al. The therapeutic efficacy of pramiracetam in Alzheimer's disease: Preliminary observations. Psychopharmacol Bull. 1983;19(4):726-30.
Status: Not included because dementia population not randomized to treatment
Branconnier R J, Harto N E, Dessain E C, et al. Speech blockage, memory impairment, and age: a prospective comparison of amitriptyline and maprotiline. Psychopharmacol Bull. 1987;23(1):230-4. [pmid: 3602325].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Branconnier R J, Harto N E, Dessain E C, et al. Palliation of the progressive memory impairment of Alzheimer's disease by nimodipine. Psychopharmacologia. 1988;96(Suppl):242.
Status: Not included because not a full article
Branconnier R J, Cole J O. Effects of chronic papaverine administration on mild senile organic brain syndrome. J Am Geriatr Soc. 1977;25(10):458-62. [pmid: 903545].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brandimonte M A, Passolunghi M C. The effect of cue-familiarity, cue-distinctiveness, and retention interval on prospective remembering. Q J Exp Psychol A. Aug. 1994;47(3):565-87. [pmid: 7938668].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brass E P, Polinsky R, Sramek J J, et al. Effects of the cholinomimetic SDZ ENS-163 on scopolamine-induced cognitive impairment in humans. J Clin Psychopharmacol. Feb. 1995;15(1):58-62. [pmid: 7714229].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brautigam M R H, Blommaert F A, Verleye G, et al. Treatment of age-related memory complaints with ginkgo biloba extract: A randomized double blind lpacebo-controlled study. Phytomedicine. 1998;5(6):425-34.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brauzer B, Goldstein B J. The differential response to parenteral chlorpromazine and mesoridazine in psychotic patients. J Clin Pharmacol New Drugs. Mar. 1970;10(2):126-31.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Braverman AM, Naylor CD. Vasoactive substances in the management of elderly patients suffering from dementia. Modern Geriatrics 1975; (5):20–9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brazzelli M, Capitani E, Della S S, et al. A neuropsychological instrument adding to the description of patients with suspected cortical dementia: The Milan overall dementia assessment. J Neurol Neurosurg Psychiatry. 1994;57(12):1510-7. [pmid: 7798982].
Status: Not included because does not meet criteria for treatment for dementia patients
Breeze R W, Cox S, Rodgers C J. Changes in P-300 latency as a result of co-dergocrine mesylate therapy in patients with senile dementia. Int J Geriatr Psychiatry. 1988;3(4):263-6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Breitbart W, Marotta R, Platt M M, et al. A double-blind trial of haloperidol, chlorpromazine, and lorazepam in the treatment of delirium in hospitalized AIDS patients. Am J Psychiatry. Feb. 1996;153(2):231-7. [pmid: 8561204].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Breitner J C, Gau B A, Welsh K A, et al. Inverse association of anti-inflammatory treatments and Alzheimer's disease: Initial results of a co-twin control study. Neurology. Feb. 1994;44(2):227-32. [pmid: 8309563].
Status: Not included because dementia population not randomized to treatment
Breitner J C. The role of anti-inflammatory drugs in the prevention and treatment of Alzheimer's disease. Annu Rev Med. 1996;Vol 47:401-11. [pmid: 8712791].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Breitner J C S, Zandi P P, In't Veld B A. Long-term use of non-steroidal anti-inflammatory drugs (NSAIDs) reduce the relative risk of Alzheimer's disease to 02. J Neurol. 2002;249(3):355-6.
Status: Not included because not a full article
Breuil V, de Rotrou J, Forette F, et al. Cognitive stimulation of patients with dementia: Preliminary results. Int J Geriatr Psychiatry. 1994;9(3):211-7.
Status: Not included because does not meet criteria for treatment for dementia patients
Bridges-Parlet S, Knopman D, Steffes S. Withdrawal of neuroleptic medications from institutionalized dementia patients: Results of a double-blind, baseline-treatment-controlled pilot study. J Geriatr Psychiatry Neurol. Jul. 1997;10(3):119-26. [pmid: 9322135].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brinkman S D, Smith R C, Meyer J S. Lecithin and memory training in suspected Alzheimer's disease. J Gerontol. 1982;37(1):4-9. [pmid: 7031118].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brinkman S D, Pomara N, Goodnick P J, et al. A dose-ranging study of lecithin in the treatment of primary degenerative dementia (Alzheimer's disease). J Clin Psychopharmacol. Aug. 1982;2(4):281-5. [pmid: 7119136].
Status: Cross-over trial;
Brodaty H, Roberts K, Peters K. Quasi-experimental evaluation of an educational model for dementia caregivers. Int J Geriatr Psychiatry. 1994;9(3):195-204.
Status: Not included because dementia population not randomized to treatment
Brodaty H, Gresham M, Luscombe G. The Prince Henry Hospital dementia caregivers' training programme. Int J Geriatr Psychiatry. Feb. 1997;12(2):183-92. [pmid: 9097211].
Status: Not included because does not meet criteria for treatment for dementia patients
Broderick J P, Gaskill M, Dhawan A, et al. Temporal changes in brain volume and cognition in a randomized treatment trial of vascular dementia. J Neuroimaging. Jan. 2001;11(1):6-12. [pmid: 11198531].
Status: Not included because Jadad Quality Scale score less than three
Brodersen P, Philbert A, Gulliksen G, et al. The effect of L-Deprenyl on on-off phenomena in Parkinson's disease. Acta Neurol Scand. Jun. 1985;71(6):494-7. [pmid: 3927650].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brodie N H. A double-blind trial of naftidrofuryl in treating confused elderly patients in general practice. Practitioner. Feb. 1977;218(1304):274-9. [pmid: 320593].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brody E M, Kleban M H, Lawton M P, et al. A longitudinal look at excess disabilities in the mentally impaired aged. J Gerontol. 1974;29(1):79-84. [pmid: 4809668].
Status: Not included because dementia population not randomized to treatment
Brooker D, Duce L. Wellbeing and activity in dementia: A comparison of group reminiscence therapy, structured goal-directed group activity and unstructured time. Aging Ment Health. 2000;4(4):354-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brooker D J, Snape M, Johnson E, et al. Single case evaluation of the effects of aromatherapy and massage on disturbed behaviour in severe dementia. Br J Clin Psychol. May. 1997;36(Pt 2):287-96. [pmid: 9167869].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brouwers P, Hendricks M, Lietzau J A, et al. Effect of combination therapy with zidovudine and didanosine on neuropsychological functioning in patients with symptomatic HIV disease: A comparison of simultaneous and alternating regimens. AIDS. Jan. 1997;11(1):59-66. [pmid: 9110076].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Brown S, Gotell E, Ekman SL. Singing as a therapeutic intervention in dementia care. Journal of Dementia Care 2001; (4):33–7.
Status: Not included because does not meet criteria for treatment for dementia patients
Brun A, Gustafson L. The lund longitudinal dementia study a 25 year prespective on neuropathology differential diagnosis and treatment. In: Corian B, Iqbal K, Nicolini M, Winblad B, Wisniewski HM, Zatta PF, editors. Alzheimer's Disease: Advances in Clinical and Basic Research, Chichester: John Wiley & Sons; 1993. Chapter 1. p. 3–18.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bruno G, Mohr E, Gillespie M, et al. Muscarinic agonist therapy of Alzheimer's disease. A clinical trial of RS-86. Arch Neurol. Jul. 1986;43(7):659-61. [pmid: 3524514].
Status: Cross-over trial;
Buettner LL, Lundegren H, Lago D, et al. Therapeutic recreation as an intervention for persons with dementia and agitation: An efficacy study. Am J Alzheimers Dis 1996; (5):4–10.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Buettner L L. Focus on caregiving. Falls prevention in dementia populations: Following a trial program of recreation therapy, falls were reduced by 164 percent. Provider. Feb. 2002;28(2):41-3. [pmid: 15988879].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Buettner L L, Fitzsimmons S. AD-venture program: Therapeutic biking for the treatment of depression in long-term care residents with dementia. Am J Alzheimers Dis Other Demen. Mar. 2002;17(2):121-7. [pmid: 12501484].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Bukatina E E, Grigor'eva I V, Sokol'chik E I. The effectiveness of amiridin in senile dementia of the Alzheimer's type. Neurosci Behav Physiol. Jan. 1993;23(1):83-9. [pmid: 8464548].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Burgener S C, Bakas T, Murray C, et al. Effective caregiving approaches for patients with Alzheimer's disease. Geriatr Nurs (Minneap). May. 1998;19(3):121-6.
Status: Not included because does not meet criteria for treatment for dementia patients
Burgio L D, Reynolds C F I, Janosky J E, et al. A behavioral microanalysis of the effects of haloperidol and oxazepam in demented psychogeriatric inpatients. Int J Geriatr Psychiatry. 1992;7(4):253-62.
Status: Not included because Jadad Quality Scale score less than three
Burns A, Marsh A, Bender D A. A trial of vitamin supplementation in senile dementia. Int J Geriatr Psychiatry. 1989;4(6):333-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cahn L A, Diesfeldt H F. The use of neuroleptics in the treatment of dementia in old age. A critical analysis with reference to an experiment with a long-acting oral neuroleptic (penfluridol Janssen). Psychiatr Neurol Neurochir. 1973;76(6):411-20. [pmid: 4592700].
Status: Not included because dementia population not randomized to treatment
Caligiuri M P, Lacro J P, Jeste D V. Incidence and predictors of drug-induced parkinsonism in older psychiatric patients treated with very low doses of neuroleptics. J Clin Psychopharmacol. Aug. 1999;19(4):322-8. [pmid: 10440459].
Status: Not included because does not meet criteria for treatment for dementia patients
Camberg L, Woods P, Ooi W L, et al. Evaluation of Simulated Presence: A personalized approach to enhance well-being in persons with Alzheimer's disease. J Am Geriatr Soc. Apr. 1999;47(4):446-52. [pmid: 10203120].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Campi N, Todeschini G P, Scarzella L. Selegiline versus L-acetylcarnitine in the treatment of Alzheimer-type dementia. Clin Ther. Jul. 1990;12(4):306-14. [pmid: 2121359].
Status: Not included because Jadad Quality Scale score less than three
Campion D, Brice A, Hannequin D, et al. A large pedigree with early-onset Alzheimer's disease: Clinical, neuropathologic, and genetic characterization. Neurology. Jan. 1995;45(1):80-5. [pmid: 7824141].
Status: Not included because does not meet criteria for treatment for dementia patients
Canal N, Imbimbo N. A 25-week double-blind randomized placebo-controlled trial of Eptastigmine in patients with diagnosis of probable Alzheimer's disease. J Neural Transm Gen Sect. 1996;103:XXIV.
Status: Not included because not a full article
Cantillon M, Brunswick R, Molina D, et al. Buspirone vs. haloperidol: A double-blind trial for agitation in a nursing home population with Alzheimer's disease. Am J Geriatr Psychiatry. 1996;4(3):263-7.
Status: Not included because Jadad Quality Scale score less than three
Capote B, Parikh N. Cyclandelate in the treatment of senility: a controlled study. J Am Geriatr Soc. Aug. 1978;26(8):360-2. [pmid: 353121].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Capurso A, Capurso S, Panza F, et al. Efficacy of cytidine diphosphate choline in patients affected by chronic cerebrovascular disease. Clin Drug Investig 1996; (1):26–38.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Caraceni T A, Girotti F, Celano I, et al. 2-dimethylaminoethanol (Deanol) in Huntington's chorea. J Neurol Neurosurg Psychiatry. 1978;41(12):1114-8. [pmid: 153384].
Status: Not included because no extractable data relevant to review
Carbonin P U, Greco A, Pisanti P, et al. Efficacy of almitrine-raubasine in cognitive disorders of aging: A double-blind, placebo-controlled, clinical and psychometric study. Clin Neuropharmacol. 1990;Vol 13(Suppl 3):S92-S99. [pmid: 2093422].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cardebat D, Demonet J-F, Puel M, et al. Brain correlates of memory processes in patients with dementia of Alzheimer's type: A SPECT activation study. J Cereb Blood Flow Metab. 1998;18(4):457-62. [pmid: 9538911].
Status: Not included because does not meet criteria for treatment for dementia patients
Carman J S, Shoulson I, Chase T N. Huntington's chorea treated with lithium carbonate. Lancet. 1974;1(7861):811. [pmid: 4132745].
Status: Not included because not a full article
Carmel R. Mild cobalamin deficiency. West J Med. Jun. 1998;168(6):522-3. [pmid: 9655994].
Status: Not included because not a full article
Caro A J, Caro S. Vitamin E in treatment of Huntington's chorea. BMJ. Jan 21. 1978;1(6106):153. [pmid: 145890]. [pmcid: 1602798].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Caro J J, Salas M, Ward A, et al. Economic analysis of galantamine, a cholinesterase inhibitor, in the treatment of patients with mild to moderate Alzheimer's disease in the Netherlands. Dement Geriatr Cogn Disord. 2002;14(2):84-9. [pmid: 12145455].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Carter L T, Howard B E, O'Neil W A. Effectiveness of cognitive skill remediation in acute stroke patients. Am J Occup Ther. May. 1983;37(5):320-6. [pmid: 6869493].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Carver A, Dobson A M. Effects of dietary supplementation on demented elderly hospital residents. Age Ageing. 1993;22(Suppl 3):37. [pmid: 8438664].
Status: Not included because not a full article
Carver A D, Dobson A M. Effects of dietary supplementation of elderly demented hospital residents. J Hum Nutr Diet. 1995;8(6):389-94.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Casale R, Giorgi I, Guarnaschelli C. Evaluation of the effect of vincamine teprosilate on behavioural performances of patients affected with chronic cerebrovascular disease. Int J Clin Pharmacol Res. 1984;4(4):313-9. [pmid: 6500778].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cebul R D. Aspirin and MID Notes of caution. J Am Geriatr Soc. 1989;37(6):573-5. [pmid: 2715564].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cenacchi T, Bertoldin T, Farina C, et al. Cognitive decline in the elderly: A double-blind, placebo-controlled multicenter study on efficacy of phosphatidylserine administration. Aging (Milano). Apr. 1993;5(Milano):123-33. [pmid: 8323999].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Chabriat H, Pappata S, Ostergaard L, et al. Cerebral hemodynamics in CADASIL before and after acetazolamide challenge assessed with MRI bolus tracking. Stroke. Aug. 2000;31(8):1904-12. [pmid: 10926955].
Status: Not included because dementia population not randomized to treatment
Challis D, Von Abendorff R, Brown P, et al. Care management, dementia care and specialist mental health services: An evaluation. Int J Geriatr Psychiatry. 2002;17(4):315-25. [pmid: 11994884].
Status: Not included because dementia population not randomized to treatment
Chandra B. Treatment of multi-infarct dementia with citicholine. Journal of Stroke and Cerebrovascular Diseases 1992; 232–3.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Chandra B. Treatment of vascular dementia with CDP choline. Journal of Stroke and Cerebrovascular Diseases. 2000;9(Suppl 2):128-9. [pmid: 17895209].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Chang B L. Cognitive-behavioral intervention for homebound caregivers of persons with dementia. Nurs Res. May. 1999;48(3):173-82. [pmid: 10337848].
Status: Not included because does not meet criteria for treatment for dementia patients
Chatellier G, Lacomblez L, and Group. Tacrine (tetrahydroaminoacridine; THA) and lecithin in senile dementia of the Alzheimer type: A multicentre trial. BMJ 1990; 300(6723):495–9.
Status: Cross-over trial;
Christe C, Janssens J P, Armenian B, et al. Midazolam sedation for upper gastrointestinal endoscopy in older persons: A randomized, double-blind, placebo-controlled study. J Am Geriatr Soc. Nov. 2000;48(11):1398-403. [pmid: 11083314].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Christensen D B, Benfield W R. Alprazolam as an alternative to low-dose haloperidol in older, cognitively impaired nursing facility patients. J Am Geriatr Soc. May. 1998;46(5):620-5. [pmid: 9588378].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Christie J E, Shering A, Ferguson J, et al. Physostigmine and arecoline: Effects of intravenous infusions in Alzheimer presenile dementia. Br J Psychiatry. 1981;Vol 138:46-50. [pmid: 7023592].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Churchill M, Safaoui J, McCabe B W, et al. Using a therapy dog to alleviate the agitation and desocialization of people with Alzheimer's disease. J Psychosoc Nurs Ment Health Serv. Apr. 1999;37(4):16-22. [pmid: 10218187].
Status: Not included because dementia population not randomized to treatment
Citrin R S, Dixon D N. Reality Orientation: A Milieu Therapy Used in an Institution for the Aged. Gerontologist. 1977;17(1):39-43. [pmid: 844707].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Clair AA, Bernstein B. Effect of no music, stimulative background music and sedative background music on agitated behaviors in persons with severe dementia. Activities Adaptation Aging 1994; (1):61–70.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Clair AA. Effect of singing on alert responses in persons with late stage dementia. J Music Ther 1996; (No. 4):234–47.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Clark L R, Fraaza V, Schroeder S, et al. Alternative nursing environments: Do they affect hospital outcomes?. J Gerontol Nurs. Nov. 1995;21(11):32-8. [pmid: 7594255].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Clark M E, Lipe A W, Bilbrey M. Use of music to decrease aggressive behaviors in people with dementia. J Gerontol Nurs. Jul. 1998;24(7):10-7. [pmid: 9801526].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Claus J J, Ludwig C, Mohr E, et al. Nootropic drugs in Alzheimer's disease: Symptomatic treatment with pramiracetam. Neurology. Apr. 1991;41(4):570-4. [pmid: 2011259].
Status: Cross-over trial;
Claus J J, Mohr E, Chase T N. Clinical trials in dementia: Learning effects with repeated testing. J Psychiatry Neurosci. Mar. 1991;16(1):1-4. [pmid: 2049365]. [pmcid: 1188280].
Status: Not included because does not meet criteria for treatment for dementia patients
Claus JJ, van Harksamp F, de K, I, et al. Serotonergic mechanisms in Alzheimer's disease: Preliminary results of a controlled clinical trial with lisuride. Can J Neurol Sci 1993; Vol 20:126.
Status: Not included because not a full article
Clifford D B, McArthur J C, Schifitto G, et al. A randomized clinical trial of CPI-1189 for HIV-associated cognitive-motor impairment. Neurology. Nov 26. 2002;59(10):1568-73. [pmid: 12451199].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Clipp E C, Moore M J. Caregiver time use: an outcome measure in clinical trial research on Alzheimer's disease. Clin Pharmacol Ther. Aug. 1995;58(2):228-36. [pmid: 7648773].
Status: Not included because Jadad Quality Scale score less than three
Cole M G, McCusker J, Bellavance F, et al. Systematic detection and multidisciplinary care of delirium in older medical inpatients: a randomized trial. CMAJ. Oct 1. 2002;167(7):753-9. [pmid: 12389836]. [pmcid: 126506].
Status: Not included because does not meet criteria for treatment for dementia patients
Colling K B, Buettner L L. Simple pleasures. Interventions from the need-driven Dementia-Compromised Behavior model. J Gerontol Nurs. Oct. 2002;28(10):16-20. [pmid: 12382455].
Status: Not included because does not meet criteria for treatment for dementia patients
Comelli M, Lucca U, Spagnoli A. Statistical analysis of the clinical trial of a therapy for Alzheimer's disease. Univariate tests and logistic regression. Acta Neurol (Napoli). Jun. 1990;12(3):222-30. [pmid: 2206016].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Commissaris K, Verhey F R, Jolles J. A controlled study into the effects of psychoeducation for patients with cognitive disturbances. J Neuropsychiatry Clin Neurosci. 1996;8(4):429-35. [pmid: 9116480].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Conti L, Re F, Lazzerini F, et al. Glycosaminoglycan polysulfate (Ateroid) in old-age dementias: Effects upon depressive symptomatology in geriatric patients. Prog Neuropsychopharmacol Biol Psychiatry. 1989;13(6):977. [pmid: 2479052].
Status: Not included because Jadad Quality Scale score less than three
Convit A, de Asis J, de Leon M J, et al. Atrophy of the medial occipitotemporal, inferior, and middle temporal gyri in non-demented elderly predict decline to Alzheimer's disease. Neurobiol Aging. Jan. 2000;21(1):19-26. [pmid: 10794844].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cook W A. Methylperiodol: Clinical trials of a new tranquilizer. Med J Aust. Jul 16. 1966;2(3):117-9. [pmid: 5328539].
Status: Not included because dementia population not randomized to treatment
Cools R, Barker R A, Sahakian B J, et al. Enhanced or impaired cognitive function in Parkinson's disease as a function of dopaminergic medication and task demands. Cereb Cortex. Dec. 2001;11(12):1136-43. [pmid: 11709484].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cooney C, Mortimer A, Smith A, et al. Carbamazepine use in aggressive behaviour associated with senile dementia. Int J Geriatr Psychiatry. 1996;11(10):901-5.
Status: Cross-over trial;
Cooper AJ, Wong YT, Packer H. A controlled trial of cosaldon in arteriosclerotic dementia: Penicillin versus penicillin-malaria in the treatment of dementia paralytica. British Journal Of Psychiatry: British Journal of Venereal Diseases 1964; 25(1):415–8, 439.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cooper A J, Magnus R V. A placebo-controlled study of pyritinol (‘Encephabol’) in dementia. Pharmatherapeutica. 1980;2(5):317-22. [pmid: 7001490].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cooper J A, Sagar H J, Doherty S M, et al. Different effects of dopaminergic and anticholinergic therapies on cognitive and motor function in Parkinson's disease. Brain. 1992;115(6):1701-25. [pmid: 1486457].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Corbeil R R, Quayhagen M P, Quayhagen M. Intervention effects on dementia caregiving interaction: A stress-adaptation modeling approach. J Aging Health. Feb. 1999;11(1):79-95. [pmid: 10848143].
Status: Not included because does not meet criteria for treatment for dementia patients
Corcoran M A, Gitlin L N. Family caregiver acceptance and use of environmental strategies provided in an occupational therapy intervention. Phys Occup Ther Geriatr. 2001;19(1):1-20.
Status: Not included because does not meet criteria for treatment for dementia patients
Corona G L, Cucchi M L, Frattini P, et al. Clinical and biochemical responses to therapy in Alzheimer's disease and multi-infarct dementia. Eur Arch Psychiatry Neurol Sci. 1989;239(2):79-86. [pmid: 2478368].
Status: Not included because Jadad Quality Scale score less than three
Corrigan F M, Van Rhijn A, Horrobin D F. Essential fatty acids in Alzheimer's disease. Ann N Y Acad Sci. 1991;Vol 640:250-2. [pmid: 1776746].
Status: Not included because no extractable data relevant to review
Cott C A, Dawson P, Sidani S, et al. The effects of a walking/talking program on communication, ambulation, and functional status in residents with Alzheimer's disease. Alzheimer Dis Assoc Disord. 2002;16(2):81-7. [pmid: 12040303].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Coull J T, Sahakian B J, Hodges J R. The alpha(2) antagonist idazoxan remediates certain attentional and executive dysfunction in patients with dementia of frontal type. Psychopharmacologia. Feb. 1996;123(3):239-49.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Covington J S. Alleviating agitation, apprehension, and related symptoms in geriatric patients: A double-blind comparison of a phenothiazine and a benzodiazepien. South Med Assoc J. Jun. 1975;68(6):719-24.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cowan P. “Special care” for dementia patients. Can Nurse. Jun. 1999;95(6):49-50. [pmid: 10624221].
Status: Not included because dementia population not randomized to treatment
Cowley L M, Glen R S. Double-blind study of thioridazine and haloperidol in geriatric patients with a psychosis associated with organic brain syndrome. J Clin Psychiatry. Oct. 1979;40(10):411-9. [pmid: 489517].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cox J R. Double-blind evaluation of naftidrofuryl in treating elderly confused hospitalised patients. Gerontol Clin (Basel). 1975;17(3):160-7. [pmid: 1102394].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cox JR, Shaw AM. Controlled trial of naftidrofuryl in dementia in old age. J Clin Exp Gerontol 1981; (4):339–43.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Coyle J, Kershaw P. Galantamine, a cholinesterase inhibitor that allosterically modulates nicotinic receptors: Effects on the course of Alzheimer's disease. Biol Psychiatry. 2001;49(3):289-99. [pmid: 11230880].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Coyne AC, Potenza M, Broken-Nose MA. Caregiving and dementia: The impact of telephone helpline services. Am J Alzheimers Dis 1995 Jul; (4):27–32.
Status: Not included because does not meet criteria for treatment for dementia patients
Coyne M L, Hoskins L. Improving eating behaviors in dementia using behavioral strategies. Clin Nurs Res. Aug. 1997;6(3):275-90. [pmid: 9281930].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Craft S, Asthana S, Newcomer J W, et al. Enhancement of memory in Alzheimer disease with insulin and somatostatin, but not glucose. Arch Gen Psychiatry. Dec. 1999;56(12):1135-40. [pmid: 10591291].
Status: Not included because dementia population not randomized to treatment
Crook T H. A 6-month, double-blind, placebo-controlled trial of nicergoline in patients with mild to moderate probable Alzheimer's disease. J Neural Transm Gen Sect. 2000;107:XVIII.
Status: Not included because not a full article
Crook T, Ferris S, Sathananthan G, et al. The effect of methylphenidate on test performance in the cognitively impaired aged. Psychopharmacologia. May 9. 1977;52(3):251-5.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Crook T H, Tinklenberg J, Yesavage J, et al. Effects of phosphatidylserine in age-associated memory impairment. Neurology. May. 1991;41(5):644-9. [pmid: 2027477].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Crook T H. Nicergoline in the treatment of probable Alzheimer's disease: Preliminary results of a double-blind, randomized, placebo-controlled study. JNS. 1997;150(Suppl 1):S18.
Status: Not included because not a full article
Cucinotta D, Passeri M, Ventura S, et al. Multicenter clinical placebo-controlled study with acetyl-l-carnitine (LAC) in the treatment of mildly demented elderly patients. Drug Dev Res. 1988;14(34):213-4.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cui Y. Anti-senility potential of Zusanli. Int J Clin Acupunct. 1995;6(1):1-4.
Status: Not included because dementia population not randomized to treatment
Culebras A. Effect of papaverine on cerebral electrogenesis. Neurology. Jul. 1976;26(7):673-9. [pmid: 778656].
Status: Not included because does not meet criteria for treatment for dementia patients
Cummings J L, Gorman D G, Shapira J. Physostigmine ameliorates the delusions of Alzheimer's disease. Biol Psychiatry. Apr 1. 1993;33(7):536-41. [pmid: 8513039].
Status: Not included because dementia population not randomized to treatment
Cummings J L, Knopman D. Advances in the treatment of behavioral disturbances in Alzheimer's disease. Neurology. 2000;53(5):899. [pmid: 10496242].
Status: Not included because not a full article
Cummings J L, Nadel A, Masterman D, et al. Efficacy of metrifonate in improving the psychiatric and behavioral disturbances of patients with Alzheimer's disease. J Geriatr Psychiatry Neurol. 2001;14(2):101-8. [pmid: 11419566].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cummings J L, Street J, Masterman D, et al. Efficacy of olanzapine in the treatment of psychosis in dementia with lewy bodies. Dement Geriatr Cogn Disord. 2002;13(2):67-73. [pmid: 11844887].
Status: Not included because Jadad Quality Scale score less than three
Curless R, James O F W, McKeith I, et al. Effects of propranolol on aggressive behaviour in elderly patients with dementia. Age Ageing. 1994;23:P19.
Status: Not included because not a full article
Curtis-Prior P, Vere D, Fray P. Therapeutic value of Ginkgo biloba in reducing symptoms of decline in mental function. J Pharm Pharmacol. May. 1999;51(5):535-41. [pmid: 10411212].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cutler N R, Haxby J, Kay A D, et al. Evaluation of zimeldine in Alzheimer's disease. Cognitive and biochemical measures. Arch Neurol. Aug. 1985;42(8):744-8. [pmid: 2411246].
Status: Cross-over trial;
Cutler N R, Haxby J V, Narang P K, et al. Evaluation of an analogue of somatostatin (L363,586) in Alzheimer's disease. N Engl J Med. Mar. 1985;312(11):725. [pmid: 2858052].
Status: Not included because not a full article
Cutler N R, Murphy M F, Nash R J, et al. Clinical safety, tolerance, and plasma levels of the oral anticholinesterase 1,2,3,4-tetrahydro-9-aminoacridin-1-oL-maleate (HP 029) in Alzheimer's disease: Preliminary findings. J Clin Pharmacol. Jun. 1990;30(6):556-61. [pmid: 2355106].
Status: Not included because no extractable data relevant to review
Cutler N R, Sramek J J, Murphy M F, et al. Implications of the study population in the early evaluation of anticholinesterase inhibitors for Alzheimer's disease. Ann Pharmacother. Sep. 1992;26(9):1118-22. [pmid: 1421679].
Status: Not included because no extractable data relevant to review
Cutler N R, Sramek J J, Murphy M F, et al. Alzheimer's patients should be included in phase I clinical trials to evaluate compounds for Alzheimer's disease. J Geriatr Psychiatry Neurol. Oct. 1992;5(4):192-4. [pmid: 1418362].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Cutler N R, Fakouhi T D, Smith W T, et al. Evaluation of multiple doses of milacemide in the treatment of senile dementia of the Alzheimer's type. J Geriatr Psychiatry Neurol. Apr. 1993;6(2):115-9. [pmid: 8512628].
Status: Not included because Jadad Quality Scale score less than three
Cutler N R, Sramek J J, Anand R. Safety and tolerance of ENA 713 in patients with alzheimer's disease. Biol Psychiatry. 1995;37(9):643.
Status: Not included because not a full article
Cutler N R, Sramek J J, Viereck C, et al. Tolerability and pharmacodynamics of besipirdine in Alzheimer's disease. Biol Psychiatry. 1995;37(9):643.
Status: Not included because not a full article
Cutler N R, Polinsky R J, Sramek J J, et al. Dose-dependent CSF acetylcholinesterase inhibition by SDZ ENA 713 in Alzheimer's disease. Acta Neurol Scand. Apr. 1998;97(4):244-50. [pmid: 9576639].
Status: Not included because dementia population not randomized to treatment
Cutler N R, Jhee S S, Cyrus P, et al. Safety and tolerability of metrifonate in patients with Alzheimer's disease: Results of a maximum tolerated dose study. Life Sci. 1998;62(16):1433-41. [pmid: 9585171].
Status: Not included because dementia population not randomized to treatment
Czerwinski A W, Clark M L, Serafetinides E A, et al. Safety and efficacy of zinc sulfate in geriatric patients. Clin Pharmacol Ther. Apr. 1974;15(4):436-41. [pmid: 4595292].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Daniele A, Moro E, Bentivoglio A R. Zolpidem in progressive supranuclear palsy. N Engl J Med. Aug 12. 1999;341(7):543-4. [pmid: 10447452].
Status: Not included because not a full article
Daniels L. A group cognitive-behavioural and process-oriented approach to treating the social impairment and negative symptoms associated with chronic mental illness. J Psychother Pract Res 1998; 7167–76.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Dansky K H, Dellasega C, Shellenbarger T, et al. After hospitalization: Home health care for elderly persons. Clin Nurs Res. May. 1996;5(2):185-98. [pmid: 8704665].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Danysz W. CX-516 Cortex Pharmaceuticals Inc. Idrugs. 1999;2(8):814-22. [pmid: 16127658].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Darreh-Shori T, Almkvist O, Guan Z Z, et al. Sustained cholinesterase inhibition in AD patients receiving rivastigmine for 12 months. Neurology. Aug 27. 2002;59(4):563-72. [pmid: 12196650].
Status: Not included because dementia population not randomized to treatment
Davidson M, Mohs R C, Hollander E, et al. Lecithin and piracetam in Alzheimer's disease. Biol Psychiatry. 1987;22(1):112-4. [pmid: 3651528].
Status: Not included because not a full article
Davidson M, Zemishlany Z, Mohs R C, et al. 4-Aminopyridine in the treatment of Alzheimer's disease. Biol Psychiatry. Mar 1. 1988;23(5):485-90. [pmid: 2830918].
Status: Cross-over trial;
Davies AE. A pilot study to measure aluminium levels in hair samples of patients with dementia and the influence of aluminium 30c compared with placebo. Communications of the British Homoeopathy Research Group Issue 18, 1988; 42–6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Davies B, Andrewes D, Stargatt R, et al. Tacrine in Alzheimer's disease. Lancet. Jul 15. 1989;2(8655):163-4. [pmid: 2567933].
Status: Not included because not a full article
Davies B, Andrewes D, Stargatt R, et al. Tetrahydroaminoacridine in Alzheimer's disease. Int J Geriatr Psychiatry. 1990;5(5):317-21.
Status: Cross-over trial;
Davies G, Hamilton S, Hendrickson E, et al. The effect of cyclandelate in depressed and demented patients: A controlled study in psychogeriatric patients. Age Ageing. Aug. 1977;6(3):156-62. [pmid: 331919].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Davies G. Drugs for dementia. Modern Geriatrics. 1978;8(1):56.
Status: Not included because not a full article
Davis K J, Sloane P D, Mitchell C M, et al. Specialized dementia programs in residential care settings. Gerontologist. Feb. 2000;40(1):32-42. [pmid: 10750311].
Status: Not included because does not meet criteria for treatment for dementia patients
Davis K L, Mohs R C. Enhancement of memory processes in Alzheimer's disease with multiple-dose intravenous physostigmine. Am J Psychiatry. 1982;139(11):1421-4. [pmid: 6753611].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Davis K L, Mohs R C, Davis B M, et al. Oral physostigmine in Alzheimer's disease. Psychopharmacol Bull. 1983;19(3):451-3. [pmid: 6635123].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Davis K L, Thal L J, Gamzu E R, et al. A double-blind, placebo-controlled multicenter study of tacrine for Alzheimer's disease. N Engl J Med. 1992;327(18):1253-9. [pmid: 1406817].
Status: Not included because Jadad Quality Scale score less than three
Davis K L, Yang R K, Davidson M, et al. Alzheimer's disease: Tacrine and tacrine metabolite concentrations in plasma and cognitive change. Drug Dev Res. 1995;34(1):55-65.
Status: Not included because Jadad Quality Scale score less than three
Davis R N, Massman P J, Doody R S. Cognitive intervention in Alzheimer disease: A randomized placebo-controlled study. Alzheimer Dis Assoc Disord. Jan. 2001;15(1):1-9. [pmid: 11236819].
Status: Not included because does not meet criteria for treatment for dementia patients
Dawson P, Kontos P. Nursing assistants reduce aggressive behaviour during bathing cognitively impaired nursing home residents. Perspectives (Montclair). 1998;22(2):20.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Dawson P. Bright light treatment for people with Alzheimer's disease. Perspectives (Montclair). 1999;23(1):25-6.
Status: Not included because dementia population not randomized to treatment
Day J J, Grant I, Atkinson J H, et al. Incidence of AIDS dementia in a two-year follow-up of AIDS and ARC patients on an initial phase II AZT placebo-controlled study: San Diego cohort. J Neuropsychiatry Clin Neurosci. 1992;4(1):15-20. [pmid: 1627957].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
de Boer J B, van Dam F S, Sprangers M A, et al. Longitudinal study on the Quality of Life of symptomatic HIV-infected patients in a trial of zidovudine versus zidovudine and interferon-alpha. AIDS. Jul. 1993;7(7):947-53. [pmid: 8357556].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
De Deyn PP, Scheltens P, Kittner B. A double-blind placebo-controlled trial assessing the effects of propentofylline in patient's with Alzheimer's disease and vascular dementia: safety, efficacy, and impact on disease progression. Alzheimers Rep 1999; (2):51.
Status: Not included because not a full article
De Deyn P P, Rabheru K, Rasmussen A. Neuroleptic for behavioral symptoms of dementia. J Fam Pract. 2000;49(1):28-9. [pmid: 10678345].
Status: Not included because not a full article
DeLuca J, Johnson S K, Ellis S P, et al. Cognitive functioning is impaired in patients with chronic fatigue syndrome devoid of psychiatric disease. J Neurol Neurosurg Psychiatry. 1997;62(2):151-5. [pmid: 9048715].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Delwaide P J, Hurlet A. Bromocriptine and buccolinguofacial dyskineasias in patients with senile dementia. A quantitative study. Arch Neurol. Jul. 1980;37(7):441-3. [pmid: 7387491].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Delwaide PJ, Devoitille JM, Ylieff M. Acute effect of drugs upon memory of patients with senile dementia. Acta Psychiatr Belg 1980; 748–54.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Delwaide P J, Gyselynck-Mambourg A M, Hurlet A, et al. Double-blind randomized controlled study of phosphatidylserine in senile demented patients. Acta Neurol Scand. Feb. 1986;73(2):136-40. [pmid: 3518329].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Dencker SJ, Lindberg D. A controlled double blind study of piracetam in the treatment of senile dementia. Nord J Psychiatry 1977; (1):48–52.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Denney A. Quiet music. An intervention for mealtime agitation?. J Gerontol Nurs. Jul. 1997;23(7):16-23. [pmid: 9287602].
Status: Not included because dementia population not randomized to treatment
Denolle T, Sassano P, Allain H, et al. Effects of nicardipine and clonidine on cognitive functions and electroencephalography in hypertensive patients. Fundam Clin Pharmacol. 2002;16(6):527-35. [pmid: 12685512].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Derouesne C, Renault B, Gueguen B, et al. Neuropsychophysiological evaluation of three doses of S 12024-2 in mild-to-moderate Alzheimer's disease. Clin Drug Investig 1997; (4):301–6.
Status: Cross-over trial;
Desai A, Grossberg G. Review of rivastigmine and its clinical applications in Alzheimer's disease and related disorders. Expert Opin Pharmacother. 2001;2(4):653-66. [pmid: 11336614].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
desRosiers G, Hodges J R, Berrios G. The neuropsychological differentiation of patients with very mild Alzheimer's disease and/or major depression. J Am Geriatr Soc. Nov. 1995;43(11):1256-63. [pmid: 7594160].
Status: Not included because does not meet criteria for treatment for dementia patients
Devanand D P, Sackeim H A, Brown R P, et al. A pilot study of haloperidol treatment of psychosis and behavioral disturbance in Alzheimer's disease. Arch Neurol. 1989;46(8):854-7. [pmid: 2667504].
Status: Not included because dementia population not randomized to treatment
Devanand D P, Cooper T, Sackeim H A, et al. Low dose oral haloperidol and blood levels in Alzheimer's disease: A preliminary study. Psychopharmacol Bull. 1992;28(2):169-73. [pmid: 1513920].
Status: Not included because Jadad Quality Scale score less than three
Devanand D P, Marder K, Michaels K S, et al. A randomized, placebo-controlled dose-comparison trial of haloperidol for psychosis and disruptive behaviors in Alzheimer's disease. Am J Psychiatry. Nov. 1998;155(11):1512-20. [pmid: 9812111].
Status: Cross-over trial;
di Bari M, Pahor M, Franse L V, et al. Dementia and disability outcomes in large hypertension trials: Lessons learned from the systolic hypertension in the elderly program (SHEP) trial. Am J Epidemiol. 2001;153(1):72-8. [pmid: 11159149].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Di Perri R, Coppola G, Ambrosio L A, et al. A multicentre trial to evaluate the efficacy and tolerability of alpha-glycerylphosphorylcholine versus cytosine diphosphocholine in patients with vascular dementia. J Int Med Res. Jul. 1991;19(4):330-41. [pmid: 1916007].
Status: Not included because Jadad Quality Scale score less than three
Dick M B, Nielson K A, Beth R E, et al. Acquisition and long-term retention of a fine motor skill in Alzheimer's disease. Brain Cogn. Dec. 1995;29(3):294-306. [pmid: 8838387].
Status: Not included because does not meet criteria for treatment for dementia patients
Dierks T, Maurer K, Ihl R. Influence of tenilsetam on AEP-P300 in Alzheimer's disease. J Neural Transm Gen Sect. 1989;1:49.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ditzler K. Efficacy and tolerability of memantine in patients with dementia syndrome. A double-blind, placebo controlled trial. Arzneimittelforschung. Aug. 1991;41(8):773-418. [pmid: 1781796].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Diwan S, Phillips V L. Agitation and dementia-related problem behaviors and case management in long-term care. Int Psychogeriatr. 2001;13(1):5-21. [pmid: 11352334].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Djernes J K, Gulmann N C, Abelskov K E, et al. Psychopathologic and functional outcome in the treatment of elderly inpatients with depressive disorders, dementia, delirium and psychoses. Int Psychogeriatr. Mar. 1998;10(1):71-83. [pmid: 9629526].
Status: Not included because does not meet criteria for treatment for dementia patients
Dominguez D, De C C L, Gomensoro J, et al. Modification of psychometric, practical and intellectual parameters in patients with diffuse cerebrovascular insufficiency during prolonged treatment with pentoxifylline: A double blind, placebo controlled trial. Pharmatherapeutica. 1977;1(8):498-506.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Doody R S, Dunn J K, Clark C M, et al. Chronic donepezil treatment is associated with slowed cognitive decline in Alzheimer's disease. Dement Geriatr Cogn Disord. Jul. 2001;12(4):295-300. [pmid: 11351141].
Status: Not included because dementia population not randomized to treatment
Doraiswamy P M, Kaiser L, Bieber F, et al. The Alzheimer's Disease Assessment Scale: Evaluation of psychometric properties and patterns of cognitive decline in multicenter clinical trials of mild to moderate Alzheimer's disease. Alzheimer Dis Assoc Disord. Oct. 2001;15(4):174-83. [pmid: 11723368].
Status: Not included because does not meet criteria for treatment for dementia patients
Doraiswamy P M, Krishen A, Stallone F, et al. NSAIDs and cognition in Alzheimer's disease. Neurology. 1996;46(4):1194. [pmid: 8780138].
Status: Not included because not a full article
Droes R M, Breebaart E, Ettema T P, et al. Effect of integrated family support versus day care only on behavior and mood of patients with dementia. Int Psychogeriatr. 2000;12(1):99-115. [pmid: 10798457].
Status: Not included because does not meet criteria for treatment for dementia patients
Duffy F H, McAnulty G, Albert M, et al. Lecithin: Absence of neurophysiologic effect in Alzheimer's disease by EEG topography. Neurology. Jun. 1987;37(6):1015-9. [pmid: 3587619].
Status: Not included because no extractable data relevant to review
Dunn J C, Thiru-Chelvam B, Beck C H. Bathing. Pleasure or pain?. J Gerontol Nurs. Nov. 2002;28(11):6-13. [pmid: 12465197].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Duret M, Goldman S, Messina D, et al. Effect of L-dopa on dementia-related rigidity. Acta Neurol Scand. Jul. 1989;80(1):64-7. [pmid: 2782043].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Durso R, Fedio P, Brouwers P. Lysine vasopressin in Alzheimer's disease. Neurology. 1982;32(6):674-7. [pmid: 7201100].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Dykierek P, Stadtmuller G, Schramm P, et al. The value of REM sleep parameters in differentiating Alzheimer's disease from old-age depression and normal aging. J Psychiatr Res. Jan. 1998;32(1):1-9. [pmid: 9693995].
Status: Not included because does not meet criteria for treatment for dementia patients
Dysken M, Kuskowski M, Love S, et al. Ondansetron in the treatment of cognitive decline in Alzheimer's dementia. Am J Geriatr Psychiatry. Mar. 2002;10(2):212-5. [pmid: 11925283].
Status: Not included because Jadad Quality Scale score less than three
Dysken M W, Anton J S, Klein L, et al. Cl-911: A placebo-controlled study in patients with primary degenerative dementia. Drug Dev Res. 1988;12(34):267-4.
Status: Cross-over trial;
Dysken M W, Mendels J, Lewitt P, et al. Milacemide: a placebo-controlled study in senile dementia of the Alzheimer type. J Am Geriatr Soc. May. 1992;40(5):503-6. [pmid: 1634705].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Dysken M W, Johnson S B, Holden L, et al. Haloperidol concentrations in patients with Alzheimer's dementia. Am J Geriatr Psychiatry. 1994;2(2):124-33.
Status: Not included because Jadad Quality Scale score less than three
Eagger S, Levi I. Serum levels of tacrine in relation to clinical response in Alzheimer's disease. Int J Geriatr Psychiatry. 1992a;7(2):115-9.
Status: Cross-over trial;
Eagger S, Morant N, Levy R, et al. Tacrine in Alzheimer's disease. Time course of changes in cognitive function and practice effects. Br J Psychiatry. 1992b;160:36-40. [pmid: 1544011].
Status: Cross-over trial;
Eagger S. Searching for a treatment for Alzheimer's disease - tales from the cutting-room floor. Int J Geriatr Psychiatry. 1996;11(4):337-42.
Status: Not included because dementia population not randomized to treatment
Eagger S A, Levy R, Sahakian B J. Tacrine in Alzheimer's disease. Lancet. Apr 27. 1991;337(8748):989-92. [pmid: 1676097].
Status: Cross-over trial;
Eagger S A, Levy R, Sahakian B J. Tacrine in Alzheimer's disease. Acta Neurol Scand Suppl. 1992;139:75-80. [pmid: 1414271].
Status: Cross-over trial;
Eaton M, Mitchell-Bonair I L, Friedmann E. The effect of touch on nutritional intake of chronic organic brain syndrome patients. J Gerontol. Sep. 1986;41(5):611-6. [pmid: 3528273].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ebmeier K P, Hunter R, Curran S M, et al. Effects of a single dose of the acetylcholinesterase inhibitor velnacrine on recognition memory and regional cerebral blood flow in Alzheimer's disease. Psychopharmacologia. 1992;108(12):103-2.
Status: Cross-over trial;
Edberg A, Hallberg I R. Actions seen as demanding in patients with severe dementia during one year of intervention. Comparison with controls. Int J Nurs Stud. Jun. 2001;38(3):271-85. [pmid: 11245864].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Edberg A K, Hallberg I R. Effects of clinical supervision on nurse-patient cooperation quality: A controlled study in dementia care. Clin Nurs Res. May. 1996;5(2):127-46. [pmid: 8704662].
Status: Not included because does not meet criteria for treatment for dementia patients
Edberg AK, Norberg A, Hallberg I. Mood and general behavior of patients with severe dementia during one year of supervised, individualized planned care and systematic clinical supervision: Comparison with a similar control group. Aging Clin Exp Res 1999; (6):395–403.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Edwards N E, Beck A M. Animal-assisted therapy and nutrition in Alzheimer's disease. West J Nurs Res. Oct. 2002;24(6):697-712. [pmid: 12365769].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ellingrod V L, Schultz S K, Ekstam-Smith K, et al. Comparison of risperidone with olanzapine in elderly patients with dementia and psychosis. Pharmacotherapy. Jan. 2002;22(1):1-5. [pmid: 11794418].
Status: Not included because dementia population not randomized to treatment
Eloniemi-Sulkava U, Notkola I L, Hentinen M, et al. Effects of supporting community-living demented patients and their caregivers: A randomized trial. J Am Geriatr Soc. Oct. 2001;49(10):1282-7. [pmid: 11890485].
Status: Not included because does not meet criteria for treatment for dementia patients
Engel R R, Satzger W, Gunther W, et al. Double-blind cross-over study of phosphatidylserine vs. placebo in patients with early dementia of the Alzheimer type. Eur Neuropsychopharmacol. Jun. 1992;2(2):149-55. [pmid: 1633433].
Status: Cross-over trial;
Engelberts N H, Klein M, Ader H J, et al. The effectiveness of cognitive rehabilitation for attention deficits in focal seizures: A randomized controlled study. Epilepsia. 2002;43(6):587-95. [pmid: 12060017].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Etienne P, Dastoor D, Gauthier S. Alzheimer's disease: Lack of effect of lecithin treatment for 3 months. Neurology. 1981;31(12):1552-4. [pmid: 7198209].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
European Propentofylline Study Group. Propentofylline in dementia (vascular dementia and Alzheimer's disease). Cardiovasc Dis. 1994;4:258.
Status: Not included because not a full article
Evans M, Hammond M, Wilson K, et al. Treatment of depression in the elderly: Effect of physical illness on response. Int J Geriatr Psychiatry. Dec. 1997;12(12):1189-94. [pmid: 9444543].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Evans M, Ellis A, Watson D, et al. Sustained cognitive improvement following treatment of Alzheimer's disease with donepezil. Int J Geriatr Psychiatry. Jan. 2000;15(1):50-3. [pmid: 10637404].
Status: Not included because dementia population not randomized to treatment
Evers S, Grotemeyer K H, Reichelt D, et al. Impact of antiretroviral treatment on AIDS dementia: A longitudinal prospective event-related potential study. J Acquir Immune Defic Syndr Hum Retrovirol. Feb 1. 1998;17(2):143-8. [pmid: 9473015].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fakouhi T D, Jhee S S, Sramek J J, et al. Evaluation of cycloserine in the treatment of Alzheimer's disease. J Geriatr Psychiatry Neurol. Oct. 1995;8(4):226-30. [pmid: 8561836].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Falsaperla A, Monici Preti P A, Oliani C. Selegiline versus oxiracetam in patients with Alzheimer-type dementia. Clin Ther. Sep. 1990;12(5):376-84. [pmid: 2125242].
Status: Not included because Jadad Quality Scale score less than three
Farina E, Fioravanti R, Chiavari L, et al. Comparing two programs of cognitive training in Alzheimer's disease: A pilot study. Acta Neurol Scand. May. 2002;105(5):365-71. [pmid: 11982487].
Status: Not included because does not meet criteria for treatment for dementia patients
Farlow M, Gracon S I, Hershey L A, et al. A controlled trial of tacrine in Alzheimer's disease. The Tacrine Study Group. JAMA. Nov 11. 1992;268(18):2523-9. [pmid: 1404819].
Status: Not included because Jadad Quality Scale score less than three
Farlow M, Brashear A, Hiu S, et al. The effects of tacrine in patients with mild versus moderate stage Alzheimer's disease. In: Iqbal K, editors. Research Advances in Alzheimer's disease and related disorders, Chichester: John Wiley & Sons; 1995. p. 283–92.
Status: Not included because not a full article
Farlow M R, Lahiri D K, Poirier J, et al. Apolipoprotein E genotype and gender influence response to tacrine therapy. Ann N Y Acad Sci. 1996;802(Dec 16):101-10. [pmid: 8993489].
Status: Not included because Jadad Quality Scale score less than three
Farlow M R, Cyrus P A, Nadel A, et al. Metrifonate treatment of AD: Influence of APOE genotype. Neurology. Dec 10. 1999;53(9):2010-6. [pmid: 10599773].
Status: Not included because dementia population not randomized to treatment
Farlow M R, Cyrus P A. Metrifonate therapy in Alzheimer's disease: A pooled analysis of four randomized, double-blind, placebo-controlled trials. Dement Geriatr Cogn Disord. Jul. 2000;11(4):202-11. [pmid: 10867446].
Status: Not included because dementia population not randomized to treatment
Faxen-Irving G, Andren-Olsson B, af GA, et al. The effect of nutritional intervention in elderly subjects residing in group-living for the demented. Eur J Clin Nutr 2002 Mar, 56(3):221–7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Feldman H, Gauthier S, Hecker J, et al. Benefits of Donepezil on global function, behavior, cognition and ADLs in patients with moderate to severe Alzheimer's disease. Neurology. 2000;54(Suppl 3):A469. [pmid: 10668716].
Status: Not included because not a full article
Feldman H, Sauter A, Donald A, et al. The disability assessment for dementia scale: A 12-month study of functional ability in mild to moderate severity Alzheimer's disease. Alzheimer Dis Assoc Disord. Apr. 2001;15(2):89-95. [pmid: 11391090].
Status: Not included because does not meet criteria for treatment for dementia patients
Fenn P, Gray A. Estimating long-term cost savings from treatment of Alzheimer's disease. A modelling approach. Pharmacoeconomics. Aug. 1999;16(2):165-74. [pmid: 10539397].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fernandez H H, Trieschmann M E, Burke M A, et al. Quetiapine for psychosis in Parkinson's disease versus dementia with Lewy bodies. J Clin Psychiatry. Jun. 2002;63(6):513-5. [pmid: 12088163].
Status: Not included because dementia population not randomized to treatment
Ferris S H, Sathananthan G, Gershon S, et al. Cognitive effects of ACTH 4–10 in the elderly. Pharmacol Biochem Behav. 1976;5(Suppl 1):73-8. [pmid: 189334].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ferris S H, Mittelman M S. Behavioral treatment of Alzheimer's disease. Int Psychogeriatr. 1996;8(Suppl 1):87-90. [pmid: 8934272].
Status: Not included because no extractable data relevant to review
Fichter M M, Bruce M L, Schroppel H, et al. Cognitive impairment and depression in the oldest old in a German and in U.S. communities. Eur Arch Psychiatry Clin Neurosci. 1995;245(6):319-25. [pmid: 8527469].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Filip V, David I, Klatschka J, et al. Selegiline slows down the decline of cognitive and electrophysiological functions in Alzheimer's disease. Basic and clinical science of mental and additive disorders. Bibl Psychiatr 1997; 238–40.
Status: Not included because not a full article
Finali G, Piccirilli M, Oliani C, et al. L-deprenyl therapy improves verbal memory in amnesic Alzheimer patients. Clin Neuropharmacol. Dec. 1991;14(6):523-36. [pmid: 1773423].
Status: Cross-over trial;
Finali G, Piccirilli M, Oliani C, et al. Alzheimer-type dementia and verbal memory performances: Influence of selegiline therapy. Ital J Neurol Sci. Mar. 1992;13(2):141-8. [pmid: 1592575].
Status: Cross-over trial;
Findlay D J, Sharma J, McEwen J, et al. Double-blind controlled withdrawal of thioridazine treatment in elderly female inpatients with senile dementia. Int J Geriatr Psychiatry. 1989;4(2):115-20.
Status: Not included because Jadad Quality Scale score less than three
Finkel S I, Lyons J S, Anderson R L, et al. A randomized, placebo-controlled trial of thiothixene in agitated, demented nursing home patients. Int J Geriatr Psychiatry. 1995;10(2):129-36.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Finkel SI, Lyons J. Nursing home research from investigators' perspective. Int Psychogeriatr 1996; 8(Suppl 3):371–3, 381–2.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fioravanti M, Bergamasco B, Bocola V, et al. A multicentre, double-blind, controlled study of piracetam vs placebo in geriatric patients with nonvascular mild-moderate impairment in cognition. New Trends in Clinical Neuropharmacology 1991; (1):27–34.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fioravanti M, Di Cesare F. Memory improvements and pharmacological treatment: A method to distinguish direct effects on memory from secondary effects due to attention improvement. Int Psychogeriatr. 1992;4(1):119-26. [pmid: 1391667].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fioravanti M, Ferrario E, Massaia M, et al. Low folate levels in the cognitive decline of elderly patients and the efficacy of folate as a treatment for improving memory deficits. Arch Gerontol Geriatr. 1997;26(1):1-13.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fischer, Gotz P. Blood transferrin and ferritin in Alzheimer's disease. Life Sci. 1997;60(25):2273-8. [pmid: 9194682].
Status: Not included because does not meet criteria for treatment for dementia patients
Fischhof P K, Saletu B, Ruther E, et al. Therapeutic efficacy of pyritinol in patients with senile dementia of the Alzheimer type (SDAT) and multi-infarct dementia (MID). Neuropsychobiology. 1992;26(12):65-2. [pmid: 1475039].
Status: Not included because Jadad Quality Scale score less than three
Fischhof P K. Divergent neuroprotective effects of nimodipine in PDD and MID provide indirect evidence of disturbances in Ca2+ homeostasis in dementia. Methods & Findings in Experimental & Clinical Pharmacology. Oct. 1993;15(8):549-55. [pmid: 7794292].
Status: Not included because Jadad Quality Scale score less than three
Fisman M, Merksey H, Helmes E. Double blind study of lecithin in patients with Alzheimer's disease. Can J Psychiatry 1981; (6):426–8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fisman M, Merskey H, Helmes E. Double-blind trial of 2-dimethylaminoethanol in Alzheimer's disease. Am J Psychiatry. 1981;138(7):970-2. [pmid: 7020434].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fitten L J, Perryman K M, Gross P L, et al. Treatment of Alzheimer's disease with short- and long-term oral THA and lecithin: A double-blind study. Am J Psychiatry. Feb. 1990;147(2):239-42. [pmid: 2405720].
Status: Cross-over trial;
Fitten L J, Ganzell S. Spouses' assessments of Alzheimer patients' response to THA and lecithin. Am J Psychiatry. 1992;149(4):575. [pmid: 1554054].
Status: Not included because not a full article
Fitzsimmons S, Buettner L L. Therapeutic recreation interventions for need-driven dementia-compromised behaviors in community-dwelling elders. Am J Alzheimers Dis Other Demen. 2002;17(6):367-81. [pmid: 12501484].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fleischhacker W W, Buchgeher A, Schubert H. Memantine in the treatment of senile dementia of the Alzheimer type. Prog Neuropsychopharmacol Biol Psychiatry. 1986;10(1):87-93. [pmid: 3517967].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Flicker C, Ferris S H, Kalkstein D, et al. A double-blind, placebo-controlled crossover study of ganglioside GM1 treatment for Alzheimer's disease. Am J Psychiatry. Jan. 1994;151(1):126-9. [pmid: 8267111].
Status: Cross-over trial;
Flicker L, Grimley EG. Piracetam for dementia or cognitive impairment. In: The Cochrane Library, 2001. Issue 2. Oxford: Update Software.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Folnegovic Smalc V, Knezevic S, Bokonjic R, et al. European pentoxifylline multi-infarct dementia trial: The epmid study. J Neurol. 1994;2(41):158.
Status: Not included because not a full article
Fontana R J, Turgeon D K, Woolf T F, et al. The caffeine breath test does not identify patients susceptible to tacrine hepatotoxicity. Hepatology. Jun. 1996;23(6):1429-35. [pmid: 8675160].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fontana R J, deVries T M, Woolf T F, et al. Caffeine based measures of CYP1A2 activity correlate with oral clearance of tacrine in patients with Alzheimer's disease. Br J Clin Pharmacol. Sep. 1998;46(3):221-8. [pmid: 9764962]. [pmcid: 1873677].
Status: Cross-over trial;
Food and Drug Administration. Tacrine as a treatment for Alzheimer's disease: Editor's note. An interim report from the FDA. A response from Summers et al. N Engl J Med. Jan 31. 1991;324(5):349-52. [pmid: 1986300].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ford J M, Truman C A, Wilcock G K, et al. Serum concentrations of tacrine hydrochloride predict its adverse effects in Alzheimer's disease. Clin Pharmacol Ther. 1993;53(6):691-5. [pmid: 8513661].
Status: Not included because dementia population not randomized to treatment
Forette F, Amery A, Staessen J, et al. Is prevention of vascular dementia possible? The Syst-Eur Vascular Demential Project. Aging (Milano). 1991;3(4):373-82. [pmid: 1841609].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Forette F, Hoover T, Gracon S, et al. A double-blind, placebo-controlled, enriched population study of tacrine in patients with Alzheimer's disease. Eur J Neurol. 1995;2:229-38.
Status: Not included because Jadad Quality Scale score less than three
Forette F, Seux M L, Staessen J A, et al. Prevention of dementia in randomised double-blind placebo-controlled Systolic Hypertension in Europe (Syst-Eur) trial. Lancet. Oct 24. 1998;352(9137):1347-51. [pmid: 9802273].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Forssell L G, Sjokvist B, Winblad B. Early stages of late onset Alzheimer's disease. III. Double blind treatment with choline chloride and lecithin with and without L-dopa and L-tryptophan, alternatively placebo. Acta Neurol Scand Suppl. 1989;79(121):43-66.
Status: Not included because dementia population not randomized to treatment
Forster D P, Newens A J, Kay D W, et al. Risk factors in clinically diagnosed presenile dementia of the Alzheimer type: A case-control study in northern England. J Epidemiol Commun Health. Jun. 1995;49(3):253-8.
Status: Not included because does not meet criteria for treatment for dementia patients
Foster H G, Hillbrand M, Chi C C. Efficacy of carbamazepine in assaultive patients with frontal lobe dysfunction. Prog Neuropsychopharmacol Biol Psychiatry. 1989;13(6):865. [pmid: 2813804].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Foster N L, Aldrich M S, Bluemlein L, et al. Failure of cholinergic agonist RS-86 to improve cognition and movement in PSP despite effects on sleep. Neurology. Feb. 1989;39(2 Pt 1):257-61. [pmid: 2644580].
Status: Cross-over trial;
Foster N L, Petersen R C, Gracon S I, et al. An enriched-population, double-blind, placebo-controlled, crossover study of tacrine and lecithin in Alzheimer's disease. Dementia. 1996;7(5):260-6. [pmid: 8872417].
Status: Cross-over trial;
Foster NA, Valentine ER. Effect of auditory stimulation on autobiographical recall in dementia. Exp Aging Res 2001 Jul; (3):215–28.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fovall P, Dysken M W, Lazarus L W. Choline bitartrate treatment of Alzheimer-type dementias. Commun Psychopharmacol. 1980;4(2):141-5. [pmid: 7428335].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Francese T. Research corner. The effects of regular exercise on muscle strength and functional abilities of late stage Alzheimer's residents. Va Nurse Today 1995; (4):25–6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Francese T, Sorrell J, Butler FR. The effects of regular exercise on muscle strength and functional abilities of late stage Alzheimer's residents. Am J Alzheimers Dis 1997; (3):122–7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Franciosi A, Zavattini G. Dihydroergocristine in the treatment of elderly patients with cognitive deterioration: A double-blind, placebo-controlled, dose- response study. Curr Ther Res Clin Exp. 1994;55(11):1391-401.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Frattola L, Piolti R, Bassi S, et al. Multicenter clinical comparison of the effects of choline alfoscerate and cytidine diphosphocholine in the treatment of multi-infarct dementia. Curr Ther Res Clin Exp. 1991;49(4):683-93.
Status: Not included because Jadad Quality Scale score less than three
Frattola L, Trabucchi H, Cucinotta D, et al. Dopamine agonist and free-radicals scavenger activities of dihydroergokryptine in dementia of alzheimer type (DAT): Multicentre, long-term double-blind clinical study versus placebo. J Neurol. 1994;241:159.
Status: Not included because not a full article
Frederick B, Satlin A, Wald L L, et al. Brain proton magnetic resonance spectroscopy in Alzheimer's disease: Changes after treatment with xanomeline. Am J Geriatr Psychiatry. Jan. 2002;10(1):81-8. [pmid: 11790638].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fric M, Horn R, Hasse S I, et al. Effects of nimodipine-treatment in primary degenerative dementia. Results of a clinical and psychometric study. Pharmacopsychiatry. 1995;28:177.
Status: Not included because not a full article
Friedman J I, Adler D N, Howanitz E, et al. Erratum: A double blind placebo controlled trial of donepezil adjunctive treatment to risperidone for the cognitive impairment of schizophrenia. Biol Psychiatry. 2002;51(12):1014. [pmid: 11904128].
Status: Not included because not a full article
Friedman J I, Adler D N, Howanitz E, et al. A double blind placebo controlled trial of donepezil adjunctive treatment to risperidone for the cognitive impairment of schizophrenia. Biol Psychiatry. Mar 1. 2002;51(5):349-57. [pmid: 11904128].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Friedman R, Tappen R M. The effect of planned walking on communication in Alzheimer's disease. J Am Geriatr Soc. Jul. 1991;39(7):650-4. [pmid: 2061529].
Status: Not included because does not meet criteria for treatment for dementia patients
Frisoni G B, Gozzetti A, Bignamini V, et al. Special care units for dementia in nursing homes: A controlled study of effectiveness. Arch Gerontol Geriatr. 1998;27(Suppl 6):215-24.
Status: Not included because dementia population not randomized to treatment
Frith C D, Stevens M, Johnstone E C, et al. Effects of ECT and depression on various aspects of memory. Br J Psychiatry. 1983;Vol 142(Jun):610-7. [pmid: 6882984].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fuglum E, Schillinger A, Andersen J B, et al. Zuclopenthixol and haloperidol/levomepromazine in the treatment of elderly patients with symptoms of aggressiveness and agitation: A double-blind, multi-centre study. Pharmatherapeutica. 1989;5(5):285-91. [pmid: 2568639].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fulop T J, Worum I, Csongor J, et al. Effects of centrophenoxine on body composition and some biochemical parameters of demented elderly people as revealed in a double-blind clinical trial. Arch Gerontol Geriatr. 1990;10(3):239-51. [pmid: 15374499].
Status: Not included because no extractable data relevant to review
Funfgeld EW, Baggen M, Nedwidek P, et al. Double blind study with phosphatidytserine (PS) in parkinsonian patients with senile dementia of Alzheimer's type (SDAT). Alzheimers Dis Relat Disord 1989; 1235–46.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Fuschillo C, La Pia S, Campana F, et al. Cognitive deficits in Alzheimer's disease: Treatment with acetylcholinesterase inhibitor agents. Arch Gerontol Geriatr. 2001;33(suppl 1):151-8. [pmid: 11431059].
Status: Not included because Jadad Quality Scale score less than three
Fusgen I, Bressel H-U, De Mey C. A randomised, placebo-controlled, double-blind study of the efficacy and tolerability of dimenhydrinate in multi-morbid patients with senile dizziness. Eur J Geriatr. 2002;4(2):92-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gaber S, Ronzoni S, Bruni A, et al. Sertaline versus small doses of haloperidol in the treatment of agitated behaviour in pateints with dementia. Arch Gerontol Geriatr Psychiatry 2001; (Suppl 1):159–62.
Status: Not included because Jadad Quality Scale score less than three
Gabrynowicz J W, Dumbrill M. A clinical trial of leptazole with nicotinic acid in the management of psycho-geriatric patients. Med J Aust. May 11. 1968;1(19):799-802. [pmid: 4872367].
Status: Not included because no extractable data relevant to review
Gainotti G, Nocentini U, Sena E. Can the pattern of neuropsychological improvement obtained with cholinergic drugs be used to infer a cholinergic mechanism in other nootropic drugs?. Prog Neuropsychopharmacol Biol Psychiatry. 1989;13(Suppl):S47-S59. [pmid: 2694229].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gaitz C M, Varner R V, Overall J E. Pharmacotherapy for organic brain syndrome in late life. Evaluation of an ergot derivative vs placebo. Arch Gen Psychiatry. Jul. 1977;34(7):839-45. [pmid: 406875].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gallai V, Mazzotta G, Firenze C, et al. Study of the P300 and cerebral maps in subjects with multi-infarct dementia treated with cytidine. Psychopharmacologia. 1991;103(1):1-5.
Status: Not included because no extractable data relevant to review
Gallai V, Mazzotta G, Del Gatto F, et al. A clinical and neurophysiological trial on nootropic drugs in patients with mental decline. Acta Neurol (Napoli). Feb. 1991;13(1):1-12. [pmid: 1867125].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gao H, Yan L, Liu B, et al. Clinical study on treatment of senile vascular dementia by acupuncture. J Tradit Chin Med. Jun. 2001;21(2):103-9. [pmid: 11498896].
Status: Not included because Jadad Quality Scale score less than three
Garetz F K, Baron J J, Barron P B, et al. Efficacy of nylidrin hydrochloride in the treatment of cognitive impairment in the elderly. J Am Geriatr Soc. May. 1979;27(5):235-6. [pmid: 372292].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gasnault J, Gueguen B, Bourdel M C, et al. Oral tacrine effects on computerised EEG activity during a double blind cross-over study in dementia of the Alzheimer type. J Neurol. 1990;237:33.
Status: Not included because not a full article
Gauthier S, Leblanc R, Robitaille Y, et al. Transmitter-replacement therapy in Alzheimer's disease using intracerebroventricular infusions of receptor agonists. Can J Neurol Sci. Nov. 1986;13(4 Suppl):394-402. [pmid: 2878712].
Status: Not included because dementia population not randomized to treatment
Gauthier S, Bouchard R, Lamontagne A, et al. Tetrahydroaminoacridine-lecithin combination treatment in patients with intermediate-stage Alzheimer's disease. N Engl J Med. 1990;322(18):1272-6. [pmid: 2183056].
Status: Cross-over trial;
Gedye J L, Exton-Smith A N, Wedgwood J. A method for measuring mental performance in the elderly and its use in a pilot clinical trial of meclofenoxate in organic dementia (preliminary communication). Age Ageing. May. 1972;1(2):74-80. [pmid: 4150311].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gedye J L, Ibrahimi G S, McDonald C. A double blind controlled trial of piracetam (2-pyrrolidone acetamide) on two groups of psychogeriatric patients. IRCS Med Sci Clin Med. 1978;6(5):202.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gelinas I, Gauthier S, Cyrus P A. Metrifonate enhances the ability of Alzheimer's disease patients to initiate, organize, and execute instrumental and basic activities of daily living. J Geriatr Psychiatry Neurol. 2000;13(1):9-16. [pmid: 10753002].
Status: Not included because dementia population not randomized to treatment
Geng J. Treatment of 50 cases of senile dementia by acupuncture combined with inhalation of herbal drugs and oxygen. J Tradit Chin Med. Dec. 1999;19(4):287-9. [pmid: 10921134].
Status: Not included because Jadad Quality Scale score less than three
George T P, Vessicchio J C, Termine A, et al. Effects of smoking abstinence on visuospatial working memory function in schizophrenia. Neuropsychopharmacology. 2002;26(1):75-85. [pmid: 11751034].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gerber G J, Prince P N, Snider H G, et al. Group activity and cognitive improvement among patients with Alzheimer's disease. Hospital & Community Psychiatry. 1991;42(8):843-5. [pmid: 1894261].
Status: Not included because does not meet criteria for treatment for dementia patients
Gerdner L A. Effects of individualized versus classical “relaxation” music on the frequency of agitation in elderly persons with Alzheimer's disease and related disorders. Int Psychogeriatr. Mar. 2000;12(1):49-65. [pmid: 10798453].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gerdner L A, Buckwalter K C, Reed D. Impact of a psychoeducational intervention on caregiver response to behavioral problems. Nurs Res. Nov. 2002;51(6):363-74. [pmid: 12464756].
Status: Not included because does not meet criteria for treatment for dementia patients
Gessner B, Voelp A, Klasser M. Study of the long-term action of a Ginkgo biloba extract on vigilance and mental performance as determined by means of quantitative pharmaco-EEG and psychometric measurements. Arzneimittelforschung. 1985;35(9):1459-65. [pmid: 3910053].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Getsios D, Caro J J, Caro G, et al. Assessment of health economics in Alzheimer's disease (AHEAD): Galantamine treatment in Canada. Neurology. Sep 25. 2001;57(6):972-8. [pmid: 11571319].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ghatak R. Effects of an intervention program on dementia patients and their caregivers. Caring 1994 Aug; (No. 8):34–9.
Status: Not included because dementia population not randomized to treatment
Ghose K. Plasma drug levels of oxpentifylline in patients with dementia. An assessment of compliance. Brain Dysfunct 1989; (2):105–10.
Status: Not included because no extractable data relevant to review
Giacobini E, Spiegel R, Enz A, et al. Inhibition of acetyl- and butyryl-cholinesterase in the cerebrospinal fluid of patients with Alzheimer's disease by rivastigmine: Correlation with cognitive benefit. J Neural Transm Gen Sect. Jul. 2002;109(78):1053-65.
Status: Not included because dementia population not randomized to treatment
Ginsburg R, Weintraub M. Caffeine in the “sundown syndrome”. Report of negative results. J Gerontol. Jul. 1976;31(4):419-20. [pmid: 774004].
Status: Not included because dementia population not randomized to treatment
Gitlin L N, Corcoran M, Winter L, et al. A randomized, controlled trial of a home environmental intervention: Effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. Feb. 2001;41(1):4-14. [pmid: 11220813].
Status: Not included because does not meet criteria for treatment for dementia patients
Giuffra M, Mouradian MM, Bammert J, et al. Prolonged intravenous infusion of physostigmine in Alzheimer's disease. Neurology 1990; 40(Suppl 1):229, 1990.
Status: Not included because not a full article
Gleason R P, Schneider L S. Carbamazepine treatment of agitation in Alzheimer's outpatients refractory to neuroleptics. J Clin Psychiatry. 1990;51(3):115-8. [pmid: 1968457].
Status: Not included because dementia population not randomized to treatment
Goad D L, Davis C M, Liem P, et al. The use of selegiline in Alzheimer's patients with behavior problems. J Clin Psychiatry. 1991;52(8):342-5. [pmid: 1907964].
Status: Not included because dementia population not randomized to treatment
Gobburu J V, Tammara V, Lesko L, et al. Pharmacokinetic-pharmacodynamic modeling of rivastigmine, a cholinesterase inhibitor, in patients with Alzheimer's disease. J Clin Pharmacol. Oct. 2001;41(10):1082-90. [pmid: 11583476].
Status: Not included because dementia population not randomized to treatment
Goety C G, Tanner C M, Cohen J A, et al. L-acetyl-carnitine in Huntington's disease: Double-blind placebo controlled crossover study of drug effects on movement disorder and dementia. Mov Disord. 1990;5(3):263-5. [pmid: 2143808].
Status: Not included because not a full article
Goldstein S E, Birnbom F. Nylidrin HCL in the treatment of symptoms of the aged: A double-blind placebo controlled study. J Clin Psychiatry. Dec. 1979;40(12):520-4. [pmid: 500575].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Goldwasser A N, Auerbach S M, Harkins S W. Cognitive, affective, and behavioral effects of reminiscence group therapy on demented elderly. Int J Aging Hum Dev. 1987;25(3):209-22. [pmid: 3429043].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Golomb B A. Statins and dementia. Arch Neurol. 2001;58(7):1169-70. [pmid: 11448316].
Status: Not included because not a full article
Goodwin G M, Conway S C, Peyro-Saint-Paul H, et al. Executive function and uptake of 99mTc-exametazime shown by single photon emission tomography after oral idazoxan in probable Alzheimer-type dementia. Psychopharmacologia. Jun. 1997;131(4):371-8.
Status: Cross-over trial;
Gori G, Pientini S, Vespa A. The selection of meaningful activities as a treatment for day-care in dementia. Arch Gerontol Geriatr. 2001;33(Suppl):207-12. [pmid: 11431066].
Status: Not included because dementia population not randomized to treatment
Gorman DG, Read S, Cummings JL. Cholinergic therapy of behavioral disturbances in Alzheimer's disease. Neuropsychiatry Neuropsychol Behav Neurol ; 6(4):229–34.
Status: Cross-over trial;
Gormley N, Lyons D, Howard R. Behavioural management of aggression in dementia: A randomized controlled trial. Age Ageing. Mar. 2001;30(2):141-5. [pmid: 11395344].
Status: Not included because does not meet criteria for treatment for dementia patients
Gortelmeyer R, Erbler H. Memantine in the treatment of mild to moderate dementia syndrome. A double-blind placebo-controlled study. Arzneimittelforschung. Jul. 1992;42(7):904-13. [pmid: 1418054].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gotestam K G, Ljunghall S, Olsson B. A double-blind comparison of the effects of haloperidol and cis-clopenthixol in senile dementia. Acta Psychiatr Scand. 1981;294(Suppl):46-53.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gotestam K G, Melin L. The effect of prompting and reinforcement of activity in elderly demented inpatients. Scand J Psychol. 1990;31(1):2-8. [pmid: 2333483].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gottfries C G, Karlsson I, Nyth A L. Treatment of depression in elderly patients with and without dementia disorders. Int Clin Psychopharmacol. 1992;6(Suppl 5):55-64. [pmid: 1431023].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gracon SI, Hoover TM, Lewis KW, et al. Tacrine in Alzheimer's disease efficacy and safety in a parallel group study. Alzheimer's Disease Advances in Clinical and Basic Research 1993; 549–57.
Status : Not included because not a full article
Gracon S I, Knapp M J, Berghoff W G, et al. Safety of tacrine: Clinical trials, treatment IND, and postmarketing experience. Alzheimer Dis Assoc Disord. Jun. 1998;12(2):93-101. [pmid: 9651138].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Graf A, Wallner C, Schubert V, et al. The effects of light therapy on mini-mental state examination scores in demented patients. Biol Psychiatry. Nov 1. 2001;50(9):725-7. [pmid: 11704081].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Grasser A, Gotthardt U, Heuser-Link M, et al. Behavioral effects of an ACTH4-9-fragment in a mixed sample of depressed patients and patients with Alzheimer's disease. Pharmacopsychiatry. 1992;Vol 25:102.
Status: Not included because not a full article
Green J, McDonald W M, Vitek J L, et al. Neuropsychological and psychiatric sequelae of pallidotomy for PD: Clinical trial findings. Neurology. 2002;58(6):858-65. [pmid: 12427877].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Green M F, Marder S R, Glynn S M, et al. The neurocognitive effects of low-dose haloperidol: A two-year comparison with risperidone. Biol Psychiatry. 2002;51(12):972-8. [pmid: 12062881].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Green R C, Goldstein F C, Auchus A P, et al. Treatment trial of oxiracetam in Alzheimer's disease. Arch Neurol. Nov. 1992;49(11):1135-6. [pmid: 1444879].
Status: Not included because dementia population not randomized to treatment
Greenberg S M, Tennis M K, Brown L B, et al. Donepezil therapy in clinical practice: A randomized crossover study. Arch Neurol. Jan. 2000;57(1):94-9. [pmid: 10634454].
Status: Cross-over trial;
Greendyke R M, Kanter D R. Therapeutic effects of pindolol on behavioral disturbances associated with organic brain disease: A double-blind study. J Clin Psychiatry. Aug. 1986;47(8):423-6. [pmid: 3525523].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Greendyke R M, Kanter D R, Schuster D B, et al. Propranolol treatment of assaultive patients with organic brain disease. A double-blind crossover, placebo-controlled study. J Nerv Ment Dis. May. 1986;174(5):290-4. [pmid: 3517228].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Greendyke R M, Berkner J P, Webster J C, et al. Treatment of behavioral problems with pindolol. Psychosomatics. 1989;30(2):161-5. [pmid: 2652180].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Greer KL, Pustay KA, Zaun TC, et al. Comparison of the effects of toys versus live animals on the communication of patients with dementia of the Alzheimer's type. Clin Gerontol 2001; (3–4):157–82.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Grioli S, Lomeo C, Quattropani M C, et al. Pyroglutamic acid improves the age associated memory impairment. Fundam Clin Pharmacol. 1990;4(2):169-73. [pmid: 2190900].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gross R J, Eisdorfer C E, Schiller H S, et al. Effect of ergot alkaloids on serum prolactin in non-psychotic organic brain syndrome of the elderly. Exp Aging Res. Aug. 1979;5(4):293-302. [pmid: 520386].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Grossberg G T, Stahelin H B, Messina J C, et al. Lack of adverse pharmacodynamic drug interactions with rivastigmine and twenty-two classes of medications. Int J Geriatr Psychiatry. Mar. 2000;15(3):242-7. [pmid: 10713582].
Status: Not included because dementia population not randomized to treatment
Grossman M, Mickanin J, Onishi K, et al. An aspect of sentence processing in Alzheimer's disease: Quantifier-noun agreement. Neurology. Jan. 1995;45(1):85-91. [pmid: 8848186].
Status: Not included because does not meet criteria for treatment for dementia patients
Grossmann W M, Standl A, May U, et al. Naftidrofuryl in the treatment of mild senile dementia. A double-blind study. Pharmacopsychiatry. Nov. 1990;23(6):265-73. [pmid: 2284328].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Grothe D R, Piscitelli S C, Dukoff R, et al. Penetration of tacrine into cerebrospinal fluid in patients with Alzheimer's disease. J Clin Psychopharmacol. 1998;18(1):78-81. [pmid: 9472847].
Status: Not included because dementia population not randomized to treatment
Group for the Advancement of Psychiatry and Committee on Aging. Impact of tacrine in the care of patients with Alzheimer's disease: What we know one year after FDA approval. Am J Geriatr Psychiatry. 1994;2(4):285-9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Growdon J H, Corkin S, Huff F J, et al. Piracetam combined with lecithin in the treatment of Alzheimer's disease. Neurobiol Aging. Jul. 1986;7(4):269-76. [pmid: 3528889].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Guerzoni A, Santambrogio S. Efficacy of dihydroergocristine 20 mg once daily in patients with organic brain psychosyndrome. A 3-month randomised, double-blind, placebo-controlled study. Clin Drug Investig. 1995;10(1):1-7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Guimon J, Blanco J, Caso C. L-Dopa carbidopa treatment of senile dementia: A control study. Eur J Psychiatry 1995; (1):29–36.
Status: Not included because Jadad Quality Scale score less than three
Gustafson L, Risberg J, Johanson M, et al. Effects of piracetam on regional cerebral blood flow and mental functions in patients with organic dementia. Psychopharmacologia. Mar 1. 1978;56(2):115-7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gustafson L, Edvinsson L, Dahlgren N, et al. Intravenous physostigmine treatment of Alzheimer's disease evaluated by psychometric testing, regional cerebral blood flow (rCBF) measurement, and EEG. Psychopharmacologia. 1987;93(1):31-5.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Gustafson L. Physostigmine and tetrahydroaminoacridine treatment of Alzheimer's disease. Acta Neurol Scand Suppl. 1993;149(Rand):39-41. [pmid: 8128836].
Status: Cross-over trial;
Haaland K Y, Harrington D L, O'Brien S, et al. Cognitive-motor learning in Parkinson's disease. Neuropsychology. 1997;11(2):180-6. [pmid: 9110325].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hackman B W, Galbraith. Replacement therapy with piperazine oestrone sulphate (harmogen) and its effect on memory. Curr Med Res Opin. 1976;4(4):303-6. [pmid: 791587].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hackman B W, Galbraith. Six-month pilot study of oestrogen replacement therapy and piperazine oestrone sulphate (‘Harmogen’) and its effect on memory. Curr Med Res Opin. 1977;4(3):21-7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hadas-Lidor N, Katz N, Tyano S, et al. Effectiveness of dynamic cognitive intervention in rehabilitation of clients with schizophrenia. Clin Rehabil. 2001;15(4):349-59. [pmid: 11518436].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Haffmans P M, Sival R C, Lucius S A, et al. Bright light therapy and melatonin in motor restless behaviour in dementia: A placebo-controlled study. Int J Geriatr Psychiatry. Jan. 2001;16(1):106-10. [pmid: 11180494].
Status: Cross-over trial;
Hagstadius S, Gustafson L, Risberg J. The effects of bromvincamine and vincamine on regional cerebral blood flow and mental functions in patients with multi-infarct dementia. Psychopharmacologia. 1984;83(4):321-6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Haley W E, Brown S L, Levine E G. Experimental evaluation of the effectiveness of group intervention for dementia caregivers. Gerontologist. 1987;27(3):376-82. [pmid: 3609812].
Status: Not included because does not meet criteria for treatment for dementia patients
Hall P, Harcup M. A trial of lipotropic enzymes in atheromatous (“arteriosclerotic”) dementia. Angiology. May. 1969;20(5):287-300. [pmid: 4976740].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Halliday G M, Shepherd C E, McCann H, et al. Effect of anti-inflammatory medications on neuropathological findings in Alzheimer's disease. Arch Neurol. Jun. 2000;57(6):831-6. [pmid: 10867780].
Status: Not included because dementia population not randomized to treatment
Hammeke T A, Haughton V M, Grogan J P, et al. A preliminary study of cognitive and affective alterations following intrathecal administration of iopamidol or metrizamide. Invest Radiol. 1984;19(Suppl 5):S268-S271.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hammen C L, Jacobs M, Mayol A, et al. Dysfunctional cognitions and the effectiveness of skills and cognitive-behavioral assertion training. J Consult Clin Psychol. Dec. 1980;48(6):685-95. [pmid: 7440825].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hanley I G, McGuire R J, Boyd W D. Reality orientation and dementia: A controlled trial of two approaches. Br J Psychiatry. 1981;138:10-4. [pmid: 7023589].
Status: Not included because dementia population not randomized to treatment
Hansson L. Antihypertensive treatment and the prevention of dementia: Further insights from the Syst-Eur trial. J Hypertens. 1999;17(3):307-8. [pmid: 10100066].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hanyu H, Tanaka Y, Sakurai H, et al. Atrophy of the substantia innominata on magnetic resonance imaging and response to donepezil treatment in Alzheimer's disease. Neurosci Lett. Feb 8. 2002;319(1):33-6. [pmid: 11814647].
Status: Not included because dementia population not randomized to treatment
Harbaugh R E, Roberts D W, Coombs D W, et al. Preliminary report: Intracranial cholinergic drug infusion in patients with Alzheimer's disease. Neurosurgery. Oct. 1984;15(4):514-8. [pmid: 6149490].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Harbaugh R E. Intracerebroventricular cholinergic drug administration in Alzheimer's disease: Preliminary results of a double-blind study. J Neural Transm Suppl. 1987;24:271-7. [pmid: 2890709].
Status: Cross-over trial;
Harbaugh R E, Reeder T M, Senter H J, et al. Intracerebroventricular bethanechol chloride infusion in Alzheimer's disease. Results of a collaborative double-blind study. J Neurosurg. Oct. 1989;71(4):481-6. [pmid: 2571689].
Status: Cross-over trial;
Harding G F, Hall P, Young J, et al. Multifocal infarct dementia treated by cyclandelate and monitored by quantitative EEG. Angiology. Feb. 1978;29(2):139-40. [pmid: 347986].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Harenko A. A comparison between chlormethiazole and nitrazepam as hypnotics in psycho-geriatric patients. Curr Med Res Opin. Jul. 1974;2(10):657-63. [pmid: 4616806].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Harkins S W, Taylor J R, Mattay V S. Response to tacrine in patients with dementia of the Alzheimer's type: cerebral perfusion change is related to change in mental status. Int J Neurosci. Feb. 1996;84(14):149-4. [pmid: 8707476].
Status: Not included because dementia population not randomized to treatment
Harrell L E, Callaway R, Morere D, et al. The effect of long-term physostigmine administration in Alzheimer's disease. Neurology. 1990;40(9):1350-4. [pmid: 2392216].
Status: Cross-over trial;
Harrell L E, Jope R S, Falgout J, et al. Biological and neuropsychological characterization of physostigmine responders and nonresponders in Alzheimer's disease. J Am Geriatr Soc. Feb. 1990;38(2):113-22. [pmid: 2405043].
Status: Cross-over trial;
Harrell T H, Ryon N B. Cognitive-behavioral assessment of depression: Clinical validation of the automatic thoughts questionnaire. J Consult Clin Psychol. Oct. 1983;51(5):721-5. [pmid: 6630686].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Harris S, Dowson J H. The effects of Meclofenoxate on cognitive performance in elderly individuals with memory impairment: A placebo-controlled study. Int J Geriatr Psychiatry. 1986;1:93-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hart B D, Wells D L. The effects of language used by caregivers on agitation in residents with dementia. Clin Nurse Spec. Jan. 1997;11(1):20-3. [pmid: 9233134].
Status: Not included because dementia population not randomized to treatment
Hart S, Smith CM, Swash M, et al. Word fluency in patients with early dementia of Alzheimer's type. Br J Clin Psychol 1988; 46(Pt 2):115–24, 1592–9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hartmann A. Cerebral blood flow in patients with cerebrovascular disorders: study with pentoxifylline. Ric Clin Lab. 1981;11(Suppl 1):243-6. [pmid: 7188111].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hartmann A. Comparative randomized study of cerebral blood flow after long-term administration of pentoxifylline and co-dergocrine mesylate in patients with chronic cerebrovascular disease. Curr Med Res Opin. 1985;9(7):475-9. [pmid: 4028808].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hartmann A, Tsuda Y. A controlled study on the effect of pentoxifylline and an ergot alkaloid derivative on regional cerebral blood flow in patients with chronic cerebrovascular disease. Angiology. May. 1988;39(5):449-57. [pmid: 3288016].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Harvey P D, Moriarty P J, Serper M R, et al. Practice-related improvement in information processing with novel antipsychotic treatment. Schizophr Res. 2000;46(23):139-48. [pmid: 11120426].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Harwart D. The treatment of chronic cerebrovascular insufficiency. A double-blind study with pentoxifylline (‘Trental’ 400). Curr Med Res Opin. 1979;6(2):73-84. [pmid: 380914].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hauber A B, Gnanasakthy A, Mauskopf J A. Savings in the cost of caring for patients with Alzheimer's disease in Canada: An analysis of treatment with rivastigmine. Clin Ther. Apr. 2000;22(4):439-51. [pmid: 10823365].
Status: Not included because does not meet criteria for treatment for dementia patients
Hauer K, Marburger C, Oster P. Motor performance deteriorates with simultaneously performed cognitive tasks in geriatric patients. Arch Phys Med Rehabil. Feb. 2002;83(2):217-23. [pmid: 11833025].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Haupt M, Karger A, Janner M. Improvement of agitation and anxiety in demented patients after psychoeducative group intervention with their caregivers. Int J Geriatr Psychiatry. Dec. 2000;15(12):1125-9. [pmid: 11180469].
Status: Not included because does not meet criteria for treatment for dementia patients
Hebert R, Leclerc G, Bravo G, et al. Efficacy of a support group programme for care-givers of demented patients in the community: A randomized controlled trial. Arch Gerontol Geriatr. 1994;18(1):1-14. [pmid: 15374309].
Status: Not included because does not meet criteria for treatment for dementia patients
Hebert R, Girouard D, Leclerc G, et al. The impact of a support group programme for care-givers on the institutionalisation of demented patients. Arch Gerontol Geriatr. 1995;20(2):129-34. [pmid: 15374241].
Status: Not included because does not meet criteria for treatment for dementia patients
Heinonen E H, Savijarvi M, Kotila M, et al. Effects of monoamine oxidase inhibition by selegiline on concentrations of noradrenaline and monoamine metabolites in CSF of patients with Alzheimer's disease. J Neural Transm Park Dis Dement Sect. 1993;5(3):193-202. [pmid: 8369100].
Status: Cross-over trial;
Heinze B, Karrass W, Peters T. Pharmacopsychological effects of flunarizine in geriatric patients with light brainorganic psychosyndrome. Preliminary communication. Eur Neurol. 1986;25(Suppl 1):115-21. [pmid: 3530773].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Heiss W D, Kessler J, Slansky I, et al. Activation PET as an instrument to determine therapeutic efficacy in Alzheimer's disease. Ann N Y Acad Sci. 1993;695(Sep 24):327-13. [pmid: 8239307].
Status: Not included because Jadad Quality Scale score less than three
Heiss W D, Kessler J, Mielke R, et al. Long-term effects of phosphatidylserine, pyritinol, and cognitive training in Alzheimer's disease. A neuropsychological, EEG, and PET investigation. Dementia. Mar. 1994;5(2):88-98. [pmid: 8038871].
Status: Not included because Jadad Quality Scale score less than three
Helkala E L, Koivisto K, Hanninen T, et al. Stability of age-associated memory impairment during a longitudinal population-based study. J Am Geriatr Soc. Jan. 1997;45(1):120-2. [pmid: 8994504].
Status: Not included because not a full article
Henderson V W, Roberts E, Wimer C, et al. Multicenter trial of naloxone in Alzheimer's disease. Ann Neurol. Apr. 1989;25(4):404-6. [pmid: 2653175].
Status: Cross-over trial;
Henderson V W, Paganini-Hill A, Miller B L, et al. A randomized controlled trial of estrogen for the treatment of Alzheimer's disease in women. Neurology. 2000;54(Suppl 3):A470. [pmid: 10668686].
Status: Not included because not a full article
Herrmann W M, Kern U, rohmel J. On the effects of pyritinol on functional deficits of patients with organic mental disorders. Pharmacopsychiatry. Sep. 1986;19(5):378-85. [pmid: 3534901].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Herrmann W M, Kern U, rohmel J. Contribution to the search for vigilance-indicative EEG variables. Results of a controlled, double-blind study with pyritinol in elderly patients with symptoms of mental dysfunction. Pharmacopsychiatry. Mar. 1986;19(2):75-83. [pmid: 3534901].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Herrmann W M, Dietrich B, Hiersemenzel R. Pharmaco-electroencephalographic and clinical effects of the cholinergic substance--acetyl-L-carnitine--in patients with organic brain syndrome. Int J Clin Pharmacol Res. 1990;10(12):81-2. [pmid: 2201660].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Herrmann W M, Stephan K. Moving from the question of efficacy to the question of therapeutic relevance: an exploratory reanalysis of a controlled clinical study of 130 inpatients with dementia syndrome taking piracetam. Int Psychogeriatr. 1992;4(1):25-44. [pmid: 1391670].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Herz L R, Volicer L, Ross V, et al. A single-case-study method for treating resistiveness in patients with Alzheimer's disease. Hospital & Community Psychiatry. Jul. 1992;43(7):720-4. [pmid: 1516904].
Status: Cross-over trial;
Heseker H, Kubler W, Pudel V, et al. Interaction of vitamins with mental performance. Bibl Nutr Dieta 1995; (52):43–55.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Heseltine P N, Goodkin K, Atkinson J H, et al. Randomized double-blind placebo-controlled trial of peptide T for HIV-associated cognitive impairment. Arch Neurol. Jan. 1998;55(1):41-51. [pmid: 9443710].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Heuser I, Heuser-Link M, Gotthardt U, et al. Behavioral effects of a synthetic corticotropin 4–9 analog in patients with depression and patients with Alzheimer's disease. J Clin Psychopharmacol. Jun. 1993;13(3):171-4. [pmid: 8394847].
Status: Not included because dementia population not randomized to treatment
Hewawasam L. Floor patterns limit wandering of people with Alzheimer's. Nurs Times. May 29. 1996;92(22):41-4. [pmid: 8716494].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Heyman A, Schmechel D, Wilkinson W, et al. Failure of long term high-dose lecithin to retard progression of early-onset Alzheimer's disease. J Neural Transm Suppl. 1987;Vol 24:279-86. [pmid: 3479525].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hinchliffe A C, Katona C, Livingston G. The assessment and management of behavioural manifestations of dementia: A review and results of a controlled trial. Int J Psychiatry Clin Pract. 1997;1(3):157-68.
Status: Not included because does not meet criteria for treatment for dementia patients
Hincliffe A C, Hyman I L, Blizard B, et al. Behavioural complications of dementia - Can they be treated?. Int J Geriatr Psychiatry. 1995;10(10):839-47.
Status: Not included because does not meet criteria for treatment for dementia patients
Hindle JV, Meara RJ, Sharma JC, et al. Prescribing pergolide in the elderly - An open label study of pergolide in elderly patients with Parkinson's disease. Int J Geriatr Psychopharmacol 1998; (2):78–81.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hindmarch I, Fuchs H H, Erzigkeit H. Efficacy and tolerance of vinpocetine in ambulant patients suffering from mild to moderate organic psychosyndromes. Int Clin Psychopharmacol. 1991;6(1):31-43. [pmid: 2071888].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hinkin C H, Castellon S A, Hardy D J, et al. Methylphenidate improves HIV-1-associated cognitive slowing. J Neuropsychiatry Clin Neurosci. 2001;13(2):248-54. [pmid: 11449032].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hirohata S, Suda H, Hashimoto T. Low-dose weekly methotrexate for progressive neuropsychiatric manifestations in Behcet's disease. JNS. Aug 14. 1998;159(2):181-5.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hjorther A, Browne E, Jakobsen K, et al. Organic brain syndrome treated with oxiracetam. A double-blind randomized controlled trial. Acta Neurol Scand. Apr. 1987;75(4):271-6. [pmid: 3296624].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hock C, Maddalena A, Heuser I, et al. Treatment with the selective muscarinic agonist talsaclidine decreases cerebrospinal fluid levels of total amyloid beta-peptide in patients with Alzheimer's disease. Ann N Y Acad Sci. 2000;920:285-91. [pmid: 11193166].
Status: Not included because no extractable data relevant to review
Hodges, Graham JR, K.S. A reversal of the temporal gradient for famous person knowledge in semantic dementia: implications for the neural organisation of long-term memory. Neuropsychologia 1998;36(8):803–25.
Status: Not included because does not meet criteria for treatment for dementia patients
Hoeffer B, Rader J, McKenzie D, et al. Reducing aggressive behavior during bathing cognitively impaired nursing home residents. J Gerontol Nurs. May. 1997;23(5):16-23. [pmid: 9180505].
Status: Not included because dementia population not randomized to treatment
Hofferberth B. The efficacy of EGb 761 in patients with senile dementia of the Alzheimer type, a double-blind, placebo-controlled study on different levels of investigation. Hum Psychopharmacol 1994; (3):215–22.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Holden M, Kelly C. Use of cholinesterase inhibitors in dementia. Adv Psychiatr Treat. 2002;8(2):89-96.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hollander E, Davidson M, Mohs R C, et al. RS 86 in the treatment of Alzheimer's disease: cognitive and biological effects. Biol Psychiatry. Sep. 1987;22(9):1067-78. [pmid: 3651528].
Status: Cross-over trial;
Holliman D C, Orgassa U C, Forney J P. Developing an interactive physical activity group in a geriatric psychiatry facility. Activities Adaptation Aging. 2001;26(1):57-69.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Holm A, Michel M, Stern G A, et al. The outcomes of an inpatient treatment program for geriatric patients with dementia and dysfunctional behaviors. Gerontologist. Dec. 1999;39(6):668-76. [pmid: 10650676].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Holmes C, Hopkins V, Hensford C, et al. Lavender oil as a treatment for agitated behaviour in severe dementia: A placebo controlled study. Int J Geriatr Psychiatry. Apr. 2002;17(4):305-8. [pmid: 11994882].
Status: Not included because dementia population not randomized to treatment
Holzman D. Ginkgo biloba for Alzheimer's disease. Altern Complement Ther 1998; (5):361–3.
Status: Not included because not a full article
Homma A, Takeda M, Imai Y, et al. Clinical efficacy and safety of donepezil on cognitive and global function in patients with Alzheimer's disease. A 24-week, multicenter, double-blind, placebo-controlled study in Japan. E2020 Study Group. Dement Geriatr Cogn Disord. Nov. 2000;11(6):299-313. [pmid: 11044775].
Status: Not included because Jadad Quality Scale score less than three
Honjo H, Ogino Y, Naitoh K, et al. In vivo effects by estrone sulfate on the central nervous system-senile dementia (Alzheimer's type). J Steroid Biochem. 1989;34(16):521-6. [pmid: 2559248].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Honjo H, Tanaka T, Urabe M, et al. Senile-dementia Alzheimer's type and estrogen. Hormone & Metabolic Research. 1995;27(4):204-7. [pmid: 7750907].
Status: Not included because dementia population not randomized to treatment
Hopman-Rock M, Staats P G, Tak E C, et al. The effects of a psychomotor activation programme for use in groups of cognitively impaired people in homes for the elderly. Int J Geriatr Psychiatry. Aug. 1999;14(8):633-42. [pmid: 10489654].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hornig P. Commentary on A 30-week randomized controlled trial of high-dose tacrine in patients with Alzheimer's disease. Nursing Scan in Research. 1994;7(4):6.
Status: Not included because not a full article
Hossain M, Jhee S S, Shiovitz T, et al. Estimation of the absolute bioavailability of rivastigmine in patients with mild to moderate dementia of the Alzheimer's type. Clin Pharmacokinet. 2002;41(3):225-34. [pmid: 11929322].
Status: Not included because no extractable data relevant to review
Hoyer S, Oesterreich K, Stoll K D. Effects of Pyritinol HCl on blood flow and oxidative metabolism of the brain in patients with dementia. Arzneimittelforschung. 1977;27(3):671-4. [pmid: 577444].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hozumi S, Hori H, Okawa M, et al. Favorable effect of transcranial electrostimulation on behavior disorders in elderly patients with dementia: a double-blind study. Int J Neurosci. Nov. 1996;88(12):1-2. [pmid: 9003961].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Huff F J, Shipley J, Somerville N J, et al. Besipirdine (HP 749) treatment trial in Alzheimer's disease. Neurology. 1995;45(Suppl 4):A288.
Status: Not included because not a full article
Huff F J. Preliminary evaluation of besipirdine for the treatment of Alzheimer's disease. Ann N Y Acad Sci. 1996;777:410-4. [pmid: 8624122].
Status: Not included because Jadad Quality Scale score less than three
Huff F J, Antuono P G, Delagandara J E, et al. A treatment and withdrawal trial of besipirdine in Alzheimer's disease. Alzheimer Dis Assoc Disord. 1996;10(2):93-102. [pmid: 8727171].
Status: Not included because Jadad Quality Scale score less than three
Huusko T M, Karppi P, Avikainen V, et al. Randomised, clinically controlled trial of intensive geriatric rehabilitation in patients with hip fracture: Subgroup analysis of patients with dementia. BMJ. Nov 4. 2000;321(7269):1107-11. [pmid: 11061730]. [pmcid: 27517].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Hyman B T, Eslinger P J, Damasio A R. Effect of naltrexone on senile dementia of the Alzheimer type. J Neurol Neurosurg Psychiatry. 1985;48(11):1169-71. [pmid: 3001233].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ikeda S, Yamada Y, Ikegami N. Economic evaluation of donepezil treatment for Alzheimer's disease in Japan. Dement Geriatr Cogn Disord. 2002;13(1):33-9. [pmid: 11731713].
Status: Not included because does not meet criteria for treatment for dementia patients
Imbimbo B P, Nicoli M, Martini C, et al. Acetylcholinesterase assay may predict cognitive response of Alzheimer patients to eptastigmine treatment. Eur J Clin Pharmacol. Nov. 1998;54(910):809-10. [pmid: 9923589].
Status: Not included because not a full article
Imbimbo B P, Lucca U, Lucchelli F, et al. A 25-week placebo-controlled study of eptastigmine in patients with Alzheimer's disease. Alzheimer Dis Assoc Disord. Dec. 1998;12(4):313-22. [pmid: 9876959].
Status: Not included because Jadad Quality Scale score less than three
Imbimbo B P, Verdelli G, Martelli P, et al. Two-year treatment of Alzheimer's disease with eptastigmine. Dement Geriatr Cogn Disord. 1999;10(2):139-47. [pmid: 10026388].
Status: Not included because dementia population not randomized to treatment
Imbimbo B P, Troetel W M, Martelli P, et al. A 6-month, double-blind, placebo-controlled trial of eptastigmine in Alzheimer's disease. Dement Geriatr Cogn Disord. Jan. 2000;11(1):17-24. [pmid: 10629357].
Status: Not included because Jadad Quality Scale score less than three
In't Veld B A, Ruitenberg A, Hofman A, et al. Antihypertensive drugs and incidence of dementia: The Rotterdam Study. Neurobiol Aging. 2001;22(3):407-12. [pmid: 11378246].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ingersoll-Dayton B, Schroepfer T, Pryce J. The effectiveness of a solution-focused approach for problem behaviors among nursing home residents. J Gerontol Soc Work. 1999;32(3):49-64.
Status: Not included because does not meet criteria for treatment for dementia patients
Innes E H. Efficacy and tolerance of flurbiprofen in the elderly using liquid and tablet formulations. Curr Med Res Opin. 1977;5(1):122-6. [pmid: 71970].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Inzitari D, Pantoni L. Subcortical vascular dementia: therapeutical aspects. Arch Gerontol Geriatr 1998; 263–8.
Status : Not included because not a full article
Iribar M C, Montes J, Gonzalez M R, et al. Alanyl-aminopeptidase activity decrease in cerebrospinal fluid of Alzheimer patients. Dement Geriatr Cogn Disord. Jan. 1998;9(1):44-9. [pmid: 9469265].
Status: Not included because does not meet criteria for treatment for dementia patients
Ishizaki J, Meguro K, Ohe K, et al. Therapeutic psychosocial intervention for elderly subjects with very mild Alzheimer disease in a community: The tajiri project. Alzheimer Dis Assoc Disord. 2002;16(4):261-9. [pmid: 12468901].
Status: Not included because dementia population not randomized to treatment
Israel L, Melac M, Milinkevitch D, et al. Drug therapy and memory training programs: a double-blind randomized trial of general practice patients with age-associated memory impairment. Int Psychogeriatr. 1994;6(2):155-70. [pmid: 7865703].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Israel L, Myslinski M, Kozarevic D. Nootropic treatment and combined therapy in age-associated memory impairment. Arch Gerontol Geriatr. 1998;27(Suppl 6):269-74.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Itil T, Martorano D. Natural substances in psychiatry (Ginkgo biloba in dementia). Psychopharmacol Bull. 1995;31(1):147-58. [pmid: 7675979].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Itil T M, Mukherjee S, Michael S T. Clinical and electrophysiological effects of suloctidil in elderly patients with multi-infarct dementia (A double-blind placebo-controlled study). Psychopharmacol Bull. 1983;19(4):730-3.
Status: Not included because Jadad Quality Scale score less than three
Itil T M, Eralp E, Ahmed I, et al. The pharmacological effects of Ginkgo biloba, a plant extract, on the brain of dementia patients in comparison with tacrine. Psychopharmacol Bull. 1998;34(3):391-7. [pmid: 9803773].
Status: Not included because dementia population not randomized to treatment
Jacobs E A, Winter P M, Alvis H J, et al. Hyperoxygenation effect on cognitive functioning in the aged. N Engl J Med. Oct 2. 1969;281(14):753-7. [pmid: 4897016].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jani J, Prettyman R. Use of a prescribing protocol in routine clinical practice: Experience following the introduction of donepezil. Psychiatr Bull. 2001;25(5):174-7.
Status: Not included because dementia population not randomized to treatment
Jann M W. Rivastigmine, a new-generation cholinesterase inhibitor for the treatment of Alzheimer's disease. Pharmacotherapy. 2000;20(1 I):1-12. [pmid: 10641971].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jansen W, Bruckner G W, Jansen P. The treatment of senile dementia associated with cerebrovascular insufficiency: a comparative study of buflomedil and dihydrogenated ergot alkaloids. J Int Med Res. 1985;13(1):48-53. [pmid: 3884411].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jansen W, O'Connolly M, Lehmann E, et al. Experimental clinical studies on the effect of eburnamonine in cerebrovascular disorders. Pharmacopsychiatry. Sep. 1986;19(5):389-94. [pmid: 3534902].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jean-Louis G, von Gizycki H, Zizi F. Melatonin effects on sleep, mood, and cognition in elderly with mild cognitive impairment. J Pineal Res. Oct. 1998;25(3):177-83. [pmid: 9745987].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jellinger K, Flament H, Riederer P. Levodopa in the treatment of (pre) senile dementia. Mech Ageing Dev. 1980;14(12):253-2. [pmid: 7010010].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jenike M A, Albert M S, Heller H, et al. Combination therapy with lecithin and ergoloid mesylates for Alzheimer's disease. J Clin Psychiatry. May. 1986;47(5):249-51. [pmid: 3700343].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jenike M A, Albert M S, Heller H, et al. Oral physostigmine treatment for patients with presenile and senile dementia of the Alzheimer's type: a double-blind placebo-controlled trial. J Clin Psychiatry. Jan. 1990;51(1):3-7. [pmid: 2403997].
Status: Not included because dementia population not randomized to treatment
Jenike M A, Albert M, Baer L, et al. Ergot mesylates for Alzheimer's disease: A year-long double-blind trial of 3 mg vs 12 mg daily. Int J Geriatr Psychiatry. 1990;5(6):375-80.
Status: Not included because Jadad Quality Scale score less than three
Jennekens-Schinkel A, Wintzen A R, Lanser J B. A clinical trial with desglycinamide arginine vasopressin for the treatment of memory disorders in man. Prog Neuropsychopharmacol Biol Psychiatry. 1985;9(3):273-84. [pmid: 3898228].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jeste D V, Lacro J P, Bailey A, et al. Lower incidence of tardive dyskinesia with risperidone compared with haloperidol in older patients. J Am Geriatr Soc. Jun. 1999;47(6):716-9. [pmid: 10366172].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jhee S S, Shiovitz T, Hartman R D, et al. Centrally acting antiemetics mitigate nausea and vomiting in patients with Alzheimer's disease who receive rivastigmine. Clin Neuropharmacol. Mar. 2002;25(2):122-3. [pmid: 11981242].
Status: Not included because not a full article
Jobe J B, Smith D M, Ball K, et al. ACTIVE: a cognitive intervention trial to promote independence in older adults. Control Clin Trials. Aug. 2001;22(4):453-79. [pmid: 11514044].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Johnson S A, Simmon V F. Randomized, double-blind, placebo-controlled international clinical trial of the AMPAKINE CX516 in elderly participants with mild cognitive impairment. A progress report. J Mol Neurosci. 2002;19(12):197-200. [pmid: 12212780].
Status: Not included because no extractable data relevant to review
Johnstone E C, Owens D G, Crow T J, et al. Does a four-week delay in the introduction of medication alter the course of functional psychosis?. J Psychopharmacol (Oxf). 1999;13(3):238-44.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jolkkonen J T, Soininen H S, Riekkinen P J. The effect of ACTH4-9 analog (Org2766) on some cerebrospinal fluid parameters in patients with Alzheimer's disease. Life Sci. Aug 19. 1985;37(7):585-90. [pmid: 2991689].
Status: Not included because does not meet criteria for treatment for dementia patients
Jones G M, Sahakian B J, Levy R, et al. Effects of acute subcutaneous nicotine on attention, information processing and short-term memory in Alzheimer's disease. Psychopharmacologia. 1992;108(4):485-94.
Status: Not included because dementia population not randomized to treatment
Jonsson A, Korfitzen E M, Heltberg A, et al. Effects of neuropsychological treatment in patients with multiple sclerosis. Acta Neurol Scand. Dec. 1993;88(6):394-400. [pmid: 8116338].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jonsson L, Lindgren P, Wimo A, et al. The cost-effectiveness of donepezil therapy in Swedish patients with Alzheimer's disease: A Markov model. Clin Ther. 1999;21(7):1230-40. [pmid: 10463520].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jonsson L, Gerth W, Fastbom J. The potential economic consequences of cognitive improvement with losartan. Blood Press. 2002;11(1):46-52. [pmid: 11926351].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jorgenson S, Bille A, Andersen J, et al. Fluvoxamine treatment of dementia: Tryptophan levels. Biol Psychiatry. 1993;34(8):587-8. [pmid: 8274593].
Status: Not included because not a full article
Jorissen B L, Brouns F, Van Boxtel M P, et al. The influence of soy-derived phosphatidylserine on cognition in age-associated memory impairment. Nutr Neurosci. 2001;4(2):121-34. [pmid: 11842880].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jorissen B L, Brouns F, Van Boxtel M P J, et al. Safety of soy-derived phosphatidylserine in elderly people. Nutr Neurosci. 2002;5(5):337-43. [pmid: 12385596].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Jotkowitz S. Lack of clinical efficacy of chronic oral physostigmine in Alzheimer's disease. Ann Neurol. Dec. 1983;14(6):690-1. [pmid: 6360031].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Judge K S, Camp C J, Orsulic-Jeras S. Use of Montessori-based activities for clients with dementia in adult day care: Effects on engagement. Am J Alzheimers Dis. 2000;15(1):42-6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Judge T G, Urquhart A. Naftidrofuryl: a double blind cross-over study in the elderly. Curr Med Res Opin. 1972;1(3):166-72. [pmid: 4589711].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Juvars K A, McDonald C. A controlled trial of butyrylperazine (“Randolectil”) in senile dementia. Med J Aust. Feb 18. 1967;1(7):334-5. [pmid: 5338146].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kahana E, Kahana B. Therapeutic potential of age integration. Effects of age-integrated hospital environments on elderly psychiatric patients. Arch Gen Psychiatry. Jul. 1970;23(1):20-9. [pmid: 5447373].
Status: Not included because no extractable data relevant to review
Kanamori M, Suzuki M, Yamamoto K, et al. A day care program and evaluation of animal-assisted therapy (AAT) for the elderly with senile dementia. Am J Alzheimers Dis. 2001;16(4):234-9.
Status: Not included because dementia population not randomized to treatment
Kanowski S, Kinzler E, Lehmann E, et al. Confirmed clinical efficacy of Actovegin in elderly patients with organic brain syndrome. Pharmacopsychiatry. Jul. 1995;28(4):125-33. [pmid: 7491366].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kapur N, Ironside J, Abbott P, et al. A neuropsychological-neuropathological case study of variant Creutzfeldt-Jakob disease. Neurocase. 2001;7(3):261-7. [pmid: 11459921].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kario K, Matsuo T, Hoshide S, et al. Effect of thrombin inhibition in vascular dementia and silent cerebrovascular disease. An MR spectroscopy study. Stroke. May. 1999;30(5):1033-7. [pmid: 10229740].
Status: Not included because dementia population not randomized to treatment
Karlsson I, Brane G, Melin E, et al. Effects of environmental stimulation on biochemical and psychological variables in dementia. Acta Psychiatr Scand. 1988;77(2):207-13. [pmid: 2452557].
Status: Not included because dementia population not randomized to treatment
Karlsson J, Hallgren P, Kral J, et al. Predictors and effects of long-term dieting on mental well-being and weight loss in obese women. Appetite. Aug. 1994;23(1):15-26. [pmid: 7826054].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Karoutas G, Milonas I, Artemis N, et al. The pharmacological effects of buflomedil in patients with multi-cerebral infarcts dementia: An open, preliminary assessment. Curr Med Res Opin. 1986;Vol 10:380-9.
Status: Not included because dementia population not randomized to treatment
Kasckow J W, McElroy S L, Cameron R I. A pilot study on the use of divalproex sodium in the treatment of behavioral agitation in elderly patients with dementia: assessment with the BEHAVE-AD and CGI rating scales. Current therapeutic research, clinical and experimental. 1997;58(981):989.
Status: Not included because dementia population not randomized to treatment
Katzman R, Zhang M, YChen P J, et al. Effects of apolipoprotein E on dementia and aging in the Shanghai Survey of Dementia. Neurology. 1997;49(3):779-85. [pmid: 9305340].
Status: Not included because does not meet criteria for treatment for dementia patients
Kaufer D I. Pharmacologic therapy of dementia with Lewy bodies. J Geriatr Psychiatry Neurol. 2002;15(4):224-32. [pmid: 12489919].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kaye W H, Sitaram N, Weingartner H, et al. Modest facilitation of memory in dementia with combined lecithin and anticholinesterase treatment. Biol Psychiatry. 1982;17(2):275-80. [pmid: 7074185].
Status: Cross-over trial;
Kazui H, Mori E, Hashimoto M, et al. Impact of emotion on memory. Controlled study of the influence of emotionally charged material on declarative memory in Alzheimer's disease. Br J Psychiatry. 2000;177:343-7. [pmid: 11116776].
Status: Not included because does not meet criteria for treatment for dementia patients
Kempenaar L, McNamara C, Creaney B. Sensory stimulation work with carers in the community. Journal of Dementia Care. 2001;9(1):16.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kertesz A. Efficacy of galantamine in probable vascular dementia and Alzheimer's disease combined with cerebrovascular disease: A randomized trial. Curr Neurol Neurosci Rep. Nov. 2002;2(6):503-4. [pmid: 12359103].
Status: Not included because not a full article
Khan A, Mirolo M H, Claypoole K, et al. Low-dose thyrotropin-releasing hormone effects in cognitively impaired alcoholics. Alcohol Clin Exp Res. Aug. 1993;17(4):791-6. [pmid: 8214416].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kieburtz K, Schifitto G, McDermott M, et al. Safety and tolerability of the antioxidant OPC-14117 in HIV-associated cognitive impairment. Neurology. 1997;49(1):142-6. [pmid: 9222182].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kieburtz K, Schifitto G, McDermott M, et al. A randomized, double-blind, placebo-controlled trial of deprenyl and thioctic acid in human immunodeficiency virus-associated cognitive impairment. Neurology. 1998;50(3):645-51. [pmid: 9521250].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kim J M, Shin I S, Yoon J S. Correlates of dropout, efficacy, and adverse events in treatment with acetylcholinesterase inhibitors in Korean patients with Alzheimer's disease. Int Psychogeriatr. 2002;14(2):187-95. [pmid: 12243209].
Status: Not included because Jadad Quality Scale score less than three
Kimura M, Robinson R G, Kosier J T. Treatment of cognitive impairment after poststroke depression: A double-blind treatment trial. Stroke. Jul. 2000;31(7):1482-6. [pmid: 10884441].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
King AC, Brassington G. Enhancing physical and psychological functioning in older family caregivers: The role of regular physical activity. Ann Behav Med 1997; (No. 2):91–100.
Status: Not included because does not meet criteria for treatment for dementia patients
Kirby M, Denihan A, Bruce I, et al. Benzodiazepine use among the elderly in the community. Int J Geriatr Psychiatry. 1999;14(4):280-4. [pmid: 10340189].
Status: Not included because dementia population not randomized to treatment
Kirrane R M, Mitropoulou V, Nunn M, et al. Physostigmine and cognition in schizotypal personality disorder. Schizophr Res. Mar 1. 2001;48(1):1-5. [pmid: 11278149].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kishimoto T, Hiraoka Y, Oribe H, et al. Auditory P300 event-relaed potentials and mini mental state examination performance in dementia; effects of Idebenone and Vinpocetine. J Nara Med Assoc. 1995;46(3):259-66.
Status: Not included because dementia population not randomized to treatment
Kittner B. Using a combined randomized start/withdrawal design to assess propentofylline's effect on disease progression in Alzheimer's disease and vascular dementia. J Neural Transm Gen Sect. 2000;107:XV.
Status: Not included because does not meet criteria for treatment for dementia patients
Kittner B. Propentofylline for the treatment of vascular dementia: A 48-week, placebo-controlled study examining safety, efficacy, and impact on disease progression. J Cereb Blood Flow Metab. 1999;19(Suppl 1):16.
Status: Not included because not a full article
Kittner B. Using a combined randomized start/withdrawal design to assess propentofylline's effects on disease progression in Alzheimer's disease and vascular dementia: Results of clinical studies. J Eur Coll Neuropsychopharmacol. 1999;9(Suppl 5):S320.
Status: Not included because not a full article
Kittner B. Clinical trials of propentofylline in vascular dementia. European/Canadian Propentofylline Study Group. Alzheimer Dis Assoc Disord. 1999;13(Suppl 3):S166-S171. [pmid: 10609697].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kittner B, De Deyn P P, Erkinjuntti T. Investigating the natural course and treatment of vascular dementia and Alzheimer's disease. Parallel study populations in two randomized, placebo-controlled trials. Ann N Y Acad Sci. Apr. 2000;903:535-41. [pmid: 10818549].
Status: Not included because Jadad Quality Scale score less than three
Knezevic S, Mubrin Z, Risberg J, et al. Pyritinol treatment of SDAT patients: evaluation by psychiatric and neurological examination, psychometric testing and rCBF measurements. Int Clin Psychopharmacol. Jan. 1989;4(1):25-38. [pmid: 2687355].
Status: Cross-over trial;
Knopman D. Long-term retention of implicitly acquired learning in patients with Alzheimer's disease. J Clin Exp Neuropsychol. 1991;13(6):880-94. [pmid: 1779028].
Status: Not included because does not meet criteria for treatment for dementia patients
Knopman D, Schneider L, Davis K, et al. Long-term tacrine treatment effects. Neurology. Feb. 1998;50(2):567-8. [pmid: 9484404].
Status: Not included because dementia population not randomized to treatment
Knopman D S. Metrifonate for Alzheimer's disease: Is the next cholinesterase inhibitor better?. Neurology. 1998;50(5):1203-5. [pmid: 9595961].
Status: Not included because dementia population not randomized to treatment
Knopman D, Gracon S. Observations on the short-term “natural history” of probable Alzheimer's disease in a controlled clinical trial. Neurology. 1994;44(2):260-5. [pmid: 7991118].
Status: Not included because does not meet criteria for treatment for dementia patients
Knott V, Mohr E, Mahoney C, et al. Pharmaco-EEG test dose response predicts cholinesterase inhibitor treatment outcome in Alzheimer's disease. Methods & Findings in Experimental & Clinical Pharmacology. Mar. 2000;22(2):115-22. [pmid: 10849895].
Status: Not included because dementia population not randomized to treatment
Knott V, Engeland C, Mohr E, et al. Acute nicotine administration in Alzheimer's disease: An exploratory EEG study. Neuropsychobiology. 2000;41(4):210-20. [pmid: 10828731].
Status: Not included because dementia population not randomized to treatment
Knox J, Hindmarch I, Wallace M. Effects of twice standard dosage of neuroactive drugs in dementia. A preliminary report. Br J Clin Pract. Sep. 1984;38(9):313-5. [pmid: 6477811].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kodjian A, Barriaga C, Turcot G. Double-blind study of pimozide in senile dementia patients. Curr Ther Res Clin Exp. 1986;40(4):694-701.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kofler B, Erhart C, Erhart P, et al. A multidimensional approach in testing nootropic drug effects (Cerebrolysin (R)). Arch Gerontol Geriatr. 1990;10(2):129-40. [pmid: 15374509].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kogan E A, Korczyn A D, Virchovsky R G, et al. EEG changes during long-term treatment with donepezil in Alzheimer's disease patients. J Neural Transm Gen Sect. 2001;108(10):1167-73.
Status: Not included because dementia population not randomized to treatment
Koh K, Ray R, Lee J, et al. Dementia in elderly patients: Can the 3R mental stimulation programme improve mental status?. Age Ageing. 1994;23(3):195-9. [pmid: 8085503].
Status: Not included because dementia population not randomized to treatment
Koivisto, Portin M, Seinela R, et al. Automatic influences of memory in Alzheimer's disease. Cortex. 1998;34(2):209-19. [pmid: 9606586].
Status: Not included because does not meet criteria for treatment for dementia patients
Koivisto K, Helkala E L, Hanninen T, et al. Long-term selegiline treatment reduces the progression of Alzheimer's disease: Results after three years' follow-up. Alzheimers Res. 1995;1(Suppl 1):28.
Status: Not included because not a full article
Koltai D C, Welsh-Bohmer K A, Schmechel D E. Influence of anosognosia on treatment outcome among dementia patients. Neuropsychol Rehab. 2001;11(34):455-75.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Koltringer P, Langsteger W, Eber O. Dose-dependent hemorheological effects and microcirculatory modifications following intravenous administration of Ginkgo biloba special extract EGb 761. Clin Hemorheol. 1995;15(4):649-56.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kompoliti K, Goetz C G, Boeve B F, et al. Clinical presentation and pharmacological therapy in corticobasal degeneration. Arch Neurol. Jul. 1998;55(7):957-61. [pmid: 9678313].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kontush A, Mann U, Arlt S, et al. Influence of vitamin E and C supplementation on lipoprotein oxidation in patients with Alzheimer's disease. Free Radic Biol Med. Aug 1. 2001;31(3):345-54. [pmid: 11461772].
Status: Not included because dementia population not randomized to treatment
Kosten T R, Rosen M I, McMahon T L, et al. Treatment of early AIDS dementia in intravenous drug users: High versus low dose peptide T. Am J Drug Alcohol Abuse. Nov. 1997;23(4):543-53. [pmid: 9366972].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kountouris D. Therapeutic effects of piracetam combined with intravenous immunoglobulin premature of Alzheimer type. J Neural Transm Gen Sect. 2000;107:XVIII.
Status: Not included because not a full article
Krebs Roubicek EM. Group theray with demented elderly. Alzheimers Dis Relat Disord 1989; 1261–72.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kristensen V, Olsen M, Theilgaard A. Levodopa treatment of presenile dementia. Acta Psychiatr Scand. Jan. 1977;55(1):41-51. [pmid: 842382].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kruck T P A, Fisher E A, McLachln D R C. Prediction of side effects in Alzheimer's disease patients on longterm deferoxamine-mesylate treatment. Alzheimers Dis Relat Disord Adv Biosci. 1993;87:257-8.
Status: Not included because no extractable data relevant to review
Kruck T P A, Fisher E A, Mclachlan D R C. A predictor for side effects in patients with alzheimer's disease treated with deferoxamine mesylate. Clin Pharmacol Ther. 1993;53(1):30-7. [pmid: 8422739].
Status: Not included because dementia population not randomized to treatment
Kuhl D E, Minoshima S, Frey K A, et al. Limited donepezil inhibition of acetylcholinesterase measured with positron emission tomography in living Alzheimer cerebral cortex. Ann Neurol. Sep. 2000;48(3):391-5. [pmid: 10976649].
Status: Not included because dementia population not randomized to treatment
Kuhn D R, de Leon C F M. Evaluating an educational intervention with relatives of persons in the early stages of Alzheimer's disease. Res Soc Work Pract. Sep. 2001;11(5):531-48.
Status: Not included because does not meet criteria for treatment for dementia patients
Kulisevsky J, Garcia-Sanchez C, Berthier M L, et al. Chronic effects of dopaminergic replacement on cognitive function in Parkinson's disease: A two-year follow-up study of previously untreated patients. Mov Disord. Jul. 2000;15(4):613-26. [pmid: 10928571].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kumar V, Smith RC, Sherman KA, et al. Cortisol responses to cholinergic drugs in Alzheimer's disease. Int J Clin Pharmacol Ther Toxicol ; 26(10):471–6.
Status: Not included because dementia population not randomized to treatment
Kumar V, Brecher M. Psychopharmacology of atypical antipsychotics and clinical outcomes in elderly patients. J Clin Psychiatry. 1999;60(Suppl 13):5-9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kuskowski M A, Morley G, Malone S M, et al. Hydergine treatment and psychophysiological measures in primary degenerative dementia. J Geriatr Psychiatry Neurol. Jan. 1990;3(1):41-7. [pmid: 2189430].
Status: Not included because dementia population not randomized to treatment
Kwiecinski H, Lusakowska A, Mieszkowski J. Improvement in concentration following treatment with Ginseng/Ginkgo biloba combination in patients with chronic cerebrovascular disorders: A double-blind, placebo-controlled study. Eur J Clin Res. 1997;9:59-67.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Kwok T, Tang C, Woo J, et al. Randomized trial of the effect of supplementation on the cognitive function of older people with subnormal cobalamin levels. Int J Geriatr Psychiatry. Sep. 1998;13(9):611-6. [pmid: 9777425].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
LaBarge E, Rosenman L S, Leavitt K, et al. Counseling Clients with Mild Senile Dementia of the Alzhemier's Type: A Pilot Study. J Neurol Rehabil. 1988;2(4):167-73.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
LaBrecque DC, Goldberg RI. A double-blind study of pentylenetetrazol combined with niacin in senile patients. Curr Ther Res Clin Exp ; 9(12):611–7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lacomblez L, Chatellier L. Tetrahydroaminoacridine (THA) in Alzheimer's disease (AD): A double-blind pilot study. Fundam Clin Pharmacol. 1989;3(2):172.
Status: Not included because not a full article
Lacomblez L, Chatellier L. A multicenter trial of tetrahydroaminoacridine in senile dementia of the Alzheimer type. Fundam Clin Pharmacol. 1990;4(4):456.
Status: Not included because not a full article
Lamb H M, Faulds D. Metrifonate. Drugs Aging. 1997;11(6):490-6. [pmid: 9413706].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lanctot K L, Herrmann N, Van Reekum R, et al. Gender, aggression and serotonergic function are associated with response to sertraline for behavioral disturbances in Alzheimer's disease. Int J Geriatr Psychiatry. 2002;17(6):531-41. [pmid: 12112177].
Status: Cross-over trial;
Landi F, Bernabei R, Russo A, et al. Predictors of rehabilitation outcomes in frail patients treated in a geriatric hospital. J Am Geriatr Soc. 2002;50(4):679-84. [pmid: 11982668].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lange K W, Robbins T W, Marsden C D, et al. L-dopa withdrawal in Parkinson's disease selectively impairs cognitive performance in tests sensitive to frontal lobe dysfunction. Psychopharmacologia. 1992;107(23):394-3.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lange K W, Paul G M, Naumann M, et al. Dopaminergic effects on cognitive performance in patients with Parkinson's disease. J Neural Transm Suppl. 1995;46:423-32. [pmid: 8821078].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Langlais P J, Mair R G, Whalen P J, et al. Memory effect of DL-threo-3,4-dihydroxyphenylserine (DOPS) in human Korsakoff's disease. Psychopharmacologia. 1988;95(2):250-4.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
LaPorte D J, Lahti A C, Koffel B, et al. Absence of ketamine effects on memory and other cognitive functions in schizophrenia patients. J Psychiatr Res. Sep. 1996;30(5):321-30. [pmid: 8923336].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lawlor B A, Mellow A M, Sunderland T, et al. A pilot study of serotonergic system responsivity in Alzheimer's disease. Psychopharmacol Bull. 1988;24(1):127-9. [pmid: 3290935].
Status: Not included because Jadad Quality Scale score less than three
Lawlor B A, Sunderland T, Mellow A M, et al. Hyperresponsivity to the serotonin agonist m-chlorophenylpiperazine in Alzheimer's disease. A controlled study. Arch Gen Psychiatry. Jun. 1989;46(6):542-9. [pmid: 2730278].
Status: Cross-over trial;
Lawlor B A, Sunderland T, Mellow A M, et al. A pilot placebo-controlled study of chronic m-CPP administration in Alzheimer's disease. Biol Psychiatry. Jul 15. 1991;30(2):140-4. [pmid: 1932406].
Status: Cross-over trial;
Lawlor B A, Radcliffe J, Molchan S E, et al. A pilot placebo-controlled study of trazodone and buspirone in Alzheimer's disease. Int J Geriatr Psychiatry. 1994;9(1):55-9.
Status: Cross-over trial;
Lawlor B A, Aisen P S, Green C, et al. Selegiline in the treatment of behavioural disturbance in Alzheimer's disease. Int J Geriatr Psychiatry. Mar. 1997;12(3):319-22. [pmid: 9152715].
Status: Cross-over trial;
Laws S M, Clarnette R M, Taddei K, et al. APOE-epsilon4 and APOE-491A polymorphisms in individuals with subjective memory loss. Mol Psychiatry. 2002;7(7):768-75. [pmid: 12192622].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lawton M P, Van Haitsma K, Klapper J, et al. A stimulation-retreat special care unit for elders with dementing illness. Int Psychogeriatr. Dec. 1998;10(4):379-95. [pmid: 9924833].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lawton M P, Brody E M, Saperstein A B, et al. Respite services for caregivers: Research findings for service planning. Home Health Care Serv Q. 1989;10(12):5-32. [pmid: 10318337].
Status: Not included because does not meet criteria for treatment for dementia patients
Lawton MP, Brody EM, Saperstein AR. Controlled study of respite service for caregivers of Alzheimer's patients. Gerontologist 1989 Feb; (1):8–16.
Status: Not included because does not meet criteria for treatment for dementia patients
Lazar P A. Ginkgo is not a smart pill. J Fam Pract. Nov. 2002;51(11):912. [pmid: 12485537].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Leblhuber F, Neubauer C, Peichl M, et al. Age and sex differences of dehydroepiandrosterone sulfate (DHEAS) and cortisol (CRT) plasma levels in normal controls and Alzheimer's disease (AD). Psychopharmacologia. 1993;111(1):23-6.
Status: Not included because dementia population not randomized to treatment
Leblhuber F, Walli J, Widner B, et al. Homocysteine and B vitamins in dementia. Am J Clin Nutr. 2001;73(1):127-8. [pmid: 11124762].
Status: Not included because not a full article
Lebowitz B D, Pollock B G, Schneider L S. Estrogen in geriatric psychopharmacology. Psychopharmacol Bull. 1997;33(2):287-8. [pmid: 9230644].
Status: Not included because not a full article
Lechner H, Walzl M, Walzl B, et al. HELP application in multi-infarct dementia. Journal of Stroke and Cerebrovascular Diseases. 1992;2:228-31.
Status: Not included because Jadad Quality Scale score less than three
Leckman J, Ananth J V, Ban T A, et al. Pentylenetetrazol in the treatment of geriatric patients with disturbed memory function. J Clin Pharmacol New Drugs. Jul. 1971;11(4):301-3. [pmid: 4932747].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lehmann H E, Ban T A, Saxena B M. Nicotinic acid, thioridazine, fluoxymesterone and their combinations in hospitalized geriatric patients: A systematic clinical study. Can Psychiatr Assoc J. Aug. 1972;17(4):315-20. [pmid: 4565508].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Leighman L, Stotsky B A, Cole J O. A controlled study of drugs in long-term geriatric psychiatric patients: A double-blind comparison of pentylenetetrazol, papaverine, and niacin. Arch Gen Psychiatry. Sep. 1971;25:284-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lerner V, Miodownik C, Kaptsan A, et al. Vitamin B6 as add-on treatment in chronic schizophrenic and schizoaffective patients: a double-blind, placebo-controlled study. J Clin Psychiatry. Jan. 2002;63(1):54-8. [pmid: 11838627].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Leszek J, Inglot A D, Janusz M, et al. Colostrinin proline-rich polypeptide complex from ovine colostrum - A long-term study of its efficacy in Alzheimer's disease. Med Sci Monit. 2002;8(10):I93-I96. [pmid: 12388930].
Status: Not included because dementia population not randomized to treatment
Levin H S. Cognitive rehabilitation. Unproved but promising. Arch Neurol. Feb. 1990;47(2):223-4. [pmid: 2222244].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Levine F M, Spitalnik R, Dobos C. Caudate nucleus effects on geriatric senility: Effect of belladonna on learning and memory of geriatric patients. Percept Mot Skills. Dec. 1973;37(3):1003-7. [pmid: 4764492].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
LeVine H III, Scholten J D. Screening for pharmacologic inhibitors of amyloid fibril formation. Methods Enzymol. 1999;309:467-76. [pmid: 10507041].
Status: Not included because dementia population not randomized to treatment
Levinson B, Wright P, Barklem S. Effect of buflomedil on behaviour, memory, and intellectual capacity in patients with dementia. A placebo-controlled study. S Afr Med J. Aug 31. 1985;68(5):302-7. [pmid: 3898413].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Levkovitz Y, Bloch Y, Kaplan D, et al. Fluvoxamine for psychosis in Alzheimer's disease. J Nerv Ment Dis. Feb. 2001;189(2):126-9. [pmid: 11225688].
Status: Cross-over trial;
Levy A, Brandeis R, Treves T A, et al. Transdermal physostigmine in the treatment of Alzheimer's disease. Alzheimer Dis Assoc Disord. 1994;8(1):15-21. [pmid: 8185877].
Status: Not included because dementia population not randomized to treatment
Levy M A, Burgio L D, Sweet R, et al. A trial of buspirone for the control of disruptive behaviors in community-dwelling patients with dementia. Int J Geriatr Psychiatry. 1994;9(10):841-8.
Status: Not included because dementia population not randomized to treatment
Levy R, Little A, Chuaqui P, et al. Early results from double-blind, placebo controlled trial of high dose phosphatidylcholine in Alzheimer's disease. Lancet. Apr 30. 1983;1(8331):987-8. [pmid: 6132292].
Status: Not included because not a full article
Lewis C, Ballinger B R, Presly A S. Trial of levodopa in senile dementia. BMJ. Mar 4. 1978;1(6112):550. [pmid: 343866].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Li C, Jiang Z, Wu D, et al. Clinical study on treating vascular dementia by muskiness injection in points. Int J Clin Acupunct. 2002;13(1):1-7.
Status: Not included because Jadad Quality Scale score less than three
Lincoln N B, Dent A, Harding J, et al. Evaluation of cognitive assessment and cognitive intervention for people with multiple sclerosis. J Neurol Neurosurg Psychiatry. 2002;72(1):93-8. [pmid: 11784832].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lindner K, Bedard M, William M D, et al. Changes in medication use and functional status of community-dwelling Alzheimer's patients after consultation at a memory clinic. Clin Gerontol. 2001;22(34):13-21.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Linn M W, Gurel L, Williford W O, et al. Nursing home care as an alternative to psychiatric hospitalization. A Veterans Administration cooperative study. Arch Gen Psychiatry. Jun. 1985;42(6):544-51. [pmid: 4063010].
Status: Not included because does not meet criteria for treatment for dementia patients
Lipper S, Tuchman M M. Treatment of chronic post-traumatic organic brain syndrome with dextroamphetamine: First reported case. J Nerv Ment Dis. May. 1976;162(5):366-71. [pmid: 1262859].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lipton S A, Dafni U, Simpson D, et al. Double blind randomised placebo-controlled trial of the calcium channel antagonist Nimodipine for the neurological manifestations of acquired immunodeficiency syndrome, including dementia and painful neuropathy. Ann Neurol. 1995;38:347.
Status: Not included because not a full article
Little A, Levy R, Chuaqui-Kidd P, et al. A double-blind, placebo controlled trial of high-dose lecithin in Alzheimer's disease. J Neurol Neurosurg Psychiatry. 1985;48(8):736-42. [pmid: 3897460].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Litvan I, Gomez C, Atack J R, et al. Physostigmine treatment of progressive supranuclear palsy. Ann Neurol. Sep. 1989;26(3):404-7. [pmid: 2802540].
Status: Cross-over trial;
Litvan I, Blesa R, Clark K, et al. Pharmacological evaluation of the cholinergic system in progressive supranuclear palsy. Ann Neurol. Jul. 1994;36(1):55-61. [pmid: 8024262].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Litvan I, Sirigu A, Toothman J, et al. What can preservation of autobiographic memory after muscarinic blockade tell us about the scopolamine model of dementia?. Neurology. Feb. 1995;45(2):387-9. [pmid: 7854546].
Status: Not included because dementia population not randomized to treatment
Litvan I, FitzGibbon E J. Can tropicamide eye drop response differentiate patients with progressive supranuclear palsy and Alzheimer's disease from healthy control subjects?. Neurology. 1996;47(5):1324-6. [pmid: 8909451].
Status: Not included because does not meet criteria for treatment for dementia patients
Litvan I, Phipps M, Pharr V L, et al. Randomized placebo-controlled trial of donepezil in patients with progressive supranuclear palsy. Neurology. Aug 14. 2001;57(3):467-73. [pmid: 11502915].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Llorente A M, van Gorp W G, Stern M J, et al. Long-term effects of high-dose zidovudine treatment on neuropsychological performance in mildly symptomatic HIV-positive patients: Results of a randomized, double-blind, placebo-controlled investigation. J Int Neuropsychol Soc. Jan. 2001;7(1):27-32. [pmid: 11253839].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lloyd-Evans S, Brocklehurst J C, Palmer M K. Piracetam in chronic brain failure. Curr Med Res Opin. 1979;6(5):351-7. [pmid: 540525].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Loher T J, Krauss J K, Wielepp J P, et al. Pallidal deep brain stimulation in a parkinsonian patient with late-life dementia: Sustained benefit in motor symptoms but not in functional disability. Eur Neurol. 2002;47(2):122-3. [pmid: 11844902].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Londos E, Passant U, Gustafson L. Blood pressure and drug treatment in clinically diagnosed Lewy body dementia and Alzheimer's disease. Arch Gerontol Geriatr. 2000;30(1):35-46. [pmid: 15374047].
Status: Not included because does not meet criteria for treatment for dementia patients
Lopez O L, Becker J T, Wisniewski S, et al. Cholinesterase inhibitor treatment alters the natural history of Alzheimer's disease. J Neurol Neurosurg Psychiatry. Mar. 2002;72(3):310-4. [pmid: 11861686].
Status: Not included because dementia population not randomized to treatment
Lord T R, Garner J E. Effects of music on Alzheimer patients. Percept Mot Skills. Apr. 1993;76(2):451-5. [pmid: 8483655].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lott I T, Osann K, Doran E, et al. Down syndrome and Alzheimer disease: Response to donepezil. Arch Neurol. 2002;59(7):1133-6. [pmid: 12117361].
Status: Not included because dementia population not randomized to treatment
Lovett W C, Stokes D K, Taylor L B, et al. Management of behavioral symptoms in disturbed elderly patients: Comparison of trifluoperazine and haloperidol. J Clin Psychiatry. Jun. 1987;48(6):234-6. [pmid: 3294815].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Lucca U, Tettamanti M, Forloni G, et al. Nonsteroidal antiinflammatory drug use in Alzheimer's disease. Biol Psychiatry. Dec. 1994;36(12):854-6. [pmid: 7893851].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Luccal U, Lucchelli F, Alberoni M, et al. Reliability and correlation measures of cognitive function and behavioural scales in controlled clinical trial of eptastigmine in Alzheimer's disease patients. J Neurol. 1995;242:S106.
Status: Not included because not a full article
Lupien S J, Wilkinson C W, Briere S, et al. Acute modulation of aged human memory by pharmacological manipulation of glucocorticoids. J Clin Endocrinol Metab. 2002;87(8):3798-807. [pmid: 12161513].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Luqman WA, Riesenberg D, Oakley N, et al. Tacrine for Alzheimer's disease. JAMA 1994; (24):1896–8.
Status: Not included because not a full article
Lyford J. Statins reduce dementia risk by 70%. Cur Control Trials Cardiovasc Med. 2000;1(3):172.
Status: Not included because not a full article
Lyketsos C G, Lindell V L, Baker A, et al. A randomized, controlled trial of bright light therapy for agitated behaviors in dementia patients residing in long-term care. Int J Geriatr Psychiatry. Jul. 1999;14(7):520-5. [pmid: 10440971].
Status: Cross-over trial;
MacGowan S H, Wilcock G K, Scott M. Effect of gender and apolipoprotein E genotype on response to anticholinesterase therapy in Alzheimer's disease. Int J Geriatr Psychiatry. Sep. 1998;13(9):625-30. [pmid: 9777427].
Status: Not included because dementia population not randomized to treatment
MacMahon S, Kermode S. A clinical trial of the effect of aromatherapy on motivational behaviour in a dementia care setting using a single subject design. Aust J Holist Nurs. Oct. 1998;5(2):47-9. [pmid: 10428895].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Madhusoodanan S, Brenner R, Cohen C I. Role of atypical antipsychotics in the treatment of psychosis and agitation associated with dementia. CNS Drugs. 1999;12(2):135-50.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Maestri N E, Brusilow S W, Clissold D B, et al. Long-term treatment of girls with ornithine transcarbamylase deficiency. N Engl J Med. Sep 19. 1996;335(12):855-9. [pmid: 8778603].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Magai C, Cohen C I, Gomberg D. Impact of training dementia caregivers in sensitivity to nonverbal emotion signals. Int Psychogeriatr. Mar. 2002;14(1):25-38. [pmid: 12094904].
Status: Not included because does not meet criteria for treatment for dementia patients
Magnus R V. A controlled trial of chlormethiazole in the management of symptoms of the organic dementias in the elderly. Clin Ther. 1978;1(6):387-96.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Maidment R, Livingston G, Katona C. ‘Just keep taking the tablets’: Adherence to antidepressant treatment in older people in primary care. Int J Geriatr Psychiatry. 2002;17(8):752-7. [pmid: 12211126].
Status: Not included because does not meet criteria for treatment for dementia patients
Mair R G, McEntee W J. Cognitive enhancement in Korsakoff's psychosis by clonidine: A comparison with L-dopa and ephedrine. Psychopharmacologia. 1986;88(3):374-80.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Malaguarnera M, Pistone G, Vinci M, et al. Tacrine treatment of Alzheimer's disease: Many expectations, few certainties. Neuropsychobiology. Nov. 1998;38(4):226-31. [pmid: 9813462].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Malaret B. Use of music to decrease aggressive behaviours in people with dementia. J Am Geriatr Soc. 1998;46(12):1586.
Status: Not included because not a full article
Manes F, Jorge R, Morcuende M, et al. A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. Int Psychogeriatr. 2001;13(2):225-31. [pmid: 11495396].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mann A H, Schneider J, Mozley C G, et al. Depression and the response of residential homes to physical health needs. Int J Geriatr Psychiatry. 2000;15(12):1105-12. [pmid: 11180466].
Status: Not included because does not meet criteria for treatment for dementia patients
Mann K, Gunther A, Stetter F, et al. Rapid recovery from cognitive deficits in abstinent alcoholics: A controlled test-retest study. Alcohol Alcohol. Jul. 1999;34(4):567-74. [pmid: 10456585].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mantero MA, Barbero M, Giannini R, et al. Acetyl-L-carnitine as a therapeutic agent for mental deterioration in geriatric patients. (Double-blind placebo controlled study). New Trends in Clinical Neuropharmacology 1989; (1):17–24.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Marder K, Tang M X, Alfaro B, et al. Postmenopausal estrogen use and Parkinson's disease with and without dementia. Neurology. Apr. 1998;50(4):1141-3. [pmid: 9566410].
Status: Not included because does not meet criteria for treatment for dementia patients
Marin D B, Bierer L M, Lawlor B A, et al. L-deprenyl and physostigmine for the treatment of Alzheimer's disease. Psychiatry Res. Oct 16. 1995;58(3):181-9. [pmid: 8570774].
Status: Cross-over trial;
Marini G, Caratti C, Peluffo F, et al. Placebo-controlled double-blind study of pramiracetam (CI-879) in the treatment of elderly subjects with memory impairment. Adv Ther. 1992;9(3):136-46.
Status : Not included because dementia population not defined by DSM, NINCDS or ICD
Marra C M, Boutin P, McArthur J C, et al. A pilot study evaluating ceftriaxone and penicillin G as treatment agents for neurosyphilis in human immunodeficiency virus-infected individuals. Clin Infect Dis. Mar. 2000;30(3):540-4. [pmid: 10722441].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. Jun. 2000;176:557-62. [pmid: 10974962].
Status: Not included because does not meet criteria for treatment for dementia patients
Marsh L, Lyketsos C, Reich S G. Olanzapine for the treatment of psychosis in patients with Parkinson's disease and dementia. Psychosomatics. Nov. 2001;42(6):477-81. [pmid: 11815682].
Status: Not included because dementia population not randomized to treatment
Martignoni E, Bono G, Blandini F, et al. Monoamines and related metabolite levels in the cerebrospinal fluid of patients with dementia of Alzheimer type. Influence of treatment with L-deprenyl. J Neural Transm Park Dis Dement Sect. 1991;3(1):15-25. [pmid: 1712206].
Status: Not included because dementia population not randomized to treatment
Martin J C. Effect of a synthetic peptide, ORG 2766, on inpatients with severe senile dementia. Acta Psychiatr Scand. 1983;67(3):205-7. [pmid: 6305110].
Status: Cross-over trial;
Martin P R, Adinoff B, Eckardt M J, et al. Effective pharmacotherapy of alcoholic amnestic disorder with fluvoxamine. Preliminary findings. Arch Gen Psychiatry. Jul. 1989;46(7):617-21. [pmid: 2472126].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Martin P R, Adinoff B, Lane E, et al. Fluvoxamine treatment of alcoholic amnestic disorder. Eur Neuropsychopharmacol. Mar. 1995;5(1):27-33. [pmid: 7542052].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Martin R M, Rink E, Wilkinson D G, et al. Did knowledge, opinions, background, and health authority advice influence early prescribing of the novel Alzheimer's disease drug donepezil in general practice? - National postal survey. Pharmacoepidemiol Drug Saf. 1999;8(6):413-22. [pmid: 15073903].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Martinez Perez J A, Chavida G F, Sanchez-Seco H P, et al. Epidemiology of cognitive impairment in Spain. Eur J Gen Pract. 2000;6(2):52-6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Marx J. Alzheimer's congress. Drug shows promise for advanced disease. Science. Jul 21. 2000;289(5478):375-7. [pmid: 11645196].
Status: Not included because not a full article
Marx J L. Alzheimer's drug trial put on hold. Science. 1987;238(4830):1041-2. [pmid: 2961061].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Masaki K H, Losonczy K G, Izmirlian G, et al. Association of vitamin E and C supplement use with cognitive function and dementia in elderly men. Neurology. 2000;54(6):1265-72. [pmid: 10746596].
Status: Not included because dementia population not randomized to treatment
Masuda Y, Akagawa Y, Hishikawa Y. Effect of serotonin 1A agonist tandospirone on depression symptoms in senile patients with dementia. Hum Psychopharmacol. Jun. 2002;17(4):191-3. [pmid: 12404687].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Matthews H P, Korbey J, Wilkinson D G, et al. Donepezil in Alzheimer's disease: Eighteen month results from Southampton Memory Clinic. Int J Geriatr Psychiatry. Aug. 2000;15(8):713-20. [pmid: 10960883].
Status: Not included because dementia population not randomized to treatment
Maurer I, Moller H J, Saletu B. Treatment with propentofylline in dementia. Pharmacopsychiatry. 1993;26:179.
Status: Not included because not a full article
McCaffrey RJ, Steckler RA, Gansler DA, et al. An experimental evaluation of the efficacy of suloctidil in the treatment of primary degenerative dementia. Arch Clin Neuropsychol 1987; (2):155–61.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McCallion P, Toseland R W, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. [pmid: 9988292].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McCarten JR, Kovera C, Maddox MK, et al. Triazolam in Alzheimer's disease: Pilot study on sleep and memory effects. Pharmacol Biochem Behav ; 52(2):447–52.
Status: Not included because dementia population not randomized to treatment
McClendon MJ, Bass DM, Brennan PF, et al. A computer network for Alzheimer's caregivers and use of support group services. J Ment Health Aging 1998; (4):403–20.
Status: Not included because dementia population not randomized to treatment
McConnachie R W. A clinical trial comparing ‘Hydergine’ with placebo in the treatment of cerebrovascular insufficiency in elderly patients. Curr Med Res Opin. 1973;1(8):463-8. [pmid: 4204090].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McConnachie R W. The clinical assessment of brain failure in the elderly. Pharmacology. 1978;Vol 16(Suppl 1):27-35. [pmid: 347464].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McCusker J, Verdon J, Tousignant P, et al. Rapid emergency department intervention for older people reduces risk of functional decline: Results of a multicenter randomized trial. J Am Geriatr Soc. 2001;49(10):1272-81. [pmid: 11890484].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McDonald C, Mowbray R M, Wilson J M. A sequential trial of amylobarbitone sodium used as sedation for confused female psychogeriatric patients. Gerontol Clin (Basel). 1970;12(6):335-8. [pmid: 4926613].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McEntee W J, Crook T H, Jenkyn L R, et al. Treatment of age-associated memory impairment with guanfacine. Psychopharmacol Bull. 1991;27(1):41-6. [pmid: 1862205].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McGeer P L, McGeer E G. Anti-inflammatory drugs in the fight against Alzheimer's disease. Ann N Y Acad Sci. 1996;777:213-20. [pmid: 8624086].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McKeith I, Del Ser T, Anand Rao. Rivastigmine provides symptomatic benefit in dementia with lewy bodies: Findings from a placebo-controlled international multicenter study. Neurology. 2000;54(Suppl 3):A450.
Status: Not included because not a full article
McKeith I, Del Ser T, Anand R. Erratum: Rivastigmine provides symptomatic benefit in dementia with lewy bodies: Findings from a placebo-controlled international multicenter study. Expert Opin Pharmacother. 2001;2(5):907.
Status: Not included because not a full article
McKeith I G, Grace J B, Walker Z, et al. Rivastigmine in the treatment of dementia with Lewy bodies: Preliminary findings from an open trial. Int J Geriatr Psychiatry. May. 2000;15(5):387-92. [pmid: 11113983].
Status: Not included because dementia population not randomized to treatment
McLachlan D R, Smith W L, Kruck T P. Desferrioxamine and Alzheimer's disease: Video home behavior assessment of clinical course and measures of brain aluminum. Ther Drug Monit. Dec. 1993;15(6):602-7. [pmid: 8122302].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McLean A Jr, Stanton K M, Cardenas D D, et al. Memory training combined with the use of oral physostigmine. Brain Inj. Oct. 1987;1(2):145-59. [pmid: 3454679].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McLean A Jr, Cardenas D D, Burgess D, et al. Placebo-controlled study of pramiracetam in young males with memory and cognitive problems resulting from head injury and anoxia. Brain Inj. Oct. 1991;5(4):375-80. [pmid: 1786500].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McLennan J, Findlay D J, Sharma J, et al. Prolactin response to withdrawal of thioridazine in dementia. Int J Geriatr Psychiatry. 1992;7(10):739-42.
Status: Not included because Jadad Quality Scale score less than three
McNamara M J, Gomez-Isla T, Hyman B T. Apolipoprotein E genotype and deposits of Abeta40 and Abeta42 in Alzheimer disease. Arch Neurol. Jul. 1998;55(7):1001-4. [pmid: 9678319].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
McNeil J K. Neuropsychological characteristics of the dementia syndrome of depression: Onset, resolution, and three-year follow-up. Clin Neuropsychol. 1999;13(2):136-46. [pmid: 10949155].
Status: Not included because does not meet criteria for treatment for dementia patients
Mcpherson A, Furniss F G, Sdogati C, et al. Effects of individualized memory aids on the conversation of persons with severe dementia a pilot study. Aging Ment Health. 2001;5(3):289-94. [pmid: 11575069].
Status: Not included because dementia population not randomized to treatment
McRae T, Griesing T, Whalen E. Donepezil and sertraline for the management of behavioral symptoms in patients with Alzheimer's disease. Neurology. 2000;54(Suppl 3):A416.
Status: Not included because not a full article
Mead M G, Castleden C M. Confusion and hypnotics in demented patients. J R Coll Gen Pract. Dec. 1982;32(245):763-5. [pmid: 6130151]. [pmcid: 1972848].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Meador K, Loring D, Nichols M, et al. Preliminary findings of high-dose thiamine in dementia of Alzheimer's type. J Geriatr Psychiatry Neurol. Oct. 1993;6(4):222-9. [pmid: 8251051].
Status: Cross-over trial;
Mecocci P, Grossi E, Buscema M, et al. Use of artificial networks in clinical trials: A pilot study to predict responsiveness to donepezil in Alzheimer's disease. J Am Geriatr Soc. Nov. 2002;50(11):1857-60. [pmid: 12410907].
Status: Not included because dementia population not randomized to treatment
Medina A, Bodick N, Goldberger A L, et al. Effects of central muscarinic-1 receptor stimulation on blood pressure regulation. Hypertension. Mar. 1997;29(3):828-34. [pmid: 9052903].
Status: Not included because dementia population not randomized to treatment
Mega M S, Dinov I D, Lee L, et al. Orbital and dorsolateral frontal perfusion defect associated with behavioral response to cholinesterase inhibitor therapy in Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 2000;12(2):209-18. [pmid: 11001599].
Status: Not included because dementia population not randomized to treatment
Mega M S, Cummings J L, O'Connor S M, et al. Cognitive and metabolic responses to metrifonate therapy in Alzheimer disease. Neuropsychiatry Neuropsychol Behav Neurol. Jan. 2001;14(1):63-8. [pmid: 11234910].
Status: Not included because dementia population not randomized to treatment
Meier D E, Ahronheim J C, Morris J, et al. High short-term mortality in hospitalized patients with advanced dementia: Lack of benefit of tube feeding. Arch Intern Med. 2001;161(4):594-9. [pmid: 11252121].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Meier U, Kintzel D. Clinical experiences with different valve systems in patients with normal-pressure hydrocephalus: Evaluation of the Miethke dual-switch valve. Childs Nerv Syst. Jul. 2002;18(67):288-94. [pmid: 12172931].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Melin L, Gotestam KG. Effects of rearranging Ward routines on communication and eating behaviors of psychogeriatric patients. J Appl Behav Anal 1981; (No. 1):47–51.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mellow A M, Sunderland T, Cohen R M, et al. Acute effects of high-dose thyrotropin releasing hormone infusions in Alzheimer's disease. Psychopharmacologia. 1989;98(3):403-7.
Status: Cross-over trial;
Mendez M F, Perryman K M. Neuropsychiatric features of frontotemporal dementia: Evaluation of consensus criteria and review. J Neuropsychiatry Clin Neurosci. 2002;14(4):424-9. [pmid: 12426410].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Merrick B J. A geriatric care management approach to a treatment plan for dementia. J Geriatr Psychiatry. 2001;34(2):233-45.
Status: Not included because dementia population not randomized to treatment
Mervis R J, Ganzell S, Fitten L J, et al. Comparison of Carbamazepine and Trazodone in the control of aggression / agitation in demented instituionalized patients. J Am Geriatr Soc. 1991;39(8):A75.
Status: Not included because not a full article
Meszaros Z, Borcsiczky D, Mate M, et al. Platelet MAO-B activity and serotonin content in patients with dementia: Effect of age, medication, and disease. Neurochem Res. Jun. 1998;23(6):863-8. [pmid: 9572675].
Status : Not included because does not meet criteria for treatment for dementia patients
Meyer J S, Rogers R L, McClintic K, et al. Controlled clinical trial of daily aspirin therapy in multi-infarct dementia. Stroke. 1988;19(1):148.
Status: Not included because not a full article
Meyer J S, Rogers R L, McClintic K, et al. Randomized clinical trial of daily aspirin therapy in multi-infarct dementia. A pilot study. J Am Geriatr Soc. Jun. 1989;37(6):549-55. [pmid: 2654259].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Meyer J S, Lotfi J, Martinez G, et al. Effects of medical and surgical treatment on cerebral perfusion and cognition in patients with chronic cerebral ischemia. Surg Neurol. Nov. 1990;34(5):301-8. [pmid: 2218849].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Meyer J S, Li Y, Xu G, et al. Feasibility of treating mild cognitive impairment with cholinesterase inhibitors. Int J Geriatr Psychiatry. Jun. 2002;17(6):586-8. [pmid: 12112184].
Status: Not included because dementia population not randomized to treatment
Meythaler J M, Depalma L, Devivo M J, et al. Sertraline to improve arousal and alertness in severe traumatic brain injury secondary to motor vehicle crashes. Brain Inj. Apr. 2001;15(4):321-31. [pmid: 11299133].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Micca J L, Sky A J, Uhrig-Hitchcock L G. Quality care: A practical guide to managing behavioral symptoms of dementia. Journal of the American Medical Directors Association. 2002;3(Suppl 4):H21-H25. [pmid: 12807630].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Miceli G, Caltagirone C, Gainotti G. Gangliosides in the treatment of mental deterioration. A double-blind comparison with placebo. Acta Psychiatr Scand. Feb. 1977;55(2):102-10. [pmid: 320829].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mielke R, Moller H J, Erkinjuntti T, et al. Propentofylline in the Treatment of Vascular Dementia and Alzheimer-Type Dementia: Overview of Phase I and Phase II Clinical Trials. Alzheimer Dis Assoc Disord. 1998;12:S29-S35. [pmid: 9769027].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Miguel-Hidalgo J J. Rivastigmine Novartis AG. Curr Opin Cent Peripher Nerv Syst Invest Drugs. 2000;2(4):438-53.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Milders M, Deelman B, Berg I. Rehabilitation of memory for people's names. Memory. Jan. 1998;6(1):21-36. [pmid: 9640431].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Miller E. On the nature of the memory disorder in presenile dementia. Neuropsychologia. 1971;9(1):75-81. [pmid: 5146488].
Status: Not included because does not meet criteria for treatment for dementia patients
Miller E. Efficiency of coding and the short-term memory defect in presenile dementia. Neuropsychologia. 1972;10(1):133-6. [pmid: 4628085].
Status: Not included because does not meet criteria for treatment for dementia patients
Miller I W, Norman W H, Keitner G I. Treatment response of high cognitive dysfunction depressed inpatients. Compr Psychiatry. Jan. 1990;31(1):62-71. [pmid: 2404660].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Miller P A, Butin D. The role of occupational therapy in dementia - C.O.P.E. (Caregiver Options for Practical Experiences). Int J Geriatr Psychiatry. 2000;15(1):86-9. [pmid: 10637409].
Status: Not included because dementia population not randomized to treatment
Miller R, Newcomer R, Fox P. Effects of the Medicare Alzheimer's disease demonstration on nursing home entry. Health Serv Res. Aug. 1999;34(3):691-714. [pmid: 10445898]. [pmcid: 1089033].
Status: Not included because does not meet criteria for treatment for dementia patients
Miller R G. Leptazol and meso-inositol hexanicotinate in the treatment of chronic cerebrovascular degenerative disorders. A double blind study. Gerontol Clin (Basel). Oct. 1995;5:95-102.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Miller T P, Fong K, Tinklenberg J R. An ACTH 4–9 analog (Org 2766) and cognitive performance: High-dose efficacy and safety in dementia of the Alzheimer's type. Biol Psychiatry. Feb 15. 1993;33(4):307-9. [pmid: 8386005].
Status: Not included because no extractable data relevant to review
Minger S L, Esiri M M, McDonald B, et al. Cholinergic deficits contribute to behavioral disturbance in patients with dementia. Neurology. 2000;55(10):1460-7. [pmid: 11094098].
Status: Not included because does not meet criteria for treatment for dementia patients
Minthon L, Gustafson L, Dalfelt G, et al. Oral tetrahydroaminoacridine treatment of Alzheimer's disease evaluated clinically and by regional cerebral blood flow and EEG. Dementia. Jan. 1993;4(1):32-42. [pmid: 8358504].
Status: Cross-over trial;
Minthon L, Edvinsson L, Gustafson L. Tacrine treatment modifies cerebrospinal fluid neuropeptide levels in Alzheimer's disease. Dementia. Nov. 1994;5(6):295-301. [pmid: 7866482].
Status: Not included because no extractable data relevant to review
Minthon L, Nilsson K, Edvinsson L, et al. Long-term effects of tacrine on regional cerebral blood flow changes in Alzheimer's disease. Dementia. Sep. 1995;6(5):245-51. [pmid: 8528370].
Status: Not included because dementia population not randomized to treatment
Mintzer J E, Brawman M O, Mirski D F, et al. Anxiety in the behavioral and psychological symptoms of dementia. Int Psychogeriatr. 2000;12(Suppl 1):139-42.
Status: Not included because dementia population not randomized to treatment
Mintzer J E, Madhusoodanan S, Brenner Ronald. Risperidone in dementia. Psychiatr Ann. 2000;30(3):181-7.
Status: Not included because dementia population not randomized to treatment
Mishima K, Okawa M, Hishikawa Y, et al. Morning bright light therapy for sleep and behavior disorders in elderly patients with dementia. Acta Psychiatr Scand. 1994;89(1):1-7. [pmid: 8140901].
Status: Not included because dementia population not randomized to treatment
Mishima K, Hishikawa Y, Okawa M. Randomized, dim light controlled, crossover test of morning bright light therapy for rest-activity rhythm disorders in patients with vascular dementia and dementia of Alzheimer's type. Chronobiol Int. Nov. 1998;15(6):647-54. [pmid: 9844752].
Status: Cross-over trial;
Mitchell A, Drachman D A, O'Connell B, et al. Oral physostigmine in Alzheimer's disease. Neurology. 1986;36(Suppl 1):295.
Status: Not included because not a full article
Mitchell A, Maercklein LA. The effect of individualized special instruction on the behaviors of nursing home residents diagnosed with dementia. Am J Alzheimers Dis 1996; (1):23
Status: Not included because does not meet criteria for treatment for dementia patients
Mitchell S. Aromatherapy's Effectiveness in Disorders Associated With Dementia. Int J Aromatherapy 1993; (2):20–3.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mittelman M S, Ferris S H, Steinberg G, et al. An intervention that delays institutionalization of Alzheimer's disease patients: Treatment of spouse-caregivers. Gerontologist. Dec. 1993;33(6):730-40. [pmid: 8314099].
Status: Not included because does not meet criteria for treatment for dementia patients
Mittelman M S, Ferris S H, Shulman E, et al. A family intervention to delay nursing home placement of patients with Alzheimer disease. A randomized controlled trial. JAMA. Dec 4. 1996;276(21):1725-31. [pmid: 8940320].
Status: Not included because does not meet criteria for treatment for dementia patients
Miyamoto Y, Ito H, Otsuka T, et al. Caregiver burden in mobile and non-mobile demented patients: A comparative study. Int J Geriatr Psychiatry. Aug. 2002;17(8):765-73. [pmid: 12211128].
Status: Not included because does not meet criteria for treatment for dementia patients
Moffoot A, O'Carroll R E, Murray C, et al. Clonidine infusion increases uptake of 99mTc-Exametazime in anterior cingulate cortex in Korsakoff's psychosis. Psychol Med. Feb. 1994;24(1):53-61. [pmid: 8208894].
Status: Not included because dementia population not randomized to treatment
Moglia A, Arrigo A, Bono G. Citicoline in patients with chronic cerebrovascular diseases (CCVD): Quantitative EEG study. Curr Ther Res Clin Exp. 1984;36(2):309-13.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mohr E, Bruno G, Foster N, et al. GABA-agonist therapy for Alzheimer's disease. Clin Neuropharmacol. 1986;9(3):257-63. [pmid: 2872956].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mohr E, Schlegel J, Fabbrini G, et al. Clonidine treatment of Alzheimer's disease. Arch Neurol. Apr. 1989;46(4):376-8. [pmid: 2650662].
Status: Cross-over trial;
Mohr E, Knott V, Sampson M, et al. Cognitive and quantified electroencephalographic correlates of cycloserine treatment in Alzheimer's disease. Clin Neuropharmacol. Feb. 1995;18(1):28-38. [pmid: 8665532].
Status: Not included because Jadad Quality Scale score less than three
Mohr E, Walker D, Randolph C, et al. Utility of clinical trial batteries in the measurement of Alzheimer's and Huntington's dementia. Int Psychogeriatr. 1996;8(3):397-411. [pmid: 9116176].
Status: Not included because does not meet criteria for treatment for dementia patients
Mohs R, Doody R, Morris J, et al. Donepezil preserves functional status in Alzheimer's disease patients: Results from a 1-year prospective placebo-controlled attrition study. J Eur Coll Neuropsychopharmacol. 1999;9(Suppl 5):S328.
Status: Not included because not a full article
Mohs R, Doody R, Morris J, et al. Donepezil preserves activities of daily living in alzheimer's disease patients results from a one-year placebo-controlled functional survival study. Neurology. Apr. 2000;54(Suppl 3):1.
Status: Not included because not a full article
Mohs R C, Davis K L. A signal detectability analysis of the effect of physostigmine on memory in patients with Alzheimer's disease. Neurobiol Aging. 1982;3(2):105-10. [pmid: 7133278].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mohs R C, Davis B M, Johns C A, et al. Oral physostigmine treatment of patients with Alzheimer's disease. Am J Psychiatry. Jan. 1985;142(1):28-33. [pmid: 3881051].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mohs R C, Davis B M, Greenwald B S. Clinical studies of the cholinergic deficit in Alzheimer's disease. II. Psychopharmacologic studies. J Am Geriatr Soc. 1985;33(11):749-57. [pmid: 2865282].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mohs R C, Ferris S H. Measuring response to treatment in Alzheimer's disease: What constitutes meaningful change?. Int J Geriatr Psychopharmacol. 1998;1(Suppl 1):S7-S14.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Molchan S E, Mellow A M, Hill J L, et al. The effects of thyrotropin-releasing hormone and scopolamine in Alzheimer's disease and normal volunteers. J Psychopharmacol (Oxf). 1992;6(4):489-500.
Status: Cross-over trial;
Molchan S E, Manji H, Chen G, et al. Effects of chronic lithium treatment on platelet PKC isozymes in Alzheimer's and elderly control subjects. Neurosci Lett. 1993;162(12):187-2. [pmid: 8121626].
Status: Not included because dementia population not randomized to treatment
Molchan S E, Hill J L, Minichiello M, et al. Scopolamine effects on the pressor response to thyrotropin-releasing hormone in humans. Life Sci. 1994;54(13):933-8. [pmid: 8139380].
Status: Not included because no extractable data relevant to review
Molloy D W, Cape R D. Acute effects of oral pyridostigmine on memory and cognitive function in SDAT. Neurobiol Aging. Mar. 1989;10(2):199-204. [pmid: 2657467].
Status: Cross-over trial;
Molloy D W, Guyatt G H, Wilson D B, et al. Effect of tetrahydroaminoacridine on cognition, function and behaviour in Alzheimer's disease. CMAJ. Jan 1. 1991;144(1):29-34. [pmid: 1984813]. [pmcid: 1452525].
Status: Cross-over trial;
Molloy DW, Guyatt G, Brown G. Effects of oxiracetam on cognition, behaviour and activities of daily living in dementia. J Clin Exp Gerontol 1992; (3–4):217–4.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Molloy D W, Guyatt G H, Standish T, et al. Effect of a new nootropic agent, CGS 5649B, on cognition, function, and behavior in dementia. J Gen Intern Med. Aug. 1993;8(8):444-7. [pmid: 8410411].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Molloy D W, Standish T I. Clinical experience with Cerebrolysin. J Neural Transm Suppl. 2000;59:293-300. [pmid: 10961441].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Moniz-Cook E, Agar S, Gibson G, et al. A preliminary study of the effects of early intervention with people with dementia and their families in a memory clinic. Aging Ment Health. Aug. 1998;2(3):199-211.
Status: Not included because dementia population not randomized to treatment
Monreal M, Lafoz E, Olive A, et al. Comparison of subcutaneous unfractionated heparin with a low molecular weight heparin (Fragmin (R)) in patients with venous thromboembolism and contraindications to coumarin. Thromb Haemost. 1994;71(1):7-11. [pmid: 8165649].
Status: Not included because does not meet criteria for treatment for dementia patients
Monteverde A, Gnemmi P, Rossi F, et al. Selegiline in the treatment of mild to moderate Alzheimer-type dementia. Clin Ther. Jul. 1990;12(4):315-22. [pmid: 2121360].
Status: Not included because Jadad Quality Scale score less than three
Montgomery P, Erickson G K. Neuropsychological perspectives in amyotrophic lateral sclerosis. Neurol Clin. 1987;5(1):61-81. [pmid: 3104753].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Moore M J, Clipp E C. Alzheimer's disease and caregiver time. Lancet. Jan 22. 1994;343(8891):239-40. [pmid: 7904698].
Status: Not included because not a full article
Moore S, Sandman C A, McGrady K, et al. Memory training improves cognitive ability in patients with dementia. Neuropsychol Rehab. 2001;11(34):245-61.
Status: Not included because does not meet criteria for treatment for dementia patients
Moretti R, Torre P, Antonello R M, et al. Rivastigmine in subcortical vascular dementia: A comparison trial on efficacy and tolerability for 12 months follow-up. Eur J Neurol. Jul. 2001;8(4):361-2. [pmid: 11784363].
Status: Not included because not a full article
Moretti R, Torre P, Antonello R M, et al. Depression and Alzheimer's disease: Symptom or comorbidity?. Am J Alzheimers Dis Other Demen. 2002;17(6):338-44. [pmid: 12501480].
Status: Not included because Jadad Quality Scale score less than three
Moretti R, Torre P, Antonello R M, et al. An open-label pilot study comparing rivastigmine and low-dose aspirin for the treatment of symptoms specific to patients with subcortical vascular dementia. Curr Ther Res Clin Exp. 2002;63(7):443-58.
Status: Not included because dementia population not randomized to treatment
Moretti R, Torre P, Antonello R M, et al. Frontotemporal dementia: Paroxetine as a possible treatment of behavior symptoms: A randomized, controlled, open 14-month study. Eur Neurol. 2003;49(1):13-9. [pmid: 12736547].
Status: Not included because Jadad Quality Scale score less than three
Morey L C, Ban T A, Cassano G, et al. Glycosaminoglycan polysulfate in old-age dementias: A factor-analytic study of change in psychopathologic symptoms. Neuropsychobiology. 1988;19(3):135-8. [pmid: 3059221].
Status: Not included because dementia population not randomized to treatment
Morganroth J, Graham S, Hartman R, et al. Electrocardiographic effects of rivastigmine. J Clin Pharmacol. May. 2002;42(5):558-68. [pmid: 12017350].
Status: Not included because does not meet criteria for treatment for dementia patients
Mori T, Inoue D, Kosugi S, et al. Effects of low dose L-triiodothyronine administration on mental, behavioural and thyroid states in elderly subjects. Endocrinol Jpn. Aug. 1988;35(4):585-92. [pmid: 3215145].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Morich FJ, Bieber F, Lewis JM, et al. Nimodipine in the treatment of probable Alzheimer's disease: Results of two multicentre trials. Clin Drug Investig 1996; (4):185–95.
Status: Not included because dementia population not randomized to treatment
Moroney J T, Tseng C-L, Paik M C, et al. Treatment for the secondary prevention of stroke in older patients: The influence of dementia status. J Am Geriatr Soc. 1999;47(7):824-9. [pmid: 10404926].
Status: Not included because dementia population not randomized to treatment
Moroney J T, Tang M X, Berglund L, et al. Low-density lipoprotein cholesterol and the risk of dementia with stroke. JAMA. 1999;282(3):254-60. [pmid: 10422994].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Morrison R S, Siu A L. A comparison of pain and its treatment in advanced dementia and cognitively intact patients with hip fracture. J Pain Symptom Manage. Apr. 2000;19(4):240-8. [pmid: 10799790].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Moss D E, Berlanga P, Hagan M M, et al. Methanesulfonyl fluoride (MSF): A double-blind, placebo-controlled study of safety and efficacy in the treatment of senile dementia of the Alzheimer type. Alzheimer Dis Assoc Disord. Jan. 1999;13(1):20-5. [pmid: 10192638].
Status: Not included because Jadad Quality Scale score less than three
Mouradian M M, Mohr E, Williams J A, et al. No response to high-dose muscarinic agonist therapy in Alzheimer's disease. Neurology. Apr. 1988;38(4):606-8. [pmid: 3281057].
Status: Not included because dementia population not randomized to treatment
Mouradian M M, Blin J, Giuffra M, et al. Somatostatin replacement therapy for Alzheimer dementia. Ann Neurol. Oct. 1991;30(4):610-3. [pmid: 1789687].
Status: Not included because dementia population not randomized to treatment
Mubrin Z, Knezevic S, Spilich G, et al. Normalization of rCBF pattern in senile dementia of the Alzheimer's type. Psychiatry Res. Sep. 1989;29(3):303-6. [pmid: 2692054].
Status: Not included because no extractable data relevant to review
Mucke H A M. Metrifonate. Treatment of Alzheimer's disease, acetylcholinesterase inhibitor. Drugs of the Future. 1998;23(5):491-7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Mulsant BH, Mazumdar S, Pollock BG, et al. Methodological issues in characterizing treatment response in demented patients with behavioral disturbances. Int J Geriatr Psychiatry 1997 May; (No. 5):537–47.
Status: Not included because dementia population not randomized to treatment
Munch-Petersen S, Pakkenberg H, Kornerup H, et al. RNA treatment of dementia. A double-blind study. Acta Neurol Scand. 1974;50(5):553-72. [pmid: 4611128].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Murali D P, Kaiser L. Variability of the mini-mental state examination in dementia. Neurology. Apr 11. 2000;54(7):1538-9. [pmid: 10751277].
Status: Not included because not a full article
Muramoto O, Sugishita M, Sugita H, et al. Effect of physostigmine on constructional and memory tasks in Alzheimer's disease. Arch Neurol. Aug. 1979;36(8):501-3. [pmid: 508162].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Muramoto O, Sugishita M, Ando K. Cholinergic system and constructional praxis: A further study of physostigmine in Alzheimer's disease. J Neurol Neurosurg Psychiatry. 1984;47(5):485-91. [pmid: 6736979].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Muratorio A, Bonuccelli U, Nuti A, et al. A neurotropic approach to the treatment of multi-infarct dementia using L-alpha-glycerylphosphorylchlorine. Curr Ther Res Clin Exp. 1992;52(5):741-52.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Muresanu DF, Rainer M, Moessler H. Improved global function and activities of daily living in patients with AD: a placebo-controlled clinical study with the neurotrophic agent Cerebrolysin. J Neural Transm Suppl 2002; (62):277–85.
Status: Not included because Jadad Quality Scale score less than three
Murialdo G, Barreca A, Nobili F, et al. Dexamethasone effects on cortisol secretion in Alzheimer's disease: Some clinical and hormonal features in suppressor and nonsuppressor patients. J Endocrinol Invest. Mar. 2000;23(3):178-86. [pmid: 10803476].
Status: Not included because does not meet criteria for treatment for dementia patients
Murri L, Bardi C, Arena R. A comparison between lormetazepam and flunitrazepam in insomniac patients affected by chronic cerebrovascular disorders. Curr Ther Res Clin Exp. 1984;35(1):113-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nadeau S E, Malloy P F, Andrew M E. A crossover trial of bromocriptine in the treatment of vascular dementia. Ann Neurol. Aug. 1988;24(2):270-2. [pmid: 3052266].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nagaraja D, Jayashree S. Randomized study of the dopamine receptor agonist piribedil in the treatment of mild cognitive impairment. Am J Psychiatry. Sep. 2001;158(9):1517-9. [pmid: 11532743].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nair NP, Ban TA, Hontela S, et al. Trazodone in the treatment of organic brain syndromes, with special reference to psychogeriatrics. Curr Ther Res Clin Exp ; 15(10):769–75.
Status: Not included because dementia population not randomized to treatment
Nakamura H, Nakanishi M, Hamanaka T, et al. Semantic priming in patients with Alzheimer and semantic dementia. Cortex. Apr. 2000;36(2):151-62. [pmid: 10815703].
Status: Not included because does not meet criteria for treatment for dementia patients
Nakamura K. Aniracetam: Its novel therapeutic potential in cerebral dysfunctional disorders based on recent pharmacological discoveries. CNS Drug Rev. 2002;8(1):70-89. [pmid: 12070527].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nakano S, Asada T, Matsuda H, et al. Donepezil hydrochloride preserves regional cerebral blood flow in patients with Alzheimer's disease. J Nucl Med. Oct. 2001;42(10):1441-5. [pmid: 11585854].
Status: Not included because Jadad Quality Scale score less than three
Namazi KH, Haynes SR. Sensory stimuli reminiscence for patients with Alzheimer's disease: Relevance and implications. Clin Gerontol 1994; 29–46.
Status: Not included because dementia population not randomized to treatment
Namazi KH, Johnson BD. Environmental effects on incontinence problems in Alzheimer's disease patients. Am J Alzheimers Care Relat Disord 1991 Nov; (6):16–21.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Naritomi H, Murata S, Shimizu T, et al. Long-term effects of bifemelane hydrochloride on post-stroke deterioration of cognitive function and cerebral blood flow. Curr Ther Res Clin Exp. 1995;Vol 56(231):238.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nasrallah H A, Varney N, Coffman J A, et al. Effects of naloxone on cognitive deficits following electroconvulsive therapy. Psychopharmacol Bull. 1985;21(1):89-90. [pmid: 3983344].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Navia B A, Dafni U, Simpson D, et al. A phase I/II trial of nimodipine for HIV-related neurologic complications. Neurology. Jul. 1998;51(1):221-8. [pmid: 9674806].
Status: Not included because dementia population not randomized to treatment
Nebes R D, Pollock B G, Mulsant B H, et al. Cognitive effects of paroxetine in older depressed patients. J Clin Psychiatry. 1999;60(Suppl):9. [pmid: 10513855].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Netz Y, Yaretzki A, Salganik I, et al. The effect of supervised physical activity on cognitive and affective state of geriatric and psychogeriatric in-patients. Clin Gerontol. 1994;15(1):47-56.
Status: Not included because does not meet criteria for treatment for dementia patients
Neumeister A, Graf A, Willeit M, et al. Effects of Light Therapy in dementia. Biol Psychiatry. 2000;Vol 47:S536.
Status: Not included because not a full article
Newcomer R, Spitalny M, Fox P, et al. Effects of the Medicare Alzheimer's disease demonstration on the use of community-based services. Health Serv Res. Aug. 1999;34(3):645-67. [pmid: 10445896]. [pmcid: 1089031].
Status: Not included because does not meet criteria for treatment for dementia patients
Newhouse P A, Sunderland T, Tariot P N, et al. Intravenous nicotine in Alzheimer's disease: A pilot study. Psychopharmacologia. 1988;95(2):171-5.
Status: Not included because dementia population not randomized to treatment
Newhouse P A, Sunderland T, Narang P K, et al. Neuroendocrine, physiologic, and behavioral responses following intravenous nicotine in nonsmoking healthy volunteers and in patients with Alzheimer's disease. Psychoneuroendocrinology. 1990;15(56):471-6. [pmid: 1966302].
Status: Not included because dementia population not randomized to treatment
Niemann H, Ruff R M, Baser C A. Computer-assisted attention retraining in head-injured individuals: A controlled efficacy study of an outpatient program. J Consult Clin Psychol. Dec. 1990;58(6):811-7. [pmid: 2292631].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nijhuis E, Hinloopen B, van Duijn C, et al. Decreased sensitivity to dexamethasone in lymphocytes from patients with Alzheimer's disease. Clin Immunol Immunopathol. Oct. 1994;73(1):45-52. [pmid: 7923916].
Status: Not included because does not meet criteria for treatment for dementia patients
Nikolova G, Traykov L. Efficacy of donepezil in patients with Alzheimer's disease - Results of 12-week open clinical trial. Acta Med Bulg. 2001;28:70-5.
Status: Not included because dementia population not randomized to treatment
Nimodipine Clinical Study Group. Effects of Nimodipine on vascular dementia. Cardiovasc Dis. 1996;6(Suppl 2):70.
Status: Not included because not a full article
Nirenberg T D. Relocation of institutionalized elderly. J Consult Clin Psychol. Oct. 1983;51(5):693-701. [pmid: 6630682].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nobili F, Vitali P, Canfora M, et al. Effects of long-term Donepezil therapy on rCBF of Alzheimer's patients. Clin Neurophysiol. 2002;113(8):1241-8. [pmid: 12140003].
Status: Not included because dementia population not randomized to treatment
Nobili F, Koulibaly M, Vitali P, et al. Brain perfusion follow-up in Alzheimer's patients during treatment with acetylcholinesterase inhibitors. J Nucl Med. Aug. 2002;43(8):983-90. [pmid: 12163621].
Status: Not included because dementia population not randomized to treatment
Noel G, Jeanmart M, Reinhardt B. Treatment of the organic brain syndrome in the elderly. A double-blind comparison on the effects of a neurotropic drug and placebo. Neuropsychobiology. 1983;10(23):90-3. [pmid: 6371575].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Norbergh K G, Hellzen O, Sandman P O, et al. The relationship between organizational climate and the content of daily life for people with dementia living in a group-dwelling. J Clin Nurs. Mar. 2002;11(2):237-46. [pmid: 11903723].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Novo F P, Ryan R P, Frazier E L. Dihydroergotoxine mesylate in treatment of symptoms of idiopathic cerebral dysfunction in geriatric patients. Clin Ther. 1978;1(5):359-69.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nyback H, Hassan M, Junthe T, et al. Clinical experiences and biochemical findings with tacrine (THA). Acta Neurol Scand Suppl. 1993;88(149):36-8. [pmid: 7510447].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nygaard H, Bakke K, Brudvik E, et al. Zuclopenthixol and melperon in the treatment of elderly patients: A double-blind, controlled, multi-centre study. Pharmatherapeutica. 1987;5(3):152-8. [pmid: 2896359].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nygaard H A, Bakke K, Brudvik E, et al. Dosing of neuroleptics in elderly demented patients with aggressive and agitated behaviour: A double-blind study with zuclopenthixol. Curr Med Res Opin. 1994;13(4):222-32. [pmid: 7882702].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Nyth A L, Gottfries C G, Lyby K, et al. A controlled multicenter clinical study of citalopram and placebo in elderly depressed patients with and without concomitant dementia. Acta Psychiatr Scand. Aug. 1992;86(2):138-45. [pmid: 1529737].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
O'Brien B J, Goeree R, Hux M, et al. Economic evaluation of donepezil for the treatment of Alzheimer's disease in Canada. J Am Geriatr Soc. 1999;47(5):570-8. [pmid: 10323651].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
O'Brien J T, Schweitzer I, Ames D, et al. The function of the hypothalamic-pituitary-adrenal axis in Alzheimer's disease. Response to insulin hypoglycaemia. Br J Psychiatry. Nov. 1994;165(5):650-7. [pmid: 7866680].
Status: Not included because dementia population not randomized to treatment
O'Carroll R E, Moffoot A, Ebmeier K P, et al. Korsakoff's syndrome, cognition and clonidine. Psychol Med. May. 1993;23(2):341-7. [pmid: 8332651].
Status: Not included because dementia population not randomized to treatment
O'Carroll R E, Moffoot A P, Ebmeier K P, et al. Effects of fluvoxamine treatment on cognitive functioning in the alcoholic Korsakoff syndrome. Psychopharmacologia. Sep. 1994;116(1):85-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
O'Connolly M, Dierdorf D, Greb W H, et al. Efficacy of denbufylline in patients with multi-infarct dementia. Drug Dev Res. 1988;14(34):195-4.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
O'Connor D W, Pollitt P A, Brook C P, et al. Does early intervention reduce the number of elderly people with dementia admitted to institutions for long term care?. BMJ. 1991;302(6781):871-5. [pmid: 1902752]. [pmcid: 1669209].
Status: Not included because dementia population not randomized to treatment
O'Keeffe S T, Lavan J N. Subcutaneous fluids in elderly hospital patients with cognitive impairment. Gerontology. 1996;42(1):36-9. [pmid: 8641599].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Oakley F, Sunderland T. Assessment of motor and process skills as a measure of IADL functioning in pharmacologic studies of people with Alzheimer's disease: A pilot study. Int Psychogeriatr. Jun. 1997;9(2):197-206. [pmid: 9309491].
Status: Cross-over trial;
Obonsawin M C, Robertson A, Crawford J R, et al. Non-mnestic cognitive function in the scopolamine model of Alzheimer's disease. Hum Psychopharmacol. 1998;13:439-49.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ohno Y. The effects of magnetized mineral water on memory loss delay in Alzheimer's diease. The centre for frontier sciences 1997; (6):38–43.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Oishi M, Mochizuki Y, Takasu T, et al. Effectiveness of traditional Chinese medicine in Alzheimer disease. Alzheimer Dis Assoc Disord. Sep. 1998;12(3):247-50. [pmid: 9772030].
Status: Not included because dementia population not randomized to treatment
Okajima Y. Quantitative pharmaco-EEG study of indeloxazine hydrochloride in psychogeriatric patients. Integr Psychiatry. 1993;9(1):25-33.
Status: Not included because dementia population not randomized to treatment
Olin J T, Schneider L S. Assessing response to tacrine using the factor analytic structure of the Alzheimer's Disease Assessment Scale (ADAS) - Cognitive subscale. Int J Geriatr Psychiatry. 1995;10(9):753-6.
Status: Not included because Jadad Quality Scale score less than three
Onofrj M, Thomas A, Luciano A L, et al. Donepezil versus vitamin E in Alzheimer's disease: Part 2: Mild versus moderate-severe Alzheimer's disease. Clin Neuropharmacol. Jul. 2002;25(4):207-15. [pmid: 12151908].
Status : Not included because Jadad Quality Scale score less than three
Opie J, Doyle C, O'Connor D W. Challenging behaviours in nursing home residents with dementia: A randomized controlled trial of multidisciplinary interventions. Int J Geriatr Psychiatry. Jan. 2002;17(1):6-13. [pmid: 11802224].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Orengo C A, Kidwell K, Kunik M E, et al. The effect of risperidone on cognitive performance in elderly psychotic and aggressive patients with dementia; a pilot study. Int J Geriatr Psychopharmacol. 1998;1(4):193-6.
Status: Not included because dementia population not randomized to treatment
Orten J D, Allen M, Cook J. Reminiscence Groups with Confused Nursing Center Residents: An Experimental Study. Soc Work Health Care. 1989;14(1):73-86. [pmid: 2781444].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ostwald S K, Hepburn K W, Caron W, et al. Reducing caregiver burden: A randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. Jun. 1999;39(3):299-309. [pmid: 10396888].
Status : Not included because does not meet criteria for treatment for dementia patients
Ousset P J, Viallard G, Puel M, et al. Lexical Therapy and episodic word learning in dementia of the Alzheimer type. Brain Lang. 2002;80(1):14-20. [pmid: 11817887].
Status: Not included because does not meet criteria for treatment for dementia patients
Ownsworth T L, Mcfarland K. Memory remediation in long-term acquired brain injury: Two approaches in diary training. Brain Inj. Aug. 1999;13(8):605-26. [pmid: 10901689].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Paire J A, Karney R J. The effectiveness of sensory stimulation for geropsychiatric inpatients. Am J Occup Ther. Aug. 1984;38(8):505-9. [pmid: 6433715].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Palmer G C. Neuroprotection by NMDA receptor antagonists in a variety of neuropathologies. Curr Drug Targets. 2001;2(3):241-71. [pmid: 11554551].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Palmieri G, Palmieri R, Inzoli M R. Double-blind controlled trial of phosphatidylserine in patients with senile mental deterioration. Clin Trials J. 1987;24(1):73-83.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Pantev M, Ritter R, Gortelmeyer R. Therapy responder analysis of dementia study with memantine. Pharmacopsychiatry. 1993;26:185.
Status: Not included because not a full article
Parkes J D, Marsden C D, Rees J E. Parkinson's disease, cerebral arteriosclerosis, and senile dementia. Clinical features and response to levodopa. Q J Med. 1974;43(169):49-61. [pmid: 4822972].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Parnetti L, Ciuffetti G, Mercuri M, et al. Relationship between haemorheological factors and initial mental deterioration in the elderly. A preliminary study. Clin Hemorheol. 1985;5(4):361-72.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Parnetti L, Ciuffetti G, Mercuri M, et al. Haemorheological pattern in initial mental deterioration: Results of a long-term study using piracetam and pentoxifylline. Arch Gerontol Geriatr. Jul. 1985;4(2):141-55. [pmid: 3899033].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Parnetti L, Ciuffetti G, Mercuri M, et al. The role of haemorheological factors in the ageing brain: Long-term therapy with pentoxifylline (‘Trental’ 400) in elderly patients with initial mental deterioration. Pharmatherapeutica. 1986;4(10):617-27. [pmid: 3602014].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Parnetti L, Senin U, Carosi M, et al. Mental deterioration in old age: results of two multicenter, clinical trials with nimodipine. The Nimodipine Study Group. Clin Ther. Mar. 1993;15(2):394-406. [pmid: 8519047].
Status: Not included because dementia population not randomized to treatment
Parnetti L, Abate G, Bartorelli L, et al. Multicentre study of l-alpha-glyceryl-phosphorylcholine vs ST200 among patients with probable senile dementia of Alzheimer's type. Drugs Aging. Mar. 1993;3(2):159-64. [pmid: 8477148].
Status: Not included because Jadad Quality Scale score less than three
Parnetti L, Amici S, Lanari A, et al. Cerebrospinal fluid levels of biomarkers and activity of acetylcholinesterase (AChE) and butyrylcholinesterase in AD patients before and after treatment with different AChE inhibitors. Neurol Sci. 2002;23(Suppl 2):S95-S96. [pmid: 12548360].
Status: Not included because not a full article
Partanen J, Wolters E C, van Duijn H. Clinical neurophysical correlates of vasopressin derivative therapy in Alzheimer's disease. Clin Neurol Neurosurg. 1987;2:34.
Status: Not included because not a full article
Passeri M, Cucinotta D, de Mello M, et al. Minaprine for senile dementia. Lancet. Apr 6. 1985;1(8432):824. [pmid: 2858705].
Status: Not included because not a full article
Passeri M, Cucinotta D. Ateroid in the clinical treatment of multi-infarct dementia. Mod Probl Pharmacopsychiatry. 1989;23:85-94. [pmid: 2469953].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Passeri M, Cucinotta D, Bonati P A, et al. Acetyl-L-carnitine in the treatment of mildly demented elderly patients. Int J Clin Pharmacol Res. 1990;10(12):75-82. [pmid: 2201659].
Status: Not included because Jadad Quality Scale score less than three
Paterson J, Hamilton M M, Grant H. The effectiveness of the Hierarchic Dementia Scale in tailoring interventions to reduce problem behaviours in people with Alzheimer's disease. Aust Occup Ther J. 2000;47(3):134-40.
Status: Not included because does not meet criteria for treatment for dementia patients
Pathy J, Menon G, Reynolds A, et al. Betahistine hydrochloride (Serc) in cerebrovascular disease: A placebo-controlled study. Age Ageing. Aug. 1977;6(3):179-84. [pmid: 331920].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Peabody C A, Thiemann S, Pigache R, et al. Desglycinamide-9-arginine-8-vasopressin (DGAVP, Organon 5667) in patients with dementia. Neurobiol Aging. 1985;6(2):95-100. [pmid: 3895014].
Status: Not included because dementia population not randomized to treatment
Peabody C A, Deblois T E, Tinklenberg J R. Thyrotropin-releasing hormone (TRH) and Alzheimer's disease. Am J Psychiatry. 1986;143(2):262-3. [pmid: 3080909].
Status: Not included because not a full article
Penn R D, Martin E M, Wilson R S, et al. Intraventricular bethanechol infusion for Alzheimer's disease: Results of double-blind and escalating-dose trials. Neurology. Feb. 1988;38(2):219-22. [pmid: 2893314].
Status: Cross-over trial;
Pepping J. Phosphatidylserine. Am J Health Syst Pharm. 1999;56(20):2038-44. [pmid: 10690214].
Status: Not included because not a full article
Pepping J. Alternative therapies. Huperzine A: A potent and selective acetylcholinesterase inhibitor. Am J Health Syst Pharm. Mar 15. 2000;57(6):530-4. [pmid: 11098305].
Status: Not included because dementia population not randomized to treatment
Perini M, Montanini R, Casucci R. Effects of eptastigmine: A new cholesterase inhibitor on regional cerebral blood flow in Alzheimer patients. J Neurol. 1995;242:S57.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Perryman K M, Fitten L J. Quantitative EEG during a double-blind trial of THA and lecithin in patients with Alzheimer's disease. J Geriatr Psychiatry Neurol. Jul. 1991;4(3):127-33. [pmid: 1953964].
Status: Not included because no extractable data relevant to review
Peskind E R, Wingerson D, Murray S, et al. Effects of Alzheimer's disease and normal aging on cerebrospinal fluid norepinephrine responses to yohimbine and clonidine. Arch Gen Psychiatry. Sep. 1995;52(9):774-82. [pmid: 7654129].
Status: Not included because does not meet criteria for treatment for dementia patients
Peters B H, Levin H S. Memory enhancement after physostigmine treatment in the amnesic syndrome. Arch Neurol. Apr. 1977;34(4):215-9. [pmid: 557318].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Peters B H, Levin H S. Effects of physostigmine and lecithin on memory in Alzheimer's disease. Ann Neurol. Sep. 1979;6(3):219-21. [pmid: 534419].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Peterson L G, Bongar B. Navane versus Haldol. Treatment of acute organic mental syndromes in the general hospital. Gen Hosp Psychiatry. Nov. 1989;11(6):412-7. [pmid: 2806891].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Petit D, Montplaisir J, Lorrain D, et al. THA does not affect sleep or EEG spectral power in Alzheimer's disease. Biol Psychiatry. 1993;33(10):753-4. [pmid: 8353172].
Status: Not included because dementia population not randomized to treatment
Petracca G, Teson A, Chemerinski E, et al. A double-blind placebo-controlled study of clomipramine in depressed patients with Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 1996;8(3):270-5. [pmid: 8854297].
Status: Cross-over trial;
Pettegrew J W, Klunk W E, Panchalingam K, et al. Clinical and neurochemical effects of acetyl-L-carnitine in Alzheimer's disease. Neurobiol Aging. Jan. 1995;16(1):1-4. [pmid: 8622789].
Status: Not included because dementia population not randomized to treatment
Pettegrew J W, Levine J, McClure R J. Acetyl-L-carnitine physical-chemical, metabolic, and therapeutic properties: Relevance for its mode of action in Alzheimer's disease and geriatric depression. Mol Psychiatry. 2000;5(6):616-32. [pmid: 11126392].
Status: Not included because does not meet criteria for treatment for dementia patients
Pettegrew J W, McClure R J. Acetyl-L-carnitine as a possible therapy for Alzheimer's disease. Expert Rev Neurother. 2002;2(5):647-54. [pmid: 19810980].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Petursson H. A controlled study of Moclobemide in elderly depression with cognitive decline. Psychopharmacologia. 1993;Vol 111:B5.
Status: Not included because not a full article
Pérodeau G, Lauzon S, Lévesque L, et al. Mental health stress correlates and psychotropic drug use or non user among aged caregivers to elders with dementia. Aging Ment Health. 2001;5(3):225-34. [pmid: 11575061].
Status: Not included because does not meet criteria for treatment for dementia patients
Pfefferbaum A, Davis K L, Coulter C L, et al. EEG effects of physostigmine and choline chloride in humans. Psychopharmacologia. Apr 25. 1979;62(3):225-33.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Phanjoo A L, Link C. Remoxipride versus thioridazine in elderly psychotic patients. Acta Psychiatr Scand Suppl. 1990;Vol 358:181-5. [pmid: 1978481].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Phillips C D, Spry K M, Sloane P D, et al. Use of physical restraints and psychotropic medications in Alzheimer special care units in nursing homes. Am J Public Health. 2000;90(1):92-6. [pmid: 10630143]. [pmcid: 1446122].
Status: Not included because dementia population not randomized to treatment
Piccinin G L, Finali G, Piccirilli M. Neuropsychological effects of L-deprenyl in Alzheimer's type dementia. Clin Neuropharmacol. Apr. 1990;13(2):147-63. [pmid: 2109658].
Status: Cross-over trial;
Piccoli F, Battistini N, Carbonin P, et al. CDP-choline in the treatment of chronic cerebrovasculopathies. Arch Gerontol Geriatr. 1994;18(3):161-8. [pmid: 15374296].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Pillemer K, Jill S J. Peer support for Alzheimer's caregivers: Is it enough to make a difference?. Res Aging. 2002;24(2):171-92.
Status: Not included because does not meet criteria for treatment for dementia patients
Pincus M M, Kilander L, Ohrvall M. Alpha-tocopherol and Alzheimer's disease. N Engl J Med. 1997;337(8):572-3. [pmid: 9265107].
Status: Not included because not a full article
Pisvejc J, Hyrman V, Sikora J, et al. A comparison of brief and ultrabrief pulse stimuli in unilateral ECT. J ECT. Jun. 1998;14(2):68-75. [pmid: 9641801].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Pittera A, Ciancitto S. Effect of oral nimodipine on cerebral blood flow in patients with chronic cerebrovascular disorders. A supra-aortic Doppler ultra-sound open study. Curr Ther Res Clin Exp. 1990;48(4):716-29.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Poitrenaud J, Piette F, Malbezin M, et al. Almitrine-raubasine and cognitive impairment in the elderly: Results of a 6-month controlled multicenter study. Clin Neuropharmacol. 1990;Vol 13(Suppl 3):S100-S108. [pmid: 2093414].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Polinsky R J. Clinical pharmacology of rivastigmine: A new-generation acetylcholinesterase inhibitor for the treatment of Alzheimer's disease. Clin Ther. 1998;20(4):634-47. [pmid: 9737824].
Status: Not included because dementia population not randomized to treatment
Pomara N, Block R, Abraham J. Combined cholinergic precursor treatment and dihydroergotoxine mesylate in Alzheimer's disease. IRCS Med Sci 1983; (12):1048–9.
Status: Not included because dementia population not randomized to treatment
Pomara N, Block R, Moore N, et al. Combined Piracetam and cholinergic precursor treatment for primary degenerative dementia. IRCS Med Sci Psychol Psychiatry 1984; (5–6):388–6.
Status: Cross-over trial;
Pomara N, Roberts R, Rhiew H B, et al. Multiple, single-dose naltrexone administrations fail to effect overall cognitive functioning and plasma cortisol in individuals with probable Alzheimer's disease. Neurobiol Aging. 1985;6(3):233-6. [pmid: 3903533].
Status: Cross-over trial;
Pomara N, Deptula D, Singh R. Pretreatment postural blood pressure drop as a possible predictor of response to the cholinesterase inhibitor velnacrine (HP 029) in Alzheimer's disease. Psychopharmacol Bull. 1991;27(3):301-7. [pmid: 1775603].
Status: Not included because dementia population not randomized to treatment
Pomara N, Doraiswamy P M, Tun H, et al. Mifepristone (RU 486) for Alzheimer's disease. Neurology. 2002;58(9):1436. [pmid: 12011303].
Status: Not included because Jadad Quality Scale score less than three
Pomeroy V M. The effect of physiotherapy input on mobility skills of elderly people with severe dementing illness. Clin Rehabil. 1993;7(2):163-70.
Status: Not included because does not meet criteria for treatment for dementia patients
Pomeroy V M. Immobility and severe dementia: When is physiotherapy treatment appropriate?. Clin Rehabil. 1994;8:226-32.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Pomeroy V M, Warren C M, Honeycombe C, et al. Mobility and dementia: Is physiotherapy treatment during respite care effective?. Int J Geriatr Psychiatry. May. 1999;14(5):389-97. [pmid: 10389044].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Portegies P, Enting R H, de Jong M D, et al. AIDS dementia complex and didanosine. Lancet. Sep 10. 1994;344(8924):759. [pmid: 7915809].
Status: Not included because not a full article
Porter R J, Lunn B S, Walker L L, et al. Cognitive deficit induced by acute tryptophan depletion in patients with Alzheimer's disease. Am J Psychiatry. Apr. 2000;157(4):638-40. [pmid: 10739429].
Status: Not included because dementia population not randomized to treatment
Porter R J, Marshall E F, O'Brien J T. Effects of rapid tryptophan depletion on salivary and plasma cortisol in Alzheimer's disease and the healthy elderly. J Psychopharmacol (Oxf). Mar. 2002;16(1):73-8.
Status: Not included because does not meet criteria for treatment for dementia patients
Postiglione A, Soricelli A, Cicerano U, et al. Effect of acute administration of L-acetyl carnitine on cerebral blood flow in patients with chronic cerebral infarct. Pharmacol Res. Apr. 1991;23(3):241-6. [pmid: 2068049].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Potkin S G, Fleming K, Jin Y, et al. Clozapine enhances neurocognition and clinical symptomatology more than standard neuroleptics. J Clin Psychopharmacol. 2001;21(5):479-83. [pmid: 11593072].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Potkin S G, Anand R, Hartman R, et al. Impact of Alzheimer's disease and rivastigmine treatment on activities of daily living over the course of mild to moderately severe disease. Prog Neuropsychopharmacol Biol Psychiatry. 2002;26(4):713-20. [pmid: 12188104].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Potkin S G, Alva G, Keator D, et al. Brain metabolic effects of Neotrofin in patients with Alzheimer's disease. Brain Res. 2002;951(1):87-95. [pmid: 12231461].
Status: Not included because dementia population not randomized to treatment
Potter A, Corwin J, Lang J, et al. Acute effects of the selective cholinergic channel activator (nicotinic agonist) ABT-418 in Alzheimer's disease. Psychopharmacologia. Mar. 1999;142(4):334-42.
Status: Cross-over trial;
Pratt RD. Patient populations in clinical trials of the efficacy and tolerability of donepezil in patients with vascular dementia. J Neurol Sci 2002 Nov 15; 203–204:57–65.:57–65.
Status: Not included because no extractable data relevant to review
Pratt R D, Perdomo C A, Surick I W, et al. Donepezil: Tolerability and safety in Alzheimer's disease. Int J Clin Pract. Nov. 2002;56(9):710-7. [pmid: 12469988].
Status: Not included because dementia population not randomized to treatment
Predescu V, Riga D, Riga S, et al. Antagonic-stress. A new treatment in gerontopsychiatry and for a healthy productive life. Ann N Y Acad Sci. 1994;717(Jun 30):315-31. [pmid: 8030848].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Preston G C, Brazell C, Ward C, et al. The scopolamine model of dementia: Determination of central cholinomimetic effects of physostigmine on congnition and biochemical markers in man. J Psychopharmacol (Oxf). 1988;2(2):67-79.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Preston G C, Ward C, Lines C R, et al. Scopolamine and benzodiazepine models of dementia: Cross-reversals by Ro 15–1788 and physostigmine. Psychopharmacologia. 1989;98(4):487-94.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Proctor R, Burns A, Powell H S, et al. Behavioural management in nursing and residential homes: a randomised controlled trial. Lancet. Jul 3. 1999;354(9172):26-9. [pmid: 10406361].
Status: Not included because does not meet criteria for treatment for dementia patients
Puchler K, Schaffler K, Plenker A. The comparative effects of single and multiple doses of RS-8359, moclobemide and placebo on psychomotor function in healthy subjects. Int Clin Psychopharmacol. 1997;Vol 12(Suppl 5):S17-S23. [pmid: 9466165].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Purandare N, Bloom C, Page S, et al. The effect of anticholinesterases on personality changes in Alzheimer's disease. Aging Ment Health. 2002;6(4):350-4. [pmid: 12425769].
Status: Not included because dementia population not randomized to treatment
Puri B K, Bydder G M, Counsell S J, et al. MRI and neuropsychological improvement in Huntington disease following ethyl-EPA treatment. NeuroReport. 2002;13(1):123-6. [pmid: 11924873].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Putt M E, Ravina B. Randomized, placebo-controlled, parallel group versus crossover study designs for the study of dementia in Parkinson's disease. Control Clin Trials. Apr. 2002;23(2):111-26. [pmid: 11943439].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Quayhagen M P, Quayhagen M, Corbeil R R, et al. A dyadic remediation program for care recipients with dementia. Nurs Res. May. 1995;44(3):153-9. [pmid: 7761291].
Status: Not included because does not meet criteria for treatment for dementia patients
Quayhagen M P, Quayhagen M, Corbeil R R, et al. Coping with dementia: Evaluation of four nonpharmacologic interventions. Int Psychogeriatr. Jun. 2000;12(2):249-65. [pmid: 10937544].
Status: Not included because does not meet criteria for treatment for dementia patients
Quayhagen M P, Quayhagen M. Testing of a cognitive stimulation intervention for dementia caregiving dyads. Neuropsychol Rehab. 2001;11(Speical issue 34):319-22.
Status: Not included because does not meet criteria for treatment for dementia patients
Quinlivan R, Hough R, Crowell A, et al. Service utilization and costs of care for severely mentally ill clients in an intensive case management program. Psychiatr Serv. Apr. 1995;46(4):365-71. [pmid: 7788458].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rabey J M, Neufeld M Y, Treves T A, et al. Cognitive effects of scopolamine in dementia. J Neural Transm Gen Sect. 1996;103(7):873-81.
Status: Cross-over trial;
Rada R T, Kellner R. Thiothixene in the treatment of geriatric patients with chronic organic brain syndrome. J Am Geriatr Soc. Mar. 1976;24(3):105-7. [pmid: 765388].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rader M A, Alston J B, Ellis D W. Sensory stimulation of severely brain-injured patients. Brain Inj. Apr. 1989;3(2):141-7. [pmid: 2730972].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Raffaele K C, Berardi A, Asthana S, et al. Effects of long-term continuous infusion of the muscarinic cholinergic agonist arecoline on verbal memory in dementia of the Alzheimer type. Psychopharmacol Bull. 1991;27(3):315-9. [pmid: 1775605].
Status: Not included because dementia population not randomized to treatment
Raffaele K C, Asthana S, Berardi A, et al. Differential response to the cholinergic agonist arecoline among different cognitive modalities in Alzheimer's disease. Neuropsychopharmacology. 1996;15(2):163-70. [pmid: 8840352].
Status: Not included because dementia population not randomized to treatment
Ragneskog H, Brane G, Karlsson I, et al. Influence of dinner music on food intake and symptoms common in dementia. Scand J Caring Sci. 1996;10(1):11-7. [pmid: 8715781].
Status: Not included because dementia population not randomized to treatment
Ragneskog H, Kihlgren M, Karlsson I, et al. Dinner music for demented patients: Analysis of video-recorded observations. Clin Nurs Res 1996 Aug; 5(3):262–77, 278–82.
Status: Not included because dementia population not randomized to treatment
Ragneskog H, Asplund K, Kihlgren M, et al. Individualized music played for agitated patients with dementia: Analysis of video-recorded sessions. Int J Nurs Pract. Jun. 2001;7(3):146-55. [pmid: 11811810].
Status: Not included because dementia population not randomized to treatment
Rai G S, Shovlin C, Wesnes K A. A double-blind, placebo controlled study of Ginkgo biloba extract (‘tanakan’) in elderly outpatients with mild to moderate memory impairment. Curr Med Res Opin. 1991;12(6):350-5. [pmid: 2044394].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rained M, Mucke H A M. Long-term cognitive benefit from galanthamine in Alzheimer's disease. Int J Geriatr Psychopharmacol. 1998;1(4):197-201.
Status: Not included because dementia population not randomized to treatment
Rainer M, Mucke H A, Chwatal K, et al. Alcohol-induced organic cerebral psychosyndromes: Partial reversal of cognitive impairments assisted by dihydroergocristine. Psychopharmacologia. Oct. 1996;127(4):365-9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Randolph C, Roberts J W, Tierney M C, et al. D-cycloserine treatment of Alzheimer's disease. Alzheimer Dis Assoc Disord. 1994;8(3):198-205. [pmid: 7986489].
Status: Cross-over trial;
Ransmayr G, Plorer S, Gerstenbrand F, et al. Double-blind placebo-controlled trial of phosphatidylserine in elderly patients with arteriosclerotic encephalopathy. Clin Trials J. 1987;24(1):62-72.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rao D B, Georgiev E L, Paul P D, et al. Cyclandelate in the treatment of senile mental changes: A double-blind evaluation. J Am Geriatr Soc. Dec. 1977;25(12):548-51. [pmid: 336670].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rapp S, Brenes G, Marsh A P. Memory enhancement training for older adults with mild cognitive impairment: A preliminary study. Aging Ment Health. Feb. 2002;6(1):5-11. [pmid: 11827617].
Status: Not included because does not meet criteria for treatment for dementia patients
Rascol O, Sieradzan K, Peyro-Saint-Paul H, et al. Efaroxan, an alpha-2 antagonist, in the treatment of progressive supranuclear palsy. Mov Disord. Jul. 1998;13(4):673-6. [pmid: 9686773].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rasmusen L, Yan B, Robillard A, et al. Effects of washout and dose-escalation periods on the efficacy, safety, and tolerability of galantamine in patients previously treated with donepezil: Ongoing clinical trials. Clin Ther. 2001;23(Suppl):A25-A30. [pmid: 11396868].
Status: Not included because dementia population not randomized to treatment
Ray P G, Meador K J, Loring D W, et al. Effects of scopolamine on visual evoked potentials in aging and dementia. Electroencephalogr Clin Neurophysiol. Sep. 1991;80(5):347-51. [pmid: 1716558].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ray W A, Taylor J A, Meador K G, et al. Reducing antipsychotic drug use in nursing homes. A controlled trial of provider education. Arch Intern Med. 1993;153(6):713-21. [pmid: 8447709].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Raz N, Torres I J, Briggs S D, et al. Selective neuroanatomic abnormalities in Down's syndrome and their cognitive correlates: Evidence from MRI morphometry. Neurology. Feb. 1995;45(2):356-66. [pmid: 7854539].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Reddy H, De Stefano N, Mortilla M, et al. Functional reorganization of motor cortex increases with greater axonal injury from CADASIL. Stroke. Feb. 2002;33(2):502-8. [pmid: 11823660].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Reeve W. Use of environmental manipulation and classroom and modified informal reality orientation with institutionalized, confused elderly patients. Age Ageing. 1985;14(2):119-21. [pmid: 4003183].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Regland B, Lehmann W, Abedini I, et al. Treatment of Alzheimer's disease with clioquinol. Dement Geriatr Cogn Disord. Nov. 2001;12(6):408-14. [pmid: 11598313].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rehman S A. Two trials comparing ‘Hydergine’ with placebo in the treatment of patients suffering from cerebrovascular insufficiency. Curr Med Res Opin. 1973;1(8):456-62. [pmid: 4204089].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Reisberg B, Ferris S H, Schneck M K. Piracetam in the treatment of cognitive impairment in the elderly. Drug Dev Res. 1982;2(5):475-80.
Status: Cross-over trial;
Reisberg B, Ferris S H, Anand R. Effects of naloxone in senile dementia: A double-blind trial. N Engl J Med. 1983;308(12):721-2. [pmid: 6338389].
Status: Not included because not a full article
Remington R. Calming music and hand massage with agitated elderly. Nurs Res. Sep. 2002;51(5):317-23. [pmid: 12352780].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Richard F, Helbecque N, Neuman E, et al. APOE genotyping and response to drug treatment in Alzheimer's disease. Lancet. Feb 22. 1997;349(9051):539. [pmid: 9048794].
Status: Not included because Jadad Quality Scale score less than three
Riekkinen M, Laakso M P, Jakala P, et al. Clonidine impairs sustained attention and memory in Alzheimer's disease. Neuroscience. 1999;92(3):975-82. [pmid: 10426537].
Status: Not included because dementia population not randomized to treatment
Riekkinen P Jr, Kuikka J, Soininen H, et al. Tetrahydroaminoacridine modulates technetium-99m labelled ethylene dicysteinate retention in Alzheimer's disease measured with single photon emission computed tomography imaging. Neurosci Lett. Jul 28. 1995;195(1):53-6. [pmid: 7478254].
Status: Not included because no extractable data relevant to review
Riekkinen P Jr, Riekkinen M, Soininen H, et al. Frontal dysfunction blocks the therapeutic effect of THA on attention in Alzheimer's disease. NeuroReport. May 27. 1997;8(8):1845-9. [pmid: 9462474].
Status: Not included because dementia population not randomized to treatment
Riekkinen P J, Koivisto K, Helkala E L, et al. Long-term, double-blind trial of selegiline in Alzheimer's disease. Neurobiol Aging. 1994;15(Suppl 1):67.
Status: Not included because not a full article
Riekkinen P J, Soininen H, Helkala E L, et al. Hippocampal atrophy, acute THA treatment and memory in Alzheimer's disease. NeuroReport. 1995;6(9):1297-300. [pmid: 7669991].
Status: Not included because dementia population not randomized to treatment
Riekkinen P Jr, Soininen H, Partanen J, et al. The ability of THA treatment to increase cortical alpha waves is related to apolipoprotein E genotype of Alzheimer disease patients. Psychopharmacologia. Feb. 1997;129(3):285-8.
Status: Not included because dementia population not randomized to treatment
Riekkinen P Jr, Paakkonen A, Karhu J, et al. THA disrupts mismatch negativity in Alzheimer's disease. Psychopharmacologia. Sep. 1997;133(2):203-6.
Status: Not included because no extractable data relevant to review
Riekkinen P Jr, Riekkinen M. THA improves word priming and clonidine enhances fluency and working memory in Alzheimer's disease. Neuropsychopharmacology. Apr. 1999;20(4):357-64. [pmid: 10481832].
Status: Not included because dementia population not randomized to treatment
Rigaud A - S, Traykov L, Latour F, et al. Presence or absence of at least one epsilon4 allele and gender are not predictive for the response to donepezil treatment in Alzheimer's disease. Pharmacogenetics. 2002;12(5):415-20. [pmid: 12142731].
Status: Not included because dementia population not randomized to treatment
Rigaud A S, Andre G, Vellas B, et al. No additional benefit of HRT on response to rivastigmine in menopausal women with AD. Neurology. 2003;60(1):148-50. [pmid: 12525745].
Status: Not included because Jadad Quality Scale score less than three
Rimon R, Rakkolainen V. Lithium iodide in the treatment of confusional states. Br J Psychiatry. Jan. 1968;114(506):109-10. [pmid: 4865741].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rinne J O, Portin R, Ruottinen H, et al. Cognitive impairment and the brain dopaminergic system in Parkinson's disease: Fluorodopa positron emission tomographic study. Arch Neurol. Apr. 2000;57(4):470-5. [pmid: 10768619].
Status: Not included because dementia population not randomized to treatment
Rinsky J R, Wikler A, Way J G, et al. ‘Mental set’ in controls, postalcoholics, chronic schizophrenics, and ‘organics’. Biol Psychiatry. 1979;14(6):881-90. [pmid: 508881].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Riordan J M, Bennet A V. An evaluation of an augmented domiciliary service to older people with dementia and their carers. Aging Ment Health. 1998;2(2):137-43.
Status: Not included because dementia population not randomized to treatment
Rivera V M, Meyer J S, Baer P E, et al. Vertebrobasilar arterial insufficiency with dementia. Controlled trials of treatment with betahistine hydrochloride. J Am Geriatr Soc. Sep. 1974;22(9):397-406. [pmid: 4212512].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Riviere S, Gillette-Guyonnet S, Voisin T, et al. A nutritional education program could prevent weight loss and slow cognitive decline in Alzheimer's disease. J Nutr Health Aging ; 5(4):295–9.
Status: Not included because dementia population not randomized to treatment
Rizzo J A, Bogardus S T Jr, Leo-Summers L, et al. Multicomponent targeted intervention to prevent delirium in hospitalized older patients: What is the economic value?. Med Care. Jul. 2001;39(7):740-52. [pmid: 11458138].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rizzo M, Ficola U, Marozzi P, et al. Effects of aniracetam on clinical pattern and cerebral blood flow of old patients with degenerative dementia (SDAT). J Neurol. 1994;241:S126.
Status: Not included because not a full article
Robbins T W, Semple J, Kumar R, et al. Effects of scopolamine on delayed-matching-to-sample and paired associates tests of visual memory and learning in human subjects: Comparison with diazepam and implications for dementia. Psychopharmacologia. Nov. 1997;134(1):95-106.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Robert P H, Allain H. Clinical management of agitation in the elderly with tiapride. Eur Psychiatry. Jan. 2001;16(Suppl):47S. [pmid: 11520478].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Roberts C J, Ford J M, Truman C A, et al. Assessment of the value of therapeutic monitoring of tacrine in Alzheimer's disease. Eur J Clin Pharmacol. Nov. 1998;54(910):721-10. [pmid: 9923574].
Status: Not included because dementia population not randomized to treatment
Robichaud L, Hebert R, Desrosiers J. Efficacy of a sensory integration program on behaviors of inpatients with dementia. Am J Occup Ther. Apr. 1994;48(4):355-60. [pmid: 8059869].
Status: Not included because does not meet criteria for treatment for dementia patients
Rochtchina I, Gavrilova S, Kolykchalov I, et al. Neuropsychological assessment of modification of efficacy of cholinergic therapy by preceding cerebrolysin treatment in Alzheimer's disease. J Eur Coll Neuropsychopharmacol 1999; (Suppl 5):S330.
Status: Not included because not a full article
Rockwood K, Stolee P, Howard K, et al. Use of Goal Attainment Scaling to measure treatment effects in an anti-dementia drug trial. Neuroepidemiology. 1996;15(6):330-8. [pmid: 8930946].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rockwood K, Graham J E, Fay S, et al. Goal setting and attainment in Alzheimer's disease patients treated with donepezil. J Neurol Neurosurg Psychiatry. Nov. 2002;73(5):500-7. [pmid: 12397141].
Status: Not included because dementia population not randomized to treatment
Rogers J D, Sanchez-Saffon A, Frol A B, et al. Elevated plasma homocysteine levels in patients treated with levodopa: Association with vascular disease. Arch Neurol. 2003;60(1):59-64. [pmid: 12533089].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rogers J F, Morrison A L, Nafziger A N, et al. Flumazenil reduces midazolam-induced cognitive impairment without altering pharmacokinetics. Clin Pharmacol Ther. 2002;72(6):711-7. [pmid: 12496752].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rogers S L, Doody R, Mohs R, et al. E2020 produces both clinical, global and cognitive test improvement in patients with mild to moderately severe Alzheimer's disease: Results of a 30-week phase III trial. Neurology. 1996;46(Suppl):217.
Status: Not included because not a full article
Rombouts S A, Barkhof F, Van Meel C S, et al. Alterations in brain activation during cholinergic enhancement with rivastigmine in Alzheimer's disease. J Neurol Neurosurg Psychiatry. Dec. 2002;73(6):665-71. [pmid: 12438467].
Status: Not included because dementia population not randomized to treatment
Ronnberg L. Quality of life in nursing-home residents: An intervention study of the effect of mental stimulation through an audiovisual programme. Age Ageing. 1998;27(3):393-7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rosen H J. Mental decline in the elderly: Pharmacotherapy (ergot alkaloids versus papaverine). J Am Geriatr Soc. Apr. 1975;23(4):169-74. [pmid: 803997].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rosenberg SJ, Ryan JJ, Prifitera A. Rey Auditory-Verbal Learning Test performance of patients with and without memory impairment. J Clin Psychol 1984; (3):785–7.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rosenzweig P, Patat A, Zieleniuk I, et al. Cognitive performance in elderly subjects after a single dose of befloxatone, a new reversible selective monoamine oxidase A inhibitor. Clin Pharmacol Ther. Aug. 1998;64(2):211-22. [pmid: 9728902].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rosewarne R, Bruce A, McKenna M. Dementia programme effectiveness in long-term care. Int J Geriatr Psychiatry 1997 Feb; (2):173–82.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rossi R, Inzitari D, Pantoni L, et al. Nimodipine in subcortical vascular dementia trial. Alzheimer Dis Assoc Disord. 1999;13(Suppl 3):S159-S165. [pmid: 10609696].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rostow C D. The effect of self- vs. external-monitoring and locus of control upon the pacing and general adjustment of psychiatric inpatients. Behav Res Ther. 1980;18(6):541-8. [pmid: 7447877].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rother M, Kittner B, Rudolphi K, et al. HWA 285 (propentofylline) - A new compound for the treatment of both vascular dementia and dementia of the Alzheimer type. Ann N Y Acad Sci. 1996;777:404-9. [pmid: 8624121].
Status: Not included because dementia population not randomized to treatment
Rother M. Long-term effects of propentofylline in patients with Alzheimer's disease: A 72-week, placebo-controlled study assessing safety, efficacy, and impact on disease progression. J Cereb Blood Flow Metab. 1999;19(Suppl 1):18.
Status: Not included because not a full article
Rouy J M, Douillon A M, Compan B, et al. Ergoloid mesylates (‘Hydergine’) in the treatment of mental deterioration in the elderly: A 6-month double-blind, placebo-controlled trial. Curr Med Res Opin. 1989;11(6):380-9. [pmid: 2651014].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Rovner B W, Steele C D, Shmuely Y, et al. A randomized trial of dementia care in nursing homes. J Am Geriatr Soc. Jan. 1996;44(1):7-13. [pmid: 8537594].
Status: Not included because does not meet criteria for treatment for dementia patients
Rozzini R, Ferrucci L, Losonczy K, et al. Protective effect of chronic NSAID use on cognitive decline in older persons. J Am Geriatr Soc. 1996;44(9):1025-9. [pmid: 8790225].
Status: Not included because dementia population not randomized to treatment
Rudman D, Racette D, Rudman I W, et al. Hyponatremia in tube-fed elderly men. J Chronic Dis. 1986;39(2):73-80. [pmid: 3080461].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ruether E, Husmann R, Kinzler E, et al. A 28-week, double-blind, placebo-controlled study with cerebrolysin in patients with mild to moderate Alzheimer's disease. Int Clin Psychopharmacol. 2001;16(6):372. [pmid: 11552768].
Status: Not included because not a full article
Ruggiero, Ovallesco U. Clozapine and validation therapy in the treatment of dementia. Funct Neurol. 1997;3–4(12):240-412.
Status: Not included because dementia population not randomized to treatment
Ryden M B, Snyder M, Gross C R, et al. Value-added outcomes: The use of advanced practice nurses in long-term care facilities. Gerontologist. Dec. 2000;40(6):654-62. [pmid: 11131082].
Status: Not included because does not meet criteria for treatment for dementia patients
Ryynanen O P, Myllykangas M, Kinnunen J, et al. Doctors' willingness to refer elderly patients for elective surgery. Fam Pract. Jun. 1997;14(3):216-9. [pmid: 9201495].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Saarela T, Kiviharju U. Evaluating the usefulness of training in psychogeriatrics. Int J Geriatr Psychiatry 1995 Dec; (12):1019–22.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sabe L, Kuzis G, Garcia C A, et al. A randomized, double-blind, placebo-controlled study of idebenone in Alzheimer's disease (AD). JNS. 1997;150(Suppl):S296.
Status: Not included because not a full article
Sacktor N, Schifitto G, McDermott M P, et al. Transdermal selegiline in HIV-associated cognitive impairment: Pilot, placebo-controlled study. Neurology. Jan 11. 2000;54(1):233-5. [pmid: 10636157].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sacktor N, McDermott M P, Marder K, et al. HIV-associated cognitive impairment before and after the advent of combination therapy. J Neurovirol. 2002;8(2):136-42. [pmid: 11935465].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sahakian B J, Coull J T. Tetrahydroaminoacridine (THA) in Alzheimer's disease: An assessment of attentional and mnemonic function using CANTAB. Acta Neurol Scand Suppl. 1993;Vol 149:29-35. [pmid: 8128835].
Status: Cross-over trial;
Sahakian B J, Owen A M, Morant N J, et al. Further analysis of the cognitive effects of tetrahydroaminoacridine (THA) in Alzheimer's disease: Assessment of attentional and mnemonic function using CANTAB. Psychopharmacologia. 1993;110(4):395-401.
Status: Cross-over trial;
Sahakian B J, Coull J T. Nicotine and tetrahydroaminoacradine: Evidence for improved attention in patients with dementia of the Alzheimer type. Drug Dev Res. 1994;31(1):80-8.
Status: Not included because dementia population not randomized to treatment
Sahin H A, Gurvit I H, Bilgic B, et al. Therapeutic effects of an acetylcholinesterase inhibitor (donepezil) on memory in Wernicke-Korsakoff's disease. Clin Neuropharmacol. Jan. 2002;25(1):16-20. [pmid: 11852291].
Status: Not included because dementia population not randomized to treatment
Saine K, Cullum C M, Martin-Cook K, et al. Comparison of functional and cognitive donepezil effects in Alzheimer's disease. Int Psychogeriatr. 2002;14(2):181-5. [pmid: 12243208].
Status: Not included because dementia population not randomized to treatment
Sajatovic M, Mullen J A, Sweitzer D E. Efficacy of quetiapine and risperidone against depressive symptoms in outpatients with psychosis. J Clin Psychiatry. 2002;63(12):1156-63. [pmid: 12523876].
Status: Not included because no extractable data relevant to review
Saldmann F, Funel A, Jacquet P. Efficacy of naftidrofuryl in patients with moderate senile dementia. Curr Med Res Opin. 1991;12(6):379-89. [pmid: 2044398].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Saletu B, Linzmayer L, Grunberger J, et al. Double-blind, placebo-controlled, clinical, psychometric and neurophysiological investigations with oxiracetam in the organic brain syndrome of late life. Neuropsychobiology. 1985;13(12):44-2. [pmid: 3897895].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Saletu B, Gruenberger J, Linzmayer L, et al. EEG brain mapping and psychometry in age-associated memory impairment after acute and 2-week infusions with the hemoderivative Actovegin®: Double-blind, placebo-controlled trials. Neuropsychobiology. 1990;24(3):135-48. [pmid: 2135068].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Saletu B, Anderer P, Fischhof P K, et al. EEG mapping and psychopharmacological studies with denbufylline in SDAT and MID. Biol Psychiatry. Oct 15. 1992;32(8):668-81. [pmid: 1457622].
Status: Not included because Jadad Quality Scale score less than three
Saletu B, Anderer P, Semlitsch H V, et al. Amantadine infusions in mild dementia: Acute double-blind placebo-controlled EEG mapping and psychometric studies. Arch Gerontol Geriatr. 1992;15(1):43-58. [pmid: 15374380].
Status: Cross-over trial;
Saletu M, Grunberger J, Saletu B, et al. Accelerated remission of the alcoholic organic brain syndrome with EMD 21657. Double-blind clinical and psychometric trials. Arzneimittelforschung. 1978;28(9):1525-7. [pmid: 383103].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Salib E, Sheridan T, Allington M. Ventricular measurements in computed tomography of responders and non-responders to donepezil in the treatment of Alzheimer's disease. Int J Psychiatry Clin Pract. 2001;5(3):189-94.
Status: Not included because dementia population not randomized to treatment
Salvioli G, Neri G. L-acetylcarnitine treatment of mental decline in the elderly. Drugs Exp Clin Res. 1994;20(4):169-76. [pmid: 7813389].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Samorajski T, Vroulis G A, Smith R C. Piracetam plus lecithin trials in senile dementia of the Alzheimer type. Ann N Y Acad Sci. 1985;444:478-81. [pmid: 3893273].
Status: Not included because dementia population not randomized to treatment
Samuel W, Caligiuri M, Galasko D, et al. Better cognitive and psychopathologic response to donepezil in patients prospectively diagnosed as dementia with Lewy bodies: A preliminary study. Int J Geriatr Psychiatry. Sep. 2000;15(9):794-802. [pmid: 10984725].
Status: Not included because dementia population not randomized to treatment
Sanders D S, Carter M J, D'Silva J, et al. Survival analysis in percutaneous endoscopic gastrostomy feeding: A worse outcome in patients with dementia. Am J Gastroenterol. 2000;95(6):1472-5. [pmid: 10894581].
Status: Not included because dementia population not randomized to treatment
Sano M, Stern Y, Marder K, et al. A controlled trial of piracetam in intellectually impaired patients with Parkinson's disease. Mov Disord. 1990;5(3):230-4. [pmid: 2388639].
Status: Not included because no extractable data relevant to review
Sano M, Bell K, Marder K, et al. Safety and efficacy of oral physostigmine in the treatment of Alzheimer's disease. Clin Neuropharmacol. Feb. 1993;16(1):61-9. [pmid: 8422658].
Status: Cross-over trial;
Sano M, Growdon J, Klauber M, et al. Expanding the severity range of patients in clinical trials for Alzheimer's disease: A multicentre clinical trial of Selegiline and alpha-tocopherol. Neurology. 1995;45(Suppl 4):A289.
Status: Not included because not a full article
Sano M, Ernesto C, Thomas R G, et al. Effects of Selegiline and alpha-Tocopherol on cognitive and functional outcome measures in moderately impaired patients with Alzheimer's disease. Neurology. 1997;48(Suppl):A377-A378.
Status: Not included because not a full article
Sano M, Bell K, Jacobs D. Cognitive effects of estrogens in women with cardiac disease: What we do not know. Am J Med. 2002;113(7):612-3. [pmid: 12459411].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sansom G. Comparing multisensory stimulation with (1) tactile stimulation and (2) themed reminiscence. Journal of Dementia Care. 2002;10(4):38.
Status: Not included because not a full article
Satlin A, Volicer L, Ross V, et al. Bright light treatment of behavioral and sleep disturbances in patients with Alzheimer's disease. Am J Psychiatry. 1992;149(8):1028-32. [pmid: 1353313].
Status: Not included because dementia population not randomized to treatment
Sato K, Kamiya S, Okawa M, et al. Effect of transcranial electrostimulation on EEG component waves of elderly patients with dementia. J Brain Sci. 1998;24(12):65-72.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Savoldi F, Nappi G, Martignoni E, et al. Brain phospholipids in the treatment of chronic cerebrovascular insufficiency. Curr Ther Res Clin Exp. 1978;24(2):209.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Scarzella L, Bono G, Bergamasco B. Dihydroergocryptine in the management of senile psycho-organic syndrome. Int J Clin Pharmacol Res. 1992;12(1):37-46. [pmid: 1526697].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Scherder E, Bouma A, Steen L. Effects of simultaneously applied short-term transcutaneous electrical nerve stimulation and tactile stimulation on memory and affective behaviour of patients with probable Alzheimer's disease. Behav Neurol 1995; (1):3–13.
Status: Not included because dementia population not randomized to treatment
Scherder E J, Bouma A, Steen L. Influence of transcutaneous electrical nerve stimulation on memory in patients with dementia of the Alzheimer type. J Clin Exp Neuropsychol. Nov. 1992;14(6):951-60. [pmid: 1360474].
Status: Not included because dementia population not randomized to treatment
Scherder E J, Bouma A, Steen A M. Effects of short-term transcutaneous electrical nerve stimulation on memory and affective behaviour in patients with probable Alzheimer's disease. Behav Brain Res. 1995;67(2):211-9. [pmid: 7779292].
Status: Not included because dementia population not randomized to treatment
Scherder E J, Bouma A, Steen L M. Effects of “isolated” transcutaneous electrical nerve stimulation on memory and affective behavior in patients with probable Alzheimer's disease. Biol Psychiatry. Mar 15. 1998;43(6):417-24. [pmid: 9532346].
Status: Not included because does not meet criteria for treatment for dementia patients
Scherder E J, Van Someren E J, Swaab D F. Transcutaneous electrical nerve stimulation (TENS) improves the rest-activity rhythm in midstage Alzheimer's disease. Behav Brain Res. May. 1999;101(1):105-7. [pmid: 10342404].
Status: Not included because no extractable data relevant to review
Scherder E J, Bouma A. Effects of transcutaneous electrical nerve stimulation on memory and behavior in Alzheimer's disease may be stage-dependent. Biol Psychiatry. Mar 15. 1999;45(6):743-9. [pmid: 10188004].
Status: Not included because does not meet criteria for treatment for dementia patients
Scherder E J, Van Someren E J, Bouma A, et al. Effects of transcutaneous electrical nerve stimulation (TENS) on cognition and behaviour in aging. Behav Brain Res. Jun 15. 2000;111(12):223-2. [pmid: 10840147].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Scherder E J, Deijen J B, Vreeswijk S H, et al. Cranial electrostimulation (CES) in patients with probable Alzheimer's disease. Behav Brain Res. Jan 22. 2002;128(2):215-7. [pmid: 11796166].
Status: Not included because Jadad Quality Scale score less than three
Scherder E, Bouma A, Steen L. Effects of peripheral tactile stimulation on memory in patients with probable Alzheimer's disease. Am J Alzheimers Dis 1995 May; (3):15–21.
Status: Not included because dementia population not randomized to treatment
Scherder E, Bouma A, Steen L. Effects of peripheral tactile nerve stimulation on affective behavior of patients with probable Alzheimer's disease. Am J Alzheimers Dis 1998 Mar; (2):61–9.
Status: Not included because does not meet criteria for treatment for dementia patients
Schiffmann R, Heyes M P, Aerts J M, et al. Prospective study of neurological responses to treatment with macrophage-targeted glucocerebrosidase in patients with type 3 Gaucher's disease. Ann Neurol. Oct. 1997;42(4):613-21. [pmid: 9382473].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schifitto G, Sacktor N, Marder K, et al. Randomized trial of the platelet-activating factor antagonist lexipafant in HIV-associated cognitive impairment. Neurological AIDS Research Consortium. Neurology. Jul 22. 1999;53(2):391-6. [pmid: 10430432].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schlegel J, Mohr E, Williams J, et al. Guanfacine treatment of Alzheimer's disease. Clin Neuropharmacol. 1989;12(2):124-8. [pmid: 2566381].
Status: Cross-over trial;
Schmechel D E, Schmitt F, Horner J, et al. Lack of effect of oral physostigmine and lecithin in patients with probable Alzheimer's disease. Neurology. 1984;34(Suppl 1):280.
Status: Not included because not a full article
Schmidt I K, Fastbom J. Quality of drug use in Swedish nursing homes. A follow-up study. Clin Drug Investig. 2000;20(6):433-46.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schmitt R, Capo T, Frazier H, et al. Cranial electrotherapy stimulation treatment of cognitive brain dysfunction in chemical dependence. J Clin Psychiatry. Mar. 1962;45(2):60-1. [pmid: 6363398].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schneider L S, Gleason R P. Carbamazepine in behaviorally disturbed primary dementia patients. J Clin Psychiatry. 1990;51(12):524. [pmid: 1968457].
Status: Not included because not a full article
Schneider L S, Lyness S A, Pawluczyk S, et al. Do blood pressure and age predict response to tacrine (THA) in Alzheimer's disease? A preliminary report. Psychopharmacol Bull. 1991;27(3):309-14. [pmid: 1775604].
Status: Not included because no extractable data relevant to review
Schneider L S, Olin J T, Pawluczyk S. A double-blind crossover pilot study of l-deprenyl (selegiline) combined with cholinesterase inhibitor in Alzheimer's disease. Am J Psychiatry. Feb. 1993;150(2):321-3. [pmid: 8422085].
Status: Cross-over trial;
Schneider L S, Farlow M R, Henderson V W, et al. Estrogen replacement therapy may enhance response to tacrine in women with Alzheimer's disease. Neurology. 1995;45:288.
Status: Not included because not a full article
Schneider L S, Farlow M K. Severity of Alzheimer's disease and response to cholinergic therapy. Eur J Neurol. 1996;3:238.
Status: Not included because not a full article
Schneider L S, Farlow M R, Pogoda J M. Potential role for estrogen replacement in the treatment of Alzheimer's dementia. Am J Med. Sep 22. 1997;103(3A):46S-50S. [pmid: 9344406].
Status: Not included because Jadad Quality Scale score less than three
Schneider L S, Tariot P N, Lyketsos C G, et al. National Institute of Mental Health Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE): Alzheimer's disease trial methodology. Am J Geriatr Psychiatry. 2001;9(4):346-60. [pmid: 11739062].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schredl M, Weber B, Braus D, et al. The effect of rivastigmine on sleep in elderly healthy subjects. Exp Gerontol. 2000;35(2):243-9. [pmid: 10767583].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schreiber M, Schweizer A, Lutz K, et al. Potential of an interactive computer-based training in the rehabilitation of dementia: An initial study. Neuropsychol Rehab 1999; (2):155–67.
Status: Not included because dementia population not randomized to treatment
Schrijnemaekers V, van Rossum E, Candel M, et al. Effects of emotion-oriented care on elderly people with cognitive impairment and behavioral problems. Int J Geriatr Psychiatry. Oct. 2002;17(10):926-37. [pmid: 12325052].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schuck S, Lebreton S. Aminotransferase levels and silymarine in de novo tacrine-treated Alzheimer's disease patients. Fundam Clin Pharmacol. 1999;13(3):422.
Status: Not included because not a full article
Schulz R, O'Brien A, Czaja S, et al. Dementia caregiver intervention research: in search of clinical significance. Gerontologist. Oct. 2002;42(5):589-602. [pmid: 12351794].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Schwartz A S, Kohlstaedt E V. Physostigmine effects in Alzheimer's disease: Relationship to dementia severity. Life Sci. Mar 17. 1986;38(11):1021-8. [pmid: 3512944].
Status: Not included because no extractable data relevant to review
Schwartz B L, Hashtroudi S, Herting R L, et al. D-Cycloserine enhances implicit memory in Alzheimer patients. Neurology. Feb. 1996;46(2):420-4. [pmid: 8614505].
Status: Not included because no extractable data relevant to review
Schweiger C. A 48-week, placebo-controlled study examining propentofylline's safety, efficacy, and impact on disease progression in patients with vascular dementia. J Eur Coll Neuropsychopharmacol 1999; (Suppl 5):S319.
Status: Not included because not a full article
Seipel J H, Fisher R, Floam J E, et al. Rheoencephalographic and other studies of betahistine in humans. III. Improved methods of diagnosis and selection in arteriosclerotic dementia. J Clin Pharmacol. Jan. 1977;17(1):63-75. [pmid: 319123].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Seipel J H, Fisher R, Blatchley R J, et al. Rheoencephalographic and other studies of betahistine in humans. IV. Prolonged administration with improvement in arteriosclerotic dementia. J Clin Pharmacol. Feb. 1977;17(23):140-3. [pmid: 319123].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Semlitsch H V, Anderer P, Saletu B, et al. Topographic mapping of cognitive event-related potentials in a double-blind, placebo-controlled study with the hemoderivative Actovegin in age-associated memory impairment. Neuropsychobiology. Sep. 1990;24(1):49-56. [pmid: 2135068].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Semlitsch H V, Anderer P, Saletu B. Topographic mapping of long latency “cognitive” event-related potentials (P 300): A double-blind, placebo-controlled study with amantadine in mild dementia. J Neural Transm Park Dis Dement Sect. 1992;4:319-36. [pmid: 1388702].
Status: Not included because no extractable data relevant to review
Semlitsch H V, Anderer P, Saletu B, et al. Cognitive psychophysiology in nootropic drug research: Effects of Ginkgo biloba on event-related potentials (P300) in age-associated memory impairment. Pharmacopsychiatry. Jul. 1995;28(4):134-42. [pmid: 7491367].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Senin U, Parnetti L, Barbagallo-Sangiorgi G, et al. Idebenone in senile dementia of Alzheimer type: A multicentre study. Arch Gerontol Geriatr. 1992;15(3):249-60. [pmid: 15374364].
Status: Not included because Jadad Quality Scale score less than three
Serafetinides E A, Willis D, Clark M L. The EEG effects of zinc in geriatric psychiatric patients. Int Pharmacopsychiatry. 1974;9(2):95-9. [pmid: 4605368].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Serby M, Angrist B, Corwin J, et al. Cholecystokinin octapeptide in dementia. Psychopharmacol Bull. 1984;20(3):546-7. [pmid: 6089253].
Status: Not included because dementia population not randomized to treatment
Serby M, Resnick R, Jordan B, et al. Naltrexone and Alzheimer's disease. Prog Neuropsychopharmacol Biol Psychiatry. 1986;10(35):587-90. [pmid: 3541052].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Serfaty M, Kennell-Webb S, Warner J, et al. Double blind randomised placebo controlled trial of low dose melatonin for sleep disorders in dementia. Int J Geriatr Psychiatry. 2002;17(12):1120-7. [pmid: 12461760].
Status: Cross-over trial;
Seux M-L, Forette F, Staessen J A, et al. Treatment of isolated systolic hypertension and dementia prevention in older patients. Results of the Systolic Hypertension in Europe trial (SYST-EUR) vascular dementia project. Eur Heart J Suppl. 1999;1(M):M6-M12.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sevush S, Guterman A, Villalon A V. Improved verbal learning after outpatient oral physostigmine therapy in patients with dementia of the Alzheimer type. J Clin Psychiatry. Jul. 1991;52(7):300-3. [pmid: 2071560].
Status: Not included because dementia population not randomized to treatment
Shaw F E, Bond J, Richardson D A, et al. Multifactorial intervention after a fall in older people with cognitive impairment and dementia presenting to the accident and emergency department: Randomised controlled trial. BMJ. 2003;326(7380):73-5. [pmid: 12521968]. [pmcid: 139930].
Status: Not included because does not meet criteria for treatment for dementia patients
Shaw T G, Meyer J S. Double-blind trial of oral papaverine in chronic cerebrovascular ischemia. Angiology. Nov. 1978;29(11):839-51. [pmid: 103467].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sheikh J I, Hill R D, Yesavage J A. Long-term efficacy of cognitive training for age-associated memory impairment: A six-month follow-up study. Dev Neuropsychol. 1986;2(4):413-21.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Shelton P, Schraeder C, Dworak D, et al. Caregivers' utilization of health services: results from the Medicare Alzheimer's Disease Demonstration, Illinois site. J Am Geriatr Soc. Dec. 2001;49(12):1600-5. [pmid: 11843991].
Status: Not included because does not meet criteria for treatment for dementia patients
Sherwin B B. Estrogen and cognitive functioning in men with Mild Cognitive Impairment. J Mol Neurosci. 2002;19(12):219-23. [pmid: 12212785].
Status: Not included because no extractable data relevant to review
Shua-Haim J R, Shua-Haim V, Sabo M, et al. Case report: Donepezil in the treatment of advanced Alzheimer's disease. Ann Long Term Care. 1999;7(2):67-71.
Status: Not included because dementia population not randomized to treatment
Shua-Haim J R, Shua-Haim V, Comsti E, et al. Donepezil (Aricept(TM)) treatment of multi infarct dementia: The caregivers and clinical impression. Am J Alzheimers Dis. 2000;15(4):201-11.
Status: Not included because dementia population not randomized to treatment
Shumaker S A, Reboussin B A, Espeland M A, et al. The Women's Health Initiative Memory Study (WHIMS): A trial of the effect of estrogen therapy in preventing and slowing the progression of dementia. Control Clin Trials. Dec. 1998;19(6):604-21. [pmid: 9875839].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sidtis J J, Gatsonis C, Price R W, et al. Zidovudine treatment of the AIDS dementia complex: Results of a placebo-controlled trial. AIDS Clinical Trials Group. Ann Neurol. Apr. 1993;33(4):343-9. [pmid: 8489204].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Silverberg G D, Levinthal E, Sullivan E V, et al. Assessment of low-flow CSF drainage as a treatment for AD: Results of a randomized pilot study. Neurology. Oct 22. 2002;59(8):1139-45. [pmid: 12391340].
Status: Not included because does not meet criteria for treatment for dementia patients
Sinforiani E, Iannuccelli M, Mauri M, et al. Neuropsychological changes in demented patients treated with acetyl-L-carnitine. Int J Clin Pharmacol Res. 1990;10(12):69-74. [pmid: 2387665].
Status: Not included because Jadad Quality Scale score less than three
Sival R C, Haffmans P M, Jansen P A, et al. Sodium valproate in the treatment of aggressive behavior in patients with dementia: A randomized placebo controlled clinical trial. Int J Geriatr Psychiatry. 2002;17(6):579-85. [pmid: 12112183].
Status: Cross-over trial;
Skelly J, Flint A, Brunt S, et al. Treatment of urinary incontinence in dementia using low dose oxybutynin chloride. Age Ageing. 1995;24(S):19.
Status: Not included because not a full article
Slooter A J C, Houwing-Duistermaat J J, van Harskamp F, et al. Apolipoprotein E genotype and progression of Alzheimer's disease: The Rotterdam Study. J Neurol. 1999;246(4):304-8. [pmid: 10367700].
Status: Not included because dementia population not randomized to treatment
Smallwood J, Brown R, Coulter F, et al. Aromatherapy and behaviour disturbances in dementia: A randomized controlled trial. Int J Geriatr Psychiatry. Oct. 2001;16(10):1010-3. [pmid: 11607948].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Smid H G, Trumper B G, Pottag G, et al. Differentiation of hypoglycaemia induced cognitive impairments. An electrophysiological approach. Brain. Jun. 1997;120(Pt 6):1041-56. [pmid: 9217687].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Smith C M, Swash M, Exton-Smith A N, et al. Choline therapy in Alzheimer's disease. Lancet. Aug 5. 1978;2(8084):318. [pmid: 79110].
Status: Not included because not a full article
Smith C M, Swash M. Physostigmine in Alzheimer's disease. Lancet. Jan 6. 1979;1(8106):42. [pmid: 83485].
Status: Not included because not a full article
Smith D F, Stromgren E, Petersen H N. Lack of effect of tryptophan treatment in demented gerontopsychiatric patients. A double-blind, crossover-controlled study. Acta Psychiatr Scand. 1984;70(5):470-7. [pmid: 6393715].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Smith D J, Yukhnevich S. Adverse reactions to rivastigmine in three cases of dementia. Aust N Z J Psychiatry. 2001;35(5):694-5. [pmid: 11551292].
Status: Not included because not a full article
Smith F. Mixed-model analysis of incomplete longitudinal data from a high-dose trial of tacrine (Cognex) in Alzheimer's patients. J Biopharm Stat. Mar. 1996;6(1):59-67. [pmid: 8969976].
Status: Not included because Jadad Quality Scale score less than three
Smith F, Gracon S, Knopman D, et al. Survival analysis to evaluate the effect of long-term tacrine (Cognex) treatment on nursing home placement in Alzheimer's patients. J Neurol. 1997;244(Suppl 3):S88.
Status: Not included because not a full article
Smith F, Gracon S, Knopman D, et al. Tacrine treatment and nursing home placement: Application of the Cox proportional hazards model with time-dependent covariates. Drug Inf J. 1998;32(3):729-35.
Status: Not included because dementia population not randomized to treatment
Smith G R, Taylor C W, Linkous P. Haloperidol versus thioridazine for the treatment of psychogeriatric patients: A double-blind clinical trial. Psychosomatics: Journal of Consultation Liasion Psychiatry. 1974;15(3):134-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Smith M K. The effects of participatory music on the reality orientation and sociability of Alzheimer's residents in a long-term-care setting. Activities Adaptation Aging. 1994;18(2):41-55.
Status: Not included because dementia population not randomized to treatment
Smith R C, Vroulis G, Johnson R, et al. Comparison of therapeutic response to long-term treatment with lecithin versus piracetam plus lecithin in patients with Alzheimer's disease. Psychopharmacol Bull. 1984;20(3):542-5. [pmid: 6433396].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Smith W L, Lowrey J B, Davis J A. The effects of cyclandelate on psychological test performance in patients with cerebral vascular insufficiency. Curr Ther Res Clin Exp. 1968;10(12):613-8. [pmid: 4972756].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Snaedal J, Johannesson T, Jonsson J E, et al. The effects of nicotine in dermal plaster on cognitive functions in patients with Alzheimer's disease. Dementia. Jan. 1996;7(1):47-52. [pmid: 8788082].
Status: Not included because dementia population not randomized to treatment
Snyder M, Egan E C, Burns K R. Interventions for decreasing agitation behaviors in persons with dementia. J Gerontol Nurs. Jul. 1995;21(7):34-40. [pmid: 7615916].
Status: Not included because dementia population not randomized to treatment
Snyder M, Tseng Y, Brandt C, et al. A glider swing intervention for people with dementia. Geriatr Nurs (Minneap). Mar. 2001;22(2):86-90.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sobel B P. Bingo vs. physical intervention in stimulating short-term cognition in Alzheimer's disease patients. Am J Alzheimers Dis Other Demen. Mar. 2001;16(2):115-20. [pmid: 11302072].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sobow T M, Maczkiewicz M, Kloszewska I. Tianeptine versus fluoxetine in the treatment of depression complicating Alzheimer's disease. Int J Geriatr Psychiatry. 2001;16(11):1108-9. [pmid: 11746660].
Status: Not included because not a full article
Solomon P R, Knapp M J, Gracon S I, et al. Long-term tacrine treatment in patients with Alzheimer's disease. Lancet. Jul 27. 1996;348(9022):275-6. [pmid: 8684234].
Status: Not included because not a full article
Soncrant T T, Raffaele K C, Asthana S, et al. Memory improvement without toxicity during chronic, low dose intravenous arecoline in Alzheimer's disease. Psychopharmacologia. 1993;112(4):421-7.
Status : Cross-over trial;
Sourander L B, Portin R, Molsa P, et al. Senile dementia of the Alzheimer type treated with aniracetam: A new nootropic agent. Psychopharmacologia. 1987;91(1):90-5.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Spagnolo C, Dallasta D, Iannuccelli M. A cntrolled double-blind trial comparing etoperidone with thioridazine in the management of severe senile dementia. Drugs Exp Clin Res. 1983;9(12):873-80.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Spector A, Orrell M, Davies S, et al. Can reality orientation be rehabilitated? Development and piloting of an evidence-based programme of cognition-based therapies for people with dementia. Neuropsychol Rehab. 2001;11(34):377-97.
Status: Not included because does not meet criteria for treatment for dementia patients
Sramek J J, Cutler N R, Hurley D J, et al. The utility of salivary amylase as an evaluation of M3 muscarinic agonist activity in Alzheimer's disease. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1995;19(1):85-91. [pmid: 7535938].
Status: Not included because does not meet criteria for treatment for dementia patients
Sramek J J, Sedman A J, Reece P A, et al. Safety and tolerability of CI-979 in patients with Alzheimer's disease. Life Sci. 1995;57(5):503-10. [pmid: 7623616].
Status: Not included because no extractable data relevant to review
Sramek J J, Hurley D J, Wardle T S, et al. The safety and tolerance of xanomeline tartrate in patients with Alzheimer's disease. J Clin Pharmacol. Aug. 1995;35(8):800-6. [pmid: 8522637].
Status: Not included because no extractable data relevant to review
Sramek J J, Viereck C, Huff F J, et al. A “bridging” (safety/tolerance) study of besipirdine hydrochloride in patients with Alzheimer's disease. Life Sci. 1995;57(12):1241-8. [pmid: 7674813].
Status: Not included because no extractable data relevant to review
Sramek J J, Block G A, Reines S A, et al. A multiple-dose safety trial of eptastigmine in Alzheimer's disease, with pharmacodynamic observations of red blood cell cholinesterase. Life Sci. 1995;56(5):319-26. [pmid: 7837931].
Status: Not included because no extractable data relevant to review
Sramek J J, Anand R, Wardle T S, et al. Safety/tolerability trial of SDZ ENA 713 in patients with probable Alzheimer's disease. Life Sci. 1996;58(15):1201-7. [pmid: 8614273].
Status: Not included because no extractable data relevant to review
Sramek J J, Forrest M, Mengel H, et al. A bridging study of LU 25–109 in patients with probable Alzheimer's disease. Life Sci. 1998;62(3):195-202. [pmid: 9488097].
Status: Not included because dementia population not randomized to treatment
Sramek J J, Hourani J, Jhee S S, et al. NXX-066 in patients with Alzheimer's disease: A bridging study. Life Sci. 1999;64(14):1215-21. [pmid: 10210264].
Status: Not included because no extractable data relevant to review
St Clair D, Norrman J, Perry R, et al. Apolipoprotein E epsilon 4 allele frequency in patients with Lewy body dementia, Alzheimer's disease and age-matched controls. Neurosci Lett. Jul 18. 1994;176(1):45-6. [pmid: 7970234].
Status: Not included because dementia population not randomized to treatment
Stapleton J M, Eckardt M J, Martin P, et al. Treatment of alcoholic organic brain syndrome with the serotonin reuptake inhibitor fluvoxamine: A preliminary study. Adv Alcohol Subst Abuse. 1988;7(34):47-4. [pmid: 2464912].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Starr J M, Whalley L J. Hypertensive Old People in Edinburgh (HOPE) Study: Electrocardiographic changes after captopril or bendrofluazide treatment. Age Ageing. Sep. 1993;22(5):343-8. [pmid: 8237624].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Starr J M, Whalley L J, Inch S, et al. A double-blind trial of captopril or bendrofluazide in newly diagnosed senile hypertension. Curr Med Res Opin. 1994;13(4):214-21. [pmid: 7882701].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Starr J M, Whalley L J, Deary I J. The effects of antihypertensive treatment on cognitive function: Results from the HOPE study. J Am Geriatr Soc. Apr. 1996;44(4):411-5. [pmid: 8636587].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Steele C, Lucas M J, Tune L. Haloperidol versus thioridazine in the treatment of behavioral symptoms in senile dementia of the Alzheimer's type: Preliminary findings. J Clin Psychiatry. Jun. 1986;47(6):310-2. [pmid: 3711028].
Status: Not included because dementia population not randomized to treatment
Stegink A J. The clinical use of piracetam, a new nootropic drug. The treatment of symptoms of senile involution. Arzneimittelforschung. Jun. 1972;22(6):975-7. [pmid: 4559159].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Steiger William A. Effects of naloxone in treatment of senile dementia. J Am Geriatr Soc. 1985;33(2):155. [pmid: 3968375].
Status: Not included because not a full article
Stern F H. Management of chronic brain syndrome secondary to cerebral arteriosclerosis, with special reference to papaverine hydrochloride. J Am Geriatr Soc. Jun. 1970;18(6):507-12. [pmid: 4910976].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Stern Y, Sano M, Mayeux R. Effects of oral physostigmine in Alzheimer's disease. Ann Neurol. Sep. 1987;22(3):306-10. [pmid: 3674795].
Status: Not included because dementia population not randomized to treatment
Stern Y, Sano M, Mayeux R. Long-term administration of oral physostigmine in Alzheimer's disease. Neurology. Dec. 1988;38(12):1837-41. [pmid: 3057398].
Status: Cross-over trial;
Stevermer J J, Lindbloom E J. Ginkgo biloba for dementia. J Fam Pract. 1998;46(1):20. [pmid: 9789505].
Status: Not included because not a full article
Stewart A, Phillips R, Dempsey G. Pharmacotherapy for people with Alzheimer's disease: A Markov-cycle evaluation of five years' therapy using donepezil. Int J Geriatr Psychiatry. Jul. 1998;13(7):445-53. [pmid: 9695032].
Status: Not included because dementia population not randomized to treatment
Stewart W F, Kawas C, Corrada M, et al. Risk of Alzheimer's disease and duration of NSAID use. Neurology. Mar. 1997;48(3):626-32. [pmid: 9065537].
Status: Not included because does not meet criteria for treatment for dementia patients
Stoppe G, Sandholzer H, Staedt J, et al. Sleep disturbances in the demented elderly: Treatment in ambulatory care. Sleep. 1995;18(10):844-8. [pmid: 8746390].
Status: Not included because dementia population not randomized to treatment
Stotsky B A, Cole J O, Tang Y T, et al. Sodium butabarbital (butisol sodium) as an hypnotic agent for aged psychiatric patients with sleep disorders. J Am Geriatr Soc. Oct. 1971;19(10):860-70. [pmid: 4949261].
Status: Not included because no extractable data relevant to review
Stotsky B A, Cole J O, Lu L M, et al. A controlled study of the efficacy of pentylenetetrazol (Metrazol) with hard-core hospitalized psychogeriatric patients. Am J Psychiatry. Oct. 1972;129(4):387-91. [pmid: 4561017].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Stracciari A, Ciucci G, Loreta R, et al. Multi-infarct dementia: Clinical trial with acetyl-l-carnitine vs placebo. J Neurol. 1988;235(Suppl):92.
Status: Not included because not a full article
Street J, Clark W S, Gannon K S, et al. Reduction of psychotic symptoms in patients with Lewy Body-like symptoms treated with olanzapine. J Eur Coll Neuropsychopharmacol. 1999;9(Suppl 5):S331.
Status : Not included because not a full article
Streim J E, Oslin D W, Katz I R, et al. Drug treatment of depression in frail elderly nursing home residents. Am J Geriatr Psychiatry. 2000;8(2):150-9. [pmid: 10804076].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sudilovsky A, Cutler N R, Sramek J J, et al. A pilot clinical trial of the angiotensin-converting enzyme inhibitor ceranapril in Alzheimer's disease. Alzheimer Dis Assoc Disord. 1993;7(2):105-11. [pmid: 8347328].
Status: Cross-over trial;
Sultzer D L, Gray K F, Gunay I, et al. A double-blind comparison of trazodone and haloperidol for treatment of agitation in patients with dementia. Am J Geriatr Psychiatry. 1997;5(1):60-9. [pmid: 9169246].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sultzer D L, Gray K F, Gunay I, et al. Does behavioral improvement with haloperidol or trazodone treatment depend on psychosis or mood symptoms in patients with dementia?. J Am Geriatr Soc. Oct. 2001;49(10):1294-300. [pmid: 11890487].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sumiyoshi T, Matsui M, Nohara S, et al. Enhancement of cognitive performance in schizophrenia by addition of tandospirone to neuroleptic treatment. Am J Psychiatry. 2001;158(10):1722-5. [pmid: 11579010].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Summers W K, Majovski L V, Marsh G M, et al. Oral tetrahydroaminoacridine in long-term treatment of senile dementia, Alzheimer type. N Engl J Med. Nov 13. 1986;315(20):1241-5. [pmid: 2430180].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Sunderland T, Tariot P, Murphy D L, et al. Scopolamine challenges in Alzheimer's disease. Psychopharmacologia. 1985;87(2):247-9.
Status: Cross-over trial;
Sunderland T, Tariot P N, Cohen R M, et al. Anticholinergic sensitivity in patients with dementia of the Alzheimer type and age-matched. Arch Gen Psychiatry. 1987;44(5):418-26. [pmid: 3579494].
Status: Not included because Jadad Quality Scale score less than three
Sunderland T, Weingartner H, Cohen R M, et al. Low-dose oral lorazepam administration in Alzheimer subjects and age-matched controls. Psychopharmacologia. 1989;99(1):129-33.
Status: Cross-over trial;
Sunderland T, Molchan S, Lawlor B, et al. A strategy of “combination chemotherapy” in Alzheimer's disease: Rationale and preliminary results with physostigmine plus deprenyl. Int Psychogeriatr. 1992;4(Suppl 2):291-309. [pmid: 1288668].
Status: Not included because dementia population not randomized to treatment
Swanson E A, Maas M L, Buckwalter K C. Alzheimer's residents' cognitive and functional measures: Special and traditional care unit comparison. Clin Nurs Res. Feb. 1994;3(1):27-41. [pmid: 8167575].
Status: Not included because does not meet criteria for treatment for dementia patients
Swanson E A, Maas M L, Buckwalter K C. Catastrophic reactions and other behaviors of Alzheimer's residents: Special unit compared with traditional units. Arch Psychiatr Nurs. 1993;7(5):292-9. [pmid: 8257198].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Swartz J R, Miller B L, Lesser I M, et al. Frontotemporal dementia: Treatment response to serotonin selective reuptake inhibitors. J Clin Psychiatry. 1997;58(5):212-6. [pmid: 9184615].
Status: Not included because dementia population not randomized to treatment
Tabet N, Mantle D, Walker Z, et al. Dietary and endogenous antioxidants in dementia. Int J Geriatr Psychiatry. 2001;16(6):639-41. [pmid: 11424174].
Status: Not included because not a full article
Tabet N, Mantle D, Walker Z, et al. Endogenous antioxidant activities in relation to concurrent vitamins A, C, and E intake in dementia. Int Psychogeriatr. 2002;14(1):7-15. [pmid: 12094909].
Status: Not included because does not meet criteria for treatment for dementia patients
Tabourne C E. The effects of a life review program on disorientation, social interaction and self-esteem of nursing home residents. Int J Aging Hum Dev. 1995;41(3):251-66. [pmid: 8666469].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Talwalker S. The cardinal features of cognitive and noncognitive dysfunction and the differential efficacy of tacrine in Alzheimer's disease patients. J Biopharm Stat. Nov. 1996;6(4):443-56. [pmid: 8969979].
Status: Not included because no extractable data relevant to review
Talwalker S, Overall J E, Srirama M K, et al. Cardinal features of cognitive dysfunction in Alzheimer's disease: A factor-analytic study of the Alzheimer's Disease Assessment Scale. J Geriatr Psychiatry Neurol. Jan. 1996;9(1):39-46. [pmid: 8679062].
Status: Not included because does not meet criteria for treatment for dementia patients
Talwalker S. Analysis of repeated measurements with dropouts among Alzheimer's disease patients using summary measures and meta-analysis. J Biopharm Stat. 1996;6(1):49-58. [pmid: 8969979].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tappen R M. The effect of skill training on functional abilities of nursing home residents with dementia. Res Nurs Health. Jun. 1994;17(3):159-65. [pmid: 8184127]. [pmcid: 1952655].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tappen R M, Roach K E, Applegate E B, et al. Effect of a combined walking and conversation intervention on functional mobility of nursing home residents with Alzheimer disease. Alzheimer Dis Assoc Disord. Oct. 2000;14(4):196-201. [pmid: 11186596]. [pmcid: 1950269].
Status: Not included because does not meet criteria for treatment for dementia patients
Tappen R M, Williams C L, Barry C, et al. Conversation intervention with Alzheimer's patients: Increasing the relevance of communication. Clin Gerontol. 2002;24(34):63-75. [pmid: 18270554]. [pmcid: 2239260].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Targum SD, Wieland S, Glasky MS, et al. Evaluation of AIT-082 in patients with mild to moderate senile dementia of the Alzheimer's type. J Eur Coll Neuropsychopharmacol 1999; (Suppl 5):S320.
Status : Not included because not a full article
Tariot P, Parys W, Kershaw P. The efficacy and tolerability of galantamine in Alzheimer's disease a 5 month placebo controlled study with slow dose escalation. Neurology. 2000;54(Suppl 3):A415. [pmid: 10881251].
Status: Not included because not a full article
Tariot P N, Sunderland T, Weingartner H, et al. Low- and high-dose naloxone in dementia of the Alzheimer type. Psychopharmacol Bull. 1985;21(3):680-2. [pmid: 3898183].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tariot P N, Sunderland T, Murphy D L, et al. Design and interpretation of opiate antagonist trials in dementia. Prog Neuropsychopharmacol Biol Psychiatry. 1986;10(35):611-26. [pmid: 3541054].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tariot P N, Sunderland T, Weingartner H, et al. Naloxone and Alzheimer's disease. Cognitive and behavioral effects of a range of doses. Arch Gen Psychiatry. Aug. 1986;43(8):727-32. [pmid: 3729666].
Status: Cross-over trial;
Tariot P N, Cohen R M, Sunderland T, et al. L-deprenyl in Alzheimer's disease. Preliminary evidence for behavioral change with monoamine oxidase B inhibition. Arch Gen Psychiatry. May. 1987;44(5):427-33. [pmid: 3579494].
Status: Not included because dementia population not randomized to treatment
Tariot P N, Sunderland T, Weingartner H, et al. Cognitive effects of L-deprenyl in Alzheimer's disease. Psychopharmacologia. 1987;91(4):489-95.
Status: Not included because dementia population not randomized to treatment
Tariot P N, Cohen R M, Welkowitz J A, et al. Multiple-dose arecoline infusions in Alzheimer's disease. Arch Gen Psychiatry. Oct. 1988;45(10):901-5. [pmid: 3048224].
Status: Cross-over trial;
Tariot P N, Sunderland T, Cohen R M, et al. Tranylcypromine compared with L-deprenyl in Alzheimer's disease. J Clin Psychopharmacol. Feb. 1988;8(1):23-7. [pmid: 3127432].
Status: Not included because dementia population not randomized to treatment
Tariot P N, Gross M, Sunderland T, et al. High-dose naloxone in older normal subjects: Implications for Alzheimer's disease. J Am Geriatr Soc. Aug. 1988;36(8):681-6. [pmid: 3042841].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tariot P N, Leibovici A, Erb R, et al. Carbamazepine therapy for agitation in dementia: Status report. Am J Geriatr Psychiatry. 1994;2(3):257-9.
Status: Not included because not a full article
Tariot P N, Erb R, Leibovici A, et al. Carbamazepine treatment of agitation in nursing home patients with dementia: A preliminary study. J Am Geriatr Soc. Nov. 1994;42(11):1160-6. [pmid: 7963202].
Status: Not included because dementia population not randomized to treatment
Tariot P N, Frederiksen K, Erb R, et al. Lack of carbamazepine toxicity in frail nursing home patients: A controlled study. J Am Geriatr Soc. Sep. 1995;43(9):1026-9. [pmid: 7657919].
Status: Not included because dementia population not randomized to treatment
Tariot P N, Goldstein B, Podgorski C A, et al. Short-term administration of selegiline for mild-to-moderate dementia of the Alzheimer's type. Am J Geriatr Psychiatry. 1998;6(2):145-54. [pmid: 9581210].
Status: Cross-over trial;
Tariot P N, Upadhyaya A, Sunderland T, et al. Physiologic and neuroendocrine responses to intravenous naloxone in subjects with Alzheimer's disease and age-matched controls. Biol Psychiatry. Aug 1. 1999;46(3):412-9. [pmid: 10435208].
Status: Not included because no extractable data relevant to review
Tariot P N, Salzman C, Yeung P P, et al. Long-Term use of quetiapine in elderly patients with psychotic disorders. Clin Ther. Sep. 2000;22(9):1068-84. [pmid: 11048905].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tekin S, Aykut B C, Tanridag T, et al. Antiglutamatergic therapy in Alzheimer's disease: effects of Lamotrigine. J Neural Transm Gen Sect. 1998;105(23):295-303.
Status: Cross-over trial;
Templeton L, Barker A, Wesnes K, et al. A double-blind, placebo-controlled single dose trial of intravenous flumazenil in Alzheimer's disease. Hum Psychopharmacol. 1999;14(4):239-45.
Status: Cross-over trial;
Tennant F S. Preliminary observations on naltrexone for treatment of Alzheimer's type dementia. J Am Geriatr Soc. 1987;35(4):369-70. [pmid: 3559033].
Status: Not included because not a full article
ter Haar H W. A comparison of chlormethiazole and haloperidol in the treatment of elderly patients with confusion of organic and psychogenic origin: A double-blind crossover study. Pharmatherapeutica. 1977;1(9):563-9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Terano T, Fujishiro S, Ban T, et al. Docosahexaenoic acid supplementation improves the moderately severe dementia from thrombotic cerebrovascular diseases. Lipids. 1999;34(Suppl):S345-S346. [pmid: 10419198].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Teri L, Reifler B V, Veith R C, et al. Imipramine in the treatment of depressed Alzheimer's patients: Impact on cognition. J Gerontol. Nov. 1991;46(6):P372-P377. [pmid: 1940094].
Status: Not included because Jadad Quality Scale score less than three
Teri L. Behavioral treatment of depression patients with dementia. Alzheimer Dis Assoc Disord. 1994;8(Suppl 3):66-74. [pmid: 7999348].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Teri L, Logsdon R G, Uomoto J, et al. Behavioral treatment of depression in dementia patients: A controlled clinical trial. J Gerontol B Psychol Sci Soc Sci. Jul. 1997;52(4):159-66. [pmid: 9224439].
Status: Not included because does not meet criteria for treatment for dementia patients
Teri L, Logsdon R G, Whall A L, et al. Treatment for agitation in dementia patients: A behavior management approach. Psychotherapy: Theory, Research, Practice, Training. 1998;35(4):354-443.
Status: Not included because dementia population not randomized to treatment
Tewfik G I, Jain V K, Harcup M, et al. Effectiveness of various tranquilisers in the management of senile restlessness. Gerontol Clin (Basel). 1970;12(6):351-9. [pmid: 4926614].
Status: Not included because dementia population not randomized to treatment
Thal LJ, Rosen W, Sharpless NS, et al. Choline chloride fails to improve cognition in Alzheimer's disease. Neurobiol Aging 1981; (3):205–8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Thal L J, Fuld P A, Masur D M, et al. Oral physostigmine and lecithin improve memory in Alzheimer disease. Ann Neurol. 1983;13(5):491-6. [pmid: 6347034].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Thal L J, Masur D M, Sharpless N S, et al. Acute and chronic effects of oral physostigmine and lecithin in Alzheimer's disease. Prog Neuropsychopharmacol Biol Psychiatry. 1986;10(35):627-36. [pmid: 3797688].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Thibault A. A double-blind evaluation of ‘Hydergine’ and placebo in the treatment of patients with organic brain syndrome and cerebral arteriosclerosis in a nursing home. Curr Med Res Opin. 1974;2(8):482-7. [pmid: 4217240].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Thienhaus O J, Wheeler B G, Simon S. A controlled double-blind study of high-dose dihydroergotoxine mesylate (Hydergine(R)) in mild dementia. J Am Geriatr Soc. 1987;35(3):219-23. [pmid: 3819261].
Status: Not included because Jadad Quality Scale score less than three
Thorpe L, Middleton J, Russell G, et al. Bright light therapy for demented nursing home patients with behavioural disturbance. Am J Alzheimers Dis. 2000;15(1):18-26.
Status: Not included because dementia population not randomized to treatment
Tian J, Du H, Yang H, et al. A clinical study on compound Da Huang (Radix et Rhizoma Rhei) preparations for improvement of senile persons' memory ability. J Tradit Chin Med. Sep. 1997;17(3):168-73. [pmid: 10437188].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tian J, Yin J, Liu H, et al. Jian Nao Ning for treatment of memory impairment in patients with mild to moderate multi-infarct dementia. J Tradit Chin Med. Dec. 2002;22(4):247-51. [pmid: 16579082].
Status: Not included because Jadad Quality Scale score less than three
Tignol J, Pujol-Domenech J, Chartres J P, et al. Double-blind study of the efficacy and safety of milnacipran and imipramine in elderly patients with major depressive episode. Acta Psychiatr Scand. Feb. 1998;97(2):157-65. [pmid: 9517912].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tinetti M E, Baker D, Gallo W T, et al. Evaluation of restorative care vs usual care for older adults receiving an acute episode of home care. JAMA. Apr 24. 2002;287(16):2098-105. [pmid: 11966384].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tollefson G D. Short-term effects of the calcium channel blocker nimodipine (Bay-e-9736) in the management of primary degenerative dementia. Biol Psychiatry. May 15. 1990;27(10):1133-42. [pmid: 2187540].
Status: Not included because Jadad Quality Scale score less than three
Toseland R W, Diehl M, Freeman K, et al. The impact of validation group therapy on nursing home residents with dementia. J Appl Gerontol. 1997;16(1):31-50.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Trappler B, Cohen C I. Use of SSRIs in “very old” depressed nursing home residents. Am J Geriatr Psychiatry. 1998;6(1):83-9. [pmid: 9469218].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Trappler B, Cohen C I. Using fluoxetine in “very old” depressed nursing home residents. Am J Geriatr Psychiatry. 1996;4(3):258-62.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tsai G E, Falk W E, Gunther J. A preliminary study of D-cycloserine treatment in Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 1998;10(2):224-6. [pmid: 9608414].
Status: Cross-over trial;
Tsai G E, Falk W E, Gunther J, et al. Improved cognition in Alzheimer's disease with short-term D-cycloserine treatment. Am J Psychiatry. Mar. 1999;156(3):467-9. [pmid: 10080566].
Status: Cross-over trial;
Tsiskaridze A, Vashadze A. Comparison study of Amiridine and Piracebral effects on cognition in patients with primary dementias. J Neural Transm Gen Sect. 1996;103:LII.
Status: Not included because not a full article
Tsuang M M, Lu L M, Stotsky B A, et al. Haloperidol versus thioridazine for hospitalized psychogeriatric patients: Double-blind study. J Am Geriatr Soc. Jul. 1971;19(7):593-600. [pmid: 4937658].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tune L, Brandt J, Frost J J, et al. Physostigmine in Alzheimer's disease: Effects on cognitive functioning, cerebral glucose metabolism analyzed by positron emission tomography and cerebral blood flow analyzed by single photon emission tomography. Acta Psychiatr Scand Suppl. 1991;366:61-5. [pmid: 1897377].
Status: Cross-over trial;
Tune L E, Steele C, Cooper T. Neuroleptic drugs in the management of behavioral symptoms of Alzheimer's disease. Psychiatr Clin North Am. Jun. 1991;14(2):353-73. [pmid: 1676507].
Status: Not included because dementia population not randomized to treatment
Turek I, Kurland A A, Ota K Y, et al. Effects of pipradrol hydrochloride on geriatric patients. J Am Geriatr Soc. Apr. 1969;17(4):408-13. [pmid: 4388256].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Tweedy J R, Garcia C A. Lecithin treatment of cognitively impaired Parkinson's patients. Eur J Clin Invest. Feb. 1982;12(1):87-90. [pmid: 6802657].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Udani JK. Extract of ginkgo biloba for treatment of dementia. Integr Med 1998; (1):43–4.
Status: Not included because not a full article
Ulmar G, Weickelt G. Anticholinergic treatment, cognition and the acetylcholine hypothesis of Alzheimer's disesase (AD). J Neural Transm Park Dis Dement Sect. 1989;1:144.
Status: Not included because not a full article
Underhill J A. Exercise for older people with dementia. Age Ageing. 1993;22(Suppl 3):35.
Status: Not included because not a full article
Uney J B, Jones G M, Rebeiro A, et al. The effect of long-term high dose lecithin on erythrocyte choline transport in Alzheimer patients. Biol Psychiatry. Mar 15. 1992;31(6):630-3. [pmid: 1581445].
Status: Not included because no extractable data relevant to review
van Asselt D Z, Pasman J W, van Lier H J, et al. Cobalamin supplementation improves cognitive and cerebral function in older, cobalamin-deficient persons. J Gerontol A Biol Sci Med Sci. Dec. 2001;56(12):M775-M779. [pmid: 11723153].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
van Diepen E, Baillon S F, Redman J, et al. A pilot study of the physiological and behavioural effects of snoezelen in dementia. Br J Occup Ther. 2002;65(2):61-6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
van Dongen M C, van Rossum E, Kessels A G, et al. The efficacy of ginkgo for elderly people with dementia and age-associated memory impairment: New results of a randomized clinical trial. J Am Geriatr Soc. Oct. 2000;48(10):1183-94. [pmid: 11037003].
Status: Not included because no extractable data relevant to review
van Duijn H, Wolters E C, Beckmann M K F. Desglycinamide arginine vasopressin (DGAVP) in Alzheimer's disease. Clin Neurol Neurosurg. 1987;2:21.
Status: Not included because not a full article
Van Dyck C H, McMahon T J, Rosen M I, et al. Sustained-release methylphenidate for cognitive impairment in HIV-1-infected drug abusers: A pilot study. J Neuropsychiatry Clin Neurosci. 1997;9(1):29-36. [pmid: 9017526].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Van Gool W A. Erratum: effect of hydroxychloroquine on progression of dementia in early alzheimer's disease: An 18-month randomised, double-blind, placebo-controlled study. Lancet. 2001;358(9288):1188. [pmid: 11513909].
Status: Not included because not a full article
Van Loveren-Huyben C M, Engelaar H F W J, Hermans M B M. Double-blind clinical and psychologic study of ergoloid mesylates (Hydergine®) in subjects with senile mental deterioration. J Am Geriatr Soc. 1984;32(8):584-8. [pmid: 6379022].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Van Reekum R, Clarke D, Conn D, et al. A randomized, placebo-controlled trial of the discontinuation of long-term antipsychotics in dementia. Int Psychogeriatr. 2002;14(2):197-210. [pmid: 12243210].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Van Someren E J, Scherder E J, Swaab D F. Transcutaneous electrical nerve stimulation (TENS) improves circadian rhythm disturbances in Alzheimer's disease. Alzheimer Dis Assoc Disord. Jun. 1998;12(2):114-8. [pmid: 9651141].
Status: Not included because no extractable data relevant to review
Vangtorp A, Simmelsgaard H, Mellegaard M. Experience with a new butyrophenone derivative (Buronil). Acta Psychiatr Scand Suppl. Jan 1. 1968;203:235-8. [pmid: 4881877].
Status: Not included because dementia population not randomized to treatment
Vecchi GP, Chiari G, Cipolli C, et al. Acetyl-l-carnitine treatment of mental impairment in the elderly: Evidence from a multicentre study. Arch Gerontol Geriatr 1991; (Suppl 2):159–68.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Vellas B, Inglis F, Potkin S, et al. Interim results from an international clinical trial with rivastigmine evaluating a 2-week titration rate in mild to severe Alzheimer's disease patients. Int J Geriatr Psychopharmacol 1998; (3):140–4.
Status: Not included because dementia population not randomized to treatment
Velligan D I, Newcomer J, Pultz J, et al. Does cognitive function improve with quetiapine in comparison to haloperidol?. Schizophr Res. Jan 15. 2002;53(3):239-48. [pmid: 11738537].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Vennerica A, Shanks M F, Staff R T, et al. Cerebral blood flow and cognitive responses to rivastigmine treatment in Alzheimer's disease. NeuroReport. 2002;13(1):83-7. [pmid: 11924899].
Status: Not included because dementia population not randomized to treatment
Versiani M, da Silva J A, Mundim F D. Loxapine versus thioridazine in the treatment of organic psychosis. J Int Med Res. 1980;8(1):22-30. [pmid: 7358200].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Vespa A, Gori G, Spazzafumo L. Evaluation of non-pharmacological intervention on antisocial behavior in patients suffering from Alzheimer's disease in a day care center. Arch Gerontol Geriatr. 2002;34(1):1-8. [pmid: 14764305].
Status: Not included because does not meet criteria for treatment for dementia patients
Vida S, Gauthier L, Gauthier S. Canadian collaborative study of tetrahydroaminoacridine (THA) and lecithin treatment of Alzheimer's disease: Effect on mood. Can J Psychiatry. 1989;34(3):165-70. [pmid: 2655861].
Status: Not included because dementia population not randomized to treatment
Villardita C, Parini J, Grioli S, et al. Clinical and neuropsychological study with oxiracetam versus placebo in patients with mild to moderate dementia. J Neural Transm Suppl. 1987;24:293-8. [pmid: 3479527].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Viukari M, Linnoila M. Effect of methyldopa on tardive dyskinesia in psychogeriatric patients. Curr Ther Res Clin Exp ; 18(3):417–24.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Viukari M, Salo H, Lamminsivu U, et al. Tolerance and serum levels of haloperidol during parenteral and oral haloperidol treatment in geriatric patients. Acta Psychiatr Scand. Apr. 1982;65(4):301-8. [pmid: 7080851].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Viukari M, Jaatinen P, Kylmamaa T. Flunitrazepam, nitrazepam and psychomotor skills in psychogeriatric patients. Curr Ther Res Clin Exp. 1983;33(5):828-34.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Vojtechovsky M, Sobotkova J, Wodniakova J. Secatoxin Spofa-super(R ) in the treatment of chronic organic psychosyndrome. Act Nerv Super (Praha). 1981;23(3):232-3.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Volicer L, Stelly M, Morris J, et al. Effects of dronabinol on anorexia and disturbed behavior in patients with Alzheimer's disease. Int J Geriatr Psychiatry. Sep. 1997;12(9):913-9. [pmid: 9309469].
Status: Cross-over trial;
Vroulis G A, Smith R C, Brinkman S, et al. The effects of lecithin on memory in patients with senile dementia of the Alzheimer's type. Psychopharmacol Bull. 1981;17(1):127-8. [pmid: 7232644].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wakelin J S. Fluvoxamine in the treatment of the older depressed patient; Double-blind, placebo-controlled data. Int Clin Psychopharmacol. Jul. 1986;1(3):221-30. [pmid: 3104446].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Walker C. Ergoloid mesylates vs. Alzheimer's: The latest round. Geriatrics 1990; 45(12):22, 24.
Status: Not included because not a full article
Walshe T M. The use of nimodipine in vascular dementia. J Neurol. 1985;Vol 232:74.
Status: Not included because not a full article
Walzl M, Walzl B, Lechner H. Results of a two-month follow-up after single heparin-induced extracorporeal LDL precipitation in vascular dementia. National Stroke Association 1994; (3):179–83.
Status : Not included because no extractable data relevant to review
Walzl M. A promising approach to the treatment of multi-infarct dementia. Neurobiol Aging. Mar. 2000;21(2):283-7. [pmid: 10867212].
Status: Not included because Jadad Quality Scale score less than three
Wang D, Huang X, Du S. A clinical trial on yu cong tang in treatment of senile dementia. J Tradit Chin Med. Mar. 1999;19(1):32-8. [pmid: 10453581].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wang X, Xie Z. A clinical study on the effect of reinforcement of kidney on senile brain functions. J Tradit Chin Med. Jun. 1997;17(2):92-5. [pmid: 10437173].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Ward C R, Los Kamp. The effects of participation in an intergenerational program on the behavior of residents with dementia. Activities Adaptation Aging. 1996;20(4):61-76.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wardle J, Rogers P, Judd P, et al. Randomized trial of the effects of cholesterol-lowering dietary treatment on psychological function. Am J Med. May. 2000;108(7):547-53. [pmid: 10806283].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Waring S C, Rocca W A, Petersen R C, et al. Postmenopausal estrogen replacement therapy and risk of AD: A population-based study. Neurology. 1999;52(5):965-70. [pmid: 10102413].
Status: Not included because dementia population not randomized to treatment
Warren P A, Dunn L, Jackson-Clark A. The Medicare Alzheimer's Project in Portland, Oregon. Pride Inst J Long Term Home Health Care. 1991;10(2):20-7. [pmid: 10170803].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Watkins P B, Zimmerman H J, Knapp M J, et al. Hepatotoxic effects of tacrine administration in patients with Alzheimer's disease. JAMA. Apr 6. 1994;271(13):992-8. [pmid: 8139084].
Status: Not included because dementia population not randomized to treatment
Watson NM, Wells TJ, Cox C. Rocking chair therapy for dementia patients: Its effect on psychosocial well-being and balance. Am J Alzheimers Dis 1998; (6):296–308.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Weiner M F, Tractenberg R E, Sano M, et al. No long-term effect of behavioral treatment on psychotropic drug use for agitation in Alzheimer's disease patients. J Geriatr Psychiatry Neurol. 2002;15(2):95-8. [pmid: 12083600].
Status: Not included because does not meet criteria for treatment for dementia patients
Weingartner H, Kaye W, Gold P, et al. Vasopressin treatment of cognitive dysfunction in progressive dementia. Life Sci. 1981;29(26):2721-6. [pmid: 7035781].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Weingartner H, Buchsbaum M S, Linnoila M. Zimelidine effects on memory impairments produced by ethanol. Life Sci. Nov 28. 1983;33(22):2159-63. [pmid: 6227781].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Weiser M, Rotmensch H H, Korczyn A D, et al. A pilot, randomized, open-label trial assessing safety and pharmakokinetic parameters of co-administration of rivastigmine with risperidone in dementia patients with behavioral disturbances. Int J Geriatr Psychiatry. Apr. 2002;17(4):343-6. [pmid: 11994888].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wells D, Dawson P, Sidani S, et al. The benefits of abilities-focused morning care for residents with dementia and their caregivers. Perspectives (Montclair). 2000;24(1):17.
Status: Not included because does not meet criteria for treatment for dementia patients
Wesensten N J, Balkin T J, Davis H Q, et al. Reversal of triazolam- and zolpidem-induced memory impairment by flumazenil. Psychopharmacologia. Sep. 1995;121(2):242-9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wesensten N J, Balkin T J, Belenky G L. Effects of daytime administration of zolpidem versus triazolam on memory. Eur J Clin Pharmacol. 1995;48(2):115-22. [pmid: 7589024].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wesnes K, Simmons D, Rook M, et al. A double-blind placebo-controlled trial of Tanakan in the treatment of idiopathic cognitive impairment in the elderly. Hum Psychopharmacol. 1987;2:159-69.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wesnes K A, McKeith I G, Ferrara R, et al. Effects of rivastigmine on cognitive function in dementia with lewy bodies: A randomised placebo-controlled international study using the cognitive drug research computerised assessment system. Dement Geriatr Cogn Disord. 2002;13(3):183-92. [pmid: 11893841].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Westreich G, Alter M, Lundgren S. Effect of cyclandelate on dementia. Stroke. Sep. 1975;6(5):535-8. [pmid: 1101457].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wettstein A. No effect from double-blind trial of physostigmine and lecithin in Alzheimer disease. Ann Neurol. 1983;13(2):210-2. [pmid: 6830183].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wettstein A, Spiegel R. Clinical trial with the cholinergic drug RS 86 in Alzheimer's disease (AD) and senile dementia of the Alzheimer type (SDAT). Psychopharmacologia. 1984;84(4):572-3.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
White C M, Dicks R S. Rivastigmine: An acetylcholinesterase inhibitor for patients with Alzheimer's disease. Hosp Formul. 1999;34(6):493-9.
Status: Not included because dementia population not randomized to treatment
White H K, Levin E D. Four-week nicotine skin patch treatment effects on cognitive performance in Alzheimer's disease. Psychopharmacologia. Apr. 1999;143(2):158-65.
Status: Cross-over trial;
White J C, Christensen J F, Singer C M. Methylphenidate as a treatment for depression in acquired immunodeficiency syndrome: an n-of-1 trial. J Clin Psychiatry. May. 1992;53(5):153-6. [pmid: 1592840].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
White L, Crovello J N, Rosenberg S N, et al. Evaluation of isobaric oxygenation for the aged with cognitive impairment: Pilot study. J Am Geriatr Soc. Feb. 1975;23(2):80-5. [pmid: 1095630].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Whitlatch CJ, Zarit SH, von Eye A. Efficacy of interventions with caregivers: A reanalysis. Gerontologist 1991 Feb; (1):9–14.
Status: Not included because does not meet criteria for treatment for dementia patients
Whitlatch CJ, Zarit SH, Goodwin PE, et al. Influence of the success of psychoeducational interventions on the course of family care. Clin Gerontol 1995; (1):17–30.
Status: Not included because does not meet criteria for treatment for dementia patients
Wiener P K, Kiosses D N, Klimstra S, et al. A short-term inpatient program for agitated demented nursing home residents. Int J Geriatr Psychiatry. 2001;16(9):866-72. [pmid: 11571766].
Status: Not included because dementia population not randomized to treatment
Wilcock G K, Scott M, Pearsall T, et al. Galanthamine and the treatment of Alzheimer's disease. Int J Geriatr Psychiatry. 1993;8(9):781-2.
Status: Not included because not a full article
Wilcock G K, Surmon D J, Scott M, et al. An evaluation of the efficacy and safety of tetrahydroaminoacridine (THA) without lecithin in the treatment of Alzheimer's disease. Age Ageing. 1993;22(5):316-24. [pmid: 8237620].
Status: Cross-over trial;
Wilkinson D, Srikumar S, Shaw K, et al. Drama and movement therapy in dementia: A pilot study. Arts in Psychotherapy 1998; (3):195–201.
Status: Not included because dementia population not randomized to treatment
Wilkinson D. Clinical experience with Donepezil (Aricept) in the UK. J Neural Transm Suppl. 1998;54:311-5. [pmid: 9850940].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wilkinson D G, Hock C, Farlow M, et al. Galantamine provides broad benefits in patients with ‘advanced moderate’ Alzheimer's disease (MMSE < or = 12) for up to six months. Int J Clin Pract. Sep. 2002;56(7):509-14. [pmid: 12296613].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wilkinson D G, Passmore A P, Bullock R, et al. A multinational, randomised, 12-week, comparative study of donepezil and rivastigmine in patients with mild to moderate Alzheimer's disease. Int J Clin Pract. Jul. 2002;56(6):441-6. [pmid: 12166542].
Status: Not included because Jadad Quality Scale score less than three
Williams R, Reeve W, Ivison D, et al. Use of environmental manipulation and modified informal reality orientation with institutionalized, confused elderly subjects: A replication. Age Ageing. 1987;16(5):315-8. [pmid: 3687572].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Willis S L, Schaie K W. Training the elderly on the ability factors of spatial orientation and inductive reasoning. Psychol Aging. Sep. 1986;1(3):239-47. [pmid: 3267404].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wilson AL, Langley LK, Monley J, et al. Nicotine patches in Alzheimer's disease: Pilot study on learning, memory, and safety. Pharmacol Biochem Behav ; 51(2–3):509–3.
Status: Not included because dementia population not randomized to treatment
Wilson R S, Martin E M. New intrathecal drugs in Alzheimer's disease and psychometric testing. Ann N Y Acad Sci. 1988;531:180-6. [pmid: 2898228].
Status: Not included because dementia population not randomized to treatment
Wincor M Z. Ginkgo biloba for dementia: A reasonable alternative?. J Am Pharm Assoc (Wash). May. 1999;39(3):415-6. [pmid: 10363472].
Status : Not included because dementia population not randomized to treatment
Winther K, Randlov C, Rein E, et al. Effects of Ginkgo biloba extract on cognitive function and blood pressure in elderly subjects. Curr Ther Res Clin Exp. 1998;59(12):881-8.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wishart L, Macerollo J, Loney P, et al. “Special steps”: An effective visiting/walking program for persons with cognitive impairment. Can J Nurs Res. Mar. 2000;31(4):57-71. [pmid: 11189671].
Status: Not included because does not meet criteria for treatment for dementia patients
Wolfgang S A. Olanzapine in whole, not half, tablets for psychosis from Alzheimer's dementia. Am J Health Syst Pharm. Nov 1. 1999;56(21):2245-6. [pmid: 10565707].
Status: Not included because not a full article
Wolters E C, Riekkinen P, Lowenthal A, et al. DGAVP (Org 5667) in early Alzheimer's disease patients: An international double-blind, placebo-controlled, multicenter trial. Neurology. Jul. 1990;40(7):1099-101. [pmid: 2192301].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wong Y T, Packer H. Penicillin versus penicillin-malaria in the treatment of dementia paralytica. Br J Vener Dis. 2000;25(1):39.
Status: Not included because not a full article
Woods B. Promoting well-being and independence for people with dementia. Int J Geriatr Psychiatry. 1999;14(2):97-109. [pmid: 10885861].
Status: Not included because dementia population not randomized to treatment
Wooltorton E. Risperidone (Risperdal): Increased rate of cerebrovascular events in dementia trials. CMAJ. Nov 26. 2002;167(11):1269-70. [pmid: 12451085]. [pmcid: 134141].
Status: Not included because not a full article
Wouters-Wesseling W, Wouters A E, Kleijer C N, et al. Study of the effect of a liquid nutrition supplement on the nutritional status of psycho-geriatric nursing home patients. Eur J Clin Nutr. Mar. 2002;56(3):245-51. [pmid: 11960300].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Wright L K, Litaker M, Laraia M T, et al. Continuum of care for Alzheimer's disease: A nurse education and counseling program. Issues Ment Health Nurs. Apr. 2001;22(3):231-52. [pmid: 11885210].
Status: Not included because does not meet criteria for treatment for dementia patients
Wroblewski T, Silvestre J, Castaner J. JTP-4819 Cognition enhancer, prolyl endopeptidase inhibitor. Drugs of the Future. 1998;23(4):384-9.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Xu H, Shao N, Cui D, et al. A clinical study of yi zhi capsules in prevention of vascular dementia. J Tradit Chin Med. Mar. 2000;20(1):10-3. [pmid: 10921161].
Status: Not included because Jadad Quality Scale score less than three
Yaffe K, Krueger K, Sarkar S, et al. Cognitive function in postmenopausal women treated with raloxifene. N Engl J Med. Apr 19. 2001;344(16):1207-13. [pmid: 11309635].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Yamamoto Y, Akiguchi I, Oiwa K, et al. Twenty-four-hour blood pressure changes in the course of lacunar disease. Cardiovasc Dis. 2001;11(2):100-6.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Yehuda S, Rabinovtz S, Carasso R L, et al. Essential fatty acids preparation (SR-3) improves Alzheimer's patients quality of life. Int J Neurosci. Nov. 1996;87(34):141-4. [pmid: 9003975].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Yesavage J A, Hollister L E, Burian E. Dihydroergotoxine: 6-mg versus 3-mg dosage in the treatment of senile dementia. Preliminary report. J Am Geriatr Soc. Feb. 1979;27(2):80-2. [pmid: 762369].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Yesavage J A, Westphal J, Rush L. Senile dementia: Combined pharmacologic and psychologic treatment. J Am Geriatr Soc. 1981;29(4):164-71. [pmid: 7204812].
Status: Not included because dementia population not randomized to treatment
Yesavage J A, Tinklenberg J R, Hollister L E, et al. Effect of nafronyl on lactate and pyruvate in the cerebrospinal fluid of patients with senile dementia. J Am Geriatr Soc. 1982;30(2):105-8. [pmid: 6173407].
Status: Not included because dementia population not randomized to treatment
Zanetti O, Frisoni G B, De Leo D, et al. Reality orientation therapy in Alzheimer disease: Useful or not? A controlled study. Alzheimer Dis Assoc Disord. 1995;9(3):132-8. [pmid: 8534411].
Status: Not included because dementia population not randomized to treatment
Zanetti O, Bianchetti A, Trabucchi M. Cost effectiveness of non pharmacological interventions in Alzheimer's disease. J Am Geriatr Soc. Nov. 1998;46(11):1481. [pmid: 9809777].
Status: Not included because not a full article
Zanetti O, Zanieri G, Di Giovanni G, et al. Effectiveness of procedural memory stimulation in mild Alzheimer's disease patients: A controlled study. Neuropsychol Rehab 2001; (3–4):263–4.
Status: Not included because dementia population not randomized to treatment
Zank S, Schacke C. Evaluation of geriatric day care units: effects on patients and caregivers. J Gerontol B Psychol Sci Soc Sci. Jul. 2002;57(4):348-57. [pmid: 12084785].
Status: Not included because does not meet criteria for treatment for dementia patients
Zappoli R, Arnetoli G, Paganini M, et al. Contingent negative variation and reaction time in patients with presenile idiopathic cognitive decline and presenile Alzheimer-type dementia. Preliminary report on long-term nicergoline treatment. Neuropsychobiology. 1987;18(3):149-54. [pmid: 3453431].
Status: Not included because Jadad Quality Scale score less than three
Zappoli R, Arnetoli G, Paganini M, et al. Topographic bit-mapped event-related neurocognitive potentials and clinical status in patients with primary presenile mental decline chronically treated with nicergoline. Curr Ther Res Clin Exp. 1991;49(6):1078-97.
Status: Not included because Jadad Quality Scale score less than three
Zarit S H, Zarit J M, Reever K E. Memory training for severe memory loss: Effects on senile dementia patients and their families. Gerontologist. 1982;22(4):373-7. [pmid: 7129168].
Status: Not included because does not meet criteria for treatment for dementia patients
Zemlan F P, Keys M, Richter R W, et al. Double-blind placebo-controlled study of velnacrine in Alzheimer's disease. Life Sci. 1996;58(21):1823-32. [pmid: 8637408].
Status: Not included because Jadad Quality Scale score less than three
Ziemba C, Foster G, Neufeld R, et al. Haloperidol holiday: Is it a beneficial vacation for some nursing home residents?. Clin Gerontol. 1997;17(3):15-24.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Zill P, Burger K, Behrens S, et al. Polymorphisms in the alpha-2 macroglobulin gene in psychogeriatric patients. Neurosci Lett. Nov 17. 2000;294(2):69-72. [pmid: 11058789].
Status: Not included because does not meet criteria for treatment for dementia patients
Zimmer J G, Eggert G M, Chiverton P. Individual versus team case management in optimizing community care for chronically ill patients with dementia. J Aging Health. 1990;2(3):357-72. [pmid: 10170566].
Status: Not included because does not meet criteria for treatment for dementia patients
Zisselman M H, Rovner B W, Shmuely Y, et al. A pet therapy intervention with geriatric psychiatry inpatients. Am J Occup Ther. Jan. 1996;50(1):47-51. [pmid: 8644836].
Status: Not included because no extractable data relevant to review
Zissis N P, Alevizos V, Dontas A S. Flunarizine, an inhibitor of Casup +sup 2-induced vascular constriction in geriatric patients. Curr Ther Res Clin Exp. 1991;29(3I):395-400.
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Zivadinov R, Rudick R A, De Masi R, et al. Effects of IV. methylprednisolone on brain atrophy in relapsing-remitting MS. Neurology. Oct 9. 2001;57(7):1239-47. [pmid: 11591843].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD
Zwerling I, Plutchik R, Hotz M, et al. Effects of a procaine preparation (Gerovital H3) in hospitalized geriatric patients: A double-blind study. J Am Geriatr Soc. Aug. 1975;23(8):355-9. [pmid: 1097490].
Status: Not included because dementia population not defined by DSM, NINCDS or ICD