# Appendix E. Outcome Measures

Acronym/ Abbreviation | Test name | Level of Impairment with higher score | Domain
ABID | Agitated Behavior Inventory for Dementia | High | Behavior
ABS | Adaptive Behavior Scale | Low | Function
ABSR | Aggressive Behavior Scale Rating | High | Behavior
ACES | Agitation Calmness Evaluation Scale | Low | Behavior
ACPT | Auditory Continuous Performance Test | | Specific cognitive test
ADAS- | Alzheimer's Disease Assessment Scale | High | Global assessment
ADAS-Cog | Cognitive Sections | | General cognitive function
ADAS-Noncog | Non-Cognitive, behavioral section | | Behavior
ADCS-CGIC | Alzheimer's Disease Cooperative Study - Clinical, Global Impression of Change | High | Global assessment
ADCS-ADL | Alzheimer's Disease Cooperative Study - Activities of Daily Living | Low | Function
ADFACS | Alzheimer's Disease Functional Assessment and Change Scale | High | Function
ADL | Activities of Daily Living | High | Function
ADL-C | Activities of Daily Living Checklist | | Function
ADL-PDS | Activities of Daily Living Progressive Deterioration Scale | | Function
ADS | Alzheimer's Deficit Scale | | Global assessment
AFBS | Aversive Feeding Behavior Scale | High | Behavior
AGS- E | Assessment of Global Symptomatology - Elderly | | Global assessment
AIMS | Abnormal Involuntary Movement Scale | High | Adverse Events, Dyskinesia
AMTS | Abbreviated Mental Test Score | | General cognitive function
--- | Barbizet Visuospatial | Low | Specific cognitive test
BARS, BAS | Barnes Akathisia Rating Scale | High | Adverse Events, Akathisia
BDI | Beck Depression Inventory | High | Behavior
BEHAVE - AD | Behavioral Pathology in Alzheimer's Disease Rating Scale | High | Behavior
BCRS | Brief Cognitive Rating Scale | High | General cognitive function
Bf-S | Self assessment according to Zerssen and Möller | | Global assessment
BGP | Behavioral Rating Scale for Geriatric Patients | | Global assessment
BI | Barthel Index | | Function
Blessed-D or BDRS | Blessed Dementia Rating Scale | High | Global assessment
BNT | Boston Naming Test | Low | Specific cognitive test
BPRS | Brief Psychiatric Rating Scale | High | Behavior
BRMS | Bech-Rafaelsen Mania Scale | | Behavior
BRSD | Behavioral Rating Scale for Dementia | | Behavior
BSR | Babcock Story Recall Test | Low | Specific cognitive test
BSRT | Buschke Selective Reminding Test | Low | Specific cognitive test
BSV | Buschke Sentence Verification | | Specific cognitive test
BLM | Buschke Letter Matching | | Specific cognitive test
BVR | Benton Visual Retention - Number Correct | | Specific cognitive test
| Benton Visual Retention - Errors
CamCOG | Cambridge Cognitive Schedule | | General cognitive function
CAPE | Clifton Assessment Procedures for the Elderly | Low | Global assessment
CASI | Cognitive Abilities Screening Instrument | Low | General cognitive function
CAUST | Canadian Utilization of Service Tracking questionnaire | --- | Health-care utilization and work productivity
--- | Category Fluency | Low | Specific cognitive test
CDR-NH | Clinical Dementia Rating - Nursing Home Version | High | Global assessment
CDR-SB | Clinical Dementia Rating-Sum of Boxes
CDT | Clock Drawing Test | | Specific cognitive test
CERAD-BRSD | Consortium to Establish a Registry for Alzheimer's Disease - Behavioral Rating Scale for Dementia | High | Behavior
CETM | --- | --- | General cognitive function
CCASSS | Computerized Cognitive Assessment System Speed Score / unweighted sum of reaction time | Low | Specific cognitive test
CATS | Caregivers' Activity Time Survey | | Caregiver burden
CGAE | Clinical Global Assessment and Efficacy | | Global assessment
CGI | Clinical Global Impression | High | Global assessment
CGIC | Clinical Global Impression of Change | High | Global assessment
CGRS | Clinician's Global Rating Scale | | Global assessment
CIBIC | Clinician's Interview Based Impression of Change | High | Global assessment
CIBIC+ | Clinician's Interview Based Impression of Change plus Caregiver | High | Global assessment
CDT | Clock Drawing Test | Low | Specific cognitive test
CMAI | Cohen Mansfield Agitation Inventory | High | Behavior
CNTB | Computerized Neuropsychological test battery | | Specific cognitive test
COWAT | Controlled Oral Word Association Test | Low | Specific cognitive test
CS or CSDD | Cornell Scale for Depression in Dementia | NR | Behavior
CSS | Caregiver Stress Scale | High | Caregiver burden
CSI | University of Iowa Caregiver Stress Inventory | | Caregiver burden
CVLT | California Verbal Learning Test | | Specific cognitive test
--- | Dependency Scale | High | Function
DAD | Disability Assessment for Dementia | Low | Function
DST | Digit Span Test | | Specific cognitive test
DBDS | Dementia Behavioral Disturbance Scale | | Global assessment
DMR | Dementia Questionnaire for Mentally Retarded Persons | High | Global assessment
DRS | Dementia Rating Scale | High | Global assessment
DSCS | Depressive Symptoms Collateral Source Cornell Scale | | Behavior
DSS | Depressive Signs Scale | High | Behavior
DSST | Digit Symbol Substitution Test | Low | Specific cognitive test
EIS | Efficacy Index Score | | Global assessment
EFRT | Emotional Face Recognition Test | Low | Specific cognitive test
ERP | Event-Related Potential (Amplitude) | Low | Response to stimuli
ESRS | Extrapyramidal Symptom Rating Scale | High | Adverse events/ Extrapyramidal symptoms
--- | Facial Behavior | NR | Behavior
--- | Finger Tapping Test | Low | Motor coordination
FAST | Functional Assessment Staging | High | Function
FCCA | Final Comprehensive Consensus Assessment | | Global assessment
FCMT | Figure Copy/ Memory Test | Low | Specific cognitive test
FIGT | Figure detection test | | Specific cognitive test
FIM | Functional Independence Measure | Low | Function
FOM | Fuld-Object Memory Evaluation | | Specific cognitive test
FRS | Functional Rating Scale test | Low | Global assessment
GAGS | Guide to Adult Assessment Battery for Physical pharmacology | | Specific cognitive test
GERRI | Geriatric Evaluation by Relative's Rating Instrument | High | Global assessment
GBS | Gottfries-Bråne-Steen | High | Global assessment Function
| Total Score | | General cognitive function
| Motor function subscale | | Behavior
| Intellectual subscale
| Emotional function subscale
| Symptoms subscale
GDS | Global Deterioration Scale | High | Global assessment
GIS | Global Impairment Scale (Adaptation of the CGIS) | | Global assessment
GPI-E | General Psychiatric Impression - Elderly | | Global assessment
GS | Gestalt Scale | High | Behavior
--- | Grooved Pegboard Test | Low | Specific cognitive test
HAM-A | Hamilton Anxiety Scale | High | Behavior
HAM-D | Hamilton Rating Scale for Depression | High | Behavior
HDRS
HDS | Hachinski Dementia Scale | | Global assessment
HDS-R | Hasegawa's Dementia Scale - Revised | | Behavior
HIS | Hachinski Ischemic Score | High | Global assessment
IADL | Instrumental Activities of Daily Living | High | Function
IDDD | Interview for Deterioration in Daily Living Activities in Dementia - complex task | High | Function
IPSC-E | Raskin's and Crook's Inventory of Psychic and Somatic Complaints for the Elderly | High | Behavior
IQCODE | Informant Questionnaire on Cognitive Decline in the Elderly | High | General cognitive function
--- | Letter Cancellation | Low | Specific cognitive test
--- | Letter Fluency | Low | Specific cognitive test
LMT | Logical Memory Test | Low | Specific cognitive test
LNNB | Luria-Nebraska Neuropsychological Battery | | Specific cognitive test
LPRS | London Psychogeriatric Rating Scale | | Behavior
MAACL-R | Multiple Affect Adjective Checklist-Revised | High | Behavior
MADRS | Montgomery-Asberg Depression Rating Scale | High | Behavior
MAE | Benton Multi-Lingual Aphasia Examination | | Specific cognitive test
MCPT | Modified Continuous Performance Test | | General cognitive function
MEMT | Memory test | | Specific cognitive test
MMSE | Mini-Mental Status Exam | Low | General cognitive function
MMMSE | Modified MMSE
SMMSE | Standardized MMSE
CMMSE | Cantonese MMSE
MNLT | Modified Names Learning test | | Specific Cognitive Test
MOSES | | | Behavior
MQ | Memory Quotient | | General cognitive function
NAA | Scale from the Nuremberg Gerontopsychological inventory for assessing activities of daily living | | Function
NAB | Nürnberg Alters-Beobachtungskala | | Behavior
NAI | Nuremburg Age Inventory | Low | Function
NCT | Number Correction Test | | Specific cognitive test
NDT | New Dot Test | Low | Specific cognitive test
NLT | Names Learning Test | | Specific cognitive test
NMIC | Newcastle Memory, Information, and Concentration Test | Low | Specific cognitive test
NMS | Nowlis Mood Scale | High | Behavior
NOSGER | Nurses Observation Scale for Geriatric Patients | High | Global assessment
NOSGER-IADL | Nurses Observation Scale for Geriatric Patients - Instrumental Activities of Daily Living subscale | High | Function
NOSIE | Nurses Observation Scale for Inpatients | High | Global assessment
NPI (NPI-4, NPI-10) | Neuropsychiatric Inventory Subscores 4,10 | Low | Behavior
NPI-NH | Neuropsychiatric Inventory - Nursing Home Version | High | Behavior
NSL | | | Behavior
NST | Number Symbol Test | | Specific cognitive test
OARS - ADL | Older Americans Resource Scale | High | Function
OAS | Overt Aggression Scale | | Behavior
OLT | Object Learning Test | | Specific cognitive test
PANSS-EC | Positive and Negative Syndrome Scale | | Behavior
PDRS | Psychogeriatric Dependency Rating Scale | | Global assessment
PDS | Progressive Deterioration Scale | High | Function
PGIR | Patient's Global Improvement Rating | | Global assessment
POMS | Profile of Mood States | | Behavior
PSMS | Physical Self-Maintenance Scale | High | Function
PSQI | Pittsburgh Sleep Quality Index | High | Function
QoL | Quality of Life | Low | Function
QoL-P | Patient-rated Quality of Life | Low | Function
QoL-C | Caregiver-rated Quality of Life
RAGS | Relative's Assessment of Global Symptomatology | | Global assessment
R-AVL | Rey Auditory-Verbal-Learning test | Low | Specific cognitive test
RGRS | Relatives' Global Rating Scale | | Global assessment
RM | Raven Matrices | | Specific cognitive test
RPM | Raven's Progressive Matrices
RMT | Randt Memory Test | Low | General cognitive function
RMBPC | Revised Memory and Behavior Problems Checklist | High | Behavior
RPT | Rivermead Profile Test | | Behavior
RVM | Rey's Verbal Memory | Low | General cognitive function
SAS | Simpson-Angus Scale | High | Adverse effects, Extra-pyramidal symptoms
SAS-G | Self Assessment - Geriatric | High | Global assessment
| Snodgrass Picture Naming Task | | Specific cognitive test
SBI | Spontaneous Behavior Interview | | Behavior
SCAG | Sandoz Clinical Assessment - Geriatric | High | Global assessment
SCB | Screen for Caregiver Burden | NR | Caregiver burden
SCWIT | Stroop Color Word Interference Test | | Specific cognitive test
| Set Test | | Specific cognitive test
SF-36 | Medical Outcomes Study Short-Form 36-Item Health Survey | Low | Function
SGRS | Stockton Geriatric Rating Scale | High | Global assessment
SHGRT | Stuard Hospital Geriatric Rating Scale | | Behavior
SKT | Syndrome Kurztest; Syndrome Short Test | High | Specific cognitive test
SIB | Severe Impairment Battery | Low | General cognitive function
SIP | Sickness Impact Profile | | Function
SMQ | Squire's Memory Questionnaire | | General cognitive function
SMST | Sternberg Memory Scanning | Low | General cognitive function
SRT-DR | Selective Reminding Procedure - delayed recall | | Specific cognitive test
SRT | Kellner and Sheffield Rating Test | | Behavior
SRT-Anxiety
SRT-Depression
SWFT | Semantic Word Fluency Test | --- | Specific cognitive test
| Time to functional decline | | Function
TK | Token Test | Low | Specific cognitive test
TP | Toulouse Piéron | Low | General cognitive function
TPAT | Toulouse Piéron Attention Test
TMT | Trail Making Test | | Specific cognitive test
TSI | Test for Severe Impairment | | Global assessment
UPDRS | Unified Parkinson's Disease Rating Scale | High | Adverse effects, Extrapyramidal symptoms
VHB | Video-recorder home-behavioral assessment | | Behavior
VRGI | Video Rating of Global Impression | | Global assessment
WAIS | Wechsler Adult Intelligence Scale (Verbal and Memory Performance scales) | Low | General cognitive function
WMS (MQ) | Memory Learning Restauration | | Specific cognitive test
WMS-RR | Wechsley Memory Scale - Russel Revised | | Specific cognitive test
ZVT | Zahlen-Verbindungs Test - | High | Specific cognitive test
ZVTG | Trail Making Test