# Appendix D Peer review

[underlined: Peer Reviewers for the Treatment of Dementia Report]

1. Dr. Sandra Black, Sunnybrook Health Sciences Centre, Toronto, Ontario, Canada
2. Dr. Malaz Boustani, Indiana University School of Medicine, Indianapolis, Indiana, USA
3. Dr. Charles Cefalu (American Geriatrics Assoc)
4. Dr. Larry Chambers, University of Ottawa Institute for Health of the Elderly, Ottawa, Ontario, Canada
5. Dr. Tommy Cross (ACP/ASIM representative), Colorado Springs, Colorado, USA
6. Dr. Rachelle Doody, Baylor College of Medicine, Houston, Texas, USA
7. Dr. John Feightner, University of Western Ontario, Canadian Task Force for Periodic Health, London, Ontario, Canada
8. Dr. Serge Gauthier, Alzheimer's Disease Research Unit, McGill Centre for Studies in Aging, Verdun Quebec, Canada
9. Lisa Gwyther (American Geriatrics Assoc), MSW Duke University, Durham, North Carolina
10. Dr. David Hogan, Division of Geriatric Medicine, Calgary, Alberta, Canada
11. Dr. Rodney Hornbake, (ACP/ASIM representative), Hadlyme, Connecticut, USA
12. Dr. Roy Jones, St. Martin's Hospital, Bath, UK
13. Dr. David Royall, UTHSCSA, San Antonio Texas, USA
14. Dr. Lon Schneider (Cochrane), Keck School of Medicine, University of Southern California, Los Angeles, California
15. Dr. Jennie Ward-Robinson, US National Alzheimer's Association, Chicago, Illinois, USA
16. Dr. Peter Whitehouse (Cochrane), Case Western Reserve University, Cleveland, Ohio

Others reviewing the report:

Dr. Vincenza Snow - partner, ACSIM

Dr. Martin Kabongo - American Association of Family Practitioners

Dr. Marcel Morrison-Bogorad - Representative from the Institute for Aging (NIH)

David Atkins, Kate Rickard and AHRQ staff

Mary Grady - technical review (AHRQ)

Criticism Editor:

Dr. Patricia Huston, Ottawa, ON

[underlined: Structured format for collecting referee comments]

Thank you for agreeing to review this report. This is still in the draft stages and a thorough copy edit will take place before the publication of the final report. Please do not feel you need to spend your time correcting spelling and punctuation - we are relying on your expertise to address the questions below and provide insight that will assist us in improving the content and format of the report.

Problem Formulation

- Are review questions well formulated with specified key components?
- Are comparison groups clearly stated?
- Were major changes in review questions avoided during the review process?

Study Identification

- Is there a thorough search for relevant data using appropriate resources?
- Are there unbiased explicit searching strategies that are appropriately matched to the question?

Study Selection

- Are appropriate inclusion and exclusion criteria used to select articles?
- Are selection criteria applied in a manner that limits bias?
- Are efforts made to identified unpublished data, if this is appropriate?
- Are major changes in selection criteria avoided during the review process?
- Are reasons for excluding studies from the report stated?

Appraisal of Studies

- Is the validity of individual studies addressed in a reliable manner?
- Are important parameters (e.g., setting, study population, study design) that could affect study results systematically addressed?

Data Collection

- Is there a minimal amount of missing information regarding outcomes and other variables considered key to interpretation of results?
- Are efforts made to reduce bias in the data collection process?

Data Synthesis

- Are important parameters, such as study designs, considered in the synthesis?
- Are reasonable decisions made concerning whether and how to combine the data?
- Are results sensitive to changes in the way the analysis was done?
- Is precision of results reported?

Discussion

- Are limitations and inconsistencies of studies stated?
- Are limitations of the review process stated?
- Are review finding integrated within the context of relevant indirect evidence?
- Are implications for research discussed
- Are implications for practice discussed?

Conclusions

- Are conclusions supported by the data reviewed?
- Are plausible competing explanations of observed effects addressed?
- Is evidence appropriately interpreted as inconclusive (no evidence of effect) or as showing a particular strategy did not work (evidence of no effect)?
- Are important considerations for decision makers identified, including values and contextual factors that might influence decisions?
- Is a summary of pertinent findings provided?