# Appendix C Evidence tables

Evidence Table 1. Key Characteristics: Carnitine (ALCAR)

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports strained
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Livingston 1991 | IF | 5 | Placebo | NINCDS | AD | Probable or Possible | 71 | 40 | 72.8y (65–80y) | NR | 24w | ADL | No
| IS | | Acetyl-L-Carnitine | | | | | | 18% M | | | CGI
| | | | | | | | | | | | Drawing
| | | | | | | | | | | | KOLT
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | MNLT
| | | | | | | | | | | | NART
| | | | | | | | | | | | PADL
| | | | | | | | | | | | Recognition memory for words and pictures
| | | | | | | | | | | | Word Fluency
Rai 1990 | IS | 7 | Placebo | NINCDS | AD | Mild-Mod | 36 | 20 | 79y (> 60y) | 2 g/d (1 g bid) | 24w | ADL | No
| | | Acetyl-L-Carnitine | | | | | | 38%M | | | CGA
| | | | | | | | | | | | Computerized psychometric tests
| | | | | | | | | | | | DCT
| | | | | | | | | | | | Digit Span
| | | | | | | | | | | | GDS
| | | | | | | | | | | | GMS-A
| | | | | | | | | | | | HMII
| | | | | | | | | | | | NART
| | | | | | | | | | | | NLT
| | | | | | | | | | | | OLT
| | | | | | | | | | | | P300
| | | | | | | | | | | | Reisberg GDS
| | | | | | | | | | | | Word Fluency Test
Sano 1992 | PI | 6 | Placebo | NINCDS | AD | Mild-Mod | 30 | 27 | Mean NR (60–80y) | 12 w 2500 mg/d and 12 w 3000 mg/d | 24w | Benton Visual Retention test | MMSE
| IS | | Acetyl-L-Carnitine | | | | | | %M NR Community | | | Cancellations
| | | | | | | | | | | | CGI
| | | | | | | | | | | | Digit span
| | | | | | | | | | | | mMMSE
| | | | | | | | | | | | SIP
| | | | | | | | | | | | SMQ
| | | | | | | | | | | | BSRT
| | | | | | | | | | | | Verbal Fluency
| | | | | | | | | | | | Wechsler memory scale
Spagnoli 1991 | PI | 7 | Placebo | DSM III | AD | Mild-Mod | 130 | 108 | 75.2y (>40y) | 2 g/d | 1y | Blessed Dementia Scale | No
| | | Acetyl-L-Carnitine | | | | | | 29%M | | | Blessed Information Memory
| | | | | | | | | 60.8% Community | | | Concentration test
| | | | | | | | | 39.3% Institution | | | Block-tapping test
| | | | | | | | | | | | Finger agnosia test
| | | | | | | | | | | | Geometrical constructive apraxia test
| | | | | | | | | | | | Ideomotor and buccofacial apraxia
| | | | | | | | | | | | Prose memory test
| | | | | | | | | | | | Raven's matrices
| | | | | | | | | | | | SBI
| | | | | | | | | | | | Supra-span verbal learning
| | | | | | | | | | | | Token test
| | | | | | | | | | | | Verbal judgement and mental calculation test
| | | | | | | | | | | | Visual search on matrices of digits
| | | | | | | | | | | | Word association test
Thal 2000a | IF | 6 | Placebo | NINCDS | AD | Probable | 227 | 167 | 59y (46–65y) | 1 g tid | 1y | ADAS-Cog | No
| | | Acetyl-L-Carnitine | | | | | | 53% M | | | ADAS-Noncog
| | | | | | | | | 90% White | | | ADL
| | | | | | | | | | | | CDR
| | | | | | | | | | | | CIBIC
| | | | | | | | | | | | MMSE
Thal 1996a | IF | 6 | Placebo | NINCDS | AD | Mild-Mod | 431 | 355 | 72y (NR) | 1 g tid | 12m | ADAS -Noncog | Age
Auxiliary Brooks 1998 | | | Acetyl-L-Carnitine | DSM-III-R | | | | | 44%M | | | ADAS-Cog
| | | | | | | | | 93.5% White | | | ADL
| | | | | | | | | | | | CDR-S
| | | | | | | | | | | | CGI-C
| | | | | | | | | | | | CGI-S
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE

Evidence Table 2. Study results: Carnitine (ALCAR)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: 12w | | Final: 24w
Livingston, 1991 | OC Analysis
| 1] Placebo | ADL | 1] 34.9 | | 1] 31.5 | 3] < 0.01 | 1] 32.3 | 3] < 0.05
| 2] ALCAR (dose not specified) | | 2] 33.0 | | 2] 33.6 | 4] NS | 2] 34.5 | 4] NS
| 3] Placebo Change from baseline | | | | | 5] NS | | 5] NS
| 4] ALCAR change from baseline | Clock Drawing | 1] 5.66 | | 1] 5.63 | 3] NS | 1] 5.22 | 3] NS
| 5] Difference between placebo and ALCAR in change from baseline | | 2] 7.68 | | 2] 8.14 | 4] NS | 2] 8.74 | 4] NS
| | | | | | 5] NS | | 5] NS
| | Word fluency | 1] 16.6 | | 1] 14.7 | 3] <0.05 | 1] 15.3 | 3] NS
| | | 2] 18.2 | | 2] 15.7 | 4] <0.05 | 2] 17.4 | 4] NS
| | | | | | 5] NS | | 5] NS
| | MMSE | 1] 16.1 | | 1] 15.3 | 3] NS | 1] 15.1 | 3] NS
| | | 2] 15.8 | | 2] 16.0 | 4] NS | 2] 17.6 | 4] NS
| | | | | | 5] NS | | 5] NS
| | MNLT | 1] 20.9 | | 1] 21.1 | 3] NS | 1] 21.9 | 3] NS
| | | 2] 18.4 | | 2] 21.6 | 4] NS | 2] 22.2 | 4] NS
| | | | | | 5] NS | | 5] NS
| | Object Learning | 1] 12.3 | | 1] 11.0 | 3] NS | 1] 13.1 | 3] NS
| | | 2] 12.1 | | 2] 14.6 | 4] NS | 2] 14.1 | 4] NS
| | | | | | 5] NS | | 5] NS
| | RM - pictures | 1] 14.5 | | 1] 14.6 | 3] NS | 1] 15.2 | 3] NS
| | | 2] 13.5 | | 2] 14.2 | 4] NS | 2] 15.1 | 4] NS
| | | | | | 5] NS | | 5] NS
| | RM - words | 1] 15.2 | | 1] 14.2 | 3] <0.05 | 1] 13.8 | 3] <0.01
| | | 2] 13.3 | | 2] 14.8 | 4] NS | 2] 15.5 | 4] NS
| | | | | | 5] NS | | 5] < 0.01

Evidence Table 3. Study results: Carnitine (ALCAR)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point:(specify)12w | | Final:(specify)24w
Rai,1990 | OCPopulation
| 1] Placebo change from baseline | GDS | | | 1] 1.00 | 1] NS | 1] 2.00 | 1] NS
| 2] ALCAR 1g bid change from baseline | | | | 2] 0.25 | 2] NS | 2] 1.00 | 2] NS
| 3] Placebo vs. ALCAR difference from baseline | | | | | 3] NS | | 3] NS
| | NLT | | | 1] -3.38 | 1] NS | 1] -1.31 | 1] NS
| | | | | 2] 1.44 | 2] NS | 2] 0.57 | 2] NS
| | | | | | 3] NS | | 3] NS
| | Word Fluency Test | | | 1] -1.00 | 1] NS | 1] -0.15 | 1] NS
| | | | | 2] -2.56 | 2] NS | 2] 0.57 | 2] NS
| | | | | | 3] NS | | 3] NS
| | ADL | | | 1] 0.31 | 1] NS | 1] 0.15 | 1] NS
| | | | | 2] 0.22 | 2] NS | 2] 0 | 2] NS
| | | | | | 3] NS | | 3] NS
| | Digit Span | | | 1] 0 | 1] NS | 1] -0.08 | 1] NS
| | | | | 2] 0.14 | 2] NS | 2] 0 | 2] NS
| | | | | | 3] NS | | 3] NS
| | Kendrick Battery | | | 1] -4.25 | 1] NS | 1] -0.42 | 1] NS
| | Tests - Digit | | | 2] 0.14 | 2] NS | 2] -1.00 | 2] NS
| | Copying Test | | | | 3] NS | | 3] NS
| | Kendrick Battery | | | 1] 2.69 | 1] NS | 1] 1.77 | 1] NS
| | Tests - Object | | | 2] 1.00 | 2] NS | 2] -0.86 | 2] NS
| | Learning Test | | | | 3] NS | | 3] NS
| | Clinical Global Improvement | | | | | 1] 3.92 | 3] NS
| | | | | | | 2] 3.6
| | Efficacy Index | | | | | 1] 12 | 3] NS
| | | | | | | 02] 10.29

Evidence Table 4. Study results: Carnitine (ALCAR)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Sano 1992 | OC Analysis
| 1] Placebo | SRT total recall | 1] 21.4 (7.6) | | | | 1] 16.0 (10.0) | 3] NS
| 2] ALCAR 2500mg/d for 3m 3000 mg/d for 6m | | 2] 22.1 (7.3) | | | | 2] 21.2 (8.8)
| 3] Difference between Placebo and ALCAR in change from baseline | WMS | 1] 2.9 (1.6) | | | | 1] 2.2 (2.1) | 3] NS
| | | 2] 2.8 (1.8) | | | | 2] 3.0 (1.6)
| | WMS Paired Associates | 1] 6.3 (1.4) | | | | 1] 6.4 (3.9) | 3] NS
| | | 2] 7.0 (2.0) | | | | 2] 6.5 (1.9)
| | mMMSE | 1] 35.3 (7.2) | | | | 1] 32.4 (9.3) | 3] NS
| | | 2] 35.5 (5.4) | | | | 2] 34.3 (6.3)
| | SIP | 1] 27.3 (15.6) | | | | 1] 24.17 (16.5) | 3] NS
| | | 2] 25.5 (12.5) | | | | 2] 22.9 (12.5)
| | SMQ | 1] 38.7 (8.5) | | | | 1] 45.1 (10.8) | 3] NS
| | | 4] 38.5 (8.3) | | | | 2] 45.0 (8.8)
| | Other Neuropsychological Tests | | | | | | 3] NS

Evidence Table 5. Study results: Carnitine (ALCAR)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point:(specify) | | Final: 12m
Spagnoli, 1991 | ITT Population
| 1] Placebo | BDS | 1] 9.5(3.8) | 3] 0.84 | | | 1] 13.0(4.6) | 3] 0.03
| 2] ALCAR 250mg/bid | | 2] 9.4(4.3) | | | | 2] 11.0(5.3) | 4] 0.01
| 3] Difference between placebo and ALCAR | Blessed Information Memory | 1] 17.1(4.4) | 3] 0.10 | | | 1] 14.5(6.7) | 3] 0.07
| 4] Difference between placebo and ALCAR in change from baseline | | 2] 18.4(4.8) | | | | 2] 16.8(7.7) | 4] 0.33
| | RPM | 1] 5.6(3.9) | 3] 0.32 | | | 1] 6.3(4.7) | 3] 0.01
| | | 2] 6.7(4.8) | | | | 2] 3.8(3.7) | 4] 0.03
| | Supra-Span Verbal Learning | 1] 2.1(2.2) | 3] 0.76 | | | 1] 2.7(3.4) | 3] 0.12
| | | 2] 2.4(2.7) | | | | 2] 1.5(2.3) | 4] 0.24
| | Block Tapping Task | 1] 3.3(4.0) | 3] 0.04 | | | 1] 2.8(3.4) | 3] 0.03
| | | 2] 3.7(2.7) | | | | 2] 4.0(3.8) | 4] 0.47
| | Token Test | 1] 21.9(6.9) | 3] 0.04 | | | 1] 17.4(9.9) | 3] 0.02
| | | 2] 24.5(7.1) | | | | 2] 21.8(9.5) | 4] 0.41
| | SBI* | 1] 33.2(8.5) | 3] 0.03 | | | 1] 41.7(13.7) | 3] 0.02
| | | 2] 29.7(9.5) | | | | 2] 35.8(13.6) | 4] 0.12

Evidence Table 6. Study results: Carnitine (ALCAR)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | | | FINAL 12m
Thal, 2000a | MITT Analysis
| 1] Placebo | [underlined: ADAS-cog] | 1] 22.9 (1.1) | | | | 1] 30.4 (1.6) | 3] 0.58
| 2] ALCAR 1g tid | | 2] 23.1 (1.2) | | | | 2] 30.0 (1.7)
| 3] Difference between ALCAR and placebo in change from baseline | [underlined: CDR] | 1] 5.1 (0.2) | | | | 1] 6.8 (0.4) | 3] 0.69
| | | 2] 5.3 (0.3) | | | | 2] 7.1 (0.4)
| | ADAS-Non cog | 1] 3.2 (0.3) | | | | 1] 5.3 (0.6) | 3] 0.89
| | | 2] 3.3 (0.3) | | | | 2] 5.2 (0.5)
| | MMSE | 1] 20.6 (0.4) | | | | 1] 17.3 (0.7) | 3] 0.10
| | | 2] 20.1 (0.5) | | | | 2] 17.5 (0.8)
| | ADL | 1] 7.1 (0.2) | | | | 1] 8.3 (0.3) | 3] 0.43
| | | 2] 7.1 (0.2) | | | | 2] 8.6 (0.4)

→ Modified ITT sample

Evidence Table 7. Study results: Carnitine (ALCAR)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12m
Thal, 1996a | ITT Population
Brooks, 1998 | 1] Placebo | [underlined: ADAS-cog] | 1] 26.0 (10.5) | | | | 1] 33.0 (14.3) | 3] 0.434
| 2] ALCAR 3g/d | | 2] 25.4 (9.8) | | | | 2] 32.8 (14.8) | 8] 0.11
| 3] ALCAR vs. Placebo | | 4] 25.8 (10.5) | | | | 4] 35.1 (14.2) | 9] 0.085
| 4] Placebo < 65 years | | 5] 26.0 (10.5) | | | | 5] 32.4 (14.4)
| 5] Placebo < 65 years | | 6] 27.8 (10.5) | | | | 6] 34.7 (16.2)
| 6] ALCAR < 65 years | | 7] 24.9 (9.5) | | | | 7] 32.3 (14.5)
| 7] ALCAR > 65 years | [underlined: CDR] | 1] 6.6 (2.7) | | | | 1] 8.8 (3.7) | 3] 0.562
| 8] Difference between Placebo and ALCAR change from baseline for subgroup <65yrs | | 2] 6.3 (2.4) | | | | 2] 8.7 (3.8) | 8] 0.056
| 9] Difference between Placebo and ALCAR change from baseline for subgroup >65yrs. | | 4] 6.2 (2.6) | | | | 4] 9.5 (4.3) | 9] 0.047
| | | 5] 6.7 (2.7) | | | | 5] 8.0 (3.7)
| | | 6] 6.1 (2.3) | | | | 6] 8.5 (3.4)
| | | 7] 6.4 (2.4) | | | | 7] 8.9 (3.8)
| | MMSE | 1] 9.6 (3.9) | | | | 1] 15.8 (6.2) | 3] 0.818
| | | 2] 19.8 (3.9) | | | | 2] 16.5 (6.4)
| | ADAS-non cog | 1] 4.7 (4.2) | | | | 1] 7.6 (6.3) | 3] 0.466
| | | 2] 4.4 (3.8) | | | | 2] 7.0 (6.3)
| | ADL | 1] 7.6 (2.1) | | | | 1] 10.1 (4.1) | 3] 0.733
| | | 2] 7.4 (2.1) | | | | 2] 9.9 (4.2)
| | IADL | 1] 16.8 (6.0) | | | | 1] 20.3 (6.6) | 3] 0.62
| | | 2] 16.8(5.7) | | | | 2] 20.8(6.0)
| | CGI-S | 1] 3.6(0.7) | | | | 1] 4.1(0.9) | 3] 0.172
| | | 2] 3.5(0.6) | | | | 2] 3.9(0.9)
| | CGI-C | | | | | 1] 4.8(0.9) | 3] 0.358
| | | | | | | 2] 4.9(0.9)

Evidence Table 8. Adverse Events: Carnitine (ALCAR)

Adverse events (AE) identified in included studies | Livingston, 1991 | Rai, 1989 | Sano, 1992 | Spagnoli, 1991 | Thal, 1996a | Thal, 2000a
Withdrawn (%) due to AE | T: 0 | T: 44 | T: 0 | T: 0 | T: 3 | T: 1
| C: 0 | C: 22 | C: 0 | C: 0 | C: 1 | C: 3
AE Checklist (Max 5) | 3 | 3 | 3 | 3 | 1 | 1
None Reported
Balance
Accidental Injury
Dizziness | | X
Falls
Behavioral | | X
Agitation | | X | | NS
Cardiovascular
Arrhythmia
Hypotension
Hypertension
Extrapyramidal | | | | | | NS
Tremor
Gastrointestinal | X | | | | | NS
Abdominal pain | | | X
Constipation
Diarrhea | X
Dyspepsia
Nausea, vomiting | X | X | X
Metabolic/nutritional | | | | | NS
Eating disorder
Weight Change
Neurological
Asthenia
Psychiatric | | X
Anxiety
Confusion, delirium | | X
Depression | | X
Respiratory | | | | | | NS
Cough, cold, infection
Rhinitis
Other | | | | | S
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia
Headache
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder | X | | | | NS
Sleep disorder
Urinary disorder | | | | | | NS

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 9. Key characteristics: Donepezil (DPZ)

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Burns 1999 | IF | 6 | Placebo | DSM-III-R | PDD | Mild-Mod | 818 | 631 | 72y (50–93y) | 5 mg/d for 7 d, then 10 mg/d | 24w+ 6w placebo washout period | ADAS-Cog | No
| | | Donepezil | NINCDS | | | | | 42%M | | | CDR-SB
| | | | | | | | | 99% white | | | CIBIC+
| | | | | | | | | | | | IDDD
| | | | | | | | | | | | QOL
Feldman 2001 | IF | 8 | Placebo | NINCDS | AD | Moderate-Severe | 290 | 247 | 73.7y (51–92y) | 10 mg/d | 24w | CAUST | MMSE
Auxiliary: | | | Donepezil | | | | | | 39%M Community | | | CIBIC | Psychoactive drug use
Gauthier 2002 | | | | | | | | | | | | CIBIC+
| | | | | | | | | | | | CSS
| | | | | | | | | | | | DAD
| | | | | | | | | | | | FRS
| | | | | | | | | | | | IADL+
| | | | | | | | | | | | sMMSE
| | | | | | | | | | | | NPI
| | | | | | | | | | | | PSMS+
| | | | | | | | | | | | SF 36
| | | | | | | | | | | | SIB
Mohs 2001 | IF | 5 | Placebo | NINCDS | AD | Probable | 431 | 111 | 75.4y (50–93y) | 10 mg/d | 54w | ADL | No
| | | Donepezil | DSM IV | | | | | 37%M | | | ADFACS
| | | | | | | | | 92.15% white | | | CDR
| | | | | | | | | 2.75% black | | | IADL
| | | | | | | | | 5.1% other | | | IDDD
| | | | | | | | | | | | MMSE
Prasher 2002 | IF | 6 | Placebo | ICD-10 | AD | Mild-Mod | 30 | 27 | 54y (43–66y) | 10 mg/d | 24w | ABS | Down Syndrome only
| | | Donepezil (DPZ) | | | | | | 50%M | | | DMR
| | | | | | | | | Community (99%) | | | NPI
| | | | | | | | | Institution (1%) | | | SIB
Pratt 2002 | IF | 5 | Placebo | NINCDS | VaD | Possible or Probable | 893 | 707 | 74.0 (0.3)y range 41–95 | 5 mg/d for 4w then either 5 or 10 mg/d for 20w | 24w | ADAS-Cog | No
| | | Donepezil | AIREN | | | | | Community | | | CIBIC+
| | | | | | | | | | | | MMSE
Rogers 1996 | IF | 6 | Placebo | DSM-III-R | AD | Mild-Modly Sev | 161 | 141 | 71.8y (54–85y) | 5 mg/d | 12w | ADAS-Cog | No
Auxiliary: | | | Donepezil | NINCDS | | | | | 40%M | | + 2w placebo washout period | ADL
Rogers 2000 | | | | | | | | | 99% white | | | CDR-SB
Neumann 1999 | | | | | | | | | | | | CGIC
Rogers 1998 | | | | | | | | | | | | MMSE
| | | | | | | | | | | | QoL
Rogers 1998a | IF | 6 | Placebo | NINCDS | AD | Mild-Modly severe | 468 | 412 | 73.7y (50–94y) | 5 mg/d for 7 d then 10 mg/d | 15w | ADAS-Cog | No
Auxiliary: | | | Donepezil | DSM-III-R | | | | | 36%M | | | CIBIC+
Doody 2001 | | | | | | | | | 96% white | | | MMSE
Steele 1999 | | | | | | | | | | | | CDR-SB
| | | | | | | | | | | | QoL
Rogers 1998b | IF | 6 | Placebo | NINCDS | AD | Mild-Mod | 473 | 367 | 73.6 (51–94y) | 10 mg/d | 24w | ADAS-Cog | No
Auxiliary: | | | Donepezil | DSM-III-R | | | | | 38%M | | | CDR-SB
Doody 2001 | | | | | | | | | 95% white | | | CIBIC+
Sparano 1998 | | | | | | | | | | | | MMSE
| | | | | | | | | | | | QoL
Tariot 2001a | IF | 8 | Placebo | NINCDS | AD with CVD | Moderate-Severe | 208 | 162 | 85.7y (65–100y) | 5 mg bid | 24w | CDR-SB | MMSE
| | | Donepezil | | | | | | 18%M | | | MMSE | Age
| | | | | | | | | Institution -100% | | | NPI-NH
| | | | | | | | | | | | PSMS
Thomas 2001 | NR | 7 | Donepezil | NINCDS | AD | Mild-Mod | 60 | 54 | 66.5y (58–73y) | DPZ: | 6m | ADAS-cog | No
| | | Vitamin E | | | | | | 46%M | 5 mg/d (month 1) | | CT/MRI
| | | Rivastigmine (open label) | | | | | | | 10 mg/d (until end) | | ERP scalp topography
| | | | | | | | | | Vit E: 2000 IU (fixed) | | GBS
| | | | | | | | | | Rivastigmine: | | GDS
| | | | | | | | | | 1.5 mg/d (month 1) | | MMSE
| | | | | | | | | | 3 mg/d (month 2) | | NPI
| | | | | | | | | | 6 mg/d (month 3) | | WAIS
| | | | | | | | | | 9 mg/d (month 4)
| | | | | | | | | | 12 mg/d (until end)
Winblad 2001b | IF | 7 | Placebo | DSM IV | AD | Mild-Mod | 286 | 192 | 72.5y (50–87y) | 10 mg/d | 1y | ADL-PDS | APOE
| | | Donepezil | NINCDS | | | | | 36%M | | | GBS | Genotype
| | | | | | | | | 100% white | | | GDS
| | | | | | | | | | | | MMSE | Gender
| | | | | | | | | | | | NPI
| | | | | | | | | | | | PDS

Evidence Table 10. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 12 w | | Final: (specify) 24 w
Burns 1999 | ITT analysis
| 1] Placebo | ADAS-cog | | | 4] 0.45 | 7] <0.0001 | 4] 1.5 | 7] 0.0315
| 2] DPZ 5 mg/d | | | | 5] -1.5 | 8] <0.0001 | 5] 0.5 | 8] <0.0001
| 3] DPZ 10 mg/d | | | | 6] -1.8 | | 6] -1.4
| 4] Placebo change from baseline | CIBIC+ | | | 4] 4.25 | 7] 0.0545 | 4] 4.45 | 7] 0.0326
| 5] DPZ 5 change from baseline | | | | 5] 4.05 | 8] 0.0001 | 5] 4.25 | 8] 0.0009
| 6] DPZ 10 change from baseline | | | | 6] 3.9 | | 6] 4.1
| 7] DPZ 5 vs. placebo | CDR-SB | | | 4] 0.15 | 7] 0.0021 | 4] 0.375 | 7] 0.0387
| 8] DPZ 10 vs. placebo | | | | 5] -0.15 | 8] 0.0014 | 5] 0.075 | 9] <0.05
| 9] DPZ both doses vs. placebo | | | | 6] -0.18 | | 6] -0.13 | 8] 0.0020
| | IDDD | 1] 69.84(1.68)* | | 4] 69.5 | 8] 0.0085 | 4] 71.0 | 8] 0.0163
| | | 2] 67.78 (1.61) | | 5] 69.0 | | 5] 70.8
| | | 3] 69.85 (1.71) | | 6] 68.0 | | 6] 69.0
| | QoL | | | | | | 4] NS
| | | | | | | | 5] NS
| | | | | | | | 6] NS

* SEM

Evidence Table 11. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 12 w | | Final: (specify) 24w LOCF
Feldman 2001 | ITT Analysis
Gauthier 2002 | 1] Placebo mean change from baseline | [underlined: CIBIC+] | | | 1] 4.1 | 3] <0.0001 | 1] 4.65 | 3] 0.0004
| 2] DPZ 10 mg/d mean change from baseline | | | | 2] 3.6 | 7] 0.0002 | 2] 4.05 | 7] 0.0044
| 3] Mean treatment difference DPZ vs. Placebo | | | | 5] -0.11 | | 5] 0.24
| 4] Mean treatment difference LOCF population | | | | 6] -0.48 | | 6] -0.22
| 5] Placebo change from baseline subgroup with MMSE of 10–17 | [underlined: CIBIC+ % improved] | | | | | 1] 42% | 3] <0.0001
| 6] DPZ 10 mg d change from baseline subgroup with MMSE of 10–17 | | | | | | 2] 63%
| 7] Difference between Placebo and DPZ change from baseline subgroup with MMSE of 10–17 | DAD | | | 1] -305 | 3] 0.0037 | 1] -8.98 | 3] <0.0001
| | | | | 2] 1.25 | 7] 0.0037 | 2] -0.74 | 7] <0.0001
| | | | | 5] -4 | | 5] -9
| | | | | 6] 2 | | 6] 0.1
| | sMMSE | | | 1] 0.2 | 3] 0.0004 | 1] -0.5 | 3] 0.0019
| | | | | 2] 1.75 | 7] 0.0004 | 2] 1.25 | 7] 0.0009
| | | | | 5] 0.0 | | 5] -0.5
| | | | | 6] 2.0 | | 6] 1.5
| | SIB | | | 1] -0.25 | 3] <0.0001 | 1] -4.0 | 3] <0.0001
| | | | | 2] 4.75 | 7] 0.0004 | 2] 2.0 | 7] 0.0012
| | | | | 5] -1.0 | | 5] -3.0
| | | | | 6] 3.5 | | 6] 2.5
| | IADL + | | | | | 3] 6.83 | 3] 0.0015
| | PSMS + | | | | | 3] 1.32 | 3] 0.0015
| | NPI | | | 5] -0.5 | | 1] -1.0 | 7] 0.021
| | | | | 6] -3.8 | | 2] 4.6
| | | | | | | 5]1.0
| | | | | | | 6] 5.0
| | FRS | | | | | 1] -1.66 | 3] 0.0002
| | | | | | | 2] -0.38 | 7] 0.0022

Evidence Table 12. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 24 w | | Final: (specify) 54w
Mohs 2001 | ITT Endpoint Analysis
| 1] Placebo | ADFACS | | | | | 3] 4.04 | 5] <0.001
| 2] DPZ 10 mg d | | | | | | 4] 2.5
| 3] Placebo mean change from baseline | ADFACS ADL -Instrumental | | | | | | 5] 0.001
| 4] DPZ mean 10mg/d change from baseline | ADFACS ADL-basic | | | | | | 5] 0.007
| 5] Mean change from baseline DPZ vs. Placebo | MMSE | 1] 17.1 (0.2)* | | 3] 0.4 | 5] <0.01 | 3] -0.7 | 5] <0.001
| | | 2] 17.1 (0.2)* | | 4] 1.8 | | 4] 0.6
| | Time to functional decline (days) | | | | | 3] 208 CI (165 to 252) | 5] 0.0051
| | | | | | | 4] 356 CI (>280)

* SEM

Evidence Table 13. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Prasher 2002 | OC Analysis
| 1] Placebo | [underlined: DMR] | 1] 58.2 (16.9) | | | | 1] 64.4 (14.2) | 5] 0.22
| 2] DPZ 10 mg d | | 2] 54.3 (16.1) | | | | 2] 55.1 (17.9)
| 5] Change from baseline placebo vs.DPZ | SIB | 1] 27.2 (13.6) | | | | 1] 11.2 (8.7) | 3] 0.002
| 3] Placebo change from baseline | | 2] 36.8 (21.9) | | | | 2] 31.6 (28.2) | 4] 0.002
| 4] DPZ change from baseline | | | | | | | 5] 0.06
| 5] Change from baseline placebo vs.DPZ | NPI | 1] 8.0 (7.6) | | | | 1] 3.6 (5.0) | 3] 0.03
| | | 2] 7.9 (5.8) | | | | 2] 5.7 (7.6)
| | ABS | 1] 93.0 (19.2) | | | | 1] 84.5 (22.4) | 3] 0.51
| | | 2] 121.4 (36.9) | | | | 2] 120.5 (44.1)

Evidence Table 14. Study results: Denepezil

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Pratt 2002 | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-cog] | | | | | 1] 0.1 | 4] <0.001
| 2] Donepezil 5mg/d change from baseline | | | | | | 2] -1.1 | 5] <0.001
| 3] Donepezil 10mg/d change from baseline | | | | | | 3] -2.2
| 4] Donepezil 5mg/d vs Placebo | [underlined: CIBIC+] | | | | | 1] 32% | 4] 0.0006
| 5] Donepezil 10mg/d vs Placebo | | | | | | 2] 46% | 5] 0.2096
| | | | | | | 3] 36%
| | MMSE | | | | | 1] 0.5 | 4] <0.001
| | | | | | | 2] 1.5 | 5] <0.001
| | | | | | | 3] 1.6

Evidence Table 15. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 6 w | | Final: (specify) 12w
Rogers 1996 | ITT Endpoint analysis
Rogers 2000 | 1] Placebo mean change from baseline | [underlined: ADAS-Cog] | | | 1] 0.5 | | 1] 0.7 | 5] 0.0359
Newman 1999 | 2] DPZ 1mg/d mean change from baseline | | | | 2] -2.0 | | 2] -0.9 | 6] 0.105
Rogers 1998 | 3] DPZ 3mg/d mean change from baseline | | | | 3] -3.2 | | 3] -1.4 | 7] 0.036
| 4] DPZ 5 mg/d mean change from baseline | | | | 4] -3.8 | | 4] -2.5 | 8] 0.002
| 5] Dose response analysis | [underlined: CGIC % success] | | | | | 1] 80% | 8] 0.039
| 6] DPZ 1 mg/d difference from placebo | | | | | | 2] 82%
| 7] DPZ 3 mg/d difference from placebo | | | | | | 3] 83%
| 8] DPZ 5mg/d difference from placebo | | | | | | 4] 90%
| | ADL | | | | | 1] 1.5 | 5] 0.0684
| | | | | | | 2] 4.0
| | | | | | | 3] 0.6
| | | | | | | 4] -3.1
| | MMSE | | | 1] 0.8 | | 4] 1.2 | 5] 0.0275
| | | | | 2] 1.15 | | 2] 0.6
| | | | | 3] 1.25 | | 3] 0.9
| | | | | 4] 1.85 | | 4] 2.0
| | QoL-P | | | | | 1] -1.3 | 5] 0.0369
| | | | | | | 2] 0.7
| | | | | | | 3] 2.6
| | | | | | | 4] 8.8
| | QoL-C | | | | | 1] 3.7 | 5] 0.8860
| | | | | | | 2] -5.3
| | | | | | | 3] 0.0
| | | | | | | 4] 0.3
| | CDR-SB | | | 1] 0.10 | | 1] 0.10 | 5]0.3375
| | | | | 2] -0.050 | | 2] 0.18
| | | | | 3] 0.0 | | 3] 0.23
| | | | | 4] -0.04 | | 4] -0.11

Evidence Table 16. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6 w | | Final: (specify) 12 w
Rogers 1998a | ITT Analysis Endpoint
Doody 2001 | 1] Placebo change from baseline | [underlined: ADAS-cog] | | | 1] -0.02 | 4] 0 .011 | 1] 0.4 (0.43)* | 4] <0.001
Steele 1999 | 2] DPZ 5mg/d change from baseline | | | | 2] -1.5 | 5] <0.001 | 2] -2.1 (0.43)* | 5] <0.001
| 3] DPZ 10mg/dchange from baseline | | | | 3] -2.9 | | 3] -2.7 (0.43)*
| 4] DPZ 5mg/d vs placebo | [underlined: CIBIC +] | | | 1] 3.99 | | 1] 4.2 (0.07)* | 4] 0.003
| 5] DPZ 10mg/d vs placebo | | | | 2] 3.85 | | 2] 3.9 (0.08)* | 5] 0.008
| | | | | 3] 3.93 | | 3] 3.8 (0.08)*
| | MMSE | | | 1] 0.65 | 5] 0.03 | 1] 0.04 (0.25)* | 4] <0.004
| | | | | 2] 0.95 | | 2] 1.0 (0.25)* | 5] <0.001
| | | | | 3] 1.4 | | 3] 1.3 (0.24)*
| | CDR-SB | | | 1] -0.15 | 5] 0.008 | 1] -0.14 (0.11)* | 4] 0.32
| | | | | 2] 0.0 | | 2] -0.10 (0.11)*
| | | | | 3] -0.25 | | 3] -0.31 (0.11)*
| | QoL | | | | | 1] 4.0 (2.7)* | 4] 0.65
| | | | | | | 2] 5.7 (2.7)* | 5] 0.02
| | | | | | | 3] -4.3 (2.7)*

* SEM

Evidence Table 17. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 12 w | | Final: (specify) 24 w
Rogers 1998b | ITT Population
Doody 2001 | 1] Placebo | [underlined: ADAS-cog] | | | 4] 1.25 | 7] 0.0007 | 4] 1.82 (0.49)* | 7] <0.0001
Sparano 1998 | 2] DPZ 5mg/d | | | | 5] -1.25 | 8] <0.0001 | 5] -0.67 (0.51)* | 8] <0.0001
| 3] DPZ 10 mg/d | | | | 6] 2.0 | | 6] -1.06 (0.51)*
| 4] Placebo change from baseline | [underlined: CIBIC +] | | | 4] 4.2 | 7] 0.0157 | 4] 4.51 (0.08)* | 7] <0.0047
| 5] DPZSP5 change from baseline | | | | 5] 3.95 | 8] 0.009 | 5] 4.15 (0.09)* | 8] <0.0001
| 6] DPZ10 change from baseline | | | | 6] 3.9 | | 6] 4.07 (0.07)*
| 7] DPZ5 vs placebo | MMSE | | | 4] -0.5 | 7] 0.0002 | 4] -0.97 (0.28)* | 7] 0.0007
| 8] DPZ10 vs. Placebo | | | | 5] 0.75 | 8] <0.0001 | 5] 0.24 (0.29)* | 8] 0.0002
| | | | | 6] 1.0 | | 6] 0.39 (0.29)*
| | CDR-SB | | | 4] 0.1 | | 4] 0.58 (0.14)* | 7] 0.0008
| | | | | 5] -0.2 | | 5] -0.01 (0.14)* | 8] 0.0007
| | | | | 6] -0.025 | | 6] -0.02 (0.14)*
| | QoL | | | | | | 7] NS
| | | | | | | | 8] NS

* SEM

Evidence Table 18. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 12 w | | Final: (specify) 24 w
Tariot 2001a | ITT Analysis
| 1] Placebo | [underlined: NPI-NH] | 1] 20.5 (14.7) | | | | 3] -4.9 (1.9)* | 7] NS
| 2] DPZ 10 mg /d | | 2] 21.0 (14.5) | | | | 4] -2.3 (1.9)*
| 3] Placebo change from baseline all patients | MMSE | 1] 14.4 (5.8) | | 3] -0.5 | 6] <0.05 | 3] -0.75 | 7] NS
| 4] DPZ change from baseline all patients | | 2] 14.4 (5.4) | | 4] 0.35 | 7] NS | 4] -0.1 | 8] <0.05
| 5] Placebo change from baseline for subgroup with baseline MMSE scores of 10–26 | | | | 5] -0.95 | | 5] -1.0
| 6] DPZ change from baseline for subgroup with baseline MMSE scores of 10–26 | | | | 6] 0.6 | | 6] 0.0
| 7] mean change DPZ over Placebo | CDR-SB | 1] 10.8 (3.7) | | 3] 0.2 | 4] 0.09 | 3] 0.7 | 4] <0.05
| 8] subjects >85 DPZ over Placebo | | 2] 11.2 (4.0) | | 4] -0.15 | 8] <0.05 | 4] -0.1 | 6] <0.05
| | | | | 5] 0.8 | | 5] 0.8 | 7] <0.05
| | | | | 6] -0.3 | | 6] -0.2 | 8] <0.05
| | PSMS | 1] 14.7 (5.0) | | | 7] 0.09 | 3] -1.0 | 7] 0.31
| | | 2] 15.1 (4.9) | | | | 4] -1.0

* SEM

Evidence Table 19. Study results: Donepezil (DPZ). Vitami E

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 3 m | | Final: (specify) 6 m
Thomas 2001 | OC Analysis
| 1] DPZ 10 mg d | WAIS | 1] 72 (2.0)* | | 1] 74 (2.0)* | | 1] 75 (2.0)* | 3] 0.15
| 2] Vitamin E 2,000 IU | | 2] 72 (2.0)* | | 2] 72 (2.0)* | | 2] 71 (2.1)* | 4] 0.43
| 3] change from baseline with DPZ | MMSE | 1] 16 (0.5)* | | 1] 16 (0.6)* | 5] <0.001 favors DZP | 1] 16 (0.5)* | 3] 0.06
| 4] change from baseline with Vitamin E | | 2] 16 (0.5)* | | 2] 15 (0.5)* | | 2] 15 (0.6)* | 4] 0.07
| 5] DPZ vs Vitamin E change from baseline | | | | | | | 5] <0.001 favors DPZ
| | ADAS-cog | 1] 33.34 (2.7)* | | 1] 31.55 (2.7)* | | 1] 31.84 2.7)* | 3] <0.001
| | | 2] 33.45 (2.6)* | | 2] 36.09 (2.8)* | | 2] 39.07 (2.7)* | 4] <0.01
| | NPI | 1] 21.9 (0.5)* | | | | 1] 16.8 (0.2)*
| | | 2] 21.9 (0.5)* | | | | 2] 22.8 (1.2)*

* SEM

Evidence Table 20. Study results: Donepezil (DPZ)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 24 w | | Final: (specify) 52 w
Winblad 2001b | ITT Endpoint Analysis
| 1] Placebo | [underlined: GBS total score] | | | | | 3] 12.0 | 5] 0.054
| 2] DPZ 10 mg/d | | | | | | 4] 9.0 | 6] 0.532
| 3] Placebo change from baseline | | | | | | | 7] 0.258
| 4] DPZ change from baseline | GBS | | | | | | 5] 0.012
| 5] DPZ vs. Placebo | MMSE | | | | | 3] -2.2 | 5] <0.001
| 6] Analysis for APOE Genotype Interaction | | | | | | 4] -0.4 | 6] 0.712
| 7] Aanlysis for Gender Interaction | | | | | | | 7] 0.743
| | ADL-PDS | | | | | 3] -15 | 5] <0.05
| | | | | | | 4] -11
| | GDS | | | | | | 5] 0.047
| | NPI | | | | 5] NS | | 5] NS

Evidence Table 21. Adverse Events: Donepezil (DPZ)

Adverse events (AE) identified in included studies | Burns, 1999 | Feldman, 2001 | Mohs, 2001 | Prasher, 2002 | Pratt, 2002 | Rogers, 1996 | Rogers, 1998a | Rogers, 1998b | Tariot, 2001a | Thomas, 2001 | Winblad, 2001b
Withdrawn (%) due to AE | T:14^+^ | T: 8 | T:11 | T: 7 | T:15^+^ | T: 8 | T: 7^+^ | T:11^+^ | T:18 | T: 0 | T: 7
| C:10 | C: 6 | C: 7 | C: 0 | C: 9 | C: 5 | C: 1 | C: 7 | C: 11 | C: 0 | C: 6
AE Checklist (Max 5) | 3 | 2 | 3 | 4 | 1 | 2 | 3 | 3 | 2 | 3 | 4
None Reported | | | | | | | | | | X
Balance | | | | | | | | | | | S
Accidental Injury | | X | NS | | | X | NS* | | X | | NS
Dizziness | NS* | X | | NS | | X | NS* | NS* | X | | NS
Falls
Behavioral | | X | | | | | | | | | NS
Agitation | | | NS | NS | | X | NS* | | X
Cardiovascular | | | | | | | | | X
Arrhythmia | | | | | | | X
Hypotension
Hypertension
Extrapyramidal
Tremor | | | | | | | | | X
Gastrointestinal | | | | | | X | X
Abdominal pain | | X | | NS | | | X | | X | | NS
Constipation | | | | | | X | | | | | NS
Diarrhea | S* | X | S | NS | | X | S* | S* | X | | NS
Dyspepsia | | | S
Nausea, vomiting | S* | X | S | NS | | X | S* | S* | X | | NS
Metabolic/nutritional | | | | | | | | | X
Eating disorder | NS* | | S | NS | | | X | NS* | X
Weight Change | | X | NS | | | | X | | X
Neurological | | | | NS
Asthenia | | X | NS | | | | | | X | | S
Psychiatric | | | | X
Anxiety | | | | | | | | | | | NS
Confusion, delirium | NS* | X | | | | | | | X | | NS
Depression | | X | | | | | | | | | NS
Respiratory | | X | | | | X | X
Cough, cold, infection | | | | | | X | NS* | | X
Rhinitis | | | NS | | | | X | NS* | X
Other | | | | | | X | X | | X
Aberrant hematology | | | | | | | | NS* | X
Fatigue, weakness | | | | S | | | NS* | S*
Fever, flu, pneumonia | | | | | | | | | X | | X
Headache | | X | S | | | X | NS* | | X | | NS
Hepatic abnormality | NS* | | | | | NS | NS
Muscle/joint disorder | | X | | NS | | | NS* | S* | X
Pain | | X | | | | X | NS* | | X
Rash, skin disorder | | | NS | | | | | | X
Sleep disorder | NS* | | NS | NS | | | S* | | | | NS
Urinary disorder | | X | S | | | X | S | | X | | NS

NR = Withdrawals due to AE Not Reported;

+ = Dose effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 22. Key characteristics Galantmine

Author, Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Reandmized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Ouctome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Erkinjuntti 2002 | PI | 8 | Placebo | NINDS | VaD | Probable | 592 | 457 | 75.1y (40–90y) | 4 mg/d on w 1 | 6m | ADAS-Cog | MID vs AD+vascular
| | | Galantamine | NINCDS | AD | | | | 53%M | 8 mg/d on w 2 | | CIBIC+
| | | | | | | | | 99.9% white | 12 mg/d on w 3 | | DAD
| | | | | | | | | | 16 mg/d on w 4 | | NPI
| | | | | | | | | | 20 mg/d on w 5
| | | | | | | | | | 24 mg/d from w 6 to the end
Raskind 2000 | IF | 8 | Placebo | NINCDS | AD | Mild-Mod | 636 | 438 | 75.4y (NR) | Loading: | 6m | ADAS-Cog | APOE Genotype
| | | Galantamine | | | | | | 38%M | 8 mg/d on w 1 | | CIBIC+
| | | | | | | | | 91.5% white | 16 mg/d on w 2 | | DAD
| | | | | | | | | | 24 mg/d on w 3
| | | | | | | | | | Then one group stayed at 24 mg/d the other group 32 mg/d
Rockwood 2001 | IF | 7 | Placebo | NINCDS | AD | Probable | 386 | 288 | 74.9y (NR) | 8 mg/d on w 1 | 3m | ADAS-Cog | No
| | | Galantamine | | | Mild-Mod | | | 44%M | 16 mg/d in w 2 | | CIBIC+
| | | | | | | | | | 24 mg/d on w 3 | | DAD
| | | | | | | | | | 32 mg/d on w 4 | | NPI
| | | | | | | | | | At the end of w 4 dose could be reduced to 24 mg/d | | PSQI
Tariot 2000 | NR | 8 | Placebo | NINCDS | AD | Probable | 978 | 679 | 76.8y (NR) | Loading: | 5m | ADAS-Cog | No
| | | Galantamine | | | Mild-Mof | | | 36%M | 8 mg/d | | ADCS
| | | | | | | | | 93% white | 16 mg/d | | CIBIC+
| | | | | | | | | | Then 24 mg/d | | IADL
| | | | | | | | | | | | NPI
Wilcock 2000 | NI | 8 | Placebo | NINCDS | AD | Mild-Mod | 653 | 525 | 72.2y (NR) | Loading: | 6m | ADAS-Cog | MMSE
Auxiliary: | | | Galantamine | | | | | | 37%M | 8 mg/d on w 1 | | ADAS | APOE
Wilcock 2001 | | | | | | | | | | 16 mg/d on w 2 | | CIBIC+ | Genotype
| | | | | | | | | | 24 mg/d on w 3 | | DAD
| | | | | | | | | | one group stayed at 24 mg/d the other group 32 mg/d
Wilkinson 2001 | IF | 7 | Placebo | NINCDS | AD | Mild-Mod | 285 | 206 | 73.8y (>45y) | Start at 4 mg/d and progressively increased every 2–3d to reach the target doses | 12w | ADAS-Cog | No
| | | | DSM-III-R | | | | | 42%M | 18mg/d | | CGIC
| | | | | | | | | 100% Community | 24 mg/d | | PDS
| | | | | | | | | | 36 mg/d

Evidence Table 23. Study results: Galantamine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Erkinjuntti 2002 | OC Analysis
| 1] Placebo from baseline | [underlined: ADAS-cog/11 change from baseline] | | | | | 1] 1.0 (0.5)* | 1] 0.045
| 2] Galantamine 24 mg/d from baseling | | | | | | 2] -1.7 (0.4)* | 2]<0.0001
| 3]Placebo vs Galantamine | | | | | | 4] 1.8 (0.6)* | 3]<0.0001
| 4] Placebo from baseline subrgroup AD+ vascular | | | | | | 5]-1.0 (0.46)* | 6] 0.0005
| 5] Galantamine from baseline subgroup AD+vascular | | | | | | 7] -0.4 (0.78)* | 9] 0.06
| 6] Placebo vs Galantamine subgroup AD+vascular | | | | | | 8] -2.4 (0.59)*
| 7] Placebo from baseline subgroup VAD | [underlined: CIBIC-plus % improved or stable] | | | | | 1] 59% | 3] 0.0011
| 8] Galantamine from baseline subgroup VAD | | | | | | 2] 74% | 6] 0.001
| 9] Placebo vs Galantamine subgroupVAD | | | | | | 4] 54%
| | | | | | | 5] 75%
| | CIBIC-plus % improved | | | | | 4] 19% | 6] 0.019
| | | | | | | 5] 32% | 9] 0.238
| | | | | | | 7] 23%
| | | | | | | 8] 31%
| | ADAS-cog/13 Change from baseline | | | | | 1] 0.9 (0.6)* | 3]<0.0001
| | | | | | | 2] -2.4 (0.4)*
| | DAD | | | | | 1] -4.4 (1.3)* | 3] 0.0017
| | | | | | | 2] 0.2 0.9)*
| | NPI | | | | | 1] 1.0 (0.9)* | 3] 0.0164
| | | | | | | 2] -1.2 0.6)*

* SEM

Evidence Table 24. Study results: Galantamine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Raskind 2000 | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-cog/11] | | | | | 1] 2.0 (0.45)* | 4] <0.001
| 2] Galantamine 24 mg/d change from baseline | | | | | | 2] 1.9 (0.36)* | 5] <0.001
| 3] Galantamine 32 mg/d change from baseline | | | | | | 3] -1.4 (0.44)*
| 4] Placebo vs. Galantamine 24mg/d change from baseline | [underlined: CIBIC-plus % improved] | | | | | 1] 13.8% | 4] <0.05
| 5] Placebo vs. Galantamine 32 mg/d change from baseline | | | | | | 2] 19.9% | 5] <0.05
| | | | | | | 3] 15.8%
| | DAD (total) | | | | | | 4] NS
| | | | | | | | 5] NS

* SEM

Evidence Table 25. Study Results: Galantmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3m
Rockwood 2001 | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-Cog-11] | | | | | 1] 0.6 (0.45)* | 3] <0.01
| 2] Galantamine 24–32mg/d change from baseline | | | | | | 2] -1.1 (0.33)*
| 2] Galantamine 24–32mg/d change from baseline | [underlined: ADAS-Cog-13] | | | | | 1] +0.7 (0.51)* | 3] <0.01
| 3] Difference between placebo and galantamine change from baseline | | | | | | 2] -1.2 (0.38)*
| | [underlined: CIBIC-+ % improved or stable] | | | | | 1] 18.7% | 3]<0.01
| | | | | | | 2] 22.1%
| | NPI | | | | | 1] 0.5 (0.65)* | 1] NS
| | | | | | | 2] -0.3 (0.7)* | 2] NS
| | DAD | | | | | 1] -5.2 (1.18)* | 3]<0.001
| | | | | | | 1] -0.4 (0.76)

* SEM

Evidence Table 26. Study results: Galantmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | REsult Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 5m
Tariot 2000 | ITT Analysis
| 1] Placebo change from baseline | ADAS-Cog | | | | | 1] 1.7 ( 0.39)* | 5] NS
| 2] Galantamine 8mg/d change from baseline | | | | | | 2] +0.4 ( 0.52)* | 6]<0.001
| 3] Galantamine 16 mg/d change from baseline | | | | | | 3] -1.4 ( 0.35)* | 7]<0.001
| 4] Galantamine 24mg/d change from baseline | | | | | | 4] -1.4 ( 0.39)* | 8] <0.05
| 5] Placebo vs. galantamine 8 mg/d in change from baseline | | | | | | | 9] <0.01
| 6] Placebo vs. galantamine 16 mg/d in change from baseline | CIBIC+ % improved | | | | | 1] 49% | 6] <0.001
| 7] Placebo vs. galantamine 24 mg/d in change from baseline | | | | | | 2] 53% | 7] <0.001
| 8] Galantamine 8mg/d vs. 16mg/d in change from baseline | | | | | | 3] 66% | 8] <0.05
| 9] Galantamine 8mg/d vs. 24mg/d in change from baseline | | | | | | 4] 64% | 9] <0.05
| | ADCS/ADL | | | | | 1] -3.8 (0.6)* | 6]<0.001
| | | | | | | 2] -3.2 ( 0.8)* | 7] <0.01
| | | | | | | 3] -0.7 ( 0.5)* | 8] <0.01
| | | | | | | 4] -1.5 (0.6)*
| | NPI | | | | | 1] 2.0 ( 0.7)* | 6] <0.05
| | | | | | | 2] 2.3 (1.0)* | 7] <0.05
| | | | | | | 3] -0.1 ( 0.7)*
| | | | | | | 4] 0.0 (0.8)*

* SEM

Evidence Table 27. Study results: Galantamine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Resul Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Wilcock 2000 | ITT Analysis
Wilcock 2001 | 1] Placebo change from baseline | [underlined: ADAS-cog] | | | | | 1] 2.4 (0.41)* | 1] <0.001
| 2] Galantamine 24mg/d change from baseline | | | | | | 2] -0.5 (0.38)* | 2] <0.001
| 3] Galantamine 32 mg/d change from baseline | | | | | | 3] -0.8 (0.43)* | 3] <0.001
| 4] Difference between placebo and Galantamine 24mg/d in change from baseline | | | | | | | 4] <0.001
| 5] Difference between placebo and Galantamine 32 mg/d in change from baseline | | | | | | | 5] <0.001
| | [underlined: DAD] | | | | | 1] -6.0 (1.08)* | 4] 0.1
| | | | | | | 2] -3.2 (1.02)* | 5] <0.05
| | | | | | | 3] -2.5 (1.07)*
| | [underlined: CIBIC+] | | | | | 1] 16.5% | 4] <0.05
| | | | | | | 2] 17% | 5] <0.001
| | | | | | | 3] 25%

* SEM

Evidence Table 28. Study results: Galantamine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Resul Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Wilkinson 2001 | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-Cog] | | | | | 1] 1.6 (0.7)* | 5] NS
| 2] Galantamine 18 mg/d Change from baseline | | | | | | 2] -01 (0.7)* | 6] <0.01
| 3] Galantamine 24 mg/d Change from baseline | | | | | | 3] -1.4 (0.9)* | 7] 0.08
| 4] Galantamine 36 mg/d Change from baseline | | | | | | 4] -0.7 (0.7)*
| 5] Placebo vs. Galantamine 18mg/d in change from baseline | CGIC | | | | | 1] 31.3% | 5] NS
| 6] Placebo vs. galantamine 24mg/d in change from baseline | % improved | | | | | 2] 36.7% | 6] NS
| 7] Placebo vs. galantamine 36mg/d in change from baseline | | | | | | 3] 28.3% | 7] NS
| | | | | | | 4] 31.9%
| | PDS-1 | | | | | 1] 9.2 % | 5] NS
| | % improved | | | | | 2] 12.5 % | 6] NS
| | | | | | | 3] 14.3% | 7] NS
| | | | | | | 4] 7.4%

* SEM

Evidence Table 29. Adverse Events: Galantamine

Adverse events (AE) identified in included studies | Erkinjuntti, 2002 | Raskind, 2000 | Rockwood, 2001 | Tariot, 2000 | Wilcock, 2000 | Wilkinson, 2001
Withdrawn (%) due to AE | T: 20 | T: 27 | T: 26 | T: 8 | T: 18 | T: 27^+^
| C: 8 | C: 8 | C: 4 | C: 7 | C: 9 | C: 9
AE Checklist (Max 5) | 3 | 3 | 4 | 3 | 3 | 3
None Reported
Balance
Accidental Injury | X
Dizziness | | X | X | | X | X
Falls
Behavioral
Agitation | | | X | X
Cardiovascular
Arrhythmia
Hypotension
Hypertension
Extrapyramidal
Tremor | | X
Gastrointestinal | X | | | X
Abdominal pain | | X | X
Constipation
Diarrhea | | X | | X | X | X
Dyspepsia
Nausea, vomiting | X | X | X | X | X | X
Metabolic/nutritional
Eating disorder | | X | X | X | X | X
Weight Change | | S | | X | S
Neurological | X
Asthenia
Psychiatric
Anxiety
Confusion, delirium
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other
Aberrant hematology | | NS | NS | NS | NS | NS
Fatigue, weakness
Fever, flu, pneumonia
Headache | | | | | X | X
Hepatic abnormality
Muscle/joint disorder | | | | X
Pain
Rash, skin disorder
Sleep disorder | | | X
Urinary disorder

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 30. Key characteristics. Metrifonate

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Becker 1996 | NI | 6 | Placebo | NINCDS | AD | Probable | 53 | 51 | 71.4y (57–85y) | Loading: 5.0 mg/kg for 2 w, 4.9 mg/kg for 1 w then 2.1 mg/kg weekly | 3m | ADAS-Cog | No
| | | Metrifonate | | | | | | 40%M | | | ADAS-Noncog
| | | | | | | | | | | | ADAS-T
| | | | | | | | | | | | ADLC
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | EEG
| | | | | | | | | | | | GIS
| | | | | | | | | | | | MMSE
Becker 1998 | NI | 6 | Placebo | NINCDS | AD | Probable | 47 | 46 | 73.0y (<90y) | Loading2 mg/kg for 5 d, 0.95 mg/kg on d 6 then 2.9 mg/kg weekly | 6m | ADAS-Cog | No
| | | Metrifonate | | | | | | 51%M Community | | | ADAS-Noncog
| | | | | | | | | | | | ADLC
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | GIS
| | | | | | | | | | | | MMSE
Cummings 1997 | NR | 5 | Placebo | NINCDS | AD | Probable | 480 | 453 | NR | Loading: | 12w | ADAS-Cog | No
| | | Metrifonate | | | Mild-Mod | | | | Low dose group: 0.5 mg/kg | | CIBIC+
| | | | | | | | | | Medium-dose group: 0.9 mg/kg | | MMSE
| | | | | | | | | | High-dose group: 2.0 mg/kg
| | | | | | | | | | Maintenance dose respectively:
| | | | | | | | | | 0.2 mg/kg
| | | | | | | | | | 0.3 mg/kg
| | | | | | | | | | 0.65 mg/kg/d
Cummings 1998 | PI | 8 | Placebo | NINCDS | AD | Probable | 480 | 443 | 73.5y (NR) | Loading for 2 w: low dose group 0.5 mg/kg ; mid-dose group: 0.9 mg/kg; high-dose group 2.0 mg/kg then respectively 0.2 mg/kg 0.3 mg/kg 0.65 mg/kg | 12w | ADAS-Cog | No
AUXILIARY | | | Metrifonate | | | | | | 41%M | | | CIBIC+
Cummings 1998b | | | | | | | | | | | | CIBIS+
| | | | | | | | | | | | GERRI
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSMS
Dubois 1999 | IF | 6 | Placebo | DSM IV | AD | Mild-Mod | 605 | 516 | 72.1y (NR) | 1 loading dose of 80 mg or 120 mg and then: 0.65 mg/Kg/d or 1.0 mg/Kg/d | 26w | AChE | No
AUXILIARY | | | Metrifonate | | | | | | 36%M | | | ADAS-Cog
McKeith 1998 | | | | | | | | | | | | ADAS-Noncog
| | | | | | | | | | | | CIBIC+
| | | | | | | | | | | | CIBIS+
| | | | | | | | | | | | DAD
| | | | | | | | | | | | ECG
| | | | | | | | | | | | GDS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NPI
| | | | | | | | | | | | Laboratory tests
Jann 1999 | PI | 6 | Placebo | NINCDS | AD | Mild-Mod | 395 | 393 | 75.0y (45–90y) | Loading dose group: 100 or 150 mg for 2 w | 6w | ADAS-Cog | No
| | | Metrifonate | | | | | | 42%M | Non loading dose group: 50 mg/d | | ADAS-Noncog
| | | | | | | | | 91% White | | | CIBIC+
| | | | | | | | | 3.8% Black | | | CIBIS+
| | | | | | | | | 2.6% Hispanic | | | EEG
| | | | | | | | | 1.8% Asian | | | MMSE
Morris 1998 | PI | 7 | Placebo | NINCDS | AD | Mild-Mod | 408 | 334 | 73.6y (NR) | 2 w loading (2.0mg/kg/d) | 26w | ADAS-Cog | No
| | | Metrifonate | | | | | | 39%M | 24w 0.65 mg/kg/d | | ADAS-NONCOG
| | | | | | | | | 93% White | | | CIBIC+
| | | | | | | | | 3.3% Black | | | CIBIS+
| | | | | | | | | 0.4% Asian | | | GDS
| | | | | | | | | 2.6% Hispanic | | | MMSE
| | | | | | | | | | | | NPI
Pettigrew 1998 | PI | 6 | Placebo | NINCDS | AD | Probable | 27 | 27 | 72.0y (55–85y) | Loading for 6 d: Panel 1: 1.5 mg/kg | 21d | ADAS-Cog | No
| | | Metrifonate | | | | | | 59%M | Panel 2: 2.5 mg/kg | | ADAS-Noncog
| | | | | | | | | 100% community | Panel 3: 4 .0 mg/kg | | Blessed - DRS
| | | | | | | | | | Panel 4: 4.0 then respectively: 0.25 mg/kg; 4.0 mg/kg; 0.65 mg/kg 1.0 mg/kg | | ECG
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | MRS
Raskind 1999 | IF | 7 | Placebo | NINCDS | AD | Probable | 264 | 219 | 74.6y (NR) | 50 mg/d | 6m | ADAS-Cog | No
| | | Metrifonate | | | Mild-Mod | | | 36% M Community | | + 6 w post-treatment follow-up period | ADAS-Noncog
| | | | | | | | | 90% White | | | CIBIC+
| | | | | | | | | 3.7% Black | | | CIBIS+
| | | | | | | | | 5.1% Hispanic | | | DAD
| | | | | | | | | 0.3% American Indian | | | GDS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NPI

Evidence Table 31. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Resul Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3 m
Becker 1996 | OC Analysis
| 1] Placebo | [underlined: ADAS-Cog] | 1] 26.39(10.20) | | | | 1] 27.49(11.04) | 3] <0.02
| 2] Metrifonate | | 2] 25.64(11.86) | | | | 2] 24.89(11.80) | 4] 0.15
| 5.0 mg/kg 2 w | | | | | | | 5] <0.01
| 4.9 mg/kg 1 w | MMSE | 1] 19.30 (5.50) | | | | 1] 18.35 (5.77) | 3] <0.03
| 2.1 mg/kg 9w | | 2] 19.47 (5.35) | | | | 2] 19.36 (6.01) | 4] 0.76
| 3] Baseline vs.Placebo | | | | | | | 5] 0.14
| 4] Baseline vs.Metrifonate | ADAS-Noncog | 1] 5.19 (5.38) | | | | 1] 5.88 (5.74) | 3] 0.09
| 5] Metrifonate vs. placebo | | 2] 5.91 (4.93) | | | | 2] 5.94 (5.11) | 4] 0.88
| | | | | | | | 5] 0.11
| | ADAS-Total | 1] 31.58(13.29) | | | | 1] 33.37(14.51) | 3] <0.02
| | | 2] 31.56(14.56) | | | | 2] 30.83(14.44) | 4] 0.21
| | | | | | | | 5] <0.01
| | GIS | 1] 3.63 (0.46) | | | | 1] 4.11 (0.59) | 3] <0.01
| | | 2] 4.08 (0.52) | | | | 2] 4.10 (0.71) | 4] 0.90
| | | | | | | | 5] 0.1
| | ADLC | 1] -2.51(13.26) | | | | 1] -2.23 (9.31) | 3] 0.93
| | | 2] -7.80(17.21) | | | | 2] -3.82(17.00) | 4] 0.17
| | | | | | | | 5] 0.80

Evidence Table 32. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Becker 1998 | OC Analysis
| 1] Placebo | [underlined: ADAS-Cog] | 1] 21.75 (8.40) | | | | 1] 23.42 (9.53) | 3] 0.01
| 2] Metrifonate 2.9 mg/kg w | | 2] 20.61 (9.33) | | | | 2] 20.61 (9.32) | 4] 1.00
| 3] Placebo vs. baseline | | | | | | | 5] <0.03
| 4] Metrifonate vs. baseline | MMSE | 1] 19.78 (4.92) | | | | 1] 18.60 (5.40) | 3] <0.01
| 5] Metrifonate vs. Placebo | | 2] 20.62 (3.85) | | | | 2] 20.38 (4.42) | 4] 0.44
| | | | | | | | 5] 0.09
| | ADAS-Noncog | 1] 3.75 (4.53) | | | | 1] 4.07 (4.92) | 3] 0.31
| | | 2] 2.72 (3.57) | | | | 2] 2.80 (3.40) | 4] 0.80
| | | | | | | | 5] 0.53
| | GIS | 1] 3.85 (0.77) | | | | 1] 4.23 (0.81) | 3] <0.02
| | | 2] 3.78 (0.45) | | | | 2] 4.34 (0.80) | 4] <0.00
| | | | | | | | 5] 0.42
| | ADLC | 1] 3.88 (8.66) | | | | 1] 9.56 (10.93) | 3] 0.01
| | | 2] 4.93 (6.66) | | | | 2] 8.94 (8.67) | 4] 0.00
| | | | | | | | 5] 0.58

Evidence Table 33. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Cummings 1997 | OC Population
| 1] Placebo | [underlined: ADAS-Cog] | | | | | 5] 1.45 | 5] <0.05
| 2] Low Dose Metrifonate 0.5 mg/kg loading 0.2 mg/kg maintenance | | | | | | 6] 3.17 | 6] <0.001
| 3] Medium Dose Metrifonate 0.9 mg/kg loading 0.3 mg/kg maintenance | [underlined: CIBIC+] | | | | | 5] 0.33 | 5] <0.05
| 4] High dose Metrifonate 2.0 mg/kg loading 0.65 mg/kg maintenance | | | | | | 6] 0.40 | 6] <0.001
| 5] Placebo vs. medium dose Metrifonate
| 6] Placebo vs. high dose Metrifonate

Evidence Table 34. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Cummings 1998a | ITT Analysis
Cummings 1998b | 1] Placebo | [underlined: CIBIC+] | | | | | 2] 0.04 | 2] 0.735
| 2] Metrifonate 20 mg qid difference from Placebo | | | | | | CI (-0.16–0.24) | 3] 0.005
| 3] Metrifonate 25mg qid difference from Placebo | | | | | | 3] 0.29 | 4] 0.0007
| 4] Metrifonate 60mg qid difference from Placebo | | | | | | CI (0.09–0.48)
| | | | | | | 4] 0.35
| | | | | | | CI (0.15–0.54)
| | [underlined: ADAS-Cog] | | | | | 2] 1.5 | 2] 0.02
| | | | | | | CI (0.18–2.83) | 3] 0.053
| | | | | | | 3] 1.30 | 4] 0.0001
| | | | | | | CI (-0.02–2.62)
| | | | | | | 4] 2.94
| | | | | | | CI (1.61–4.27)
| | MMSE | | | | | 2] 1.11 C1(0.39 – 1.84) | 2] 0.0029
| | | | | | | 3] 0.63 | 3] 0.0905
| | | | | | | C1(-0.10–-1.35) | 4] 0.0003
| | | | | | | 4] 1.37 C1(0.64 – 2.10)
| | PSMS | | | | | | 2] NS
| | | | | | | | 3] NS
| | | | | | | | 4] NS
| | CIBS+ | | | | | | 2] NS
| | | | | | | | 3] NS
| | | | | | | | 4] NS
| | GERRI | | | | | | 2] NS
| | | | | | | | 3] NS
| | | | | | | | 4] NS
| | IADL | | | | | | 2] NS
| | | | | | | | 3] NS
| | | | | | | | 4] NS

Evidence Table 35. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 26w
Dubois 1999 | ITT Analysis (LOCF)
McKeith 1998 | 1] Placebo | [underlined: ADAS-cog] | | | | | 3] 1.3 | 3] 0.032
| 2] Metrifonate 40 to 50 mg/d variable by weight | | | | | | 4] 3.24 | 4] 0.0001
| 3] Metrifonate 60 to 80 mg/d variable by weight | [underlined: CIBIC+] | | | | | 3] 0.21 | 3] 0.052
| 4] mean change from baseline Placebo vs. 40/50mg dose Metrifonate | | | | | | 4] 0.35 | 4] 0.0014
| 5] mean change from baseline Placebo vs. 60/80 mg dose Metrifonate | DAD total | | | | | 3] 3.00 | 3] 0.0522
| | | | | | | 4] 5.45 | 4] 0.0005
| | MMSE | | | | | 3] 0.40 | 3] 0.26
| | | | | | | 4] 1.19 | 4] 0.0009
| | CIBIS+ | | | | | 3] 0.20 | 3] 0.0002
| | | | | | | 4] 0.23 | 4] 0.0001
| | ADAS-Noncog Total | | | | | 3] 0.59 | 3] 0.14
| | | | | | | 4] 1.37 | 4] 0.0008
| | NPI total | | | | | 3] 0.83 | 3] 0.48
| | | | | | | 4] 1.44 | 4] 0.23
| | GDS | | | | | 3] 0.08 | 3] 0.22
| | | | | | | 4] 0.21 | 4] 0.0026
| | IADL | | | | | | 3] <0.05
| | | | | | | | 4] <0.05
| | ADL | | | | | | 3] NS
| | | | | | | | 4] NS

Evidence Table 36. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Jann 1999 | ITT Analysis
| 1] Placebo | [underlined: ADAS-Cog] | | | 4] 0.0 | 7] NS | 4] 0.55 | 7] 0.01
| 2] Metrifonate loading dose 100/150 mg d 2w by weight plus 50 mg d 4 w | | | | 5] -0.85 | | 5] -1.0 | 8] NS
| 3] Metrifonate 50 mg d 6w | | | | 6] -0.1 | | 6] 0.0
| 4] Placebo change from baseline | CIBIC+ | | | 4] 4.02 | 7] <0.05 | 4] 4.1 | 7] <0.05
| 5] Metifonate loading dose change from baseline | | | | 5] 4.25 | | 5] 3.9 | 8] <0.05
| 6] Metrifonate no loading dose change from baseline | | | | 6] 3.85 | | 6] 3.72
| 7] Metrifonate loading dose vs. placebo change from baseline | ADAS-Noncog | | | | | | 7] NS
| 8] Metrifonate no loading dose vs Placebo change from baseline | | | | | | | 8] NS
| | CIBIS+ | | | | | | 7] NS
| | | | | | | | 8] NS
| | MMSE | | | | | | 7] NS
| | | | | | | | 8] NS

Evidence Table 37. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 12w | | Final: (specify) 26w
Morris 1998 | ITT Analysis
| 1] Placebo | [underlined: ADAS-Cog] | | | 4] 1.5 | 3] 0.0002 | 1] 2.7 | 3] 0.0001
| 2] Metrifonate 180mg loading 60 mg maintenance | | | | 5] -0.5 | | 2] -0.3
| 3] Difference between Placebo and Metrifonate change from baseline | | | | | | 3] 2.86 CI (1.37–4.34)
| 4] Placebo change from baseline | | | | | | 4] 2.5
| 5] Metrifonate change from baseline | | | | | | 5] -0.3
| | [underlined: CIBIC+] | | | 1] 4.15 | 3] 0.0152 | 1] 4.35 | 3] 0.0071
| | | | | 2] 3.95 | | 2] 4.05
| | | | | | | 3] 0.28 CI (0.06–0.50)
| | | | | | | 4] 4.38
| | | | | | | 5] 4.05
| | DAD | | | | | | 3] 0.0860
| | GDS | | | | | | 3] 0.0734
| | ADAS-Noncog | | | | | | 3] 0.1221
| | MMSE | | | | | | 3] 0.1788

Evidence Table 38. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 21d
Pettigrew 1998 | OC Analysis
| 1] Placebo change from baseline | ADAS-Cog | | | | | 1] 0.00 (3.65)
| 2] Metrifonate 135mg loading 25mg maintenance from baseline | | | | | | 2] 1.67 (2.52)
| 3] Metrifonate 225mg loading 35mg maintenance change from baseline | | | | | | 3] 1.33 (4.04)
| 4] Metrifonate 335mg loading 60mg maintenance change from baseline | | | | | | 4] -1.33 (2.4)
| 5] Metrifonate 335mg loading 90mg maintenance change from baseline | | | | | | 5] -2.63 (6.7)
| | ADAS-Noncog | | | | | 1] -1.86 (2.1)
| | | | | | | 2] -3.67 (1.5)
| | | | | | | 3] 1.33 (5.77)
| | | | | | | 4] -2.00 (2.1)
| | | | | | | 5] -1.75 (2.6)
| | MMSE | | | | | 1] 0.71 (2.50)
| | | | | | | 2] -67 (3.5)
| | | | | | | 3] 1.33 (0.58)
| | | | | | | 4] 0.50 (1.87)
| | | | | | | 5] 2.63 (2.07)
| | Blessed-DRS | | | | | 1] -2.64 (2.46)
| | | | | | | 2] -1.17 (2.52)
| | | | | | | 3] 0.50 (2.29)
| | | | | | | 4] 0.67 (3.40)
| | | | | | | 5] 0.56 (1.66)

Evidence Table 39. Study results: Metrifonate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 12 w | | Final: (specify) 26 w
Raskind 1999 | ITT analysis
| 1] Placebo | MMSE | | | 3] -0.60 | 5] <0.05 | 3] -1.25 | 6] 0.0001
| 2] Metrifonate 50mg d | | | | 4] 0.75 | | 4] 0.60 | 5] <.05
| 3] Placebo mean change from baseline | NPI | | | | | 3] .075 | 6] 0.013
| 4] Metrifonate mean change from baseline | | | | | | 4] 0.30 | 5] <0.05
| 5] Metrifinate vs. placebo | CIBIC+ | | | 3] 4.2 | | 3] 4.4 | 5] <0.05
| 6] Mean drug-placebo difference change from baseline | | | | 4] 4.05 | | 4] 4.78 | 6] 0.039
| | GDS | | | | | | 6] 0.570
| | ADAS-Cog | | | | | | 6] 0.012
| | ADAS-Noncog | | | | | | 6] 0.185
| | DAD | | | | | | 6] 0.036
| | CIBIS+ | | | | | | 6] 0.260

Evidence Table 40. Adverse Events: Metrifonate

Adverse events (AE) identified in included studies | Becker, 1996 | Becker, 1998 | Cummings, 1997 | Cummings, 1998 | Dubois, 1999 | Jann, 1999 | Morris, 1998 | Pettigrew, 1998 | Raskind, 1999
Withdrawn (%) due to AE | T:0 | T:0 | T:6 | T:6 | T:6 | T:6 | T:12 | T:0 | T:11
| C:0 | C:0 | C:4 | C:4 | C:6 | C:2 | C:4 | C:0 | C:9
AE Checklist (Max 5) | 5 | 2 | 4 | 3 | 3 | 4 | 4 | 5 | 3
None Reported | | X
Balance | | | | | X
Accidental Injury | | | | | X
Dizziness | X | | | | X | | | X
Falls
Behavioral
Agitation | X | | | | | | | X | X
Cardiovascular | X | | X
Arrhythmia | | | | X | X | X | | X
Hypotension | | | | | X | | | X
Hypertension
Extrapyramidal
Tremor
Gastrointestinal | X | | X | X | | | | X
Abdominal pain | X | | X | X | | | | X | X
Constipation
Diarrhea | X | | X | X | X | S* | X | X
Dyspepsia | | | | | | X
Nausea, vomiting | X | | X | X | X | S* | X | X
Metabolic/nutritional
Eating disorder
Weight Change
Neurological | | | | | | | | X
Asthenia | | | | | X
Psychiatric
Anxiety
Confusion, delirium
Depression
Respiratory | X
Cough, cold, infection
Rhinitis | | | | | | | X | X | X
Other | X | | X | X | X | | | X
Aberrant hematology | | | | | X
Fatigue, weakness | | | | | X
Fever, flu, pneumonia
Headache | X
Hepatic abnormality | | | | X
Muscle/joint disorder | | | X | X | X | S* | X | | X
Pain
Rash, skin disorder
Sleep disorder | X | | | | | | | X
Urinary disorder

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 41. Key characteristics: Nicergoline

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total# Randomized | # completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Hermann 1997 | NR | 6 | Placebo | DSM III | MID | Mild-Mod | 139 | 136 | 73.5y (55–85y) | 30 mg bid | 6m | BL-A | No
| | | Nicergoline | | | | | | 48%M | | | CGI
| | | | | | | | | | | | DSPT
| | | | | | | | | | | | DST
| | | | | | | | | | | | DTIC
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Laboratory Tests
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | WAIS
Nappi 1997 | IF | 6 | Placebo | DSM-III-R | P DD | Mild-Mod | 108 | 101 | 69.3y (55–81y) | 30 mg bid | 12m | CGI | No
| | | Nicergoline | | VaD | | | | 55%M | | | HAM-D
| | | | | Mixed | | | | | | | MMSE
| | | | | | | | | | | | Neurological
| | | | | | | | | | | | Exam
| | | | | | | | | | | | Physician Global
| | | | | | | | | | | | Impression
| | | | | | | | | | | | Patient Global
| | | | | | | | | | | | Impression
| | | | | | | | | | | | SCAG
Saletu 1995 | NR | 6 | Placebo | DSM-III-R | SDAT | Mild-Mod | 112 | 98 | Mean NR (>60y) | 30 mg bid | 8w | AAMD | SDAT vs MID
AUXILIARY | | | Nicergoline | | MID | | | | %M NR | | | CGI
Saletu 1997 | | | | | | | | | | | | CT Scan
| | | | | | | | | | | | EEG/ERG
| | | | | | | | | | | | Mapping
| | | | | | | | | | | | Ham-D
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | TESS-DOTES
Winblad 2001a | IF | 6 | Placebo | NINCDS | AD | Probable Mild-Mod | 346 | 285 | 73.7y (NR) | 30 mg bid | 6m | ADAS-cog | No
| | | Nicergoline | DSM-III-R | | | | | 38%M | | | ADAS-noncog
| | | | | | | | | | | | ADAS-Total
| | | | | | | | | | | | IADL
| | | | | | | | | | | | CGIC
| | | | | | | | | | | | CT/MRI
| | | | | | | | | | | | ECG
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSMS
DRUG VS DRUG
Schneider 1994 | NR | 5 | Nicergoline | DSM IV | AD | Mild-Mod | 62 | NR | 69.8y (65–85y) | 60 mg/d | 3m | SAS-G | No
| | | Antagonic Stress | ICD-10 | | | | | 53%M | | | SCAG
| | | | | | | | | | | | WAIS
| | | | | | | | | | | | WMS

Evidence Table 42. Study results: Nicergoline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 4m | | Final: (specify) 6m
Hermann 1997 | ITT Analysis
| 1] Placebo | [underlined: SCAG] | 1] 63.17(12.73) | | 1] 59.59(16.88) | 3] <0.0001 | 1] 57.48(17.16) | 3]<0.0001
| 2] Nicergoline 30 mg BID | | 2] 63.74(11.31) | | 2] 52.50(12.41) | | 2] 49.54(12.82)
| 3] change from baseline of differences between Placebo and Nicergoline | [underlined: MMSE] | 1] 20.28 (2.62) | | 1] 4.50 (1.07) | 3] <0.0001 | 1] 21.56 (3.81) | 3]<0.0001
| | | 2] 20.23 (2.06) | | 2] 3.69 (0.70) | | 2] 24.03 (3.06)
| | CGI (Item 2) | 1] 5.02 (0.22) | | 1] 22.31(10.19) | 3] 0.1292 | 1] 4.43 (1.18) | 3]<0.0001
| | | 2] 4.97 (0.18) | | 2] 24.17(10.21) | | 2] 3.46 (0.92)
| | WAIS-DST | 1] 19.73 (8.73) | | 1] 8.02 (1.57) | 3] .0004 | 1] 22.44 (9.91) | 3] 0.0602
| | | 2] 20.62 (7.93) | | 2] 8.93 (1.53) | | 2] 5.37(11.08)
| | WAIS-DSPT | 1] .67 (1.63) | | 1] 12.00 (4.78) | 3] 0.0328 | 1] 8.13 (1.66) | 3] 0.0042
| | | 2] 7.56 (1.64) | | 2] 13.66 (4.11) | | 2] 8.98 (1.86)
| | WAIS-DTIC | 1] 10.63 (4.58) | | 1] 10.41 (3.48) | 3] 0.0017 | 1] 12.15 (4.52) | 3] 0.0026
| | | 2] 11.33 (4.08) | | 2] 8.63 (3.54) | | 2] 14.57 (3.79)
| | Blessed-A scale | 1] 10.85 (3.32) | | | | 1] 9.94 (3.98) | 3] 0.0010
| | | 2] 10.69 (3.35) | | | | 2] 7.69 (3.75)

Evidence Table 43. Study results: Nicergoline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6m | | Final: (specify) 12m
Nappi 1997 | OC Analysis
| 1] Placebo | [underlined: SCAG] | 1] 49.14 (6.9) | | 1] 50.12 (7.8) | 3] <0.05 | 1] 53.72 (10.2) | 3] <0.001
| 2] Nicergoline 30 mg bid | Total Score | 2] 49.14 (9.2) | | 2] 45.53 (10.4) | | 2] 45.37 (11.7)
| 3] Nicergoline difference from placebo | [underlined: MMSE] | 1] 21.98 (2.6) | | 1] 20.35 (3.5) | 3] <0.05 | 1] 19.14 (3.8) | 3] <0.01
| | | 2] 21.25 (2.9) | | 2] 21.78 (4.0) | | 2] 21.27 (4.1)
| | Physician Global Impression (% improved) | | | | | 1] 10% | 3] <0.001
| | | | | | | 2] 53%
| | Patient-Global Impression (% improved) | | | | | 1] 8% | 3] <0.001
| | | | | | | 2] 64%

Evidence Table 44. Study results: Nicergoline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Saletu 1995 | OC Analysis
| 1] Placebo (SDAT) | CGI(Item 1) | 1] 4.29 (0.95) | | | | 1] 4.04 (0.95) | 5] <0.05
| 2] Nicergoline 30 mg bid (SDAT) | | 2] 4.33 (1.01) | | | | 2] 3.54 (0.88) | 6] <0.001
| 3] Placebo (MID) | | 3] 4.23 (1.03) | | | | 3] 4.00 (1.17) | 7] <0.03
| 4] Nicergoline 30 mg bid (MID) | | 4] 4.42 (1.02) | | | | 4] 3.83 (1.09) | 8] <0.001
| 5] Placebo change from baseline (SDAT) | | | | | | | 9] <0.025
| 6] Nicergoline change from baseline (SDAT) | | | | | | | 10] <0.05
| 7] Placebo change from baseline (MID) | CGI(Item 2) | | | | | 1] 3.75 (0.61) | 9] 0.001
| 8] Nicergoline change from baseline (MID) | | | | | | 2] 3.21 (0.78) | 10] 0.04
| 9] Placebo vs Nicergoline change from baseline (SDAT) | | | | | | 3] 3.81 (0.57)
| 10] Placebo vs Nicergoline change from baseline (MID) | | | | | | 4] 3.29 (0.62)
| | SCAG total | 1] 55.2 (13.4) | | | | 1] 51.5 (11.0) | 5] <0.05
| | | 2] 56.8 (15.5) | | | | 2] 46.6 (11.4) | 6] <0.01
| | | 3] 54.3 (13.8) | | | | 3] 50.1 (14.3) | 7] NS
| | | 4] 55.8 (16.1) | | | | 4] 49.1 (15.9) | 8] NS
| | | | | | | | 9] <0.01
| | | | | | | | 10] <0.05
| | MMSE | 1] 21.8 (4.8) | | | | 1] 24.0 (5.3) | 5] <0.01
| | | 2] 21.5 (3.1) | | | | 2] 25.7 (3.5) | 6] <0.01
| | | 3] 22.0 (3.4) | | | | 3] 22.9 (5.4) | 7] NS
| | | 4] 22.1 (3.0) | | | | 4] 25.8 (3.7) | 8] <0.01
| | | | | | | | 9] <0.01
| | | | | | | | 10] <0.01
| | HAM-D | | | | | | 9] NS
| | | | | | | | 10] NS
| | NOSIE | | | | | | 9] NS
| | | | | | | | 10] NS

Evidence Table 45. Study results: Nicergoline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 3m | | Final: (specify) 6m
Winblad, 2001a | ITT Analysis
| 1] Placebo | [underlined: CGIC Informant rated] | | | 1] 4.26 | | 1] 4.39 | 5] NS
| 2] Nicergoline 30mg bid | | | | 2] 4.08 | | 2] 4.32
| 3] Placebo change from baseline | CGIC Patient rated | | | 1] 4.07 | | 1] 4.16 | 5] NS
| 4] Nicergoline change from baseline | | | | 2] 3.91 | | 2] 4.09
| 5] Nicergoline change from Placebo | [underlined: ADAS-Cog] | | | | | 3] 1.38 (0.57)* | 3] <0.01
| | | | | | | 4]-0.17 (0.55)* | 4] NS
| | | | | | | 5] 1.55 | 5] <0.05
| | ADAS-Noncog | | | | | 3] 0.75 (0.26)* | 3] <0.01
| | | | | | | 4] 0.14 (0.26)* | 4] NS
| | | | | | | 5] 0.61 | 5] <0.1
| | ADAS-Total | | | | | 3] 1.93 (0.68)* | 3] NS
| | | | | | | 4]-0.08 (0.65)* | 4] <0.01
| | | | | | | 5] 2.01 | 5] <0.05
| | IADL | 1] 18.6 (6.6) | | | | 3] 1.47 (0.34) | 5] NS
| | | 2] 18.3 (6.9) | | | | 4] 1.13 (0.33)
| | PSMS | 1] 9.5 (3.8) | | | | 3] 1.07 (0.19) | 5] NS
| | | 2] 9.6 (3.5) | | | | 4] 0.84 (0.19)

* SEM

Evidence Table 46. Study results: Nicergoline - Antagonic Stress

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3m
Schneider 1994 | OC Analysis
| 1] Nicergoline 20 mg tid | SCAG | 1] 66.5 (11.5) | | | | 1] 50.5 (8.6) | 3] <0.001
| 2] Antagonic Stress 3 capsules tid | | 2] 71.2 (7.7) | | | | 2] 46.1 (6.5) | 4] <0.001
| 3] Nicergoline change from baseline | | | | | | | 5] 0.002 favours AS
| 4] Antagonic Stress change from baseline
| 5] Difference between Nicergoline and Antagonic Stress in change from baseline | SASG | 1] 65.8 (9.5) | | | | 1] 52.1 (9.4) | 3] <0.001
| | | 2] 68.4 (8.9) | | | | 2] 47.3 (6.5) | 4] <0.001
| | | | | | | | 5] 0.000 favours AS
| | WAIS Digit symbol | 1] 7.8 (1.2) | | | | 1] 9.6 (1.6) | 3] <0.001
| | | 2] 7.5 (1.6) | | | | 2] 11.5 (2.4) | 4] <0.001
| | | | | | | | 5] 0.000 favours AS

Evidence Table 47. Adverse Events: Nicergoline

Adverse events (AE) identified in included studies | Hermann, 1997 | Nappi, 1997 | Saletu, 1995 | Winblad, 2001a | NICERGOLINE ANTAGONIC STRESS Schneider, 1994
Withdrawn (%) due to AE | T: 1 | T: 0 | T: 2 | T: 9 | T: NR
| C: 3 | C: 0 | C: 2 | C: 8 | C: NR
AE Checklist (Max 5) | 2 | 4 | 5 | 3 | 0
None Reported | | | | | x
Balance
Accidental Injury
Dizziness | x | | x
Falls
Behavioral
Agitation | x | | | x
Cardiovascular | x
Arrhythmia | x | | x
Hypotension
Hypertension
Extrapyramidal | x
Tremor
Gastrointestinal | x | x | | x
Abdominal pain
Constipation | x | | x
Diarrhea | x | | x
Dyspepsia | x
Nausea, vomiting | x
Metabolic/nutritional | | | | x
Eating disorder | x
Weight Change | | | x
Neurological | | | | x
Asthenia
Psychiatric | | | | x
Anxiety | x
Confusion, delirium
Depression | x | | x
Respiratory
Cough, cold, infection | x
Rhinitis | x | | x
Other | x | x | x
Aberrant hematology
Fatigue, weakness | x
Fever, flu, pneumonia | x
Headache | x | x | x | x
Hepatic abnormality
Muscle/joint disorder | x
Pain | x
Rash, skin disorder | x | | x
Sleep disorder | x | | x | x
Urinary disorder | | | | x

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 48. Key characteristics: Physostigmine

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Moller 1999 | NR | 6 | Placebo | DSM-III-R | AD | Mild-Mod | 181 | 143 | 69.3y (50–85y) | 30 and 60 mg patch | 24w | ADAS | No
| | | Physostigmine | NINCDS | | | | | 48%M | | | CGIC
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSGER
Thal 1996b | IS | 6 | Placebo | NINCDS | AD | Probable | 366 | 333 | 68.6y (47–87y) | Titration: 9, 12, 15 mg bid, increased weekly | 6w | ADAS-Cog | No
| PI | | Physostigmine | | | Physostigmine | | | 51%M | | | CGI-C
| | | | | | | | | 97% White | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSMS
Thal 1999 | IF | 5 | Placebo | NINCDS | AD | Probable | 475 | 210 | 73.4y range 51–92 | 2w washout | 24w | ADAS-Cog | No
| | | Physostigmine | | | | | | 39.8% M | Titration: 9mg bid, 12mg bid, 15mg bid | | GERRI
| | | | | | | | | 91% White | 24w drug in increased every 3w | | IADL
| | | | | | | | | 80% High School Grads | week 9 to 24 30mg/d or 36mg/d | | CIBIC+
| | | | | | | | | Community | | | CGIC
VanDyck 2000 | IF | 7 | Placebo | NINCDS | AD | Probable Mild-Mod | 176 | 148 | 71.5y (44–88y) | 30 mg/d (15 mg bid) | 12w | ADAS-Cog | No
| | | Physostigmine | | | | | | 63%M | | | CIBIC+
| | | | | | | | | 95 % White | | | CIBIC
| | | | | | | | | 4 %Black | | | CGIC
| | | | | | | | | 1% Hispanic | | | IADL
| | | | | | | | | | | | MMSE

Evidence Table 49. Study results: Physostigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Moller, 1999 | OC Analysis
| 1] Placebo | ADAS-Cog | 1] 28.5 | | | | 1] 27.1
| 2] Physostigmine 30 mg patch | | 2] 29.8 | | | | 2] 31.4
| 3] Physostigmine 60 mg patch | | 3] 30.8 | | | | 3] 31.3
| 4] Treatment vs Placebo from baseline | ADAS-Noncog | 1] 7.7 | | | | 1] 6.6
| | | 2] 7.5 | | | | 2] 7.0
| | | 3] 6.9 | | | | 3] 6.5
| | ADAS-Total | 1] 36.2 | | | | 1] 33.7
| | | 2] 37.3 | | | | 2] 38.4
| | | 3] 37.6 | | | | 3] 37.9
| | NOSGER | 1] 68.8 | | | | 1] 68.8
| | | 2] 67.5 | | | | 2] 72.0
| | | 3] 66.6 | | | | 3] 38.8
| | CGIC % improved | | | | | 1] 47% | 4] NS
| | | | | | | 2] 36%
| | | | | | | 3] 21%

Evidence Table 50. Study results: Physostigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Thal 1996b | ITT Analysis
| 1] Placebo difference from baseline | [underlined: ADAS-Cog] | | | | | 1] 0.63 | 3] 0.003
| 2] Physostigmine 15 mg best dose difference from baseline | | | | | | 2] -1.12
| 3] Difference between change from baseline between placebo and Physostigmine | [underlined: CGIC] | | | | | 1] -0.04 | 3] 0.0120
| | | | | | | 2] 0.22
| | MMSE | | | | | 1] -0.60 | 3] 0.132
| | | | | | | 2] 0.05
| | PSMS | | | | | 1] 0.14 | 3] 0.383
| | | | | | | 2] 0.33
| | IADL | | | | | 1] 4.13 | 3] 0.101
| | | | | | | 2] 1.67

Evidence Table 51. Study results: Physostigmine

Author Year | Analysis Groups | Outcomes Measured | Results Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24 w
Thal 1999 | ITT Analysis (LOCF)
| 1] Placebo | [underlined: ADAS-cog] | | | | | 2] -2.9 | 2] 0.002
| 2] Physostigmine Controlled-release 15mg bid DIFFERENCE FROM PLACEBO | | | | | | 3] -2.9 | 3] 0.001
| 3] Physostigmine Controlled-release 18mg bid DIFFERENCE FROM PLACEBO | [underlined: CIBIC+] | | | | | 2] 0.31 | 2] 0.019
| | | | | | | 3] 0.26 | 3] 0.042
| | CGIC | | | | | 2] 0.16 | 2] NS
| | | | | | | 3] 0.24 | 3] NS
| | GERRI | | | | | 2] -0.07 | 2] NS
| | | | | | | 3] -0.03 | 3] NS
| | IADL | | | | | 2] -3.85 | 2] NS
| | | | | | | 3] -0.10 | 3] NS

Evidence Table 52. Study results: Physostigmine

Author Year | Analysis Groups | Outcomes Measured | Results Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Van Dyck 2000 | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-Cog] | | | | | 1] 1.06 (5.17) | 3] 0.01
| 2] Physostigmine 12 or 15 mg BID change from baseline | | | | | | 2] -0.96 (5.22)
| 3] difference between Placebo and Physostigmine in change from baseline | [underlined: CIBIC+] | | | | | 1] -0.33 (0.82) | 3] 0.02
| | | | | | | 2] 0.00 (0.88)
| | [underlined: CGIC] | | | | | 1] -0.30 (0.84) | 3] 0.17
| | | | | | | 2] -0.12 (0.87)
| | MMSE | | | | | 1] -0.87 (3.20) | 3] 0.22
| | | | | | | 2] -0.25 (2.98)
| | IADL | | | | | 1] 3.51 (12.54) | 3] 0.25
| | | | | | | 2] 1.28 (12.48)

Evidence Table 53. Adverse Events: Physostigmine

Adverse events (AE) identified in included studies | Moller, 1999 | Thal, 1999b | Thal, 1999 | Van Dyck, 2000
Withdrawn (%) due to AE | T: 12 | T: 16 | T: 55 | T: NR
| C: 1 | C: 5 | C: 5 | C: NR
AE Checklist (Max 5) | 1 | 2 | 2 | 2
None Reported
Balance | | | | X
Accidental Injury | | | X | X
Dizziness | | X | | S
Falls
Behavioral
Agitation | | | X | X
Cardiovascular
Arrhythmia
Hypotension
Hypertension
Extrapyramidal
Tremor | X | X | | S
Gastrointestinal | X | | X | X
Abdominal pain | X | X | X | X
Constipation
Diarrhea | | X | X | X
Dyspepsia | | | X | X
Nausea, vomiting | X | X | X | X
Metabolic/nutritional | | X
Eating disorder | | X | X | X
Weight Change | | | | S
Neurological
Asthenia | | X | X | S
Psychiatric
Anxiety | | | | X
Confusion, delirium | | | | S
Depression
Respiratory | | | | S
Cough, cold, infection
Rhinitis
Other | X | X | X | S
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia
Headache | X | X | | X
Hepatic abnormality
Muscle/joint disorder | | | | X
Pain | | | | X
Rash, skin disorder | X
Sleep disorder | | | X | X
Urinary disorder

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

X = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 54. Key characteristics: Posatirelin

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Ferrari 1998 | NR | 5 | Placebo | DSM-III- R | AD | Probable | 213 | 172 | 78.8y (≥65y) | 10 mg/d | 3m | GBS | AD vs Vad
| | | Posatirelin | ICD-10 | PDD | | | | 42%M | | | GDS
| | | | NINCDS | VaD | | | | | | | HDRS
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | RMT
Gasbarrini 1997 | NR | 6 | Placebo | NINCDS | AD | Probable | 360 | 357 | 77.6y (≥60y) | 10mg/d | 3m | GBS | No
| | | Posatirelin | NINDS-AIREN | VaD | Mild-Mod | | | 38%M | | | Laboratory tests
| | | | | | | | | | | | Rey Memory Test
Parnetti 1996 | PI | 7 | Placebo | NINDS-AIREN | VaD | Probable | 136 | 105 | 69.4y (60–75y) | 10 mg ml/d | 12w | GBS | No
| | | Posatirelin | | | | | | 66%M comorbity: hypertension | | | Laboratory tests
| | | | | | | | | | | | RMT
| | | | | | | | | | | | TPAT
Parnetti 1995 | NR | 6 | Placebo | NINCDS | AD | Probable | 222 | 214 | 74.9y (65–85y) | 10 mg/d | 3m | GBS | No
| | | Posatirelin | | | Mild-Mod | | | 34%M | 500 mg/d | | GDS
| | | Citicoline | | | | | | | | | HDRS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Laboratory tests

Evidence Table 55. Study results: Posatirelin

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3m
Ferrari, 1998 | ITT population (LOCF)
| 1] Placebo change from baseline (ALL) | [underlined: GBS] Rating Scale | | | | | 1] 1.1 (2.0)* | 3]<0.001
| 2] Posatirelin 10mg/ml IM change from baseline (ALL) | Total score | | | | | 2] -9.2 (3.4)*
| 3] Posatirelin vs. Placebo change from baseline | | | | | | 4] 0.3 (3.2)
| 4] Placebo change from baseline (AD) | | | | | | 5] -2.2 (3.6)
| 5] Posatirelin 10mg/ml IM change from baseline (AD) | [underlined: GBS] Rating Scale motor function | | | | 7] 1.5 (2.5) | 1] 0.9 (0.5)* | 3] 0.010
| 6] Posatirelin Placebo change from baseline (AD) | | | | | 8] -17.4 (5.8) | 2] -1.5 (0.7)*
| 7] Placebo change from baseline (VaD) | | | | | | 4] -0.4 (1.6)
| 8] Posatirelin 10 mg/ml IM change from baseline (VaD) | | | | | | 5] -0.6 (0.9)
| 9] Posatirelin vs. Placebo change from baseline (VaD) | [underlined: GBS] Rating Scale intellectual | | | | 7] -0.4 (1.2) | 1] -0.4 (0.9)* | 3] 0.005
| | | | | | 8] -8.8 (3.1) | 2] -4.5 (1.8)*
| | | | | | | 4] -0.4 (1.6)
| | | | | | | 5] -0.9 (1.9)
| | [underlined: GBS] Rating Scale emotional | | | | 7] -0.4 (1.2) | 1] -0.04 (0.3)* | 3] 0.078
| | | | | | 8] -8.8 (3.1) | 2] -0.7 (0.4)*
| | | | | | | 4] 0.0 (0.4)
| | | | | | | 5] -0.03 (0.4)
| | | | | | | 7] -0.1 (0.4)
| | | | | | | 8] -1.6 (0.7)

* SEM

Evidence Table 56. Study results: Posatirelin

Author Year | Outcome Measures | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 45d | | Final: (specify) 90d
Gasbarrini 1997 | ITT Population
| 1] Placebo | [underlined: GBS motor impairment] | 1] 12.2(7.7) | | 1] 11.8(7.3) | | 1] 11.9(7.6) | 3] <0.001
| 2] Posatirelin 10mg/d IM | | 2] 12.1(7.7) | | 2] 11.1(7.4) | | 2] 10.5(7.6)
| 3] difference between Placebo and Posatirelin from baseline | [underlined: GBS intellectual impairment] | 1] 25.9(10.7) | | 1] 25(10.7) | | 1] 24.5(11.4) | 3] <0.001
| | | 2] 25.7(10.7) | | 2] 23.6(10.2) | | 2] 21.9(10.7)
| | [underlined: GBS emotional impairment] | 1] 7.4(3.6) | | 1] 7.1(3.6) | | 1] 6.9(3.8) | 3] <0.001
| | | 2] 7.4(3.6) | | 2] 6.6(3.4) | | 2] 6.1(3.5)
| | GBS Factor I | 1] 11.6 (5.1) | | 1] 11.3 (5.2) | | 1] 11.2 (5.6) | 3] <0.001
| | | 2] 11.6 (5.0) | | 2] 10.7 (4.6) | | 2] 9.9 (4.9)
| | GBS Factor II | 1] 12.2 (7.7) | | 1] 11.8 (7.3) | | 1] 11.9 (7.6) | 3] <0.001
| | | 2] 12.1 (7.7) | | 2] 11.1 (7.4) | | 2] 10.5 (7.6)
| | GBS Factor III | 1] 6.1 (3.2) | | 1] 6.1 (3.2) | | 1] 5.9 (3.2) | 3] <0.001
| | | 2] 6.4 (3.2) | | 2] 5.8 (3.3) | | 2] 5.4 (3.3)
| | GBS Factor IV | 1] 19.3 (8.3) | | 1] 18.6 (8.4) | | 1] 18.1 (8.9) | 3] <0.001
| | | 2] 19.4 (8.3) | | 2] 17.5 (8.3) | | 2] 16.2 (8.6)

Evidence Table 57. Study results: Posatirelin

Author Year | Analysis Groups | Outcome Measures | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 45d | | Final: (specify) 90d
Parnetti, 1996 | OC Population
| 1] Placebo | GBS-ADL | 1] 7.8 (5.1) | | 1] 8.0 (5.2) | | 1] 7.9 (5.0) | 3] 0.001
| 2] Posatirelin 10mg/ml | | 2] 8.5 (5.1) | | 2] 7.5 ( 5.8) | | 2] 7.0 (5.1)
| 3] Posatirelin 10mg/ml vs Placebo change from baseline | GBS Emotional Impairment | 1] 6.1 (2.3) | | 1] 5.9 ( 2.4) | | 1] 5.7 (2.6) | 3] 0.066
| | | 2] 5.6 (2.4) | | 2] 4.8 ( 2.3) | | 2] 4.3 (2.1)
| | GBS Motor impairment | 1] 7.9 (5.1) | | 1] 8.0 (5.2) | | 1] 7.9 (5.0) | 3] 0.001
| | | 2] 8.5 (5.1) | | 2] 7.5 (4.8) | | 2] 7.1 (5.1)
| | GBS Intellectual impairment | 1] 19.8 (8.9) | | 1] 19.9 (9.3) | | 1] 20.4 (9.6) | 3]<0.001
| | | 2] 20.3 (8.8) | | 2] 16.1 (7.2) | | 2] 14.7 (7.5)
| | TP Global | 1] 0.6 (0.4) | | 1] 0.7 (0.4) | | 1] 0.6 (0.4) | 3] 0.076
| | | 2] 0.7 (0.4) | | 2] 0.8 (0.5) | | 2] 0.9 (0.5)
| | Randt acquisition | 1] 65.1 (13.0) | | 1] 63.4 (2.3) | | 1] 63.1 (12.9) | 3] <0.001
| | | 2] 64.2 (10.0) | | 2] 69.0 (10.1) | | 2] 70.3 (11.2)
| | Randt recall | 1] 64.8 (23.7) | | 1] 61.4 (24.3) | | 1] 63.0 (26.9) | 3] 0.058
| | | 2] 66.7 (25.5) | | 2] 67.5 (23.1) | | 2] 72.2 (26.8)
| | Randt memory | 1] 60.8 (20.8) | | 1] 57.0 (18.9) | | 1] 57.7 (21.4) | 3] <0.001
| | | 2] 60.5 (18.8) | | 2] 63.5 (16.0) | | 2] 67.1 (19.0)

Evidence Table 58. Study results: Citicoline - Posatirelin

Author Year | Analysis Groups | Outcome s Measures | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 45 d | | Final: (specify) 90 d
Parnetti 1995 | OC Population
| 1] Placebo (Ascorbic Acid 100 mg/d) | [underlined: GBS] Emotional impairment | 1] 1.9 (1.0) | | 1] 1.8 (1.0) | | 1] 1.9 (1.0) | 4] NS
| 2] Citicoline 500 mg/d | | 2] 1.9 (1.0) | | 2] 1.9 (1.1) | | 2] 1.7 (1.0) | 5] NS
| 3] Posatirelin 10 mg/d | | 3] 1.9 (1.2) | | 3] 1.7 (1.0) | | 3] 1.6 (0.9) | 6] <0.025
| 4] Ascorbic Acid change from baseline | [underlined: GBS] Impaired orientation & memory | 1] 2.2 (0.9) | | 1] 2.1 (1.0) | | 1] 2.1 (1.1) | 4] NS
| 5] Citicoline change from baseline | | 2] 2.2 (1.0) | | 2] 2.1 (1.0) | | 2] 2.1 (1.0) | 5] NS
| 6] Posatirelin change from baseline | | 3] 2.1 (1.0) | | 3] 2.0 (1.0) | | 3} 1.8 (1.0) | 6] NS
| 7] Posatirelin vs Citicoline change from baseline | | | | | | | 7] 0.038 favors Posatirelin
| | [underlined: GBS] Impaired ability ADL | 1] 1.2 (0.8) | | 1] 1.3 (0.8) | | 1] 1.3 (0.9) | 4] NS
| | | 2] 1.4 (1.1) | | 2] 1.3 (1.0) | | 2] 1.4 (1.0) | 5] NS
| | | 3} 1.2 (1.0) | | 3] 1.1 (1.0) | | 3] 1.1 (1.0) | 6] <0.025
| | [underlined: GBS] Depression / Anxiety | 1] 1.5 (0.9) | | 1] 1.5 (0.9) | | 1] 1.4 (0.9) | 4] NS
| | | 2] 1.5 (0.8) | | 2] 1.5 (0.9) | | 2] 1.4 (0.9) | 5] NS
| | | 3] 1.6 (1.1) | | 3] 1.5 (1.0) | | 3] 1.4 (0.9) | 6] NS
| | | | | | | | 7] 0.031 favors Posatirelin
| | [underlined: GBS] Impaired attention & motivation | 1] 2.2 (0.9) | | 1] 2.1 (0.9) | | 1] 2.1 (1.0) | 4] NS
| | | 2] 2.1 (1.0) | | 2] 2.0 (1.0) | | 2] 1.9 (1.0) | 5] NS
| | | 3] 2.1 (1.1) | | 3] 1.9 (0.9) | | 3] 1.8 (0.8) | 6] <0.025
| | [underlined: GBS] Intellectual impairment | 1] 2.2 (0.8) | | 1] 2.1 (0.9) | | 1] 2.1 (1.0) | 5] <0.025
| | | 2] 2.1 (0.9) | | 2] 2.0 (0.9) | | 2] 2.0 (0.9) | 7] 0.037 favors Posatirelin
| | | 3] 2.0 (0.9) | | 3] 1.9 (0.9) | | 3] 1.8 (0.8)
| | [underlined: GBS] Motor impairment | 1] 1.2 (0.8) | | 1] 1.3 (0.8) | | 1] 1.3 (0,9) | 5] <0.025
| | | 2] 1.4 (1.1) | | 2] 1.3 (1.0) | | 2] 1.4 (1.0)
| | | | | 3] 1.1 (1.0) | | 3] 1.1 (1.0)
| | MMSE | 1] 16.4 (2.7) | | | | 1] 17.1 (4.1) | 4] NS
| | | 2] 16.5 (2.6) | | | | 2] 17.6 (3.9) | 5] NS
| | | 3] 16.6 (2.5) | | | | 3] 17.8 (3.4) | 6] NS
| | HDRS | 1] 13.0 (5.0) | | | | 1] 11.4 (4.9) | 4] NS
| | | 2] 11.4 (4.9) | | | | 2] 11.3 (5.2) | 5] NS
| | | 3] 12.6 (5.0) | | | | 3] 11.1 (5.3) | 6] NS

Evidence Table 59. Adverse Events: Posatirelin

Adverse events (AE) identified in included studies | Ferrari, 1998 | Gasbarrini, 1997 | Parnetti, 1995 | Parnetti, 1996
Withdrawn (%) due to AE | T: 4 | T: 3 | T: 0 | T: NR
| C: 3 | C: 1 | C: 0 | C: NR
AE Checklist (Max 5) | 3 | 4 | 4 | 2
None Reported
Balance | X
Accidental Injury
Dizziness | X | X
Falls
Behavioral
Agitation | X | X | X | X
Cardiovascular
Arrhythmia | X | | X | X
Hypotension
Hypertension | | X
Extrapyramidal
Tremor | | | X | X
Gastrointestinal | | | | X
Abdominal pain | X
Constipation
Diarrhea | | X
Dyspepsia | | | X
Nausea, vomiting | X | X | | X
Metabolic/nutritional | | X
Eating disorder
Weight Change
Neurological
Asthenia | | | | X
Psychiatric
Anxiety
Confusion, delirium | | | X
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other | | X | X | X
Aberrant hematology | | X
Fatigue, weakness
Fever, flu, pneumonia
Headache | X | X | X
Hepatic abnormality
Muscle/joint disorder | | X
Pain
Rash, skin disorder | X | X | X
Sleep disorder | X | | X | X
Urinary disorder | | X | X

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

X = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 60. Key characteristics: Rivastigmine

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Agid 1998 | IF | 7 | Placebo | DSM-III-R | Dementia | Mild-Mod | 386 | 357 | 69.4y (50–90y) | Titration: 3 w | 15w | Benton Visual | No
| | | Rivastigmine | NINCDS | AD | Probable | | | 44%M | Then 4 or 6 mg/d | | Retention
| | | | | | | | | | | | CGIC
| | | | | | | | | | | | Digit Symbol
| | | | | | | | | | | | Substitution
| | | | | | | | | | | | ECG
| | | | | | | | | | | | Fuld Object-Memory
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSGER
| | | | | | | | | | | | Trail Making
Corey-Bloom 1998 | IF | 8 | Placebo | DSM-IV | AD | Mild-Modly | 699 | 545 | 74.5y (45–89y) | Titration: w 1–7; | 26w | ADAS-Cog | Vascular Risk (HIS)
Auxiliary: | | | Rivastigmine | NINCDS | | Sev | | | 39%M | Then dose range: 1 –6 mg/d | | CIBIC+
Farlow 2001 | | | | | | | | | 93% of patients were taking medications for other conditions: | | | GDS
Farlow 2000 | | | | | | | | | cardiovascular (43%), gastro (59%) analgesics (56%) 95% White | | | MMSE
Kumar 2000 | | | | | | | | | | | | PDS
Del Ser 2000
Doraiswamy 2002
Forette 1999 | IF | 6 | Placebo | NINCDS | DAT | Mild-Mod | 114 | 85 | 70.6y (NR) | Titration: 2 mg/d, 3 mg/d at d 4, increment of 0.5 mg q4d until d 28 and increment of 1 mg qw 12 mg/d | 18w | ADAS-cog | No
| | | Rivastigmine | DSM-III-R | | | | | %M NR | | | CIBIC+
| | | | | | | | | | | | Digit span test
| | | | | | | | | | | | ECG
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | NOSGER
| | | | | | | | | | | | Wechsler logical memory test
McKeith 2000 | IF | 8 | Placebo | Consensus | Lewy-body | Mild-Mod | 120 | 92 | 73.9y (57–87y) | Titration: 1.5 mg bid for 2 w up to 6 mg bid | 20w | CGC-plus | No
| | | Rivastigmine | Criteria | Dementia | | | | 56%M | | | ECG
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NPI
| | | | | | | | | | | | NPI-10
| | | | | | | | | | | | NPI-4
| | | | | | | | | | | | UPDRS
Potkin 2001 | PI | 5 | Placebo | DSM IV | AD | Mild-Modly | 27 | 27 | 75.9y (64–89y) | Titration over a period of 12 w then 3, 6, or 9 mg/d | 26w | CIBIC+ | No
| | | Rivastigmine | NINCDS | | Sev | | | %M NR | | | FDG-PET scan
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | MRI
| | | | | | | | | | | | Snodgross Picture
| | | | | | | | | | | | Naming Task
Rosler 1999 | IF | 8 | Placebo | DSM IV | AD | Mild-Modly | 725 | 581 | 72y (45–95y) | Titration on w 1 to 12 with increments of 1.5 mg/d4 mg/d 12 mg/d | 14w | ADAS-Cog | No
AUXILIARY | | | Rivastigmine | NINCDS | | Sev | | | 41%M | | | CIBIC
Rosler 2001 | | | | | | | | | Community.Comorbidity: diabetes, hypertension, arthritis | | | CIBIC
Farlow 2000 | | | | | | | | | | | | Progressive Deterioration scale
Rosler 1998 | | | | | | | | | | | | Global Deterioration scale
Doraiswamy 2002 | | | | | | | | | | | | MMSE

Evidence Table 61. Study results: Rivastigmine

REF ID# | Author Year | Analysis Groups | Test used | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) 7w | | Final: (specify) 13w
| AGID 1998 | Observed Cases
| | 1] Placebo | CGIC Successful outcome | | | | | 1] 29.91% | 5] <0.05
| | 2] Rivastigmine 4 mg BID | | | | | | 2] 31.53%
| | 3] Rivastigmine 6 mg BID | | | | | | 3] 42.72%
| | 4] Rivastigmine 4 mg bid versus Placebo change from baseline | Digit Symbol Substitution | | | 6] 0.1(7.4) | 5] <0.005 | 6] 0.5(6.9) | 4] NS
| | 5] Rivastigmine 6 mg bid versus Placebo change from baseline | | | | 7] 2.1(5.8) | | 7] 1.7(5.1) | 5] <0.05
| | 6] Placebo change from baseline | | | | 8] 2.0(5.4) | | 8] 2.8(8.1)
| | 7] Rivastigmine 4 mg bid change from baseline | MMSE | | | | | 6] 0.0(2.6)
| | 8] Rivastigmine 6 mg bid change from baseline | | | | | | 7] 0.0(3.3)
| | | | | | | | 8] 0.3(3.1)
| | | Trail Making | | | 6] -0.6(31.2) | | 6] 0.5(28.7)
| | | | | | 7] -4.3(36.9) | | 7] -1.6(39.0)
| | | | | | 8] -5.4(45.3) | | 8] -7.3(48.9)
| | | NOSGER | | | | | 6] -0.2 (3.3) | 4] NS
| | | IADL | | | | | 7] 0.0 (3.3) | 5] NS
| | | | | | | | 8] -0.7 (3.5)
| | | NOSGER | | | | | | 4] NS
| | | Mood, memory, self-care, social behavior, disturbing behavior | | | | | | 5] NS
| | | FULD Object-Memory Evaluation (TS) | | | 6] 0.0 (6.2) | 4] <0.01 | 6] -0.9(5.5) | 4] <0.05
| | | | | | 7] 2.2 (7.3) | 5] <0.05 | 7] -0.4 (6.2) | 5] <0.05
| | | | | | 8] 2.0 (6.6) | | 8] 0.7 (6.2)
| | | FULD Object- Memory Evaluation (TR) | | | 6] 0.5 (4.6) | 4] <0.05 | 6] 0.1 (4.3) | 4] NS
| | | | | | 7] 1.7 (5.3) | 5] <0.05 | 7] 0.8 (4.6) | 5] <0.05
| | | | | | 8] 2.4 (4.8) | | 8] 1.1 (4.2)

Evidence Table 62. Study results: Rivastigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 26w
Corey-Bloom 1998 | ITT Analysis
Farlow 2001 | 1] Placebo | [underlined: ADAS-Cog] | 1] 21.7 | | | | 4] -4.09 | 8] <0.001
Farlow 2000 | 2] Rivastigmine 1–4 mg/ d | | 2] 22.4 | | | | 5] -2.36
Kumar 2000 | 3] Rivastigmine 6–12 mg/ d | | 3] 22.3 | | | | 6] -0.31
Delser 2000 | 4] Placebo change from baseline | [underlined: CIBIC+] | | | | | 4) 0.49 | 8] < 0.01
Dorais-warny 2002 | 5] Rivastigmine low dose change from baseline | | | | | | 5) 0.23
| 6] Rivastigmine high dose change from baseline | | | | | | 6) 0.20
| 7] Placebo vs Rivastigmine low dose | [underlined: PDS] | | | | | 4] -4.90 | 8] < 0.001
| 8] Placebo vs Rivastigmine high dose | | | | | | 5] -5.19
| 9] Difference among groups | | | | | | 6] -1.52
| | [underlined: GDS] | 1] 3.9 | | | | 4] -0.32 | 7] <0.05
| | | 2] 4.0 | | | | 5] -0.16 | 8] < 0.030
| | | 3] 4.0 | | | | 6] -0.13
| | MMSE | 1] 20 | 9] 0.481 | | | 4] -7.9 | 8]< 0.05
| | | 2] 19.5 | | | | 5] -0.35
| | | 3] 19.6 | | | | 6] 0.30

Evidence Table 63. Study results: Rivastigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 18 w
Forette 1999 | Completers Analysis
| 1] Placebo | ADAS-Cog | 1] 21.7 (8) | | | | 4] 2 | 7] 0.054
| 2] Rivastigmine 12 mg d variable bid | | 2] 24.1 (11.6) | | | | 5] -2.75
| 3] Rivastigmine 12 mg d varibale tid | | 3] 23.2 (8.5) | | | | 6] 0.25
| 4] Placebo mean change from baseline | NOSGER | | | | | 4] -0.3 (2.5) | 8] NS
| 5] Rivastigmine bid mean change from baseline | Self-care | | | | | 5] -0.4 (2.0)
| 6] Rivastigmine tid mean change from baseline | | | | | | 6} -0.6 (2.4)
| 7] Rivastigmine bid vs. placebo | NOSGER | | | | | 4] 0.1 (3.1) | 8] NS
| 8] Rivastigmine bid & tid vs. placebo | Disturbing behaviour | | | | | 5] -0.3 (2.1)
| | | | | | | 6] -0.7 (3.4)
| | NOSGER | | | | | 4] 0.8 (4.0) | 8] NS
| | IADL | | | | | 5] 0.4 (3.1)
| | | | | | | 6] -0.7 (4.0)
| | NOSGER | | | | | 4] 1.3 (3.7) | 5] 0.037
| | Memory | | | | | 5] -0.7 (2.9) | 6] 0.014
| | | | | | | 6] -1.0 (2.7) | 8] 0.032
| | NOSGER | | | | | 4] -0.6 (3.2) | 8] NS
| | Mood | | | | | 5] 0.7 (3.0)
| | | | | | | 6] -0.4 (3.4)
| | NOSGER | | | | | 4] 0.3 (3.3) | 8] NS
| | Social behaviour | | | | | 5] 0.0 (2.6)
| | | | | | | 6] -1.1 (3.8)
| | CIBIC+ Improved | | | | | 1] 16% | 7] 0.027
| | | | | | | 2] 57%
| | | | | | | 3] 36%
| | Wechsler logical memory test | | | | | 5] 1.8 (2.3) | 8] 0.012 immediate recall only
| | | | | | | 6] 0.1 (2.3)

Evidence Table 64. Study results: Rivastigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 20w
McKeith 2000 | ITT Analysis
| 1] Placebo | [underlined: NPI-4] | 1] 11.7 (8.6) | | | | 3] 0.8 (7.3) | 5] 0.088
| 2] Rivastigmine 12 mg d | | 2] 12.2 (8.2) | | | | 4] 2.5 (8.4) | CI (-1.1 – 4.6)
| 3] Placebo mean change from baseline | [underlined: NPI-10] | | | | | 3] 1.2 (10.7) | 5] 0.048
| 4] Rivastigmine mean change from baseline | | | | | | 4] 5.0 (16.2) | CI (-1.6 – 9.2)
| 5] Rivastigmine versus placebo change from baseline | [underlined: CCASSS] | | | | 5] 0.01 | | 5] 0.048
| | CGC+ | | | | | | 5] NS
| | MMSE | 1] 17.8 (4.4) | | | | | 5] NS
| | | 2] 17.9 (4.7)

Evidence Table 65. Study results: Rivastigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 26 w
Potkin 2000 | OC Population
| 1] Placebo | Snodgrass Picture Naming Task | | | | | | 3] NS
| 2] Rivastigmine 9 mg/ d | CIBIC+ Ratio stabilized | | | | | 1] 2/7 | 3] <0.03*
| 3] Placebo vs. Rivastigmine | | | | | | 2] 15/20
| 4] Rivastigmine metabolism change from baseline

* Tested the difference between the placebo and treatment group that had deteriorated (CIBIC+ score 5–7) only

Evidence Table 66. Study results: Rivastigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 18w | | Final: (specify) 26w
Rosler 1999 | ITT Analysis
Rosler 2001 | 1] Placebo | ADAS-Cog | 1] 23.4 | | | | 4] - 1.34 | 7] > 0.05
Farlow 2000 | 2] Rivastigmine 1–4 mg/ d | | 2] 23.9 | | | | 5] - 1.37 | 8] > 0.011
Rosler 1998 | 3] Rivastigmine 6–12 mg/ d | | 3] 23.6 | | | | 6] 0.26
Dorais-wamy 2002 | 4] Placebo change from baseline | ADAS COG | | | | | 1] 16% | 7] >0.05
| 5] Rivastigmine low dose change from baseline | >4 point improvement | | | | | 2] 15% | 8] <0.1
| 6] Rivastigmine high dose change from baseline | | | | | | 3] 24%
| 7] Placebo vs Rivastigmine low dose | CIBIC | | | | | 4] 4.38 | 7] > 0.05
| 8] Placebo versus Rivastigmine high dose | | | | | | 5] 4.24 | 8] < 0.001
| | | | | | | 6] 3.91
| | CIBIC+ | | | 4] 4.09 | | 4] 4.34 | 8] <0.05
| | | | | 5] 4.06 | | 5] 4.20
| | | | | 6] 3.85 | | 6] 3.93
| | PDS | 1] 54.1 | | | | 4] -2.18 | 7] > 0.05
| | | 2] 53.8 | | | | 5] -3.37 | 8] < 0.07
| | | 3] 55.2 | | | | 6] 0.05
| | GDS | | | | | 4] -0.26 | 8] < 0.05
| | | | | | | 5] -0.22
| | | | | | | 6] -0.06
| | MMSE | | | | | 4] -0.47 | 8] < 0.05
| | | | | | | 5] -0.62
| | | | | | | 6] 0.21

Evidence Table 67. Adverse Events: Rivastigmine

Adverse events (AE) identified in inclufed studies | Agid, 1998 | Corey-Bloom, 1998 | Forette, 1999 | McKeith, 2000 | Potkin, 2001 | Rosler, 1999
Withdrawn (%) due to AE | T: 11 | T:18^+^ | T:27 | T: 12 | T:NR | T: 15^+^
| C: 4 | C: 7 | C: 4 | C: 11 | C: NR | C: 7
AE Checklist (Max 5) | 4 | 3 | 5 | 4 | 2 | 2
None Reported | | | | | X
Balance
Accidental Injury
Dizziness | X | S* | X | | | X
Falls
Behavioral
Agitation | | | | X
Cardiovascular | | | NS | NS
Arrhythmia
Hypotension
Hypertension | | S*
Extrapyramidal
Tremor
Gastrointestinal | | S*
Abdominal pain | X | | X | | | X
Constipation
Diarrhea | X | | | | | X
Dyspepsia | | S*
Nausea, vomiting | X | S* | X | S | | S*
Metabolic/nutritional
Eating disorder | | S* | X | S | | X
Weight Change | | S* | X | X
Neurological | | S* | X
Asthenia | | S*
Psychiatric
Anxiety
Confusion, delirium
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other | | S* | X | | | X
Aberrant hematology | NS* | | NS | NS
Fatigue, weakness | | S* | | | | X
Fever, flu, pneumonia
Headache | X | | X | | | X
Hepatic abnormality | NS*
Muscle/joint disorder
Pain
Rash, skin disorder
Sleep disorder | | S* | | S
Urinary disorder

NR= Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x= Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS*= Reported and tested for statistical differences between two (three) treatment groups

[ ]= Symptom NOT reported in the paper

Evidence Table 68. Key characteristics: Tacrine

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | #Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Allain 1999 | NR | 7 | Tacrine + | NINCDS | AD | Mild-Mod | 222 | 194 | 74.2y (NR) | 420 mg/d | 15w | MMSE | No
| | | Placebo | DSM-III-R | | | | | 39%M | | | SKT
| | | Tacrine + | | | | | | Community
| | | Silymarin | | | | | | All subjects + Tacrine
Gutzmann 2002 | PI | 7 | Idebenone | NINCDS | AD | Mild-Mod | 203 | 44 | 71.2y (44–90y) | 360 mg/d | 60w | ADAS-Cog | No
| | | Tacrine | DSM-III-R | PDD | | | | 36%M | 160 mg/d | | ADAS-Noncog
| | | | | | | | | 100% White | | | ADAS-Total
| | | | | | | | | 100% Community | | | CGI
| | | | | | | | | | | | CT
| | | | | | | | | | | | EIS
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MRI
| | | | | | | | | | | | NOSGER-IADL
Knapp 1994b | IF | 7 | Placebo | NINCDS | AD | Probable | 663 | 279 | 72.8y (49–95y) | Titration: | 30w | ADAS-Cog | ERT
Auxiliary: Farlow 1998, Schneider 1997, Raskind 1997, Henke 1997, Schneider 1996, Knopman 1996, Gracon 1996, Smith 1996, Knapp 1994 | | | Tacrine | | | Mild-Mod | | | 48%M | Group1-40 mg/d for 6w then 80 mg/d for 24w | | ADAS-Noncog | APOE Genotype
| | | | | | | | | | Group2-40 mg/d for 6w then 80 mg/d for 6w then 120 mg/d for 18w | | ADAS-Total GDS | Gender
| | | | | | | | | | Group3-40 mg/d for 6w then 80 mg/d for 6w then 120 mg/d for 6w then 160 mg/d for 12w | | CIBI
| | | | | | | | | | | | FCCA
| | | | | | | | | | | | GDS
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PDS
| | | | | | | | | | | | PSMS
Maltby 1994 | NI | 6 | Placebo | NINCDS | AD | Probable | 41 | 32 | 68.8y (52–84y) | Tacrine: | 36w | Activities of daily living | No
| | | Tacrine + Lecithin | DSM-III-R | | Mild-Mod | | | 51%M | Started at 25 mg/d and doses increased by 25 mg q2w up to 100 mg/d | | Carer Stress Assessment
| | | | | | | | | 100% Community | | | Cholinergic sensitive test
| | | | | | | | | | | | Extrapyramidal score
| | | | | | | | | | | | Digit Span
| | | | | | | | | | | | Face recognition
| | | | | | | | | | | | GDS
| | | | | | | | | | | | LFT-Liver function test
| | | | | | | | | | | | London psychogeriatric rating scale
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Mood states scale
| | | | | | | | | | | | National adult reading test
| | | | | | | | | | | | Neurological exam
| | | | | | | | | | | | Selective reminding test
| | | | | | | | | | | | Symptoms of stress
| | | | | | | | | | | | Verbal Fluency
| | | | | | | | | | | | Walsh tests
Prentice 1996 | NI | 5 | Placebo | DSM-III-R | AD | Probable | 23 | 19 | 68.0y(NR) | 40 mg/d for 6 w, then 80 mg/d for 6 w | 13w | CAMCOG | No
| PI | | Tacrine | NINCDS | | | | | 13%M | | | CAMTOT
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Rivermead Behavioral
| | | | | | | | | | | | Memory Test - Profile
| | | | | | | | | | | | RPT Score
| | | | | | | | | | | | SPET Scan
Weinstein 1991 | NI | 7 | Placebo | DSM-III-R | AD | Probable | 13 | 12 | 74.6y (56–79y) | Titration: increments of 25 mg/d for 4 w, then 100 mg/d | 12w | Burden Scale | No
Auxiliary: Goad 1991 | IS | | THA & Lecithin | | | | | | 50%M | 10 g/d | | CAMCOG
| | | | | | | | | 100% Community | | | CAMDEX
| | | | | | | | | | | | CT
| | | | | | | | | | | | HDRS
| | | | | | | | | | | | IDDD
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
Wong 1999 | IS | 5 | Placebo | NINCDS | AD | Probable | 100 | 94 | 73.8y (52–94y) | 30 mg/d for 6 w, | 30w | CGIC | No
| | | Tacrine | | | Mild-Mod | | | 50%M | 60 mg/d for 6 w, | | CASI
| | | | | | | | | | 90 mg/d for 6 w, then 120 mg/d | | IQCODE
| | | | | | | | | | | | ADS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | FCCA
| | | | | | | | | | | | HIS
Wood 1994 | IF | 6 | Placebo | NINCDS | AD | Mild-Mod | 154 | 131 | 75y (NR) | Titration: 20 mg/bid for 2 d, | 12w | ADAS-Noncog | No
| | | Tacrine | | | | | | 54%M | 20 mg/tid for 2 d | | AMTS
| | | | | | | | | 100% Community | 40 mg bid for 7 d. Then the dose could be increased or decreased in 20 mg amount to reach optimum dose. | | Blessed Scale
| | | | | | | | | | Max dose: 120 mg/d | | CGRS
| | | | | | | | | | | | GBS
| | | | | | | | | | | | LFT-Liver function test
| | | | | | | | | | | | Mann-Whitney test
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | RGRS
| | | | | | | | | | | | Rosen

Evidence Table 69. Study results: Tacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 15w
Allain 1999 | ITT Analysis
| 1] Placebo + Tacrine 80mg qid | [underlined: SKT] | 1] 17.2 (6.1) | | | | 1] 17.4 (6.3) | 1] NS
| 2] Silymarin 140mg tid + Tacrine 80 mg qid | | 2] 17.6 (6.1) | | | | 2] 18.2 (6.6) | 2] NS
| | [underlined: MMSE] | 1] 17.8 (4.4) | | | | 1] 18.3 (5.4) | 1] NS
| | | 2] 17.1 (4.2) | | | | 2] 17.3 (5.3) | 2] NS

Evidence Table 70. Study results: Idebenone-Tacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 60 w
Gutzmann 2002 | ITT Analysis
| 1] Idebenone 360 mg d | [underlined: EIS%] | | | | | 1] 28.9% | 3] <0.0001 favours Idebenone
| 2] Tacrine 160 mg d variable | | | | | | 2] 9.0%
| 3] Difference between Idebenone and Tacrine | Rating = -1 | | | | | 1] 54.8%
| | | | | | | 2] 83.8%
| | Rating = 0 | | | | | 1] 16.3%
| | | | | | | 2] 7.1%
| | Rating = 1 | | | | | 1] 13.5%
| | | | | | | 2] 3.0%
| | Rating = 2 | | | | | 1] 8.7%
| | | | | | | 2] 4.0%
| | Rating = 3 | | | | | 1] 6.7%
| | | | | | | 2] 2.0%
| | ADAS-Total | 1] 41.55(16.46) | | | | 1] 34.51(17.43)
| | | 2] 41.52(14.92) | | | | 2] 30.44(16.32)
| | ADAS-Cog | 1] 30.23(11.59) | | | | 1] 26.40(16.67) | 3] NS
| | | 2] 30.93(10.59) | | | | 2] 24.81(14.92)
| | ADAS-Noncog | 1] 11.32 (6.79) | | | | 1] 8.11(7.56)
| | | 2] 10.55(5.86) | | | | 2] 5.63(6.10)
| | CGI-S | 1] 5.22 (0.46) | | | | 1] 4.43 (1.58) | 3] NS
| | | 2] 5.19 (0.44) | | | | 2] 4.53 (1.45)
| | NOSGER- IADL | 1] 13.88(4.43) | | | | 1] 13.13 (5.49) | 3] NS
| | | 2] 13.78(4.55) | | | | 2] 12.5 (6.25)

Evidence Table 71. Study results: Tacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 30w
Knapp 1994 | ITT Analysis
| 1] Placebo | [underlined: CIBI] | | | | | 1] 19% improved | 5] 0.33
| 2] Tacrine 80mg/d | | | | | | 4] 41% improved | 6] 0.04
| 3] Tacrine 120mg/d | | | | | | 5] -0.01 CI (-0.4–0.1) | 7] 0.04
| 4] Tacrine 160mg/d variable | | | | | | 6] -0.02 CI (-0.4 –0.006)
| 5] Tacrine 80mg/d versus Placebo | | | | | | 7] 0.2 CI (-0.4 – -0.01)
| 6] Tacrine 120mg/d versus Placebo | [underlined: ADAS-Cog] | | | | | 1] 29.2 (11.8) | 5] 0.20
| 7] Tacrine 160mg/d variable versus Placebo | | | | | | 2] 30.9 (13.4) | 6] 0.008
| | | | | | | 3] 28.5 (11.1) | 7] 0.002
| | | | | | | 4] 28.0 (11.8)
| | | | | | | 5] -1.4 CI (-3.5–0.7)
| | | | | | | 6] -2.0 CI (-3.5 – -0.5)
| | | | | | | 7] -2.2 CI (-3.5 – -0.8)
| | [underlined: FCCA] (% improved) | | | | | 1) 16% | 7) <0.002
| | | | | | | 4) 42%
| | GDS | | | | | 5] 0.07 CI (-0.1–0.3) | 5] 0.48
| | | | | | | 6] -.05 CI (-0.2–0.08) | 6] 0.47
| | | | | | | 7] -0.2 CI (-0.3 – -0.04) | 7] 0.01
| | ADAS-Noncog | | | | | 5] -0.8 CI (-2.2–0.6) | 5] 0.26
| | | | | | | 6] -0.3 CI (-1.3–0.7) | 6] 0.52
| | | | | | | 7] -0.7 CI (-1.6–0.2) | 7] 0.12
| | ADAS-Total | | | | | 5] -2.4 CI (-5.2–0.4) | 5] 0.09
| | | | | | | 6]-2.2 CI (-4.2 – -0.3) | 6] 0.03
| | | | | | | 7] -3.0 CI (-4.8– -1.1) | 7] 0.002
| | MMSE | | | | | 1] 18.2 (5.0) | 5] 0.33
| | | | | | | 2] 17.1 (4.6) | 6] 0.37
| | | | | | | 3] 18.7 (4.6) | 7] 0.02
| | | | | | | 4] 18.8 (4.5)
| | | | | | | 5] 0.6 CI (-0.6–1.7)
| | | | | | | 6] 0.4 CI (-0.4 – -1.2)
| | | | | | | 7] 0.9 CI (0.1–1.6)

Evidence Table 72. Study results: Tacrine & Lethicin

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6 m | | Final: (specify) 9 m
Maltby 1994 | OC Population
| 1] Placebo & Lethicin 9×1200mg d | MMSE | 1] 17.3 (6.7) | | 1] 16.4 (6.8) | | 1] 15.2 (8.0) | 3] 0.9444
| 2] Tacrine 100 mg/d variable & Lethicin 9×1200mg d | | 2] 16.6 (6.8) | | 2] 16.1 (6.5) | | 2] 14.4 (6.7)
| 3] Treatment effect Tacrine & Lethicin vs. Placebo & Lethicin | IADL | 1] 10.3 (2.6) | | 1] 9.5 (2.6) | | 1] 9.6 (2.7) | 3] 0.622
| | | 2] 8.5 (2.5) | | 2] 8.3 (2.8) | | 2] 7.6 (3.4)
| | LPRS | 1] 14.1 (7.7) | | 1] 15.7 (10.9) | | 1] 18.9 (12.1) | 3] 0.638
| | | 2] 15.2 (6.5) | | 2] 18.2 (9.6) | | 2] 19.5 (10.9)
| | Verbal (words) | 1] 35.5 (15.9) | | 1] 37.5 (16.0) | | 1] 34.9 (16.3) | 3] 0.200
| | | 2] 34.9 (15.1) | | 2] 38.7 (16.5) | | 2] 38.5 (16.3)
| | Visual (objects) | 1] 36.8 (21.2) | | 1] 32.8 (22.8) | | 1] 30.8 (22.7) | 3] 0.359
| | | 2] 30.7 (13.3) | | 2] 31.4 (18.1) | | 2] 26.2 16.9)
| | Digit forward | 1] 5.9 (2.7) | | 1] 5.2 (2.6) | | | 3] 0.723
| | | 2] 6.1 (2.8) | | 2] 5.9 (2.4)
| | Verbal fluency | 1] 22.4 (13.2) | | 1] 19.8 (11.8) | | | 3] 0.198
| | | 2] 23.1 (15.0) | | 2] 24.3 (14.8)
| | Face recognition | 1] 3.8 (1.4) | | 1] 3.4 (1.8) | | | 3] 0.651
| | | 2] 3.9 (2.0) | | 2] 3.4 (1.2)
| | Carer stress assess. | 1] 2.4 (4.4) | | 1] 2.6 (4.9) | | 1] 2.2 (3.9) | 3] 0.397
| | | 2] 4.0 (6.3) | | 2] 2.0 (2.2) | | 2] 3.1 (4.8)

Evidence Table 73. Study results: Tacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Prentice 1996 | OC Population
| 1] Placebo | MMSE | 1] 18.4 (6.7) | | | | 1] 19.1 (7.0) | 3] NS
| 2] Tacrine 40 mg/d 6w, then 80 mg/d 6w. | | 2] 14.9 (5.0) | | | | 2] 15.7 (5.2)
| 3] Placebo vs. Tacrine | CAMTOT | 1] 67.0 (12.5) | | | | 1] 68.4 (18.0) | 3] NS
| | | 2] 53.5 (17.3) | | | | 2] 54.7 (20.7)
| | RPT | 1] 4.1 (3.7) | | | | 1] 5.6 (4.7) | 3] NS
| | | 2] 4.1 (3.0) | | | | 2] 3.6 (3.1)

Evidence Table 74. Study results: Tetrahydroaminoacridine & Lethicin

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Weinstein 1990 | OC Population
| 1] Placebo | CAMCOG | 1] 63 (12) | | | | 1] 64 (16) | 3] NS
| 2] Tetrahydro-aminoacridine (THA) 100 mg/d & Lethicin 10 g/d | | 2] 44 (26) | | | | 2] 45 (29)
| 3] THA vs. Placebo | IDDD | | | | | | 3] NS
| | Burden scale | | | | | | 3] NS
| | MMSE | | | | | | 3] NS

Evidence Table 75. Study results: Tacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 18w | | Final: (specify) 30w
Wong 1998 | ITT Analysis
| 1] Placebo | [underlined: CGIC] | | | | | 3] 0.05 | 5] 0.802
| 2] Tacrine 120 mg/d | | | | | | 4] 0.02
| 3] Placebo mean change from baseline | [underlined: CASI] | | | | | 3] -3.60 | 5] 0.050
| 4] Tacrine mean change from baseline | | | | | | 4] -0.85
| 5] Tacrine vs. Placebo mean change from baseline | [underlined: IQCODE] | | | | | 3] 2.95 | 5] 0.835
| | | | | | | 4] 3.13
| | ADS | | | | | 3] -1.00 | 5] 0.978
| | | | | | | 4] -0.66
| | MMSE | 1] 17.9 (4.8) | | | | 3] 1.50 | 5] 0.057
| | | 2] 16.2 (4.8) | | | | 4] -0.21

Evidence Table 76. Study results: Tacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12 w
Wood 1994 | ITT (LOCF) Analysis
| 1] Placebo | [underlined: MMSE] | | | | | 3] 18.44 (0.54)* | 5] 0.55
| 2] Tacrine 80 mg/d variable | | | | | | 4] 18.82 (0.55)*
| 3] Placebo least squares mean | [underlined: CGRS] | | | | | | 5] 0.012
| 4] Tacrine least squares mean | RGRS | | | | | | 5] 0.03
| 5] Tacrine vs. Placebo | Blessed | | | | | 3] 4.89 (0.24)* | 5] 0.60
| | | | | | | 4] 4.73 (0.25)*
| | GBS | | | | | 3] 31.70 (1.70)* | 5] 0.20
| | | | | | | 4] 29.10 (1.71)*
| | Adas-noncog | | | | | 3] 8.11 (0.48)* | 5] 0.53
| | | | | | | 4] 7.97 (0.51)*
| | AMTS | | | | | 3] 4.87 (0.21)* | 5] 0.18
| | | | | | | 4] 5.21 (0.22)*

* SEM

Evidence Table 77. Adverse Events: Tacrine

Adverse events (AE) identified in included studies | Knapp, 1994 | Maltby, 1994 | Prentice 1996 | Weinstein, 1991 | Wong, 1999 | Wood, 1994 | Tacrine+Silymarin (T) Tacrine+Placebo(C) Allain 1988 | TACRINE (T) IDEBENONE (C) Gutzmann, 2002
Withdrawn (%) due to AE | T:55 | T:43 | T:0 | T:14 | T:27 | T:16 | T:8 | T:41
| C:11 | C:0 | C:0 | C:0 | C:12 | C:5 | C:8 | C:17
AE Checklist (Max 5) | 3 | 3 | 1 | 3 | 2 | 3 | 3 | 3
None Reported
Balance
Accidental Injury
Dizziness | X | | | | X | X
Falls
Behavioral | | X | | | | | NS
Agitation | X
Cardiovascular
Arrhythmia
Hypotension
Hypertension
Extrapyramidal
Tremor | | | | | X
Gastrointestinal | X | | | | | | | S*
Abdominal pain | X | | | | X
Constipation
Diarrhea | X | | | | X | X | NS
Dyspepsia | X
Nausea, vomiting | X | X | | X | X | X | NS | S*
Metabolic/nutritional
Eating disorder | X | | | | X | | NS
Weight Change | X
Neurological | | | X
Asthenia | | | | | | | NS
Psychiatric
Anxiety
Confusion, delirium
Depression | | X
Respiratory | | | | | | | NS
Cough, cold, infection
Rhinitis | X
Other | | X | | | X | X
Aberrant hematology
Fatigue, weakness | | | | | | | NS
Fever, flu, pneumonia
Headache | X | | | | | X
Hepatic abnormality | X | X | X | X | X | X | | S*
Muscle/joint disorder | | X
Pain
Rash, skin disorder
Sleep disorder | | | | | | | NS
Urinary disorder | | X | | | | X

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 78. Key characteristics: Velnacrine

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male
| | | | | | | | | Population
Antuono 1995 | IF | 7 | Placebo Velnacrine | NINCDS | AD | Probable | 449 | 280 | 72.8y (47–90y) | 150 or 225 mg/d | 24 w | ADAS-Cog | No
| | | | | | | | | 38%M | | | CATS
| | | | | | | | | | | | CGI-C
| | | | | | | | | | | | PGR
| | | | | | | | | | | | PSMS
| | | | | | | | | | | | RAGS
Huff 1991 | PI | 6 | Placebo HP 128 (Velnacrine) | NINCDS | AD | Probable | 16 | 15 | 70.5y (46–84y) | 100 mg bid | 13d | ADAS | No
| | | | | | | | | 31%M | | | Benton MAE
| | | | | | | | | | | | CGI
| | | | | | | | | | | | Plasma Levels
| | | | | | | | | | | | RAGS
| | | | | | | | | | | | Sentence Repetition
| | | | | | | | | | | | Token Test
| | | | | | | | | | | | Verbal Fluency
| | | | | | | | | | | | Visual Naming
Zemlan 1996 | IF | 6 | Placebo Velnacrine | NINCDS | AD | Probable | 309 | 225 | 71.6y (51–89y) | 10 mg, 25 mg, 50 mg or 75 mg tid | 15w | ADAS-Cog | No
| | | | | | | | | 41%M | | | CGI-C
| | | | | | | | | | | | IADL
| | | | | | | | | | | | PGIR
| | | | | | | | | | | | PSMS

Evidence Table 79. Study results: Velnacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 12w | | Final: (specify) 24w
Antuono 1995 | LOCF Analysis
| 1] Placebo | [underlined: ADAS-Cog estimate] | | | 4] -0.5 | 4] NS | 4] 1.5 | 7] NS
| 2] Velnacrine 150 mg/d | | | | 5] -0.5 | 5] NS | 5] 1.5 | 8] NS
| 3] Velnacrine 225 mg/d | | | | 6] -2.0 | 6] <0.001 | 6] -1.0 | 9] <0.05
| 4] Placebo change from baseline | [underlined: CGI-C estimate] | | | 1] 4.1 | 4] 0.001 | 1] 4.3 | 4] 0.001
| 5] Velnacrine 150 mg/d change from baselin | | | | 2] 4.0 | 5] 0.001 | 2] 4.1 | 5] 0.001
| 6] Velnacrine 225 mg/d change from baseline | | | | 3] 3.8 | 6] 0.001 | 3] 0.0 | 6] 0.001
| 7] Combined Velnacrine vs Placebo change from baseline | | | | | | | 7] 0.001
| 8] Velnacrine 150 mg/d vs Placebo change from baseline | PGIR | | | 1] 4.1 | | 1] 4.4 | 7] <0.05
| 9] Velnacrine 225 mg/d vs Placebo change from baseline | | | | 2] 3.9 | | 2] 4.3
| | | | | 3] 3.8 | | 3] 3.9
| | PSMS | | | 4] 0.62 | | 4] 1.07 | 7] <0.05
| | | | | 5] -0.01 | | 5] 0.49
| | | | | 6] 0.30 | | 6] 0.43
| | RAGS | | | 4] 1.12 | | 4] 2.68 | 7] NS
| | | | | 5] 0.46 | | 5] 2.87 | 8] NS
| | | | | 6] 0.10 | | 6] 1.55 | 9] NS
| | CATS | | | | | | 7] <0.05
| | | | | | | | 9] <0.01

Evidence Table 80. Study results: HP 128 (Velnarcrine)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 10 d
Huff, 1991 | OC Population
| 1] Placebo | ADAS | | | | | 4] 0.3 | 5] NS
| 2] HP 128 (Velnacrine) 100 mg bid | MAE Controlled oral word association | | | | | 4] 2.6 | 5] NS
| 3] Placebo mean change from baseline | Visual naming | | | | | 4] 3.0 | 5] NS
| 4] HP 128 mean change from baseline | Token test | | | | | 4] 0.9 | 5] NS
| 5] HP 128 vs. placebo | Sentence repetition test | | | | | 4] 0.0 | 5] NS
| | RAGS | | | | | 3] 4.0 | 5] NS
| | | | | | | 4] 3.3
| | CGI | | | | | | 5] >0.05

Evidence Table 81. Study results: Velnacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 15w
Zemlan 1996 | OC Analysis
| 1] Placebo | [underlined: ADAS-Cog] | | | | | 2] 2.15 | 2] <0.001
| 2] Velnacrine 75 mg tid best dose improvement relative to placebo | [underlined: CGI- Improvement] | | | | | 2] 0.25 | 2] 0.046
| | ADAS-Total | | | | | 2] 2.36 | 2] 0.001
| | ADAS-Noncog | | | | | 2] 0.03 | 2] 0.934
| | PGIR | | | | | 2] 0.24 | 2] 0.073
| | CGI-Severity | | | | | 2] -0.01 | 2] 0.776
| | PSMS | | | | | 2] 0.19 | 2] 0.294
| | IADL | | | | | 2] -0.28 | 2] 0.453

Evidence Table 82. Adverse Events: Velnacrine

Adverse events (AE) identified in included studies | Antuono, 1995 | Huff, 1991 | Zemlan, 1996
Withdrawn (%) due to AE | T: 5 | T: 8 | T: 33
| C: 4 | C: 0 | C: 22
AE Checklist (Max 5) | 3 | 3 | 3
None Reported
Balance
Accidental Injury
Dizziness | X | X
Falls
Behavioral
Agitation | X
Cardiovascular | | | X
Arrhythmia | | X
Hypotension | | X
Hypertension | | X
Extrapyramidal
Tremor
Gastrointestinal | | X | X
Abdominal pain | | | X
Constipation | | X
Diarrhea | X | X | X
Dyspepsia
Nausea, vomiting | X | X | X
Metabolic/nutritional
Eating disorder | X | | X
Weight Change
Neurological
Asthenia | | | X
Psychiatric
Anxiety
Confusion, delirium
Depression
Respiratory | | | X
Cough, cold, infection
Rhinitis
Other | X
Aberrant hematology | X | | X
Fatigue, weakness
Fever, flu, pneumonia
Headache | X
Hepatic abnormality | X | | X
Muscle/joint disorder
Pain
Rash, skin disorder | X | | X
Sleep disorder | X
Urinary disorder

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 83. Key Characteristics: Various cholinergic neurotransmitter modifying agents

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Highest Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male
| | | | | | | | | Population (ethnicity, setting, comorbidity)
Canal 1996 | IF | 6 | Placebo | NINCDS | AD | Mild-Mod | 103 | 94 | 67.5y (48–85y) | 20 mg bid (if ≤ 65 kg) | 4w | ADL | No
| | | Eptastigmine | | | | | | 49%M | 20 mg tid (if >65 kg) | | CGI-C
| | | | | | | | | | | | CGCI
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | IADL
| | | | | | | | | | | | LMT
| | | | | | | | | | | | Semantic Word Fluency Test
| | | | | | | | | | | | Trail Making
Imbimbo 1999 | IF | 8 | Placebo | NINCDS | AD | Mod-Modly Sev | 491 | 424 | 71.0y (52–90y) | 5 mg tid (start) | 24w | ADAS-Cog | No
| | | Eptastigmine | DSM IV | | | | | 37%M | 4-week step-wise increase to 15 mg tid & 20 mg tid | | CIBIC+
| | | | | | | | | 99% White | | | GDS
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | IADL
Xu 1995 | IS | 6 | Placebo | DSM-III-R | AD | Mild-Sev | 103 | 103 | 66.0y (54–90y) | 1.6 mg/d | 8w | ADL | No
| | | Huperzine | | | | | | 55%M | | | HDS
| | | | | | | | | Asian | | | HIS
| | | | | | | | | | | | MMS
| | | | | | | | | | | | MQ
Rockwood 1997 | IF | 7 | Placebo | DSM-III-R | AD | Mild-Mod | 382 | 311 | 71.6y (NR) | 30 mg tid | 6m | ADAS-Total | No
Auxiliary: | | | Linopirdine | NINCDS | | | | | 44%M | | | ADAS-Noncog
Rockwood 2000 | | | | | | | | | 98% White | | | ADAS-Cog
| | | | | | | | | | | | CGI
| | | | | | | | | | | | DBDS
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSMS A
| | | | | | | | | | | | SKT
VanDyck 1997 | PI | 5 | Placebo | NINCDS | AD | Mild-Mod | 37 | 34 | 68.7y (NR) | 40 mg tid | 4w | ADAS-Cog | No
| | | Linopirdine | | | | | | 54%M | | | CGIC
| | | | | | | | | | | | DBDS
Mohr 1997 | NR | 5 | Placebo | DSM-III-R | AD | Mild-Mod | 39 | 15 | 68.8y (53–79y) | 10 mg bid | 48w | ADAS-Cog | No
| | | Sabeluzole | NINCDS | | | | | 49%M | | | CT Scan
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | COG9
| | | | | | | | | | | | Memory
Popa 1994 | IS | 5 | Meclofenoxate (MF) | DSM-III-R | AD | Mild-Mod | 63 | NR | 69.7y (65–87y) | 260 mg tid | 3m | SAS-G | No
| | | Antagonic Stress | | | | | | 52%M | | | SCAG
| | | | | | | | | | | | WAIS
| | | | | | | | | | | | WMS
Schneider 1994 | NR | 5 | Nicergoline | DSM IV | AD | Mild-Mod | 62 | NR | 69.8y (65–85y) | 60 mg/d | 3m | SAS-G | No
| | | Antagonic Stress | ICD-10 | | | | | 53%M | | | SCAG
| | | | | | | | | | | | WAIS
| | | | | | | | | | | | WMS
Xu 1999 | IS | 7 | Huperzine capsules | NINCDS | AD | Mild-Sev | 60 | 60 | 72.0y (54–80y) | 400 μg/d | 60d | CGI | No
| | | Huperzine tablets | DSM-III-R | | | | | 43%M | | | CGI-C
| | | | | | | | | Asian | | | GBS-SDS
| | | | | | | | | | | | HDS-R
| | | | | | | | | | | | IADL
| | | | | | | | | | | | Memory Quotient
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | TESS

Evidence Table 84. Study results: Eptastigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 29d
Canal 1996 | OC Population
| 1] Placebo change from baseline | ADL | | | | | 1] 0.35 (0.32)* | 3] 0.383
| 2] Eptastigmine 20 mg BID or TID change from baseline | | | | | | 2] -0.10 (0.10)*
| 3] Difference between Placebo and Eptastigmine in change from baseline | IADL | | | | | 1] 0.65 (0.40)* | 3] 0.020
| | | | | | | 2] -0.39 (0.20)*
| | LMT | | | | | 1] 0.00 (0.65)* | 3] 0.157
| | | | | | | 2] 1.46 (0.43)*
| | SWFT | | | | | 1] -0.75 (0.54)* | 3] 0.087
| | | | | | | 2] 0.65 (0.43)*
| | TMT | | | | | 1] -4.60 (5.13)* | 3] 0.247
| | | | | | | 2] -17.15(4.68)*
| | CGI | | | | | 1] 0.05 (0.05)* | 3] 0.258
| | | | | | | 2] -0.14 (0.05)*
| | CGIC Physician | | | | | 1] 4.10 (0.07)* | 3] 0.006
| | | | | | | 2] 3.68 (0.06)*
| | CGIC Caregiver | | | | | 1] 3.75 (0.10)* | 3] 0.180
| | | | | | | 2] 3.54 (0.08)*

* SEM

Evidence Table 85. Study results: Eptastigmine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Imbimbo 1999 | ITT Population
| 1] Placebo | [underlined: ADAS-Cog] | | | | | 4] 2.62 (7.58) | 7] 0.04
| 2] Eptastigmine 15 mg TID | | | | | | 5] 1.05 (6.79) | 8] 0.005
| 3] Eptastigmine 20 mg TID | | | | | | 6] 0.41 (6.88)
| 4] Placebo change from baseline | [underlined: CIBIC+] | | | | | 4] 4.36 (0.89) | 7] 0.138
| 5] Eptastigmine 15 mg TID change from baseline | | | | | | 5] 4.21 (0.86) | 8] 0.001
| 6] Eptastigmine 20 mg TID change from baseline | | | | | | 6] 4.03 (0.33)
| 7] Eptastigmine 15 mg TID change from placebo | IADL | | | | | 4] 1.23 (2.55) | 7] 0.088
| 8] Eptastigmine 20 mg TID change from placebo | | | | | | 5] 0.83 (2.20) | 8] 0.005
| | | | | | | 6] 0.58 (1.78)

Evidence Table 86. Study results: Haboyin (Huperzine-A)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 30d | | Final: (specify) 60d
XU 1999 | OC Analysis
| 1] Haboyin (Huperzine-A) 400ug capsules bid | Memory Quotient | 1] 40(13) | 5] >0.05 | | | 1] 48(17) | 3] <0.01
| 2] Haboyin (Huperzine-A) 400ug tablets bid | | 2] 43(12) | | | | 2] 49(16) | 4] <0.01
| 3] Capsules difference from baseline | | | | | | | 5] >0.05
| 4] Tablets difference from baseline | MMSE | 1] 13(5) | 5] >0.05 | 1] 14(7) | 3] <0.01 | 1] 18(8) | 3] <0.01
| 5] Difference between capsules and tablets | | 2] 15(4) | | 2] 16(5) | 4] <0.01 | 2] 19(6) | 4] <0.01
| | | | | | 5] >0.05 | | 5] >0.05
| | HDS-R | 1] 11(5) | 5] >0.05 | 1] 13(6) | 3] <0.01 | 1] 16(8) | 3] <0.01
| | | 2] 13(5) | | 2] 15(6) | 4] <0.01 | 2] 17(7) | 4] <0.01
| | | | | | 5] >0.05 | | 5] >0.05
| | IADL | 1] 21(5) | 5] >0.05 | 1] 20(5) | 3] <0.01 | 1] 19(6) | 3] <0.01
| | | 2] 22(6) | | 2] 21(6) | 4] <0.01 | 2] 19(6) | 4] <0.01
| | | | | | 5] >0.05 | | 5] >0.05
| | GBS-SDS | 1] 52(23) | 5] >0.05 | 1] 47(22) | 3] <0.01 | 1] 40(25) | 3] <0.01
| | | 2] 51(21) | | 2] 44(22) | 4] <0.01 | 2] 36(24) | 4] <0.01
| | | | | | 5] >0.05 | | 5] >0.05

Evidence Table 87. Study results: Linopirdine

Author Year | Analysis Groups | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Rockwood 1997 | ITT Analysis (Endpoint)
Rockwood 2000 | 1] Placebo | [underlined: ADAS-cog] | 1] 20.5 (8.44)* | | | | 1] 22.5 | 3] .001
| 2] Linopirdine 30 mg tid | | 2] 20.3 (8.58)* | | | | 2] 20.2
| 3] Linopirdine vs Placebo | [underlined: CGI] | 1] 3.92 (0.87)* | | | | 1] 3.69 (0.72
| | | 2] 3.91 (0.86)* | | | | 2] 3.81 (0.74)
| | [underlined: CGI % improved] | | | | | 1] 13% (est) | 3] 0.558
| | | | | | | 2] 15% (est)
| | ADAS-noncog | ] 2.4 (2.6)* | | | | 1] 3.4 (0.9)* | 3] NS
| | | 2] 2.3 (2.6)* | | | | 2] 3.0 (0.8)*
| | ADAS total | 1] 22.8 (9.5)* | | | | 1] 25.4 (2.6)* | 3] <0.05
| | | 2] 22.6 (10.0)* | | | | 2] 23.2 (0.7)*
| | SKT | 1] 38.5 (6.6)* | | | | 1] 40.8 (2.4)* | 3] NS
| | | 2] 37.8 (6.3)* | | | | 2] 39.5 (1.5)*
| | IADL | 1] 19.8 (5.1)* | | | | 1] 21.2 (1.4)* | 3] NS
| | | 2] 19.1 (5.2)* | | | | 2] 20.1 (1.0)*
| | Dementia behavior disturbance scale | 1] 14.7 (9.7)* | | | | 1] 15.7 (1.1)* | 3] NS
| | | 2] 14.3 (9.6)* | | | | 2] 14.9 (0.6)*
| | MMSE | 1] 19.6 (4.51)
| | | 2] 19.4 (4.05)

* SEM

Evidence Table 88. Study results: Linopirdine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 4w
VanDyck 1997 | OC Analysis
| 1] Placebo | ADAS | | | | | | 3] 0.12
| 2] Linopirdine 40 mg tid | DBDS | | | | | | 3] 0.13
| 3] Linopirdine vs Placebo | CGIC | | | | | | 3] 0.07

Evidence Table 89. Study results: Sabeluzole

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 48w
Mohr, 1997 | OC Analysis
| 1] Placebo | ADAS-cog | 1] 20.4 (2.0)* | | | | 1] 27.1 (2.8)* | 4] <0.01
| 2] Sabeluzole 5 mg | | 2] 17.8 (1.8)* | | | | 2] 22.3 (3.0)* | 5] <0.05
| 3] Sabeluzole 10 mg | | 3] 23.3 (2.8)* | | | | 3] 28.4 (3.5)* | 6] <0.05
| 4] Placebo change from baseline | | | | | | | 7] NS
| 5] Sabeluzole 5mg change from baseline | MMSE | 1] 18.5 (1.1)
| 6] Sabeluzole 10mg change from baseline | | 2] 18.9 (0.9)
| 7] Between groups | | 3] 17.9 (0.6)
| | Cog-9 | 1] 11.0 (1.8) | | | | 1] 17.3 (2.9) | 4] <0.01
| | | 2] 7.2 (1.2) | | | | 2] 11.3 (2.3) | 5] <0.05
| | | 3] 13.4 (2.4) | | | | 3] 17.9 (2.9) | 6] <0.05
| | | | | | | | 7] NS
| | Memory | 1] 10.5 (0.6) | | | | 1] 11.7 (0.6) | 4] <0.05
| | | 2] 10.7 (0.7) | | | | 2] 11.0 (0.8) | 5] NS
| | | 3] 11.5 (0.5) | | | | 3] 12.2 (0.5) | 6] NS
| | | | | | | | 7] NS

* SEM

Evidence Table 90. Study results: Antagonic Stress - Meclofenoxate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3m
Popa, 1994 | OC Population
| 1] Meclofenoxate (MF) 260 mg tid | SCAG | 1] 68.3 (7.2) | | | | 1] 52.0 (7.6) | 3] <0.001
| 2] Antagonic Stress (AS) | | 2] 71.2 (7.7) | | | | 2] 46.1 (6.5) | 4] <0.001
| 3] MF final v baseline | | | | | | | 5] <0.001
| 4] AS final v baseline | | | | | | | favors AS
| 5] AS vs MF final | SASG | 1] 67.4 (10.6) | | | | 1] 53.3 (13.1) | 3] <0.001
| | | 2] 68.4 (8.9) | | | | 2] 47.3 (6.5) | 4] <0.001
| | | | | | | | 5] <0.01
| | | | | | | | favors AS
| | WMS (MQ) | 1] 82.0 (6.5) | | | | 1] 100.0 (11.3) | 3] <0.001
| | | 2] 81.3 (9.8) | | | | 2] 108.6 (11.4) | 4] <0.001
| | | | | | | | 5] <0.05
| | | | | | | | favors AS
| | WAIS (DI) | 1] 13.8 (4.4) | | | | 1] 9.8 (4.1) | 3] <0.001
| | | 2] 15.4 (4.3) | | | | 2] 6.7 (3.9) | 4] <0.001
| | | | | | | | 5] <0.010
| | | | | | | | favors AS

Evidence Table 91. Study results: Nicergoline - Antagonic Stress

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3m
Schneider 1994 | OC Analysis
| 1] Nicergoline 20 mg tid | SCAG | 1] 66.5 (11.5) | | | | 1] 50.5 (8.6) | 3] <0.001
| 2] Antagonic Stress 3 capsules tid | | 2] 71.2 (7.7) | | | | 2] 46.1 (6.5) | 4] <0.001
| 3] Nicergoline change from baseline | | | | | | | 5] 0.002
| 4] Antagonic Stress change from baseline | | | | | | | favors AS
| 5] Difference between Nicergoline and Antagonic Stress in change from baseline | SASG | 1] 65.8 (9.5) | | | | 1] 52.1 (9.4) | 3] <0.001
| | | 2] 68.4 (8.9) | | | | 2] 47.3 (6.5) | 4] <0.001
| | | | | | | | 5] 0.000
| | | | | | | | favors AS
| | WAIS Digit symbol | 1] 7.8 (1.2) | | | | 1] 9.6 (1.6) | 3] <0.001
| | | 2] 7.5 (1.6) | | | | 2] 11.5 (2.4) | 4] <0.001
| | | | | | | | 5] 0.000
| | | | | | | | favors AS

Evidence Table 92. Study results: Huperzine A

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Xu 1995 | OC Analysis
| 1] Placebo | MQ | 1] 48 (21) | 3] >0.05 | | | 1] 52 (26) | 3]<0.05
| 2] Huperzine A | | 2] 56 (21) | | | | 2] 64 (26) | 4] <0.01
| 3] Difference between Placebo and Huperzine A | | | | | | | 5] <0.01
| 4] Placebo difference from baseline | MMS | 1] 14 (5) | 3] >0.05 | | | 1] 15 (6) | 3] <0.01
| 5] Huperzine A difference from baseline | | 2] 16 (5) | | | | 2] 19 (6) | 4] >0.05
| | | | | | | | 5] <0.01
| | HDS | 1] 16 (5) | 3] >0.05 | | | 1] 15 (7) | 3] <0.01
| | | 2] 16 (6) | | | | 2] 20 (6) | 4] >0.05
| | | | | | | | 5] <0.01
| | ADL | 1] 31 (9) | 3] >0.05 | | | 1] 31.9 (0.7) | 3] >0.05
| | | 2] 33 (10) | | | | 2] 29 (9) | 4] >0.05
| | | | | | | | 5] <0.01

Evidence Table 93. Adverse Events: Neurotransmitters - Various Cholinergic neurotransmitter modifying agents

Adverse events (AE) identified in included studies | EPTASTIGMINE Canal, 1996 | EPTASTIGMINE Imbimbo, 1999 | HUPERZINE Xu, 1995 | HUPERZINE Xu, 1999 | LINOPIRDINE Van Dyck, 1997 | LINOPIRDINE Rockwood, 1997 | SABELUZOLE Mohr, 1997 | MECLOFENOXATE ANTAGONIC STRESS Popa, 1994 | NICERGOLINE ANTAGONIC STRESS Schneider, 1994 | HUPERZINE Xu, 1999
Withdrawn (%) due to AE | T: 4 | T: 8 | T: 0 | T: 0 | T: 0 | T: 21 | T: 0 | T: NR | T: NR | T: NR
| C: 0 | C: 7 | C: 0 | C: 0 | C: 0 | C: 2 | C: 0 | C: NR | C: NR | C: NR
AE Checklist (Max 5) | 4 | 4 | 3 | 5 | 0 | 3 | 0 | 1 | 0 | 5
None Reported | | | | | x | | x | X | X
Balance | | | | NS | | | | | | NS
Accidental Injury
Dizziness | | | NS
Falls | | x
Behavioral | | | NS
Agitation | | | NS | NS | | | | | | NS
Cardiovascular | | x
Arrhythmia | x | x
Hypotension
Hypertension | | x
Extrapyramidal
Tremor
Gastrointestinal | | x
Abdominal pain | | x
Constipation
Diarrhea | | x | NS
Dyspepsia
Nausea, vomiting | x | x | NS | NS | | | | | | NS
Metabolic/nutritional
Eating disorder | | x | NS | NS | | | | | | NS
Weight Change
Neurological
Asthenia
Psychiatric
Anxiety | | x
Confusion, delirium | | x
Depression | | x
Respiratory | | x
Cough, cold, infection
Rhinitis | | | NS
Other | | x | | NS | | | | | | NS
Aberrant hematology | | x
Fatigue, weakness
Fever, flu, pneumonia | | x
Headache | | x
Hepatic abnormality | | | | | | S
Muscle/joint disorder | | x
Pain | | x
Rash, skin disorder | | x
Sleep disorder | | x | NS | NS | | | | | | NS
Urinary disorder | | x

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 94. Key characteristics: Haloperidol

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Allain 2000 | NR | 6 | Placebo | DSM-III-R | AD | Mild-Mod | 306 | 259 | 79.6y (55–94y) | 300 mg/d | 21d | CGI | No
| | | Tiapride | | | | | | 36%M | 6 mg/d | | Global Improvement
| | | Haloperidol | | | | | | | | | MMSE
| | | | | | | | | | | | MOSES
| | | | | | | | | | | | UKU
Auchus 1997 | NI | 6 | Placebo | NINCDS | AD | Probable | 15 | 12 | 75.6y (NR) | 3 mg/d | 6w | BEHAVE-AD | No
| | | Haloperidol | | | | | | 33%M | 20 mg/d | | CMAI
| | | Fluoxetine | | | | | | 100% Community | | | CSI
DeDeyn 1999 | PI | 7 | Placebo | DSM IV | PDD | Severe | 344 | 223 | 81.0y (median) (56–97y) | 0.25 mg with increments of 0.25 every 4d then: | 12w | BEHAVE-AD | VaD vs all
| | | Risperidone | | VaD | | | | 44%M | 4 mg/d | | CGI
| | | Haloperidol | | Mixed | | | | 99.9% white | 4 mg/d | | CMAI
| | | | | | | | | 100% Institution | | | CMH
| | | | | | | | | | | | ECG
| | | | | | | | | | | | EPS
| | | | | | | | | | | | ESRS
| | | | | | | | | | | | FAST
| | | | | | | | | | | | Heart Rate
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
Petrie 1982 | PI | 6 | Placebo | DSM III | PDD | Mod-Sev | 64 | 37 | 72.7y (60–95y) | Gradually increased with a fixed-flexible dosage for 4 w | 10w | BPRS | No
| | | Loxapine | | MID | | | | 49%M | 50 mg/d | | CGI
| | | Haloperidol | | | | | | 100% institution | 10 mg/d | | CGIC
| | | | | | | | | | variable | | EKG
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | SCAG
Teri 2000 | NI | 6 | Placebo | NINCDS | AD | Probable - Possible | 149 | 91 | 74.8y (NR) | 3 mg/d | 16w | ABID | No
| IS | | Haloperidol | | | | | | 45%M | 300 mg/d | | ADCS-CGIC
| | | Trazodone | | | | | | 86% white | | | BRSD-CERAD
| | | BMT | | | | | | | | | Caregiver Burden Screen
| | | | | | | | | | | | CMAI
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSM
| | | | | | | | | | | | RMBPC
| | | | | | | | | | | | SCB
DRUG VS DRUG (NO PLACEBO)
Carlyle 1993 | NR | 5 | Loxapine | DSM-III-R | PDD | Mod-Sev | 40 | 31 | 79.0y (65–91y) | 50 mg tid | 28d | Aggression Chart | No
| | | Haloperidol | | AD | | | | 55%M | 10 mg tid | | Blood count
| | | | | MID | | | | 100% Institution | | | Electrolytes
| | | | | | | | | | | | ESR
| | | | | | | | | | | | Renal & Liver Function Test
Coccaro 1990 | NI | 6 | Haloperidol | DSM III | Dementia | NR | 59 | 52 | 75.3y (58–99y) | Started with 0.5 or 1.0 mg/d (haloperidol), 10 or 20mg/d (oxazepam), 25 or 50 mg/d (diphenhydramine) and increased to max doses of 5 mg/d | | ADAS | No
| IS | | Oxazepam | | | | | | 59%M | 60 mg/d | | BPRS
| | | Diphenhydramine | | | | | | 100% Institution | 200 mg/d respectively | | CDRS
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | PSMS
| | | | | | | | | | | | Treatment emergent
Chan 2001 | NI | 6 | Haloperidol | DSM IV | AD | Severe | 58 | 55 | 80.5y (≥55y) | 2 mg/d | 12w | BEHAVE-AD | No
| | | Risperidone | | VaD | | | | 28%M | | | CMAI
| | | | | | | | | 100% Asian | | | CMMSE
| | | | | | | | | | | | FAST
| | | | | | | | | | | | Simpson-Angus Scale

Evidence Table 95. Study results: Haloperidol - Tiapride

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 21d
Allain 2000 | ITT Endpoint Analysis
| 1] Placebo | [underlined: MOSES % responders (% with 25% decrease in irritability/ aggressiveness subscore)] | | | | | 1] 49% | 8] 0.04
| 2] Tiapride 100–300 mg/d | | | | | | 2] 63% | 9] 0.004
| 3] Haloperidol 2–6 mg/d | | | | | | 3] 69% | 10] 0.38
| 4] Across treatment | MOSES | 1] 20.28 (2.85) | | | | 1] 15.53 (5.25) | 5] 0.0009
| 5] Tiapride vs Placebo | | 2] 19.90 (2.92) | | | | 2] 13.33 (4.20) | 6] 0.008
| 6] Haloperidol vs Placebo | | 3] 20.52 (3.27) | | | | 3] 13.75 (4.59) | 7] 0.53
| 7] Tiapride vs Haloperidol | Global Improvement very improved | | | | | 1] 14% | 4] NS
| 8] Placebo vs Tiapride change from baseline | | | | | | 2] 24%
| 9] Placebo vs Haloperidol change from baseline | | | | | | 3] 31%
| 10] Triapride vs Haloperidol change from baseline | Global Improvement no change | | | | | 1] 21%
| | | | | | | 2] 12%
| | | | | | | 3] 12%
| | CGI | | | | | | 8] 0.03
| | | | | | | | 9] 0.02
| | | | | | | | 10] NS
| | MMSE | | | | | | 8] NS
| | | | | | | | 9] NS
| | | | | | | | 10] NS

Evidence Table 96. Study results: Haloperidol - Fluoxetine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point] (specify) | | Final] (specify) 6 w
Auchus 1996 | OC Population
| 1] Placebo | [underlined: CMAI] | 1] 34.4 (8.2) | | | | 1] 33.0 (3.5) | 4] 0.82
| 2] Fluoxetine 20 mg/d | | 2] 33.8 (3.0) | | | | 2] 35.2 (10.3)
| 3] Haloperidol 3mg/d | | 3] 37.4 (4.4) | | | | 3] 35.0 (11.2)
| 4] Across group treatment effect | BEHAVE-AD | 1] 5.6 (3.4) | | | | 1] 6.6 (3.5) | 4] 0.35
| | | 2] 7.0 (4.2) | | | | 2] 8.8 (3.5)
| | | 3] 11.8 (4.9) | | | | 3] 9.2 (7.1)
| | CSI | 1] 116.2 (57.0) | | | | 1] 134.8 (62.1) | 4] 0.67
| | | 2] 160.4(121.8) | | | | 2] 143.6 (79.3)
| | | 3] 165.4 (50.3) | | | | 3] 179.4 (91.9)

Evidence Table 97. Study results: Risperidone - Haloperidol

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
DeDeyn 1999 | ITT Population
| 1] Placebo | BEHAVE-AD total | 1] 16.6 | | | | 1] -4.2 | 4] 0.19
| 2] Haloperidol 1.2mg/d | | 2] 16.5 | | | | 2] -6.6 | 6] 0.01
| 3] Risperidone 1.1 mg/d | | 3] 16.3 | | | | 3] -5.2
| 4] Risperidone vs Placebo | Behave-AD Aggressiveness | 1] 5.0 | | | | 1] -0.8 | 4] 0.004
| 5] Risperidone vs Placebo change from baseline | | 2] 4.7 | | | | 2] -1.6 | 6] 0.01
| 6] Haloperidol vs Placebo change from baseline | | 3] 5.0 | | | | 3] -1.7 | 7] 0.05 favors Risperidone
| 7] Risperidone vs Placebo change from baseline | CMAI total aggressive | 1] 27.5 | | | | 1] -1.6 | 4] 0.01
| | | 2] 26.3 | | | | 2] -3.3 | 7] 0.02
| | | 3] 25.6 | | | | 3] -3.9
| | CMAI physical aggressive | 1] 19.7 | | | | 1] -0.7 | 4] 0.01
| | | 2] 19.3 | | | | 2] -0.3 | 7] 0.01
| | | 3] 18.9 | | | | 3] -2.7
| | CMAI verbal aggressive | 1] 7.7 | | | | 1] -0.8 | 4] 0.01
| | | 2] 7.0 | | | | 2] -1.0
| | | 3] 6.8 | | | | 3] -1.2
| | CGI | | | | | | 5] <0.05
| | MMSE | | | | | | 5] NS
| | FAST | | | | | | 5] NS
| | Behave-AD % with > 30% reduction from baseline | | | | | 1] 47% | 5] 0.25
| | | | | | | 2] 63%
| | | | | | | 3] 54%

Evidence Table 98. Study results: Loxapine - Haloperidol

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: 10w
Petrie, 1982 | Efficacy Analysis Population
| 1] Placebo | CGIC (marked or moderate improvement) | | | | | 1] 9%
| 2] Haloperidol 10 mg/d (max) | | | | | | 2] 35%
| 3] Loxapine 50 mg/d (max) | | | | | | 3] 32%
| 4] Haloperidol vs baseline | BPRS total | 1] 46.36 | | | | 1] 48.90 | 4] < 0.05
| 5] Loxapine vs baseline | | 2] 46.35 | | | | 2] 39.60 | 5] < 0.05
| 6] Placebo vs Haloperidol change from baseline | | 3] 50.79 | | | | 3] 43.84 | 6] <0.05
| 7] Placebo vs Loxapine change from baseline | | | | | | | 7] <0.05
| | SCAG total | 1] 61.0 | | | | 1] 60.9 | 4] < 0.05
| | | 2] 55.9 | | | | 2] 47.3 | 5] < 0.05
| | | 3] 62.9 | | | | 3] 54.4
| | NOSIE | 1] 157.2 | | | | 1] 151.2 | 5] < 0.05
| | | 2] 184.0 | | | | 2] 192.0
| | | 3] 155.0 | | | | 3] 171.4

Evidence Table 99. Study results: Haloperidol - Trazodone

REF ID# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) | | Final: (specify) 16w
| Teri, 2000 | Efficacy Analysis
| | 1] BMT | ADCS-CGIC | | | | | 1] 32% | 6] 0.99
| | 2] Haloperidol mean dose 1.8 mg/d | %improvement | | | | | 2] 32% | 7] 0.81
| | 3] Trazodone mean dose 200 mg/d | | | | | | 3] 41% | 8] 0.65
| | 4] Placebo | | | | | | 4] 31% | 9] 0.75
| | 5] Group Effect | | | | | | | 10] 0.52
| | 6] Placebo vs Trazodone | | | | | | | 11] 0.86
| | 7] Placebo vs Haloperidol | BRSD | | | | | 1] -3.56 12.85) | 5] NS
| | 8] Placebo vs BMT | Change score | | | | | 2] -5.35(22.41)
| | 9] Traxodon vs Haloperidol | | | | | | 3] -6.95(20.87)
| | 10] Trazodone vs BMT | | | | | | 4] -5.28 (24.36)
| | 11] Haloperidol vs BMT | MMSE | | | | | 1] -0.05 (2.58) | 6] NS
| | | Change score | | | | | 2] -0.61 (2.69) | 7] NS
| | | | | | | | 3] -1.97 (3.15) | 8] NS
| | | | | | | | 4] -0.28 (3.35) | 9] NS
| | | | | | | | | 10] <0.05 favours BMT
| | | | | | | | | 11] NS
| | | Lawton-Brody ADL | | | | | 1] -0.27 (1.96) | 6] <0.05 favours placebo
| | | Physical | | | | | 2] 2.53 (4.00) | 7] <0.05 favours placebo
| | | Change score | | | | | 3] 1.62 (2.56)
| | | | | | | | 4] 1.31 (2.47)
| | | Lawton-Brody | | | | | 1] 0.17 (1.84) | 6] <0.05
| | | ADL | | | | | 2] 1.79 (3.20) | 7] <0.05 favours placebo
| | | Instrumental | | | | | 3] 1.81 (3.32)
| | | Change score | | | | | 4] 0.89 (3.32)
| | | SCB | | | | | 1] -2.95 (7.29 | 5] NS
| | | Subjective | | | | | 2] -1.88 (8.89)
| | | | | | | | 3] -1.97 (10.06)
| | | | | | | | 4] -2.58 (9.67)
| | | Screen for Caregiver | | | | | 1] -2.95 (7.29
| | | Burden | | | | | 2] -1.88 (8.89)
| | | Subjective | | | | | 3] -1.97 (10.06)
| | | | | | | | 4] -2.58 (9.67)
| | | Objective | | | | | 1] -1.23 (3.32)
| | | | | | | | 2] -0.44 (3.22)
| | | | | | | | 3] -1.14 (4.04)
| | | | | | | | 4] -1.25 (4.02)

Evidence Table 100. Study results: Loxapine - Haloperidol

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 14d | | Final: (specify) 28d
Carlyle 1993 | OC Analysis
| 1] Haloperidol 7.0 mg/d (mean) | Mean Aggression Score for responders | 1] 6.0 | | 1] 4.8 | 3] NS | 1] 2.5 | 3] NS
| 2] Loxapine 36.0 mg/d (mean) | | 2] 8.6 | | 2] 6.6 | | 2] 4.2
| 3] Difference between Haloperidol and Loxapine | Mean depression score | | | | | 1] 11/14 | 3] NS
| | Response rate | | | | | 2] 14/17

Evidence Table 101. Study results: Haloperidol - Oxazepam - Diphenhydramine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: | | Final: 8w
Coccaro 1990 | Completers Analysis
| 1] Haloperidol 5 mg/d (max) | CDRS mean score | 1] 2.78 | 4] > 0.10
| 2] Oxazepam 60 mg/d (max) | | 2] 2.76
| 3] Diphenhydramine 200 mg/d (max) | | 3] 2.66
| 4] Between groups, change from baseline | ADAS | 1] 11.00 (5.95) | | | | 1] 8.39 (6.09) | 4] NS
| 5] Change from baseline | | 2] 11.50 (4.90) | | | | 2] 9.12 (4.33) | 5] < 0.001
| 6] Between groups at timepoint | | 3] 9.82 (3.68) | | | | 3] 6.12 (4.78) | 6] NS
| | BPRS | 1] 6.33 (3.01) | | | | 1] 4.78 (2.44) | 4] NS
| | | 2] 5.81 (2.17) | | | | 2] 5.50 (2.71) | 5] < 0.02
| | | 3] 5.67 (2.72) | | | | 3] 4.47 (2.85) | 6] NS
| | PSMS | 1] 42.17 (12.95) | | | | 1] 37.89 (15.36) | 4] NS
| | | 2] 45.75 (11.02) | | | | 2] 43.68 (11.47) | 5] < 0.001
| | | 3] 39.35 (10.36) | | | | 3] 34.76 (9.94) | 6] NS
| | NOSIE | 1] 78.19 (7.67) | | | | 1] 78.31 (9.45) | 4] NS
| | | 2] 80.69 (9.10) | | | | 2] 80.69 (9.89) | 5] NS
| | | 3] 73.47 (5.88) | | | | 3] 73.00 (11.53) | 6] <0.02

Evidence Table 102. Study results: Haloperidol - Risperidone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12 w
Chan 2001 | OC Analysis
| 1] Haloperidol 0.5–2 mg/d | CMAI | 1] 46.4 (10.5) | | | | 1] 36.3 (10.4) | 3] 0.000
| 2] Risperidone 0.5–2 mg/d | | 2] 48.9 (14.5) | | | | 2] 40.8 (16.9) | 4] 0.002
| 3] Haloperidol change from baseline | | | | | | | 5] 0.95
| 4] Risperidone change from baseline | BEHAVE-AD | 1] 2.1 (2.0) | | | | 1] 0.8 (1.5) | 3] 0.011
| 5] Between treatments | (Aggressiveness) | 2] 2.2 (2.5) | | | | 2] 0.9 (2.0) | 4] 0.019
| | | | | | | | 5] 0.56
| | FAST | | | | | No data extracted
| | CMMSE | 1] 8.2 (5.0) | | | | 3] -0.15 | 3] 0.84
| | | 2] 7.9 (6.0) | | | | 4] -0.42 | 4] 0.70

Table 103 Evidence Table 103. Adverse Events: Haloperidol

Adverse events (AE) identified in included studies | TIAPRIDE (T1) | HALOPERIDOL (T1) | HALOPERIDOL (T1) | HALOPERIDOL (T) | HALOPERIDOL (T1) | HALOPERIDOL (T) | HALOPERIDOL (T) | DIPHENHYDRAMINE (T1)
| HALOPERIDOL (T2) | FLUOXETINE (T2) | RISPERIDONE (T2) | LOXAPINE (T2) | TRAZODONE (T2) | RISPERIDONE (C) | LOXAPINE (C) | HALOPERIDOL (T2)
| PLACEBO (C) | PLACEBO (C) | PLACEBO (C) | PLACEBO (C) | PLACEBO (C) | Chan, 2001 | Carlyle, 1993 | OXAZEPAM (T3)
| Allain, 2000 | Auchus, 1997 | De Deyn, 1999 | Petrie, 1982 | Teri, 2000 | | | Coccaro, 1990
Withdrawn (%) due to AE | T1: 5 | T1: 33 | T1: NR | T1: 18 | T1: NR | T: 4 | T: 20 | T1: 5
| T2: 17 | T2: 0 | T2: NR | T2: 21 | T2: NR | C: 7 | C: 15 | T2: 10
| C: 6 | C: 17 | C: NR | C: 5 | C: NR | | | T3: 11
AE Checklist (Max 5) | 3 | 3 | 1 | 5 | 2 | 1 | 5 | 3
None Reported
Balance | | x | | | S*
Accidental Injury | | | NS*
Dizziness | | | | | NS*
Falls | | | NS*
Behavioral | x | | | NS*
Agitation | | | NS* | | | | x
Cardiovascular | x | | | x
Arrhythmia
Hypotension | x | | | x | | NS* | x
Hypertension | x
Extrapyramidal | S* | | | x | S* | S* | x | x
Tremor | x | x | | | NS*
Gastrointestinal | | | | x
Abdominal pain
Constipation | x | | | | | x
Diarrhea | x
Dyspepsia
Nausea, vomiting | x | | | | | x
Metabolic/nutritional
Eating disorder
Weight Change
Neurological | | | | x
Asthenia | x
Psychiatric
Anxiety | x | x
Confusion, delirium | | x | | | | | x
Depression | | x
Respiratory
Cough, cold, infection
Rhinitis
Other | NS* | | | S* | NS* | | x | x
Aberrant hematology
Fatigue, weakness | | | | | NS*
Fever, flu, pneumonia
Headache
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder
Sleep disorder | x | | NS* | | | x
Urinary disorder | x

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 104. Key characteristics: Memantine

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Orgogozo 2002 | IF | 6 | Placebo | NINDS-AIREN | VaD | Mild-Mod | 321 | 234 | 76.4y (NR) | 5 mg/d on w 1 | 28w | ADAS-cog | No
| | | Memantine | | | | | | 53%M | 10 mg/d on w 2 | | CGIC
| | | | | | | | | 100% white | 15 mg/d on w 3 then 20 mg/d | | CIBIC-plus
| | | | | | | | | | | | ECG
| | | | | | | | | | | | GBC
| | | | | | | | | | | | GBS
| | | | | | | | | | | | MIS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSGER
| | | | | | | | | | | | Laboratory Tests
Wilcock 2002 | IS | 7 | Placebo | DSM-III-R | VaD | Mild-Mod | 579 | 464 | 77.4y (54–97y) | 5 mg/d increasing of 5 mg/d each week for 4 w then 20 mg/d | 28w | ADAS-Cog | MMSE
| | | Memantine | NINDS-AIREN | | | | | 51%M | | | CIBIC+ | Type of VaD
| | | | | | | | | 100% Community | | | CGI-C | Gender
| | | | | | | | | | | | CGI-S
| | | | | | | | | | | | GBS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSGER
Winblad 1999 | NR | 6 | Placebo | DSM-III-R | DAT | Modly Sev-Severe | 166 | 151 | 71.2y (60–80y) | 5 mg/d on w 1 then 10 mg/d | 12w | BGP | AD/VaD
| | | Memantine | | VaD | | | | 42%M | | | CGI-C | Care Dependence
| | | | | PDD | | | | 100% Institution | | | CGI-S
| | | | | | | | | | | | CT Scan
| | | | | | | | | | | | Ferm's D-test
| | | | | | | | | | | | GDS
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MMSE

Evidence Table 105. Study results: Memantine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 28w
Orgogozo 2002 | ITT/OC Analysis
| 1] Placebo change from baseline | [underlined: ADAS-Cog] | | | | | 1] 1.58 (6.42) | 3] 0.0016
| 2] Memantine 20mg/d change from baseline | | | | | | 2] -1.25 (1.39)
| 3] Memantine vs Placebo | [underlined: CIBIC-plus] | | | | | 1] 4.11 (1.48) | 3] 0.284
| ITT for Primary outcomes | | | | | | 2] 3.82 (1.39)
| Per protocol For Secondary outcomes | MMSE | | | | | 1] 0.52 (4.07) | 3] 0.0121
| | | | | | | 2] 1.75 (3.38)
| | CGI-C Clinician | | | | | 1] 3.85 (1.19) | 3] 0.0938
| | | | | | | 2] 3.58 (1.09)
| | CGI-C Caregiver | | | | | 1] 3.82 (1.31) | 3] 0.0921
| | | | | | | 2] 3.52 (1.26)
| | NOSGER | | | | | 1] 3.26 (12.95) | 3] 0.8119
| | | | | | | 2] 2.73 (11.67)
| | GBS | | | | | 1] 3.38 (16.34) | 3] 0.1194
| | | | | | | 2] -0.36(15.38)

Evidence Table 106. Study results: Memantine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 28w
Wilcock 2002 | ITT and PP Analysis
| 1] Placebo | [underlined: ADAS-Cog] | | | | | 3] -2.28 (7.77) | 5] 0.0005
| 2] Memantine 20mg/d | | | | | | 4] -0.53 (7.02)
| 3] Placebo change from baseline | [underlined: CGI-C] | | | | | | 5] 0.292
| 4] Memantine change from baseline | MMSE | | | | | 3] 0.51 (3.9) | 5] NS
| 5] Memantine vs Placebo | | | | | | 4] 0.24 (3.8)
| | NOSGER | 1] 67.69 (14.21) | | | | 3] 3.45 (11.08) | 5] 0.22
| | | 2] 68.90 (15.84) | | | | 4] 2.32 (11.12)
| | GBS | 1] 32.15 (14.58) | | | | 3] 2.48 (15.95) | 5] 0.02
| | | 2] 33.83 (14.26) | | | | 4] 1.65 (12.00)

Evidence Table 107. Study results: Memantine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 2h | | Final: (specify) 24h
Winblad 1999 | ITT Analysis
| 1] Placebo change from baseline | [underlined: CGI-C] | | | 1] 40% | | 1] 46% | 3] <0.001
| 2] Memantine 10mg/d change from baseline | | | | 2] 48% | | 2] 73%
| 3] Difference between placebo and memantine in change from baseline | [underlined: BGP] (care dependence) | | | | | 1] -1.1 (11.8) | 3] 0.016
| | | | | | | 2] -3.1 (12.2)
| | CGI-S | | | | | 1] 53%
| | | | | | | 2] 78%
| | BGP (total) | | | | | 1] -4.6 (7.0) | 3] 0.015
| | | | | | | 2] -7.2 (7.1)

Evidence Table 108. Adverse Events: Memantine

Adverse Events (AE) identified in included studies | Orgogozo, 2002 | Wilcock, 2002 | Winblad, 1999
Withdrawn (%) due to AE | T: 12 | T: 9 | T: NR
| C: 13 | C: 7 | C: NR
AE Checklist (Max 5) | 4 | 4 | 3
None Reported
Balance
Accidental Injury | | X
Dizziness | NS | X
Falls | | X
Behavioral
Agitation | NS | X
Cardiovascular | NS | | X
Arrhythmia
Hypotension
Hypertension
Extrapyramidal | | X
Tremor
Gastrointestinal
Abdominal pain | | | X
Constipation | | X
Diarrhea | | X
Dyspepsia
Nausea, vomiting | | X | X
Metabolic/nutritional | | | X
Eating disorder
Weight Change
Neurological | NS | X
Asthenia
Psychiatric | | X
Anxiety
Confusion, delirium | NS | X
Depression
Respiratory | | X | X
Cough, cold, infection | | X
Rhinitis
Other | | X | X
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia | | | X
Headache | | X
Hepatic abnormality
Muscle/joint disorder | | X | X
Pain | | X
Rash, skin disorder
Sleep disorder | | X
Urinary disorder | | X

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

X = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 109. Key characteristics: Selegiline

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
Agnoli 1991 | NR | 5 | Placebo | NINCDS | PDD | Probable | 10 | 10 | 68.6y (NR) | 5 mg bid | 60d | Cerebral Blood Flow | No
| | | L-Deprenyl | | | Mild-Mod | | | 40%M | | | GBS
| | | | | | | | | | | | RMT
| | | | | | | | | | | | SPECT-Tc-HMPAO
| | | | | | | | | | | | TP
Burke 1993a | PI | 6 | Placebo | NINCDS | DAT | Mild | 39 | 33 | 73.1y (NR) | 5 mg bid | 15m | BDS | No
Auxiliary: | IS | | L-Deprenyl | | | | | | 74%M | | | BNT
Burke 1993b | | | | | | | | | | | | BPRS
| | | | | | | | | | | | CDR-SB
| | | | | | | | | | | | COWA
| | | | | | | | | | | | CS
| | | | | | | | | | | | DDS
| | | | | | | | | | | | DSCS
| | | | | | | | | | | | GERRI
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Neuropsychological Battery
| | | | | | | | | | | | WAIS-R Block design
| | | | | | | | | | | | WAIS-R Digit Span
| | | | | | | | | | | | WSM-R
Filip 1998 | NR | 6 | Placebo | DSM III | PDD | Mild-Mod | 173 | 142 | 83.0y(≥60y) | 10 mg/d | 24w | CGI | Clock drawing test result
| | | Selegiline | | AD | | | | 29%M | | | Clock Drawing Test
| | | (L-Deprenyl) | | | | | | 100% Institution | | | ECG
| | | | | | | | | | | | EEG
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | Sternberg's Memory Scanning
Freedman 1998 | IS | 5 | Placebo | NINCDS | AD | Probable | 51 | 41 | 70.4y (50–80y) | 5 mg/d for 7 d then 10 mg/d | 6m | ADAS-Noncog | No
| NI | | Deprenyl | | | | | | 47%M | | | BPRS
| | | | | | | | | | | | BSRT
| | | | | | | | | | | | GDS
| | | | | | | | | | | | COWATT
| | | | | | | | | | | | MCPT
| | | | | | | | | | | | CSDD
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | RAGS-E
Mangoni 1991 | NR | 7 | Placebo | NINCDS | DAT | Probable | 119 | 112 | 68.8y (NR) | 10 mg/d | 3m | Blessed-D | GDS result
Auxiliary: | | | L-Deprenyl | DSM III | PDD | Mild-Mod | | | 38%M | | | Digit Span
Smirne 1993 | | | | | | | | | | | | Drawing test
| | | | | | | | | | | | IPSC-E
| | | | | | | | | | | | Short Story
| | | | | | | | | | | | TP
| | | | | | | | | | | | Word Fluency
| | | | | | | | | | | | WMS
Sano 1997 | NI | 5 | Placebo | NINCDS | AD | Moderate | 341 | 341 | 73.4y (NR) | Vitamin E | 2y | ADAS-Cog | No
Auxiliary: | IS | | Vitamin E | | | | | | 35%M | 1000 IU bid | | Blessed Dementia Scale
Thal 1996 | | | Selegiline | | | | | | | Selegiline | | CDR
| | | Selegiline + VitaminE | | | | | | | 5mg bid | | MMSE
| | | | | | | | | | | | Time to end-point (event free survival)

Evidence Table 100. Study results: Selegiline

Author Year | Analysis Groups | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 60d
Agnoli 1992 | OC Analysis
| 1] Placebo | RMT A&R | 1] 62 (17.2) | 3] <0.05 | | | 1] 54 (16.1) | 3] <0.05
| 2] L-Deprenyl | | 2] 54.8 (8.6) | | | | 2] 64.2 (15)
| 3] Difference between placebo and L-Deprenyl | RMT DR | 1] 45.8 (7.3) | 3] NS | | | 1] 40.8 (5.4) | 3] NS
| | | 2] 36.6 (7.2) | | | | 2] 47.2 (8.0)
| | RMT MI | 1] 47 (13.7) | 3] <0.05 | | | 1] 39 (12.7) | 3] <0.05
| | | 2] 37.2 (6.1) | | | | 2] 49 (12.8)
| | TP time | 1] 6.7 (2.7) | 3] <0.05 | | | 1] 7.9 (1.5) | 3] <0.05
| | | 2] 6.2 (2.6) | | | | 2] 5.4 ( 2.7)
| | TP omissions | 1] 11.8 (6.7) | 3] <0.05 | | | 1] 14 (6.8) | 3] <0.05
| | | 2] 8.5 (3.9) | | | | 2] 5.2 (2.7)
| | TP errors | 1] 10.4 (7.0) | | | | 1] 5.8 (4.9) | 3] <0.05
| | | 2] 10.2 (14) | | | | 2] 1.0 (1.4)
| | GBS Intellectual function | 1] 22.4 (8.4) | 3] <0.05 | | | 1] 23 (11.1) | 3] <0.05
| | | 2] 20 (8.9) | | | | 2] 18 (9.6)
| | GBS verb fluency | 1] 8.6 (3.5) | 3] <0.05 | | | 1] 6.9 (2.5) | 3] <0.05
| | | 2] 5.5 (2.5) | | | | 2] 7.1 (3.2)
| | GBS picture copying | 1] 16 (2.9) | 3] <0.05 | | | 1] 13 (4.2) | 3] <0.05
| | | 2] 16.2 (3) | | | | 2] 17.2 (3)

Evidence Table 111. Study results: Selegeline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 8m | | Final: (specify) 15m
Burke 1993a | OC Analysis
Burke 1993 | 1] Placebo | CDR | 1] 1.0 ( 0.0) | | 1] 1.2 (0.5) | 3] <0.01 | 1] 1.3 (0.5) | 3] 0.31
| 2] L-Deprenyl | | 2] 1.0 ( 0.0) | | 2] 1.3 (0.5) | | 2] 1.3 (0.6)
| 3] Placebo vs. L-Deprenyl vs. baseline | CDRS-sum of boxes | 1] 5.7 (1.1) | | 1] 6.7 (2.3) | 3] <0.01 | 1] 8.3 (3.2) | 3] NS
| | | 2] 6.2 (1.4) | | 2] 7.4 (2.4) | | 2] 7.8 (3.1)
| | MMSE | 1] 19.6 (4.5) | | 1] 17.7 (7.8) | 3] <0.01 | 1] 13.1 (7.4) | 3] 0.25
| | | 2] 18.8 (5.0) | | 2] 16.1 (6.2) | | 2] 15.5 (6.3)
| | BDS | 1] 5.4 (2.5) | | 1] 6.1 (3.9) | 3] NS | 1] 7.7 (3.9) | 3] NS
| | | 2] 7.7 (4.0) | | 2] 7.5 (4.2) | | 2] 9.6 (4.8)
| | GERRI | 1] 101.2 (21.4) | | 1] 106.9 (23.6) | 3] NS | 1] 118 (23.6) | 3] NS
| | | 2] 110.0 (30.4) | | 2] 112.1 (30.7) | | 2] 113.9 (33.6)
| | DSS | 1] 1.8 (1.4) | | 1] 1.5 (1.7) | 3] NS | 1] 0.9 (1.8) | 3] NS
| | | 2] 0.8 (1.0) | | 2] 0.7 (1.1) | | 2] 0.5 (0.9)
| | DSCS | 1] 2.1 (1.5) | | 1] 2.8 (2.0) | 3] NS | 1] 2.1 (2.4) | 3] NS
| | | 2] 2.5 (1.6) | | 2] 2.6 (1.9) | | 2] 2.4 (1.6)
| | CS | 1] 4.3 (4.0) | | 1] 3.2 (3.1) | 3] NS | 1] 4.7 (4.7) | 3] NS
| | | 2] 3.2 (2.3) | | 2] 3.7 (3.9) | | 2] 2.4 (1.9)
| | BPRS | 1] 24.4 (2.9) | | 1] 24.6 (3.7) | 3] NS | 1] 28.2 (6.2) | 3] NS
| | | 2] 25.6 (3.5) | | 2] 28.4 (9.0) | | 2] 25.1 (5.9)

Evidence Table 112. Study results: Selegiline

REF Id# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) 12w | | Final: (specify) 24 w
| Filip 1999 | OC Analysis
| | 1] Placebo | SMST-intercept | 1] 87.8 (56.4) | | 1] 82.0 (56.2) | | 1] 77.8 (54.2) | 8] NS
| | 2] Selegiline | | 2] 97.6 (54.8) | | 2] 67.5 (42.2) | | 2] 69.2 (51.5) | 9] 0.011
| | 3] Placebo (normal subgroup by CDT) | | 3] 98.3 (53.0) | | 3] 86.7 (64.7) | | 3] 73.5 (55.7)
| | 4] Selegiline (normal subgroup by CDT) | | 4] 103.6(53.4) | | 4] 70.4 (34.9) | | 4] 71.8 (65.2)
| | 5] Placebo (pathologic subgroup by CDT) | | 5] 79.6 (58.3) | | 5] 78.3 (49.3) | | 5] 81.1 (53.5)
| | 6] Selegiline (pathologic subgroup by CDT) | | 6] 94.7 (55.8) | | 6] 66.1 (45.6) | | 6] 68.0 (44.3)
| | 7] Selegiline vs. Placebo (ALL) | SMST-slope | 1] 6.2 (13.8) | | 1] 4.8 (9.3) | | 1] 4.6 (8.3) | 8] NS
| | 8] Selegiline vs. Placebo (normal subgroup) | | 2] 2.5 (10.8) | | 2] 7.4 (8.4) | | 2] 6.9 (9.5) | 9] 0.047
| | 9] Seleiline vs. Placebo (pathologic subgroup) | | 3] 6.3 (12.8) | | 3] 4.9 (12.7) | | 3] 5.8 (10.3)
| | | | 4] 4.2 (8.0) | | 4] 9.8 (10.6) | | 4] 9.7 (11.6)
| | | | 5] 6.1 (14.7) | | 5] 4.7 (5.7) | | 5] 3.7 (6.4)
| | | | 6] 1.7 (11.9) | | 6] 6.2 (7.0) | | 6] 5.6 (8.1)
| | | SMST-total error | 1] 7.4 (5.7) | | 1] 11.1 (8.7) | | 1] 11.3 (10.1) | 8] NS
| | | | 2] 8.3 (6.8) | | 2] 9.8 (7.8) | | 2] 9.2 (8.5) | 9] 0.029
| | | | 3] 6.6 (3.9) | | 3] 9.8 (6.4) | | 3] 9.5 (7.1)
| | | | 4] 5.8 (5.1) | | 4] 8.2 (7.8) | | 4] 5.9 (7.3)
| | | | 5] 8.0 (6.8) | | 5] 12.1 (10.2) | | 5] 12.8 (11.8)
| | | | 6] 9.5 (7.2) | | 6] 105. (7.7) | | 6] 10.8 (8.6)
| | | CDT | 1] 3.1 (1.4) | | | | 1] 3.0 (1.3) | 8] 0.001
| | | | 2] 3.2 (1.2) | | | | 2] 2.8 (1.4) | 9] NS
| | | | 3] 1.8 (0.7) | | | | 3] 2.7 (1.3)
| | | | 4] 2.1 (0.7) | | | | 4] 1.9 (1.1)
| | | | 5] 4.1 (1.0) | | | | 5] 3.3 (1.3)
| | | | 6] 3.7 (0.9) | | | | 6] 3.3 (1.31)
| | | MMSE | 1] 3.9 (1.1) | | | | 1] 3.7 (1.4) | 7] 0.004
| | | | 2] 3.4 (1.1) | | | | 2] 3.9 (1.1) | 8] 0.041
| | | | 3] 3.8 (1.1) | | | | 3] 3.6 (1.4) | 9] NS
| | | | 4] 3.5 (0.8) | | | | 4] 4.2 (1.1)
| | | | 5] 3.9 (1.1) | | | | 5] 3.7 (1.3)
| | | | 6] 3.4 (1.3) | | | | 6] 3.8 (1.1)
| | | CGI | | | | | | 7] <0.005

Evidence Table 113. Study results: Selegiline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Freedman 1998 | ITT OC Analysis
| 1] Placebo | [underlined: BPRS] | 1] 24.0 (3.3) | | | | 1] 25.8 (6.0) | 5] 0.6
| 2] L-Deprenyl | | 2] 23.8 (3.5) | | | | 2] 24.8 (4.0)
| 3] Change from baseline placebo | | | | | | 3] 1.79 (4.5)
| 4] Change from baseline L-Deprenyl | | | | | | 4] 1.02 (2.9)
| 5] Difference between placebo and L-Deprenyl in change from baseline | MMSE | 1] 18.4 (4.4) | | | | 1] 18.5 (6.2) | 5] NS
| | | 2] 17.3 (3.7) | | | | 2] 17.3 (5.1)
| | GDS | 1] 3.9 (0.8) | | | | 1] 4.0 (0.8) | 5] NS
| | | 2] 4.3 (0.8) | | | | 2] 4.4 (0.9)
| | ADAS-Noncog | 1] 3.7 (3.1) | | | | 1] 4.3 (4.0) | 5] NS
| | | 2] 3.4 (2.3) | | | | 2] 2.7 (2.3)
| | CSDD | 1] 3.3 (2.3) | | | | 1] 3.2 (3.0) | 5] NS
| | | 2] 3.1 (1.9) | | | | 2] 2.6 (1.9)
| | BSRT | 1] 24.5 (11.7) | | | | 1] 23.2 (12.6) | 5] NS
| | | 2] 20.4 (9.4) | | | | 2] 20.4 (10.5)
| | RAGS-E | 1] 39.3 (8.8) | | | | 1] 39.0 (11.1) | 5] NS
| | | 2] 38.1 (7.9) | | | | 2] 37.6 (9.6)
| | COWAT | 1] 28.4 (15.3) | | | | 1] 28.0 (18.4) | 5] NS
| | | 2] 26.6 (17.2) | | | | 2] 22.4 (15.8)
| | MCPT | 1] 24.6 (3.0) | | | | 1] 24.6 (1.8) | 5] NS
| | | 2] 23.4 (4.4) | | | | 2] 24.6 (2.0)

Evidence Table 114. Study results: Selegeline

REF Id# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) 60d | | Final: (specify) 90d
| Mangoni 1991 | OC Analysis
| Smirne 1993 | 1] Placebo | BDS-1 daily living | 1] 8.73 (4.34) | | 1] 8.94 (4.57) | | 1] 9.18 (4.72) | 4] <0.01
| | 2] L-Deprenyl 10 mg/d | | 2] 8.76 (3.98) | | 2] 7.33 (3.49) | | 2] 6.86 (3.43)
| | 3] ANOVA within treatment | BDS-II Total | 1] 23.57 (8.69) | | 1] 20.80 (9.17) | | 1] 21.24 (9.21) | 4] <0.01
| | 4] Multivariate ANOVA between treatments including all four test occasions | | 2] 23.35 (7.40) | | 2] 25.52 (7.06) | | 2] 26.69 (6.42)
| | 5] Placebo GDS=3 | IPSC-E Psychic Total | 1] 104.98 (26.10) | | 1] 107.49 (27.64) | | 1] 113.80 (31.27) | 4] <0.01
| | 6] Placebo GDS=4 | | 2] 116.32 (32.39) | | 2] 101.71 (21.43) | | 2] 96.16 (17.81)
| | 7] Placebo GDS=5 | IPSC-E Somatic Total | 1] 24.71 (9.94) | | 1] 25.04 (9.75) | | 1] 25.37 (9.38) | 4] <0.05
| | 8] L-Deprenyl GDS=3 | | 2] 24.68 (9.24) | | 2] 23.08 (7.00) | | 2] 22.27 (7.36)
| | 9] L-Deprenyl GDS=4 | Digit Span | 1] 4.45 (1.35) | | 1] 4.24 (1.58) | | 1] 3.93 (1.50) | 4] <0.01
| | 10] L-Deprenyl GDS=5 | | 2] 4.19 (1.64) | | 2] 4.81 (1.23) | | 2] 4.90 (1.33)
| | | WMS short story - int. | 1] 3.73 (3.66) | | 1] 2.89 (2.68) | | 1] 2.33 (2.88) | 4] <0.01
| | | | 2] 2.87 (2.65) | | 2] 4.60 (3.69) | | 2] 4.94 (3.83)
| | | WMS short story-del | 1] 2.01 (2.77) | | 1] 2.49(2.78) | | 1] 1.78 (2.45) | 4] <0.01
| | | | 2] 3.10 (3.08) | | 2] 3.30 (3.86) | | 2] 3.9 (3.49)
| | | Word fluency | 1] 9.41 (5.37) | | 1] 7.13 (4.91) | | 1] 7.35 (5.84) | 4] <0.01
| | | | 2] 8.26 (5.38) | | 2] 9.75 (5.71) | | 2] 10.47 (5.62)
| | | Drawing test | 1] 12.33 (5.98) | | 1] 11.73 (6.14) | | 1] 11.39 (6.02) | 4] <0.05
| | | | 2] 13.76 (4.97) | | 2] 14.78 (4.64) | | 2] 15.82 (4.23)
| | | TPAT | 5] 25 (9) | | 5] 25 (8) | | 5] 25 (8)
| | | | 6] 19 (8) | | 6] 15 (11) | | 6] 16 (10)
| | | | 7] 11 (8) | | 7] 8 (10) | | 7] 8 (10)
| | | | 8] 24 (8) | | 8] 25 (7) | | 8] 27 (5)
| | | | 9] 20 (9) | | 9] 24 (7) | | 9] 26 (5)
| | | | 10] 13 (13) | | 10] 16 (13) | | 10] 20 (10)

Evidence Table 115. Study results: Selegiline - Vitamin E

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 10m | | Final: (specify) 20m
Sano 1997 | ITT Analysis
Thal 1996 | 1] Placebo | [underlined: Event-free survival] | | | 1] 79% | | 1] 40% | 5] 0.077
| 2] Vitamin E 1000IU bid | | | | 2] 86% | | 2] 51% | 6] 0.087
| 3] Selegeline 5mg bid | | | | 3] 60% | | 3] 60% | 7] 0.21
| 4] Vitamin E 1000IU bid + Selegiline 5mg bid | | | | 4] 80% | | 4] 49%
| 5] Vitamin E 1000IU bid vs Placebo from baseline | Event-free survival with MMSE as covariate | | | | | | 5] 0.001
| 6] Selegeline 5mg bid vs Placebo from baseline | | | | | | | 6] 0.012
| 7] Vitamin E 1000IU bid + Selegiline 5mg bid vs Placebo from baseline | | | | | | | 7] 0.049

Evidence Table 116. Adverse Events: Selegiline

Adverse events (AE) identified in include studies | Agnoli, 1992 | Burke, 1993 | Filip, 1999 | Freedman, 1998 | Mangoni, 1991 | Sano, 1997
Withdrawn (%) due to AE | T:0 | T: 0 | T: 9 | T: 0 | T: 4 | T: 0
| C:0 | C:0 | C:4 | C:0 | C:2 | C:0
AE Checklist (Max 5) | 0 | 3 | 1 | 3 | 3 | 1
None Reported | X | X
Balance | | | | | | S*
Accidental Injury
Dizziness | | | | X | X
Falls | | | | | | S*
Behavioral
Agitation | | | | X
Cardiovascular | | | X | | | NS*
Arrhythmia | | | | X
Hypotension
Hypertension
Extrapyramidal | | | | | | NS*
Tremor | | | | X
Gastrointestinal | | | | X | X | NS*
Abdominal pain
Constipation
Diarrhea
Dyspepsia | | | | | X
Nausea, vomiting | | | | | X
Metabolic/nutritional | | | | X
Eating disorder
Weight Change | | | | X
Neurological | | | X | | | NS*
Asthenia
Psychiatric | | | X
Anxiety | | | | | X
Confusion, delirium | | | | X
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other | | | X | X | X | S*
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia | | | X
Headache | | | | X
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder | | | | X | | NS*
Sleep disorder | | | | X
Urinary disorder

NR= Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x= Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS*= Reported and tested for statistical differences between two (three) treatment groups

[ ]= Symptom NOT reported in the paper

Evidence Table 117. Key Characteristics. Various non-cholinergic neurotransmitter/neuropeptide modifying agents

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total Number Randomized | Numer Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Dehlin 1985 | NR | 6 | Placebo | DSM III | PDD | Mild-Sev | 43 | 40 | 82.0y (65–93y) | 200 mg bid | 4w | CPRS | No
| | | Alaproclate | | MID | | | | 44%M | | | GBS
| | | | | Mixed | | | | 100%Institution
Alvarez 2000 | PI | 5 | Placebo | NINCDS | AD | Mild-Mod | 45 | 42 | Mean NR (≥50y) | 360 mg/d or | 4w | ADAS-Cog | Disease Severity
| | | Anapsos | DSM IV | VaD | | | | %M NR | 720 mg/d
| | | | | | | | | 100% Community
Cutler 1993 | PI | 6 | Placebo | DSM-III-R | AD | Mild-Mod | 69 | 54 | 72.0y (54–92y) | 300 mg tid | 12w + 4w washout | ADAS | No
| | | BMY | NINCDS | | | | | 41%M | | | CGI
| | | | | | | | | | | | CNTB
| | | | | | | | | | | | GERRI
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | WFT
Tariot 1998 | NI | 7 | Placebo | DSM-III-R | AD | Probable | 51 | 47 | 85.5y (>60y) | 100 mg/d (start) | 6w | BPRS | No
| IS | | Carbamazepine | NINCDS | Mixed | Possible | | | 20%M | increase by 50 mg q2–5d; | | BRSD
| | | | | VaD | | | | 98% White | modal dose: 300 mg/d | | CGI
| | | | | | | | | 100%Institution | | | MMSE
| | | | | | | | | | | | Overt Aggression Scale
| | | | | | | | | | | | PSMS
Olin 2001 | NI | 5 | Placebo | NINCDS | AD | Mild-Sev | 21 | 16 | 74.7y (63–86y) | 100 mg/d (Day 1–3) | 6w | BPRS | No
| | | Carbamazepine | | | | | | 33%M | 100 mg bid (Day 4–7) | | CBC/SMAC Levels
| | | | | | | | | 71% White | 100 mg bid (Day 8–14) | | CGIC
| | | | | | | | | 100% Community Agitation | 100 mg gid (end) | | Ham-D
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSMS
Nyth1990 | NR | 7 | Placebo | DSM III | AD, SDAT | Mild-Mod | 98 | 61 | 77.6y (NR) | 20 mg/d for 2 w | 4w | CGI | AD/SDAT vs VaD
| | | Citalopram | | VaD | | | | 22%M | 30 mg/d for 2 w | | GBS
| | | | | PDD | | | | | | | MADRS
| | | | | MID | | | | | | | UKU side-effect rating scale
| | | | | | | | | | | | Laboratory tests
Pollock 2002 | NI | 6 | Placebo | DSM IV | AD | Probable | 85 | 39 | 80.6y (NR) | 10 mg/d (c) or 0.05 mg/kg (p) for 3 d | 17d | BPRS | No
| | | Citalopram | NINCDS | VaD | Possible | | | 35%M | 20 mg/d (c) | | Laboratory tests
| | | Perphenazine | | MIXED | | | | 90% White | 0.1 mg/kg/d (p) for 14 d | | MMSE
| | | | | | | | | | | | Neurobehavioural Rating Scale
| | | | | | | | | | | | UKU Side effect scale
Porsteinsson 2001 | IS | 7 | Placebo | DSM IV | AD | Probable | 56 | 49 | 85.0y (>60y) | 375 mg/d + 125 mg/q3d (until side effects) | 6w | BPRS | No
| PI | | Divalproex | NINCDS | VaD | Possible | | | 30%M | | | BRSD
| | | | | MIXED | | | | 100% Institution | | | CGI
| | | | | | | | | | | | CMAI
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Overt Aggression
| | | | | | | | | | | | Scale
| | | | | | | | | | | | PSM
Tariot 2000b | IF | 6 | Placebo | DSM IV | DAT | Probable | 173 | 100 | 83.4y (68–100y) | 125 mg bid + 125 mg/d until 20 mg/kg/d | 6w | BPRS | No
| | | Divalproex | | VaD | | | | 35%M | | | BRMS
| | | | | | | | | 158 White | | | CGI
| | | | | | | | | 11 Black | | | CMAI
| | | | | | | | | 3 Hispanic | | | Laboratory tests
| | | | | | | | | 100% Institution | | | MMSE
Olafsson 1992 | NR | 6 | Placebo | DSM III | SDAT | NR | 46 | 29 | 81.0y (median) (65–93y) | 50 mg/d (start) | 6w | GBS Scale | No
| | | Fluvoxamine | | MID | | | | 41%M | 150 mg/d (end) | | Neuropsychological Battery
| | | | | PDD | | | | 100% Institution | | | Trail Making Test
Reifler 1989 | NI | 6 | Placebo | DSM III | PDD | Mild-Mod | 61 | 57 | 72.0y (NR) | 25 mg/d + 25 mg/w until therapeutic response | 8w | DRS | Depression
| IS | | Imipramine | | AD | | | | 41%M | 83 mg/d (mean) | | ECG
| | | | | | | | | 100% Community Depression | | | Ham-D
| | | | | | | | | | | | HDS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | OARSADL
| | | | | | | | | | | | WAIS-R
Claus 1998 | NR | 5 | Placebo | NINCDS | AD | Mild-Modly Sev | 22 | 22 | 74.1y (NR) | 0.075 mg/d (start) | 8w | CGI | No
| | | Lisuride | | | | | | 50%M | increments of 0.075 mg/w until 0.3 mg/d | | CVLT
| | | | | | | | | | | | DMSE
| | | | | | | | | | | | MMSE
Thal 2000b | PI | 5 | Placebo | NINCDS | AD | Mild-Mod | 496 | 303 | 75.5y (47–95y) | 2 weeks dose titration then fixed doses: 25, 50, or 100 mg bid | 6m | ADAS-Cog | No
| | | Lu 25–109 | | | | | | 42%M | | | ADCS-CGIC
| | | | | | | | | 92% White | | | ADCS-ADL
| | | | | | | | | 8% Other | | | BEHAVE-AD
| | | | | | | | | Community (100%)
Fuchs 1992 | NR | 5 | Placebo | DSM-III-R | PDD | NR | 127 | 94 | 80.0y (median) (48–96y) | From 25 to 75 mg tid | 8w | Blood pressure | No
| | | Maprotiline | | | | | | 43%M | | | GDS
| | | | | | | | | 100% Institution Mild depression | | | MMS
| | | | | | | | | | | | Std
| | | | | | | | | | | | Video rating of global impression
Passeri 1987 | NR | 6 | Placebo | DSM III | MID | Probable | 122 | 122 | Mean NR (60–80y) | 100 mg bid | 3m | CGI | SDAT vs MID
| | | Minaprine | NINCDS | SDAT | | | | 30%M | | | HDRS
| | | | | | | | | 100% Institution | | | Neuropsychological Battery
| | | | | | | | | | | | Nowlis MRS
| | | | | | | | | | | | SHGRS
| | | | | | | | | | | | SRT
| | | | | | | | | | | | TP
Roth 1996 | NR | 7 | Placebo | DSM III | AD | Mild-Mod | 511 | NR | 73.6y (60–90y) | 400 mg/d | 6w | BGP | No
| | | Moclobemide | | | | | | 25%M | | | CGAE
| | | | | | | | | 22% Community | | | CGI-T
| | | | | | | | | 78% Institution, Depression | | | ECG
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | SCAG
Moller 2001 | NR | 7 | Placebo | NINDS-AIREN | VaD | Mild-Sev | 378 | 278 | 71.5y (50–85y) | 600 mg/d or 600 mg/d | 6m | ADAS-cog | No
| | | Naftidrofuryl | DSM-III-R | MIXED | | | | 45%M | | | CGI
| | | | | | | | | | | | CT
| | | | | | | | | | | | HIS
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MADRS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | MRI
| | | | | | | | | | | | NOSGER
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Trage 8 test kit
Street 2000 | IF | 8 | Placebo | NINCDS | AD | Moderate | 206 | 152 | 82.8y (61–97y) | Fixed doses: 5, 10 or 15 mg/d | 6w | ADAS-Cog | Psychosis
Auxiliary: | | | Olanzapine | | | | | | 39%M | | | Barnes Akathisia | Cognitive impairment level
Clark 2001 | | | | | | | | | 100% Institution | | | BPRS
Kennedy 2001 | | | | | | | | | | | | ECG
Mintzer 2001 | | | | | | | | | | | | EPS scales
Street 2002 | | | | | | | | | | | | MMSE
| | | | | | | | | | | | NPI/NH
| | | | | | | | | | | | Simpson-Angus Gait
Amaducci 1988 | IS | 5 | Placebo | NINCDS | AD | Mild-Sev | 142 | 115 | 62.1y (40–80y) | 200mg/d | 3m | BDS | Severity of illness
Auxiliary: | | | Phosphatidylserine | | | | | | 40%M | | | Block tapping
SMID 1987 | | | | | | | | | 100% Institution | | | BSR
| | | | | | | | | | | | CASE
| | | | | | | | | | | | RMT
| | | | | | | | | | | | SCT test
| | | | | | | | | | | | Self Test
| | | | | | | | | | | | TK
Crook 1992a | PI | 5 | Placebo | NINCDS | AD | Mild-Mod | 51 | 49 | 71.0y (55–85y) | 100 mg tid | 12w | CGI | Severity of illness
| | | Phosphatidylserine | DSM III | PDD | | | | 31%M | | | Concern of memory
| | | | | | | | | 100% Community | | | Facial recognition
| | | | | | | | | | | | First-last name test
| | | | | | | | | | | | Interviewer notices memory loss
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Name-Face association
| | | | | | | | | | | | Recall Tests
| | | | | | | | | | | | Verbal Selective Reminding
| | | | | | | | | | | | WAIS
Magai 2000 | PI | 7 | Placebo | DSM IV | AD | Late-stage | 31 | 27 | 89.0y (NR) | 25 mg/d (week 1–2) | 8w | AFBS | No
| | | Sertraline | NINCDS | | | | | 0%M | 50 mg/d (week 3–4) | | CMAI
| | | | | | | | | 84% White | 100 mg/d (week 5–6) | | CSDD
| | | | | | | | | 16% Other | | | Facial Behavior
| | | | | | | | | 100% Institution | | | GS
| | | | | | | | | Major depression
Lyketsos 2000 | NI | 6 | Placebo | NINCDS | AD | Mild-Mod | 22 | 16 | 77.0y (NR) | 25 mg/d (start) increased by 50 mg/w to 150/d | 13w | ADL | No
| | | Sertraline | DSM IV | | | | | 41%M | | | CS
| | | | | | | | | 77% White | | | HAM-D
| | | | | | | | | 23% Other | | | IADL
| | | | | | | | | 100% Community Depression | | | MMSE
| | | | | | | | | | | | PDRS
Petracca 2001 | NR | 7 | Placebo | NINCDS | AD | Probable | 41 | 35 | 70.8y (NR) | 10 mg/d for w 1 | 6w | CGI | No
| | | Fluoxetine | DSM IV | | | | | 45%M | 20 mg/d for w 2 | | FIM
| | | | | | | | | 76% Major depression | 30 mg/d for w 3 | | HAM-A
| | | | | | | | | 24% minor depression | 40 mg/d for w 4 to 6 | | HAM-D
| | | | | | | | | | | | MMSE
Auchus 1997 | NI | 6 | Placebo | NINCDS | AD | Probable | 15 | 12 | 75.6y (NR) | 3 mg/d | 6w | BEHAVE-AD | No
| | | Haloperidol | | | | | | 33%M | 20 mg/d | | CMAI
| | | Fluoxetine | | | | | | 100% Community | | | CSI
Katz 1999 | IF | 6 | Placebo | DSM IV | AD | Mod-Sev | 625 | 435 | 82.7y (≥55y) | 0.5, 1.0 or 2.0 mg/d | 12w | BEHAVE-AD | Gender
Auxiliary: | IS | | Risperidone | | VaD | | | | 32%M | | | | Age
Jeste 2000 | | | | | Mixed | | | | 100% Institution | | | | Race
Pryse-Phillips 2000
Teri 2000 | NI | 6 | Placebo | NINCDS | AD | Probable | 149 | 91 | 74.8y (NR) | Haloperidol: | 16w | ABID | No
| IS | | Haloperidol | | | Possible | | | 45%M | 0.5 mg/d (start) | | ADCS-CGIC
| | | Trazodone | | | | | | 85% White | 3 mg/d (end) | | BRSD-CERAD
| | | BMT | | | | | | 15% Other Community | Trazodone: | | Caregiver Burden Screen
| | | | | | | | | | 50 mg/d (start) | | CMAI
| | | | | | | | | | 300 mg/d (end) | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSM
| | | | | | | | | | | | RMBPC
| | | | | | | | | | | | SCB
DeDeyn 1999 | PI | 7 | Placebo | DSM IV | PDD | Severe | 344 | 223 | 81.0y (median) (56–97y) | Titration: 0.25 mg q4d up to 1 mg bid, then if no therapeutic effect and no signs of EPS 4 mg/d | 12w | BEHAVE-AD | No
| | | Risperidone | | VaD | | | | 44%M | 4 mg/d | | CGI | VaD vs ALL
| | | Haloperidol | | Mixed | | | | | | | CMAI
| | | | | | | | | | | | ECG
| | | | | | | | | | | | EPS
| | | | | | | | | | | | ESRS
| | | | | | | | | | | | FAST
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
Allain 2000 | NR | 6 | Placebo | DSM-III-R | AD | Mild-Mod | 306 | 259 | 79.6y (55–94y) | Tiapride: | 21d | CGI | No
| | | Tiapride | | | | | | 36%M | 100 mg/d (Day 1–3) | | Global Improvement
| | | Haloperidol | | | | | | 100% White | 200 mg/d (Day 4-end) | | MMSE
| | | | | | | | | 100% Institution | Haloperidol: | | MOSES
| | | | | | | | | Irritability | 2 mg/d (Day 1–3) | | UKU
| | | | | | | | | Aggressiveness | 4 mg/d (Day 4-end)
Meehan 2002 | IF | 6 | Placebo | NINCDS | AD | Possible-Probable | 272 | 248 | 77.6y (54–97y) | Additional injections optional | 24h | ACES | No
| | | Olanzapine | DSM IV | VaD | | | | 39%M | Olanzapine: 12.5 mg/d (max) | | BPRS Positive
| | | Lorazepam | | MIXED | | | | 92% White | Loxapine: 2.5 mg/d (max) | | BPRS Total
| | | | | | | | | 100%Institution | | | CGI-S
| | | | | | | | | Agitation | | | CMAI
| | | | | | | | | | | | COSTART
| | | | | | | | | | | | ECG
| | | | | | | | | | | | MMSE Total
| | | | | | | | | | | | NPI/NH
| | | | | | | | | | | | PANSS-EC
| | | | | | | | | | | | Simpson-Angus score
Barnes 1982 | PI | 6 | Placebo | DSM III | PDD | NR | 60 | 34 | 83.0y (>65y) | Titration: 1 capsule every 2–5 days as needed | 8w | BPRS | No
| | | Thioridazine | | MID | | | | %M NR | Thioridzine: | | CGI
| | | Loxapine | | | | | | 100% Institution | 25 mg/d (start) | | NOSIE
| | | | | | | | | Irritability, agitation | 62.5 mg/d (mean) | | SCAG
| | | | | | | | | | Loxapine:
| | | | | | | | | | 5 mg/d (start)
| | | | | | | | | | 10.5 mg/d (mean)
Pollock 2002 | NI | 6 | Placebo | DSM IV | AD | Mod-Sev | 85 | 39 | 80.6y (NR) | Citalopram: | 17d | BPRS | No
| | | Citalopram | NINCDS | VaD | | | | 35%M | 10 mg/d (Day 1–3) | | Laboratory tests
| | | Perphenazine | | MIXED | | | | 89% White | 20 mg/d (Day 4–17) | | MMSE
| | | | | | | | | 100% Institution | Perphenazine: | | Neurobehavioural Rating Scale
| | | | | | | | | | 0.05 mg/kg/d (Day 1–3) | | UKU Side effect scale
| | | | | | | | | | 0.1 mg/kg/d (Day 4–17)
Bodick 1997 | IF | 6 | Placebo | NINCDS | AD | Mild-Mod | 343 | 205 | 75.0y (60–90y) | 75mg/d, or 150 mg/d or 225 mg/d | 6m | ADAS-Cog | No
Auxiliary: | | | Xanomeline | | | | | | 43%M | | | ADSS
Veroff 1998 | | | | | | | | | 92% White | | | CIBIC+
Satlin 1997 | | | | | | | | | 8% Other | | | CNTB
| | | | | | | | | 100% Community | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSGER
Chan 2001 | NI | 6 | Haloperidol | DSM IV | AD | Severe | 58 | 55 | 80.5y (≥55y) | Titration: increases of 0.5 mg/q2d | 12w | BEHAVE-AD | No
| | | Risperidone | | VaD | | | | 28%M | 2 mg/d | | CMAI
| | | | | | | | | Community and institution | | | CMMSE
| | | | | | | | | All Chinese | | | FAST
| | | | | | | | | | | | Simpson-Angus Scale
Taragano 1996 | NR | 7 | Fluoxetine | NINCDS | AD | Probable | 37 | 25 | 72.1y (NR) | 10 mg/d | 45d | HAM-D | No
| | | Amitriptyline | | | | | | 22%M | 25 mg/d | | MMSE
Ancill 1991 | IF | 6 | Lorazepam | DSM-III-R | AD | NR | 40 | 27 | 78.9y (>65y) | 0.5 mg tid | 28d | AE | No
| | | Alprazolam | | | | | | 50%M | 0.25 mg tid | | CGI
| | | | | | | | | 100% Institution Agitation
Karlsson 2000 | PI | 7 | Citalopram | DSM-III-R | AD | Mild-Mod | 345 | 289 | 75.0y (64–95y) | Citalopram: | 12w | CGI | No
| | | Mianserin | | | | 53 demented | 50 demented | 21%M | 20 mg/d (week 1–4) | | GBS
| | | | | | | | | 58% Community | 40 mg/d (week 5–12) | | MADRS
| | | | | | | | | 42% Institution | Mianserin: | | MMSE
| | | | | | | | | Major depression | 30 mg/d (week 1–4) | | WHO Well-being
| | | | | | | | | | 60 mg/d (week 5–12)
Coccaro 1990 | NI | 6 | Haloperidol | DSM III | PDD | Mild-Sev | 59 | 52 | 75.3y (58–99y) | 5 mg/d | 8w | ADAS | No
| IS | | Oxazepam | | | | | | 59%M | 60 mg/d | | BPRS
| | | Diphen-hydramine | | | | | | 100% Institution | 200 mg/d | | CDRS
| | | | | | | | | Agitation | | | NOSIE
| | | | | | | | | | | | PSMS
Carlyle 1993 | NR | 5 | Loxapine | DSM-III-R | PDD | Mod-Sev | 40 | 31 | 79.0y (65–91y) | Loxapine: | 28d | Aggression Chart | No
| | | Haloperidol | | AD | | | | 55%M | 5 mg bid (start) | | Blood count
| | | | | MID | | | | 100% Institution | 50 mg tid (end) | | Electrolytes
| | | | | | | | | Aggression | Haloperidol: | | ESR
| | | | | | | | | | 1 mg bid (start) | | Renal & Liver Function Test
| | | | | | | | | | 10 mg tid (end)
Passeri 1993 | NR | 5 | 5′-MTHF | DSM III-R | AD | Mild-Moderate | 96 | 96 | Mean NR (65–94y) | 50 mg/d | 8w | Blood levels | AD vs MID
| | | Tradozone | | MID | | | | 45%M | 100 mg/d | | HDRS
| | | | | | | | | Depression | | | RVM - immediate recall
| | | | | | | | | | | | RVM - delayed recall
Gutzmann 1997 | NR | 7 | Tiapride | DSM-III-R | Mixed | Mild-Sev | 176 | 156 | 73.8y (40–100y) | 400 mg/d | 28d | AGGR | No
| | | Melperone | | | | | | 29%M | 100 mg/d | | AIMS
| | | | | | | | | 100% Institution | | | BePU (German Test)
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | CGI
| | | | | | | | | | | | CLEX
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | RAPSU (German Test)
| | | | | | | | | | | | VAS-ADL
Katona 1998 | NR | 6 | Paroxetine | DSM-III-R | PDD | Mild-Mod | 198 | 147 | 76.6y (59–98y) | Paroxetine: | 8w | CGI | No
| | | Imipramine | | | | | | 22%M | 20 mg/d (week 1–2) | | Cornell Rating Scale
| | | | | | | | | 99% White | 30 mg/d (week 3–4) | | GBS
| | | | | | | | | 1% Other | 40 mg/d (end) | | MADRS
| | | | | | | | | Depression | Imipramine:
| | | | | | | | | | 25 mg/d (3d)
| | | | | | | | | | 50 mg/d (11d)
| | | | | | | | | | 75 mg/d (2w)
| | | | | | | | | | 100 mg/d (end)
Petrie 1982 | PI | 6 | Placebo | DSM III | PDD | Mod-Sev | 64 | 37 | 72.7y (60–95y) | Gradually increased with a fixed-flexible dosage for 4 w | 10w | BPRS | No
| | | Loxapine | | MID | | | | 49%M | 50 mg/d | | CGI
| | | Haloperidol | | | | | | 100% insstitution | 10 mg/d | | CGIC
| | | | | | | | | | variable | | EKG
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | SCAG

Evidence Table 118. Study results: Alaproclate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Dehlin 1985 | Endpoint Analysis | | Estimated | | | | Estimated
| 1] Placebo | GBS motor function | 1] 13.2 | | | | 1] 14.1 | 3] <0.05
| 2] Alaproclate 200 mg bid | | 2] 9.8) | | | | 2] 8.9
| 3] Alaproclate vs. Placebo | GBS intellectual function | 1] 25.7 | | | | 1] 26.4 | 3] NS
| | | 2] 21.8 | | | | 2] 20.1
| | GBS emotional function | 1] 6.0 | | | | 1] 5.3 | 3] NS
| | | 2] 4.8 | | | | 2] 3.8

Evidence Table 119. Study results: Anapsos

REF ID# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) | | Final: (specify) 4w
| Alvarez, 2000 | OC Analysis
| | 1] Placebo total population | [underlined: ADAS-Cog] | 1] 28.78 (4.06)* | | | | 1] 29.20 (3.84)* | 2] <0.05 vs. baseline
| | 2] Anapsos 360 mg qid total population | | 2] 36.07 (4.17)* | | | | 2] 34.60 (4.48)* | 5] <0.05 vs. baseline
| | 3] Anapsos 720mg qid total population | | 3] 34.44 (3.16)* | | | | 3] 35.11 (3.45)* | 5] <0.01 vs. placebo
| | 4] Placebo mild dementia subpopulation | | 4] 21.00 (4.09)* | | | | 4] 22.51 (4.04)* | 8] <0.05 vs. baseline
| | 5] Anapsos 360 mg qid mild dementia sub-population | | 5] 27.98 (4.53)* | | | | 5] 25.42 (4.57)* | 8] <0.05 vs. placebo
| | 6] Anapsos 720 mg qid mild dementia subpopulation | | 6] 28.15 (3.59)* | | | | 6] 27.21 (3.60)*
| | 7] Placebo Alzheimer's Disease subpopulation | | 7] 29.34 (7.93)* | | | | 7] 30.88 (8.09)*
| | 8] Anapsos 360 mg QID Alzheimer's Disease subpopulation | | 8] 30.56 (6.08)* | | | | 8] 28.04 (6.48)*
| | 9] Anapsos 720 mg QID Alzheimer's Disease subpopulation | | 9] 39.23 (3.19)* | | | | 9] 40.31 (3.68)*
| | 10] Placebo Vascular Dementia subpopulation | | 10] 8.47(4.92)* | | | | 10] 28.27 (4.32)*
| | 11] Anapsos 360 mg QID Vascular Dementia subpopulation | | 11] 43.42 (4.19)* | | | | 11] 43.35 (4.07)*
| | 12] Anapsos 720 mg QID Vascular Dementia subpopulation | | 12] 29.64 (5.04)* | | | | 12] 29.91(5.38)*

* SEM

Evidence Table 120. Study results: BMY-21,502

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Cutler, 1993 | OC Analysis
| 1] Placebo | MMSE | 1] 22.5 | 3] >0.05 | | | 4] -0.5
| 2] BMY-21,502 300mg tid | | 2] 23.5 | | | | 5] -1.5
| 3] BMY-21,502 vs. Placebo | ADAS | | 3] NS | | | | 3] NS
| 4] Placebo change from baseline | CGI | | 3] >0.05 | | | 1] 3.69 | 3] >0.05
| 5] BMY-21,502 change from baseline | | | | | | 2] 3.64

Evidence Table 121. Study results: Carbamazepine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Tariot, 1998 | ITT Analysis
| 1] Placebo | [underlined: CGI improved] | | | | | 1] 21%
| 2] Carbamazepine 304 mg tid variable | | | | | | 2] 77% | 3] 0.001
| 3] Difference in change between Placebo and Carbamazepine | [underlined: BPRS total] | 1] 53.3 (8.8) | | | | 1] 52.4 (9.8) | 3] 0.0003
| | | 2] 55.1 (9.6) | | | | 2] 47.4 (10.2)
| | OAS | 1] 13.2 (6.3) | | | | 1] 11.3 (7.3) | 3] 0.008
| | | 2] 15.0 (6.4) | | | | 2] 8.3 (8.0)
| | BRS for Dementia | 1] 63.1 (25.8) | | | | 1] 55.0 (29.2) | 3] 0.03
| | | 2] 77.7 (34.8) | | | | 2] 53.4 (32.0)

Evidence Table 122. Study results: Carbamazepine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Olin, 2001 | OC Population
| 1] Placebo change from baseline | [underlined: BPRS total] | | | | | 1] -4.2 (8.2) | 3] 0.519
| 2] Carbamazepine 400 mg/d variable change from baseline | | | | | | 2] -4.0 (7.9)
| 3] Difference between Placebo and Carbamazepine change from baseline | [underlined: CGIC % improved or no change] | | | | | 1] 58% | 3] 0.055
| | | | | | | 2] 89%
| | Ham-D | | | | | 1] -1.4 (3.3) | 3] 0.150
| | | | | | | 2] -4.2 (4.3)
| | PSMRS | | | | | 1] -0.6 (1.6) | 3] 1.00
| | | | | | | 2] -0.5 (1.6)
| | IADL | | | | | 1] 0.3 (2.2) | 3] 0.408
| | | | | | | 2] 0.7 (2.2)
| | MMSE | | | | | 1] -0.5 (2.9) | 3] 0.644
| | | | | | | 2] -0.1 (2.7)

Evidence Table 123. Study results: Citalopram

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 4w
Nyth, 1990 | OC Analysis
| 1] Placebo average rating scores | CGI-SI | 1] 3.909 | | | | 1] 4.032 | 3] 0.284
| AD/SDAT | | 2] 3.897 | | | | 2] 3.897 | 4]NS
| 2] Citalopram 30 mg/d variable average rating scores | CGI-ANS | 1] 1.795 | | | | 1] 1.971 | 3] 0.423
| AD/SDAT | | 2] 1.607 | | | | 2] 1.643 | 4] NS
| 3] Improvement between group differences | GBS-MI | 1] 7.813 | | | | 1] 7.813 | 3] 0.731
| AD/SDAT | | 2] 6.667 | | | | 2] 6.667 | 4] NS
| 4] Placebo vs Citalopram VaD | GBS-II | 1] 20.063 | | | | 1] 19.875 | 3] 0.321
| | | 2] 22.666 | | | | 2] 21.333 | 4] NS
| | GBS -EB | 1] 4.406 | | | | 1] 3.781 | 3] 0.384
| | | 2] 4.555 | | | | 2] 3.296 | 4] NS
| | GBS-Confus. | 1] 1.188 | | | | 1] 1.063 | 3] 0.148
| | | 2] 1.223 | | | | 2] 0.704 | 4] NS
| | GBS-Irritabiliy | 1] 0.969 | | | | 1] 0.938 | 3] 0.017
| | | 2] 1.297 | | | | 2] 0.667 | 4] NS
| | GBS-anxiety | 1] 0.876 | | | | 1] 0.688 | 3] 0.276
| | | 2] 1.408 | | | | 2] 0.889 | 4] NS
| | GBS-restless | 1] 0.782 | | | | 1] 0.719 | 3] 0.081
| | | 2] 0.888 | | | | 2] 0.444 | 4] NS
| | MADRS Total score | 1] 7.690 | | | | 1] 7.690 | 3] 0.358
| | | 2] 8.307 | | | | 2] 6.115 | 4] NS

Evidence Table 124. Study results: Citalopram

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) up to 17d
Pollock, 2002 | ITT Analysis
| 1] Placebo | [underlined: Neuro-Behavioural Rating Score] | 1] 58.3 (11.9) | | | | 1] 56.0 (15.2) | 4] 0.002
| 2] Citalopram 20 mg/d | | 2] 53.5 (10.2) | | | | 2] 43.5 (12.1) | 5] 0.14
| 3] Perphenazine 0.1mg/kg/d | | 3] 57.1 (14.0) | | | | 3] 49.9 (14.2)
| 4] Citalopram vs. placebo
| 5] Perphenazine vs. placebo

Evidence Table 125. Study results: Divalproex

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Porsteinsson 2001 | OC Analysis
| 1] Placebo | [underlined: BPRS-total] | 1] 55.4 (7.4) | | | | 1] 49.5 (10.5) | 3] 0.61
| 2] Divalproex 826 mg/d variable | | 2] 543.9 (8.7) | | | | 2] 47.9 (12.4)
| 3] Difference between Placebo and Divalproex change from baseline | Overt Aggression Scale | 1] 16.9 (9.0) | | | | 1] 12.0 (8.5) | 3] 0.95
| | | 2] 14.8 (7.6) | | | | 2] 10.0 (8.3)
| | CERAD BRSD Weighted | 1] 53.9 (20.9) | | | | 1] 45.3 (26.0) | 3] .73
| | | 2] 48.2 (16.2) | | | | 2] 38.3 (9.9)
| | CMAI | 1] 77.2 (21.1) | | | | 1] 69.9 (22.9) | 3] 0.65
| | | 2] 77.2 (18.9) | | | | 2] 67.7 (23.3)
| | MMSE | 1] 6.7 (6.7) | | | | 1] 5.1 (6.2) | 3] 0.91
| | | 2] 7.0 (6.6) | | | | 2] 5.2 (6.9)
| | PSMS | 1] 14.3 (4.8) | | | | 1] 14.6 (4.7) | 3] 0.41
| | | 2] 15.4 (4.4) | | | | 2] 15.2 (4.5)
| | CGI % with therapeutic effect | | | | | 1] 52% | 3] 0.07
| | | | | | | 2] 68%

Evidence Table 126. Study results: Divalproex

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Tariot 2001b | ITT Analysis
| 1] Placebo | [underlined: BRMS] | 1] 17.7 (0.50)* | | | | 3] -3.9 (0.79)* | 5] 0.941
| 2] Divalproex Sodium 20 mg/kd/d variable | | 2] 17.2 (0.48)* | | | | 4] -3.9 (0.77)*
| 3] Placebo change from baseline | CMAI Total score | 1] 81.8 (2.70)* | | | | 3] -7.3 (2.72)* | 5] 0.035
| 4] Divalproex change from baseline | | 2] 86.8 (2.63)* | | | | 4] -14.3 (2.65)*
| 5] Divalproex vs. Placebo | BPRS Total score | 1] 41.7 (1.33)* | | | | 3] -7.1 (1.73)* | 5] 0.690
| | | 2] 43.3 (1.29)* | | | | 4] -8.0 (1.67)*
| | CGI (Part II) | | | | | 3] 3.4 (0.14)* | 5] 0.035 favors placebo
| | | | | | | 4] 3.9 (0.15)*
| | MMSE | 1] 7.7 (0.77)* | | | | | 5] NS
| | | 2] 7.1 (0.75)*

* SEM

Evidence Table 127. Study results: Fluvoxamine

Author Year | Analysis Groups | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Olafsson | OC Analysis
| 1] Placebo | Trail-making test - Median (range) | 1] 2.8 (0–16) | | | | 1] 0.8 (0–8) | 3] NS
| 2] Fluvoxamine 150 mg/d | | 2] 8.3 (0–15) | | | | 2] 5.0 (0–17) | 4] NS
| 3] Placebo difference from baseline | | | | | | | 5] NS
| 4] Fluvoxamine difference from baseline | GBS - Median (range) | 1] 63 (22–104) | | | | 1] 68 (17–102) | 3] NS
| 5] difference between changes in Placebo and Fluvoxamine | | 2] 78 (13–132) | | | | 2] 68 (19–120) | 4] NS
| | | | | | | | 5] NS
| | Picture recall | 1] 0.2 (0–5) | | | | 1] 0.2 (0–4) | 3] NS
| | Immediate recall | 2] 0.4 (0–4) | | | | 2] 0.6 (0–4) | 4] NS
| | | | | | | | 5] NS
| | Delayed recall | 1] 0.1 (0–2) | | | | 1] 0.1 (0–4) | 3] NS
| | | 2] 0.2 (0–3) | | | | 2] 0.4 (0–4) | 4] NS
| | | | | | | | 5] NS
| | Picture recognition | 1] 2.5 (0–8) | | | | 1] 4.8 (0–8) | 3] NS
| | Correct recognition | 2] 3.7 (1–8) | | | | 2] 4.8 (0–8) | 4] NS
| | | | | | | | 5] NS
| | Concept distracters | 1] 1.5 (0–7) | | | | 1] 2.5 (0–7) | 3] NS
| | | 2] 0.8 (0–4) | | | | 2] 1.0 (0–8) | 4] NS
| | | | | | | | 5] NS
| | Other distracters | 1] 2.2 (0–8) | | | | 1] 3.0 (0–6) | 3] NS
| | | 2] 1.3 (0–6) | | | | 2] 1.0 (0–8) | 4] NS
| | | | | | | | 5] NS
| | Finger Tapping | 1] 31 (12–59) | | | | 1] 30 (5–67) | 3] NS
| | Dominant index finger | 2] 20 (0–60) | | | | 2] 14 (0–64) | 4] NS
| | | | | | | | 5] NS
| | Non-dominant index finger | 1] 25 (0–48) | | | | 1] 31 (0–51) | 3] NS
| | | 2] 20 (0–50) | | | | 2] 16 (0–54) | 4] NS
| | | | | | | | 5] NS

Evidence Table 128. Study results: Imipramine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Resul Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Reifler 1998 | OC Analysis
| 1] Placebo Depressed group | HDS | 1] 18.6 (4.0) | | | | 1] 10.8 (3.5) | 5] NS
| 2] Imaprine 83 mg/d Depressed group | | 2] 19.3 (3.5) | | | | 2] 11.5 (3.7) | 6] NS
| 3] Placebo Not Depressed Group | | 3] 6.8 (2.4) | | | | 3] 6.5 (1.8)
| 4] Imaprine 83mn/d Not Depressed Group | | 4] 6.9 (2.9) | | | | 4] 7.9 (3.1)
| 5] Imipramine vs. Placebo Depressed group | MMSE | 1] 18.0 (5.5) | | | | 1] 19.3 (6.5) | 5] NS
| 6] Imipramine vs. Placebo Not Depressed group | | 2] 16.9 (4.6) | | | | 2] 18.7 (5.4) | 6] NS
| | | 3] 14.8 (15.1) | | | | 3] 15.1 (6.2)
| | | 4] 13.4 (6.9) | | | | 4] 13.1 (7.7)
| | DRS | 1] 115.9 (14.3) | | | | 1] 117.4 (13.7) | 5] <0.01
| | | 2] 111.2 (14.3) | | | | 2] 104.3 (20.9) | 6] <0.01
| | | 3] 98.6 (24.8) | | | | 3] 98.1 (26.4)
| | | 4] 80.4 (44.6) | | | | 4] 72.7 (43.8)
| | OARS-ADL | 1] 19.6 (3.9) | | | | 1] 17.8 (4.1) | 5] NS
| | | 2] 19.5 (3.6) | | | | 2] 18.0 (3.8) | 6] NS
| | | 3] 19.5 (3.8) | | | | 3] 18.3 (3.5)
| | | 4] 16.7 (5.8) | | | | 4] 15.5 (5.4)

Evidence Table 129. Study results: Lisuride

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Resul Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Claus, 1998 | OC Analysis
| 1] Placebo | MMSE | 1] 18.7 (5.5)* | | | | 1] 17.1 (5.7)* | 3] 0.03
| 2] Lisuride 0.3 mg tid | | 2] 22.9 (3.8)* | | | | 2] 22.6 (4.9)*
| 3] Placebo vs. Lisuride in change from baseline | Dementia Mood Assessment Scale | 1] 23.3 (4.5)* | | | | 1] 25.9 (5.2)* | 3] 0.71
| | | 2] 19.9 (3.3)* | | | | 2] 21.6 (3.8)*
| | CGI Improved | | | | | 1] 8.3% | 3] 0.72
| | | | | | | 2] 20%
| | CVLT Total recall | 1] 17.6 (2.3)* | | | | 1] 16.3 (2.8)* | 3] 0.06
| | | 2] 23.5 (3.1)* | | | | 2] 26.6 (3.2)*
| | Verbal Fluency Total correct | 1] 12.3 (2.0) | | | | 1] 11.2 (1.9) | 3] 0.10
| | | 2] 17.3 (2.5) | | | | 2] 20.0 (3.7)
| | Visuospatial Associative Learning | 1] 18.4 (4.4) | | | | 1] 11.1 (3.6) | 3] 0.73
| | | 2] 20.1 (3.8) | | | | 2] 14.7 (2.4)
| | Delayed Matching to sample | 1] 12.4 (2.2) | | | | 1] 10.8 (2.0) | 3] 0.59
| | | 2] 15.9 (2.5) | | | | 2] 16.3 (2.1)
| | Working Memory Test between errors | 1] 27.1 (9.8) | | | | 1] 28.9 (9.8) | 3] 0.22
| | | 2] 49.9 (9.4) | | | | 2] 28.6 (6.6)
| | Working Memory Test within errors | 1] 2.1 (0.8) | | | | 1] 1.8 (0.8) | 3] 0.46
| | | 2] 3.1 (1.2) | | | | 2] 1.6 (0.4)
| | Visual Vigilance Task | 1] 18.7 (5.1) | | | | 1] 22.5 (5.5) | 3] 0.09
| | | 2] 18.7 (2.9) | | | | 2] 11.7 (3.1)
| | Pegboard | 1] 104.3 (24.4) | | | | 1] 118.3 (14.9) | 3] 0.28
| | | 2] 139.7 (8.1) | | | | 2] 136.1 (14.4)

Evidence Table 130. Study results: Lu25-109

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Thal, 2000b | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-Cog] | | | | | 1] 1.16 | 5] 0.51
| 2] Lu25-109 25 mg tid change from baseline | | | | | | 2] 1.04
| 3] Lu25-109 50 mg tid change from baseline | | | | | | 3] 0.90
| 4] Lu25-109 100 mg tid change from baseline | | | | | | 4] 1.90
| 5] General linear ANCOVA vs. baseline | [underlined: ADCS-CGIC] | | | | | 1] 0.25 | 5] 0.63
| | | | | | | 2] 0.34
| | | | | | | 3] 0.22
| | | | | | | 4] 0.33
| | ADCS-ADL | | | | | 1] -2.62 | 5] 0.91
| | | | | | | 2] -2.79
| | | | | | | 3] -2.40
| | | | | | | 4] -3.13
| | BEHAVE-AD | | | | | 1] 0.07 | 5] 0.35
| | | | | | | 2] -0.72
| | | | | | | 3] -0.15
| | | | | | | 4] -0.26

Evidence Table 131. Study results: Maprotiline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Fuchs 1993 | OC Analysis
| 1] Placebo | [underlined: Video rating of Global Impression] | | | | | 3] 0.6 | 5] 0.60
| 2] Maprotiline 75 mg/d variable | | | | | | 4] -0.2
| 3] Placebo change from baseline | MMSE | 1] 15.8 | | | | 1] 17.5 | 5] 0.22
| 4] Maprotiline change from baseline | | 2] 15.0 | | | | 2] 15.3
| 5] Placebo vs. Maprotiline change from baseline | GDS | 1] 8.4 | | | | 1] 6.6 | 5] 0.09
| | | 2] 8.2 | | | | 2] 5.3

Evidence Table 132. Study results: Minaprine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 60d | | Final: (specify) 90d
Passeri, 1998 | Endpoint Analysis
| 1] Placebo SDAT patients | HDRS | 1] 13 (7) | | 1] 12 (7) | 5] <0.01 | 1] 12 (7) | 5] <0.05
| 2] Minaprine 50mg bid SDAT patients | | 2] 15 (6) | | 2] 11 (5) | 6] <0.01 | 2] 10 (5) | 6] <0.05
| 3] Placebo MID patients | | 3] 15 (5) | | 3] 14 (4) | 7] <0.05 | 3] 13(5) | 7] <0.01
| 4] Minaprine 50mg bid MID patients | | 4] 13 (5) | | 4] 8.8 (4) | 8] <0.01 | 4] 8.4 (5) | 8] <0.01
| 5] Minaprine vs. Placebo (SDAT) | SRT Anxiety | 1] 5.5 (4.7) | | 1] 4.8 (3.6) | 6] <0.05 | 1] 4.7 (3.5) | 5] <0.05
| 6] Minaprine vs. Placebo (MID) | | 2] 4.8 (3.7) | | 2] 4.3 (3.7) | | 2] 3.6 (3.8) | 6] <0.05
| 7] Minaprine vs. baseline (SDAT) | | 3] 5.5 (3.1) | | 3] 4.2 (2.5) | | 3] 4.2 (2.4)
| 8] Miaprine vs. baseline (MID) | | 4] 4.3 (2.9) | | 4] 3.0 (1.8) | | 4] 2.7 (1.9)
| | SRT Depression | 1] 6.9 (5.2) | | 1] 5.6 (4.4) | 5] <0.01 | 1] 5.5 (4.7) | 6] <0.1
| | | 2] 6.9 (3.2) | | 2] 4.8 (3.1) | 8] <0.01 | 2] 4.4 (3.1) | 8] <0.01
| | | 3] 7.0 (3.6) | | 3] 6.8 (4.2) | | 3] 6.4 (4.0)
| | | 4] 7.6 (3.8) | | 4] 4.8 (3.1) | | 4] 3.8 (3.8)
| | SHGRS | 1] 35 (8) | | 1] 34 (8) | 6] <0.01 | 1] 34(8) | 6] <0.5
| | | 2] 34 (10) | | 2] 33 (10) | | 2] 32 (10) | 7] <0.01
| | | 3] 42 (11) | | 3] 41 (11) | | 3] 40 (12) | 8] <0.01
| | | 4] 38 (11) | | 4] 35 (10) | | 4] 34 (10)
| | Nowlis | 1] 14 (3.7) | | 1] 14 (4) | 6] <0.01 | 1] 14 (4.1) | 5] <0.01
| | | 2] 15 (4) | | 2] 13 (3.9) | | 2] 13 (39) | 6] <0.01
| | | 3] 16 (3.7) | | 3] 15 (3.4) | | 3] 14 (2.9) | 7] <0.01
| | | 4] 14 (3.8) | | 4] 12 (2.8) | | 4] 12 (3.4) | 8] <0.01

Evidence Table 133. Study results: Moclobemide

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Roth 1996 | ITT Analysis
| 1] Placebo Difference from baseline | HAM-D | | | | | 1] 91 | 3] 0.001
| 2] Moclobemide 400 mg/d Difference from baseline | | | | | | 2] 12.6
| 3] Placebo vs. Moclobemide Change from baseline | MMSE | | | | | 1] 1.9 | 3] 0.05
| | | | | | | 2] 2.6
| | SCAG | | | | | 1] 14.8 | 3] NS
| | | | | | | 2] 17.3
| | BGP | | | | | 1] 1.2 | 3] NS
| | | | | | | 2] 1.6
| | CGAE | | | | | 1] 59% | 3] <0.001
| | Any improvement | | | | | 2] 72%

Evidence Table 134. Study results: Naftidrofuryl

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) Response Rate no deterioration
Moller 2001 | ITT Analysis
| 1] Placebo- response rate | [underlined: ADAS-cog & SCAG (positive response)] | | | | | 1] 58% | 4] 0.005
| 2] Naftidrofuryl 400 mg/d - | | | | | | 2] 75% | 5] 0.015
| 3] Naftidrofuryl 600 mg/d - response rate | | | | | | 3] 73% | 6] 0.73
| 4] Placebo vs.Naftidrofuryl 400 mg | [underlined: ADAS-Cog] | 1] 28.6 (7.7) | | | | 1] 67% | 4] 0.003
| 5] Placebo vs.Naftidrofuryl 600 mg/d | | 2] 29.0 (8.5) | | | | 2] 84% | 5] 0.013
| 6] Naftidrofuryl 400 mg/d vs.600 mg/d | | 3] 29.5 (7.5) | | | | 3] 73% | 6] 0.61
| | [underlined: SCAG] | 1] 51.0 (8.3) | | | | 1] 65% | 4] 0.001
| | | 2] 52.3 (9.8) | | | | 2] 84% | 5] 0.001
| | | 3] 50.7 (8.6) | | | | 3] 84% | 6] 0.97
| | NOSGER | 1] 69.6 (15.4) | | | | 1] 50% | 4] 0.049
| | | 2] 69.8 (14.3) | | | | 2] 63% | 5] 0.21
| | | 3] 66.2 (15.8) | | | | 3] 58% | 6] 0.49
| | CGI | | | | | 1] 55% | 4] 0.004
| | | | | | | 2] 73% | 5] 0.10
| | | | | | | 3] 66% | 6] 0.21

Evidence Table 135. Study results: Olanzapine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6w
Street 2000 | ITT Analysis
Clarke 2001 | 1] Placebo change from baseline | [underlined: NPI/NH Core total] | | | | | 1] -3.7 (10.3) | 5] <0.001
Kennedy 2001 | 2] Olanzapine 5mg/d change from baseline | | | | | | 2] -7.6 (7.7) | 6] 0.006
Mitzner 2001 | 3] Olanzapine 10mg/d change from baseline | | | | | | 3] -6.1 (8.2) | 7] 0.24
Street 2001 | 4] Olanzapine 15mg/d change from baseline | | | | | | 4] -4.9 (7.8)
| 5] Olazapine 5mg/d vs.placebo | BPRS total | | | | | 1] -1.4 (11.1) | 5] 0.005
| 6] Olanzapine 10mg/d vs.placebo | | | | | | 2] -6.8 (8.6) | 6] 0.06
| 7] Olanzapine 15mg/d vs. placebo | | | | | | 3] -5.6 (10.0) | 7] 0.13
| | | | | | | 4] -4.0 (10.9)
| | ADAS-Cog | | | | | 1] 1.38 (6.23) | 5] 0.703
| | In sub-group with mild to moderate cognitive impairment | | | | | 2] -0.94 (8.10) | 6] 0.203
| | | | | | | 3] 4.00 (7.03) | 7] 0.695
| | | | | | | 4] 1.83 (8.98)

Evidence Table 136. Study results: Phosphatidylserine (PS)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 3m | | Final: (specify) 3m & 3m post
Amaducci 1988 | OC Analysis
SMID Group 1987 | 1] Placebo moderate impairment | Set test | 1] 27.57 | | 2] 11 | 5] <0.10 | 1] 23.93 | 5] <0.01
| 2] Placebo severe impairment | | 2] 16.33 | | 4] 13 | 6] NS | 2] 9.22
| 3] PS 200 mg/d moderate impairment | | 3] 26.02 | | | | 3] 27.10
| 4] PS 200mg/d severe impairment | | 4] 10.75 | | | | 4] 15.63
| 5] PS vs Placebo change from baseline severe impairment | BDS Nonpersonal memory | 1] 3.00 | | 2] 2.0 | 5] <0.10 | 1] 3.11 | 5] 0.05
| 6] PS vs placebo change from baseline moderate impairment | | 2] 2.10 | | 4] 2.0 | 6] NS | 2] 1.20
| | | 3] 3.23 | | | | 3] 2.96
| | | 4] 1.25 | | | | 4] 1.25
| | BDS part 2 | 1] 19.40 | | | | 1] 18.51 | 5] 0.005
| | | 2] 14.50 | | | 5] NS | 2] 10.40
| | | 3] 19.27 | | | 6] NS | 3] 17.77
| | | 4] 11.50 | | | | 4] 14.25
| | Block tapping | 1] 1.38 | | | 5] < 0.10 | 1] 1.38 | 5] 0.05
| | | 2] 0.00 | | | 6] NS | 2] 0.11
| | | 3] 1.03 | | | | 3] 0.89
| | | 4] 0.44 | | | | 4] 1.25
| | BDS Personal Memory | 2] 5.5 | | 2] 4.4 | 5] NS
| | | 4] 4.0 | | 4] 4.4 | 6] NS
| | BDS Daily Living Score | 2] 15.6 | | 2] 16.3 | 5] NS
| | | 4] 16.4 | | 4] 16.6 | 6] NS

Evidence Table 137. Study results: Phosphatidylserine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 9w | | Final: (specify) 12w
Crook, 1992a | ITT Analysis
| 1] Placebo | PRS-Concern of Memory F - Value | | | | | 3] 5.73 | 3] 0.02
| 2] Phosphatidylserine 100mg tid | PRS-Recall of Interviewer and staff F - Value | | | | | 3] 4.92 | 3] 0.04
| 3] Phosphatidylserine 100mg tid vs. Placebo | PRS-Recall of past day F - Value | | | | | 3] 6.36 | 3] 0.02
| | PRS-Recall of past week F - Value | | | | | 3] 9.76 | 3] 0.01
| | PRS-Interviewer Notices memory Loss F - Value | | | | | 3] 13.21 | 3] 0.00
| | MAC-F First-last name test | | | | | 3] 12.29 | 3] <0.00
| | MAC-F Name-face association | | | | | | 3] <0.05
| | Memory for names of familiar persons | | | 3] 6.12 | 3] <0.02
| | Ability to recall the location of misplaced objects | | | | | | 3] <0.05

Evidence Table 138. Study results: Sertraline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Magai, 2000 | ITT Analysis
| 1] Placebo | CSDD | 1] 6.36 (2.13) | | | | 1] 4.43 (1.95) | 3] NS
| 2] Sertraline 100 mg escalating | | 2] 5.76 (1.89) | | | | 2] 3.53 (2.07)
| 3] Difference between Placebo and Sertraline change from baseline | GS | 1] 0.93 (0.91) | | | | 1] 0.57 (0.64) | 3] NS
| | | 2] 0.47 (0.87) | | | | 2] 0.06 (0.24)
| | CMAI | 1] 27.71(19.49) | | | | 1] 21.57(11.52) | 3] NS
| | | 2] 28.05(21.45) | | | | 2] 23.24(20.00)
| | AFBS | 1] 2.29 (2.23) | | | | 1] 1.71 (2.23) | 3] NS
| | | 2] 3.88 (2.64) | | | | 2] 3.06 (2.73)
| | Knit-brow face | 1] 4.86 (2.71) | | | | 1] 4.43 (3.63) | 3] <0.1
| | | 2] 3.94 (3.07) | | | | 2] 1.94 (2.65)
| | Sad face | 1] 2.57 (2.27) | | | | 1] 1.43 (1.74) | 3] NS
| | | 2] 2.65 (3.75) | | | | 2] 2.18 (2.35)

Evidence Table 139. Study results: Sertraline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 6w | | Final: (specify) 13w
Lyketsos 2000 | ITT Analysis
| 1] Placebo change from baseline | [underlined: Psychiatrist rating of responders] | | | | | 1] 10% | 3] <0.05
| 2] Sertraline 150 mg (escalating) change from baseline | | | | | | 2] 75%
| 3] Placebo vs. Sertraline change from baseline | CSDD | | | 1] 2.7 (6.2) | 1] <0.05 | 1] -2.6 (5.9) | 3] 0.03
| | | | | 2] -12.5 (7.0) | | 2: -9.7 (8.3)
| | HAM-D | | | 1] -4.4 (4.9) | 1] <0.05 | 1] -3.4 (5.5) | 3] 0.20
| | | | | 2] -14.6 (10.0) | 2] <0.05 | 2] -8.9 (12.4)
| | PDRS | | | 1] 0.7 (5.2) | | 1] 3.4 (3.5) | 3] 0.09
| | ADL subscale | | | 2] -0.9 (4.7) | | 2] -0.8 (5.2)
| | MMSE | | | 1] 0.3 (1.6) | | 1] 0.8 (2.3) | 3] 0.18
| | | | | 2] -2.1 (5.0) | | 2] -1.2 (4.7)

Evidence Table 140. Study results: Fluoxetine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point] (specify) 3m | | Final] (specify) 6w
Petracca 2001 | ITT Analysis
| 1] Placebo | Ham-D | 1] 17.2 (3.6) | | | | 1] 10.0 (5.1) | 3] <0.001
| 2] Fluoxetine 40 mg/d dose escalation | | 2] 15.8 (2.1) | | | | 2] 9.4 (5.7) | 4] <0.001
| 3] Placebo change from baseline | | | | | | | 5] NS
| 4] Fluoxetine change from baseline | | | | | | | 6] NS
| 5] Difference between Placebo and Fluoxetine change from baseline | CGI Severity | 1] 3.0 (0.8) | | | | 1] 2.4 (0.8) | 3] <0.001
| 6] Difference between Placebo and Fluoxetine | | 2] 2.7 (0.9) | | | | 2] 2.1 (0.7) | 4] <0.001
| | Ham-A | 1] 9.1 (5.8) | | | | 1] 6.2 (4.4) | 3] <0.001
| | | 2] 8.3 (5.1) | | | | 2] 7.0 (5.6) | 4] <0.001
| | | | | | | | 5] NS
| | | | | | | | 6] NS
| | MMSE | 1] 23.2 (5.3) | | | | 1] 23.9 (5.9) | 3] NS
| | | 2] 23.2 (4.5) | | | | 2] 23.1 (6.8) | 4] NS
| | | | | | | | 5] NS
| | | | | | | | 6] NS
| | FIM | 1] 64.2 (8.9) | | | | 1] 67.1 (7.3) | 3] <0.01
| | | 2] 68.5 (3.4) | | | | 2] 69.8 (2.8) | 4] <0.01
| | | | | | | | 5] NS
| | | | | | | | 6] NS

Evidence Table 141. Study results: Haloperidol - Fluoxetine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point] (specify) | | Final] (specify) 6 w
Auchus 1996 | OC Population
| 1] Placebo | [underlined: CMAI] | 1] 34.4 (8.2) | | | | 1] 33.0 (3.5) | 4] 0.82
| 2] Fluoxetine 20 mg/d | | 2] 33.8 (3.0) | | | | 2] 35.2 (10.3)
| 3] Haloperidol 3mg/d | | 3] 37.4 (4.4) | | | | 3] 35.0 (11.2)
| 4] Across group treatment effect | BEHAVE-AD | 1] 5.6 (3.4) | | | | 1] 6.6 (3.5) | 4] 0.35
| | | 2] 7.0 (4.2) | | | | 2] 8.8 (3.5)
| | | 3] 11.8 (4.9) | | | | 3] 9.2 (7.1)
| | CSI | 1] 116.2 (57.0) | | | | 1] 134.8 (62.1) | 4] 0.67
| | | 2]160.4(121.8) | | | | 2] 143.6 (79.3)
| | | 3] 165.4 (50.3) | | | | 3] 179.4 (91.9)

Evidence Table 142. Study results: Risperidone

Author Year | Analysis Groups | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Katz, 1999 | ITT Endpoint Analysis
Jeste, 2000 | 1] Placebo | [underlined: BEHAVE-AD] | 1] 15.9 | | | | 8] -4.2 (0.6)* | 5] 0.37
Camilleri 2000 | 2] Risperidone 0.5 mg/d | | 2] 15.9 | | | | 9] -4.8 (0.7)* | 6] 0.002
| 3] Risperidone 1 mg/d | | 3] 16.0 | | | | 10] -6.5 (0.7)* | 7] 0.001
| 4] Risperidone 2 mg/d | | 4] 15.4 | | | | 11] -6.4 (0.6)*
| 5] Risperidone 0.5 mg/d vs Placebo | CMAI Total | | | | | | 6] 0.006
| 6] Risperidone 1 mg/d vs Placebo | | | | | | | 7] <0.001
| 7] Risperidone 2 mg/d vs Placebo | CMAI Verbal | | | | | 8] -0.50
| 8] Placebo change from baseline | | | | | | 9] -1.25
| 9] Risperidone 0.5 mg/d change from baseline | | | | | | 10] -1.80
| 10] Risperidone 1 mg/d change from baseline | | | | | | 11] -2.30
| 11] Risperidone 2 mg/d change from baseline | CMAI Physical aggressive | | | | | 8] -2.1
| | | | | | | 9] -3.0
| | | | | | | 10] -5.4
| | | | | | | 11] -6.4
| | CGIC | 1] 4.2 | | | | 1] 3.7 | 6] 0.002
| | | 3] 4.2 | | | | 2] 3.3 | 7] <0.001
| | | 4] 4.2 | | | | 3] 3.2

* SEM

Evidence Table 143. Study results: Haloperidol - Trazodone

REF ID# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) | | Final: (specify) 16w
| Teri, 2000 | Efficacy Analysis
| | 1] BMT | ADCS-CGIC %improvement | | | | | 1] 32% | 6] 0.99
| | 2] Haloperidol mean dose1.8 mg/d | | | | | | 2] 32% | 7] 0.81
| | 3] Trazodone mean dose 200 mg/d | | | | | | 3] 41% | 8] 0.65
| | 4] Placebo | | | | | | 4] 31% | 9] 0.75
| | 5] Group Effect | | | | | | | 10] 0.52
| | 6] Placebo vs Trazodone | | | | | | | 11] 0.86
| | 7] Placebo vs Haloperidol | BRSD | | | | | 1] -3.56 12.85) | 5] NS
| | 8] Placebo vs BMT | Change score | | | | | 2] -5.35(22.41)
| | 9] Traxodon vs Haloperidol | | | | | | 3] -6.95(20.87)
| | 10] Trazodone vs BMT | | | | | | 4] -5.28 (24.36)
| | 11] Haloperidol vs BMT | MMSE | | | | | 1] -0.05 (2.58) | 6] NS
| | | Change score | | | | | 2] -0.61 (2.69) | 7] NS
| | | | | | | | 3] -1.97 (3.15) | 8] NS
| | | | | | | | 4] -0.28 (3.35) | 9] NS
| | | | | | | | | 10] <0.05 favours BMT
| | | | | | | | | 11] NS
| | | Lawton-Brody ADL | | | | | 1] -0.27 (1.96) | 6] <0.05 favours placebo
| | | Physical | | | | | 2] 2.53 (4.00) | 7] <0.05 favours placebo
| | | Change score | | | | | 3] 1.62 (2.56)
| | | | | | | | 4] 1.31 (2.47)
| | | Lawton-Brody ADL | | | | | 1] 0.17 (1.84) | 6] <0.05
| | | Instrumental | | | | | 2] 1.79 (3.20) | 7] <0.05 favours placebo
| | | Change score | | | | | 3] 1.81 (3.32)
| | | | | | | | 4] 0.89 (3.32)
| | | SCB Subjective | | | | | 1] -2.95 (7.29 | 5] NS
| | | | | | | | 2] -1.88 (8.89)
| | | | | | | | 3] -1.97 (10.06)
| | | | | | | | 4] -2.58 (9.67)
| | | Screen for Caregiver | | | | | 1] -2.95 (7.29
| | | Burden Subjective | | | | | 2] -1.88 (8.89)
| | | | | | | | 3] -1.97 (10.06)
| | | | | | | | 4] -2.58 (9.67)
| | | Objective | | | | | 1] -1.23 (3.32)
| | | | | | | | 2] -0.44 (3.22)
| | | | | | | | 3] -1.14 (4.04)
| | | | | | | | 4] -1.25 (4.02)

Evidence Table 144. Study results: Risperidone - Haloperidol

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
DeDeyn 1999 | ITT Population
| 1] Placebo | BEHAVE-AD total | 1] 16.6 | | | | 1] -4.2 | 4] 0.19
| 2] Haloperidol 1.2 mg/d | | 2] 16.5 | | | | 2] -6.6 | 6] 0.01
| 3] Risperidone 1.1 mg/d | | 3] 16.3 | | | | 3] -5.2
| 4] Risperidone vs Placebo | Behave-AD Aggressiveness | 1] 5.0 | | | | 1] -0.8 | 4] 0.004
| 5] Risperidone vs Placebo change from baseline | | 2] 4.7 | | | | 2] -1.6 | 6] 0.01
| 6] Haloperidol vs Placebo change from baseline | | 3] 5.0 | | | | 3] -1.7 | 7] 0.05 favors Risperidone
| 7] Risperidone vs Placebo change from baseline | CMAI total aggressive | 1] 27.5 | | | | 1] -1.6 | 4] 0.01
| | | 2] 26.3 | | | | 2] -3.3 | 7] 0.02
| | | 3] 25.6 | | | | 3] -3.9
| | CMAI physical aggressive | 1] 19.7 | | | | 1] -0.7 | 4] 0.01
| | | 2] 19.3 | | | | 2] -0.3 | 7] 0.01
| | | 3] 18.9 | | | | 3] -2.7
| | CMAI verbal aggressive | 1] 7.7 | | | | 1] -0.8 | 4] 0.01
| | | 2] 7.0 | | | | 2] -1.0
| | | 3] 6.8 | | | | 3] -1.2
| | CGI | | | | | | 5] <0.05
| | MMSE | | | | | | 5] NS
| | FAST | | | | | | 5] NS
| | Behave-AD % with > 30% reduction from baseline | | | | | 1] 47% | 5] 0.25
| | | | | | | 2] 63%
| | | | | | | 3] 54%

Evidence Table 145. Study results: Haloperidol - Tiapride

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 21 d
Allain 2000 | ITT Endpoint Analysis
| 1] Placebo | [underlined: MOSES % responders (% with 25% decrease in irritability/ aggressiveness subscore)] | | | | | 1] 49% | 8] 0.04
| 2] Tiapride 100–300 mg/d | | | | | | 2] 63% | 9] 0.004
| 3] Haloperidol 2–6 mg/d | | | | | | 3] 69% | 10] 0.38
| 4] Across treatment | MOSES | | | | | 1] 15.53 (5.25) | 5] 0.0009
| 5] Tiapride vs Placebo | | | | | | 2] 13.33 (4.20) | 6] 0.008
| 6] Haloperidol vs Placebo | | | | | | 3] 13.75 (4.59) | 7] 0.53
| 7] Tiapride vs Haloperidol | Global Improvement very improved | 1] 20.28 (2.85) | | | | 1] 14% | 4] NS
| 8] Placebo vs Tiapride change from baseline | | 2] 19.90 (2.92) | | | | 2] 24%
| 9] Placebo vs Haloperidol change from baseline | | 3] 20.52 (3.27) | | | | 3] 31%
| 10] Triapride vs Haloperidol change from baseline | Global Improvement no change | | | | | 1] 21%
| | | | | | | 2] 12%
| | | | | | | 3] 12%
| | CGI | | | | | | 8] 0.03
| | | | | | | | 9] 0.02
| | | | | | | | 10] NS
| | MMSE | | | | | | 8] NS
| | | | | | | | 9] NS
| | | | | | | | 10] NS

Evidence Table 146. Study results: Olanzapine - Lorazepam

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 2h | | Final: (specify) 24h
Meehan, 2002 | OC Analysis
| 1] Placebo change from baseline | [underlined: PANSS-EC] | | | 1] -5.27 (6.87) | 5]<0.05 | 1] -3.81 (6.20) | 5]<0.05
| 2] Olanzapine 2.5mg change from baseline | | | | 2] -7.86 (6.05) | 6]<0.01 | 2] -6.44 (6.00) | 6]<0.05
| 3] Olanzapine 5mg change from baseline | | | | 3] -8.67 (6.97) | 7]<0.01 | 3] -6.29 (6.75) | 7] NS
| 4] Lorazepam 1mg change from baseline | | | | 4] -8.49 (6.55) | | 4] -5.75 (5.99)
| 5] Olanzapine 2.5mg vs. placebo | CMAI | | | 1] -2.78 (3.4) | 5] NS | 1] -2.21 (3.7) | 5] NS
| 6] Olanzapine 5mg vs. placebo | | | | 2] -3.77 (2.93) | 6]<0.05 | 2] -2.82 (3.21) | 6] NS
| 7] Lorazepam 1mg vs. placebo | | | | 3] -3.97 (3.89) | 7]<0.05 | 3] -3.36 (3.92) | 7] NS
| | | | | 4] -4.18 (3.52) | | 4] -2.82 (3.08)
| | ACES | | | 1] 1.04 (1.66) | 5]<0.05 | 1] 0.63 (1.14) | 5] NS
| | | | | 2] 1.80 (1.61) | 6]<0.01 | 2] 0.90 (1.19) | 6] <0.01
| | | | | 3] 1.88 (1.86) | 7]<0.01 | 3] 1.29 (1.49) | 7] <0.05
| | | | | 4] 2.19 (1.83) | | 4] 1.07 (1.12)
| | BPRS Total | | | | | 1]-10.29(11.72) | 5] NS
| | | | | | | 2]-10.51(11.50) | 6] NS
| | | | | | | 3]-10.59(11.31) | 7] NS
| | | | | | | 4]- 9.12(10.27)
| | BPRS Positive | | | | | 1] -2.09 (3.80) | 5] NS
| | | | | | | 2] -1.72 (3.50) | 6] NS
| | | | | | | 3] -1.86 (3.39) | 7] NS
| | | | | | | 4] -1.32 (3.32)
| | CGI-S | | | | | 1] -0.59 (0.92) | 5] NS
| | | | | | | 2] -0.38 (0.80) | 6] NS
| | | | | | | 3] -0.47 (0.89) | 7] NS
| | | | | | | 4] -0.46 (0.80)
| | MMSE Total | | | | | 1] 0.37 (3.62) | 5] NS
| | | | | | | 2] 0.31 (2.29) | 6] NS
| | | | | | | 3] 0.10 (3.01) | 7] NS
| | | | | | | 4] 0.08 (3.04)

Evidence Table 147. Study results: Thoridazine - Loxapine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Barnes 1981 | Endpoint Analysis
| 1] Placebo | BPRS Total | | | | | 1] 39.74 | 4] <.05
| 2] Thoridazine 62.5mg/d | | | | | | 2] 39.73 | 5] <.05
| 3] Loxapine 10.5mg/d | | | | | | 3] 36.89 | 6] <.01
| 4] Improvement from baseline Placebo | | | | | | | 7] NS
| 5] Improve from baseline Thoridazine | | | | | | | 8] NS
| 6] Improve from baseline Loxapine | SCAG | | | | | 1] 59.24 | 4] <.05
| 7] Thioridazine vs Placebo from baseline | | | | | | 2] 58.82 | 5] <.05
| 8] Loxapine vs Placebo from baseline | | | | | | 3] 53.58 | 6] <.01
| 9] Loxapine vs Thioridazine from baseline | | | | | | | 7] NS
| | | | | | | | 8] NS
| | CGI- Improvement | | | | | 1] 3.41 | 7] NS
| | | | | | | 2] 3.18 | 8] NS
| | | | | | | 3] 3.11
| | NOSIE | | | | | | 7] NS
| | | | | | | | 8] NS
| | | | | | | | 9] NS
| | CGI Severity | | | | | 1] 3.17 | 4] NS
| | | | | | | 2] 3.07 | 5] <0.01
| | | | | | | 3] 3.05 | 6] <0.01

Evidence Table 148. Study results: Citalopram

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) up to 17d
Pollock, 2002 | ITT Analysis
| 1] Placebo | [underlined: Neuro- Behavioural Rating Score] | 1] 58.3 (11.9) | | | | 1] 56.0 (15.2) | 4] 0.002
| 2] Citalopram 20 mg/d | | 2] 53.5 (10.2) | | | | 2] 43.5 (12.1) | 5] 0.14
| 3] Perphenazine 0.1mg/kg/d | | 3] 57.1 (14.0) | | | | 3] 49.9 (14.2)
| 4] Citalopram vs. placebo
| 5] Perphenazine vs. placebo

Evidence Table 149. Study results: Xanomeline Tartrate (XT)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Bodick 1997 | Endpoint analysis | [underlined: ADAS-Cog] | | | | | 1] 1.42 | 5] 0.935
Veroff, 1998 | 1] Placebo change from baseline | | | | | | 2] 1.03 | 6] 0.367
Satlin 1997 | 2] XT 25 mg tid change from baseline | | | | | | 3] 0.38 | 7] 0.045
| 3] XT 50 mg tid change from baseline | | | | | | 4] -1.42 | 8] 0.033
| 4] XT 75 mg tid change from baseline | [underlined: CIBIC+] | | | | | 1] 4.33 | 5] 0.846
| 5] XT 25 mg tid difference from Placebo | | | | | | 2] 4.44 | 6] 0.036
| 6] XT 50 mg tid difference from Placebo | | | | | | 3] 4.09 | 7] 0.022
| 7] XT 75 mg tid difference from Placebo | | | | | | 4] 4.00 | 8] 0.005
| 8] Dose response | ADSS | | | | | | 8] 0.002
| | NOSGER | | | | | 1] 1.15 | 5] 0.457
| | | | | | | 2] 0.06 | 6] 0.078
| | | | | | | 3] -1.49 | 7] 0.032
| | | | | | | 4] -1.69 | 8] 0.018
| | IADL | | | | | 1] 0.48 | 5] 0.786
| | | | | | | 2] 0.58 | 6] 0.088
| | | | | | | 3] -0.29 | 7] 0.026
| | | | | | | 4]-0.12 | 8] 0.010
| | CNTB | | | | | 4] 2.77 | 7] 0.039

Evidence Table 150. Study results: Haloperidol - Risperidone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12 w
Chan 2001 | OC Analysis
| 1] Haloperidol 0.5–2 mg/d | CMAI | 1] 46.4 (10.5) | | | | 1] 36.3 (10.4) | 3] 0.000
| 2] Risperidone 0.5–2 mg/d | | 2] 48.9 (14.5) | | | | 2] 40.8 (16.9) | 4] 0.002
| 3] Haloperidol change from baseline | | | | | | | 5] 0.95
| 4] Risperidone change from baseline | BEHAVE-AD (Aggressiveness) | 1] 2.1 (2.0) | | | | 1] 0.8 (1.5) | 3] 0.011
| 5] Between treatments | | 2] 2.2 (2.5) | | | | 2] 0.9 (2.0) | 4] 0.019
| | | | | | | | 5] 0.56
| | FAST | | | | | No data extracted
| | CMMSE | 1] 8.2 (5.0) | | | | 3] -0.15 | 3] 0.84
| | | 2] 7.9 (6.0) | | | | 4] -0.42 | 4] 0.70

Evidence Table 151. Study results: Fluoxetine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 30d | | Final: (specify) 45d
Taragano 1997 | OC Analysis
| 1] Fluoxetine 10 mg/d | Ham-D | 1] 25.3 (3.8) | 3] 0.10 | 1] 19.3 (3.2) | 3] 0.10 | 1] 16.7 (2.9) | 3] 0.10
| 2] Amitriptyline 25 mg/d | | 2] 26.3 (4.0) | | 2] 17.8 (2.5) | | 2] 15.6 (3.2)
| 3] Between treatments | MMSE | 1] 20.0 (3.2) | 3] 0.10 | | | 1] 21.4 (2.9) | 3] 0.10
| | | 2] 18.8 (4.2) | | | | 2] 21.5 (3.5)

Evidence Table 152. Study results: Lorazepam, Alprazolam

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 28d
Ancill, 1991 | OC Analysis
| 1] Lorazepam mean 3.1 mg/d | CGI % improved | | | | | 1] 29% | 3] NS
| 2] Alprazolam mean 1.5 mg/d | | | | | | 2] 42%
| 3] Larazepam vs Alprazolam

Evidence Table 153. Study results: Citalopram

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6w | | Final: (specify) 12w
Karlsson, 2000 | OC Analysis
| 1] Citalopram 40 mg variable | [underlined: MADRS] | 1] 26 | | 1] 18 | | 1] 15 | 3] >0.7
| 2] Mianserin 60 mg variable | | 2] 27 | | 2] 18 | | 2] 16
| 3] Citalopram vs. Mianserin from baseline

Evidence Table 154. Study results: Haloperidol - Oxazepam - Diphenhydramine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: | | Final: 8w
Coccaro 1990 | Completers Analysis
| 1] Haloperidol 5 mg/d (max) | CDRS mean score | 1] 2.78 | 4] > 0.10
| 2] Oxazepam 60 mg/d (max) | | 2] 2.76
| 3] Diphenhydramine 200 mg/d (max) | | 3] 2.66
| 4] Between groups, change from baseline | ADAS | 1] 11.00 (5.95) | | | | 1] 8.39 (6.09) | 4] NS
| 5] Change from baseline | | 2] 11.50 (4.90) | | | | 2] 9.12 (4.33) | 5] < 0.001
| 6] Between groups at timepoint | | 3] 9.82 (3.68) | | | | 3] 6.12 (4.78) | 6] NS
| | BPRS | 1] 6.33 (3.01) | | | | 1] 4.78 (2.44) | 4] NS
| | | 2] 5.81 (2.17) | | | | 2] 5.50 (2.71) | 5] < 0.02
| | | 3] 5.67 (2.72) | | | | 3] 4.47 (2.85) | 6] NS
| | PSMS | 1] 42.17 (12.95) | | | | 1] 37.89 (15.36) | 4] NS
| | | 2] 45.75 (11.02) | | | | 2] 43.68 (11.47) | 5] < 0.001
| | | 3] 39.35 (10.36) | | | | 3] 34.76 (9.94) | 6] NS
| | | | | | | 1] 78.31 (9.45)
| | | | | | | 2] 80.69 (9.89)
| | | | | | | 3] 73.00 (11.53)
| | NOSIE | 1] 78.19 (7.67) | | | | | 4] NS
| | | 2] 80.69 (9.10) | | | | | 5] NS
| | | 3] 73.47 (5.88) | | | | | 6] <0.02

Evidence Table 155. Study results: Loxapine - Haloperidol

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 14d | | Final: (specify) 28d
Carlyle 1993 | OC Analysis
| 1] Haloperidol 7.0 mg/d (mean) | Mean Aggression Score for responders | 1] 6.0 | | 1] 4.8 | 3] NS | 1] 2.5 | 3] NS
| 2] Loxapine 36.0 mg/d (mean) | | 2] 8.6 | | 2] 6.6 | | 2] 4.2
| 3] Difference between Haloperridol and Loxapine | Mean depression score Response rate | | | | | 1] 11/14 | 3] NS
| | | | | | | 2] 14/17

Evidence Table 156. Study results: 5′-MTHF - Trazodone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 4w | | Final: (specify) 8w
Passeri 1992 | OC Analysis
| 1] 5′-MTHF 50 mg/d | HDRS | 1] 23 (5) | | 1] 20(6) | 3] <0.01 | 1] 18 (6) | 3] <0.01
| 2] Trazodone 100mg/d | | 2] 23 (3) | | 2] 21 (4) | 4] <0.05 | 2] 19 (5) | 4] <0.01
| 3] 5′-MTHF change from baseline | | 5] 23 (5) | | 5] 21 (6) | 7] <0.01 | 5] 18 (6) | 7] <0.01
| 4] Trazodone change from baseline | | 6] 23 (4) | | 6] 21 (5) | 8] <0.01 | 6] 19 (6) | 8] <0.01
| 5] 5′-MTHF subgroup AD | | 9] 21 (5) | | 9] 17 (7) | | 9] 18 (5) | 11] <0.01
| 6] Trazodone subgroup AD | | 10] 23 (3) | | 10] 22 (2) | | 10] 20 (3)
| 7] 5′-MTHF change from baseline subgroup AD | RVM immediate recall | 1] 20 (7) | | | | 1] 23 (8) | 3] <0.01
| 8] Trazodone change from baseline subgroup AD | | 2] 22 (9) | | | | 2] 22 (9) | 7] <0.01
| 9] 5′-MTHF subgroup MID | | 5] 20 (7) | | | | 5] 23 (7)
| 10] Trazodone subgroup MID | | 6] 22 (9) | | | | 6] 22 (8)
| 11] Trazodone change from baseline subgroup MID | | 9] 20 (8) | | | | 9] 22 (7)
| | | 10] 20 (8) | | | | 10] 22 (11)
| | RVM delayed recall | 1] 2 (2) | | | | 1] 3 (2)
| | | 2] 3 (2) | | | | 2] 3 (2)
| | | 5] 3 (2) | | | | 5] 3 (2)
| | | 6] 3 (2) | | | | 6] 3 (2)
| | | 9] 2 (2) | | | | 9] 3 (2)
| | | 10] 4 (2) | | | | 10] 3 (2)

Evidence Table 157. Study results: Tiapride - Melperone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 28d
Gutzmann 1997 | ITT Analysis
| 1] Melperone 400 mg/d | CGI (item 1) | 1] 68% | | | | 1] 35.9%
| 2] Tiapride 100 mg/d | Severity of illness % | 2] 77% | | | | 2] 52.6%
| 3] Melperone vs Tiapride change from baseline | Severely III or markedly III
| | CGI (Item 2) global change % responders | | | | | 1] 72.5% | 3] 0.675
| | | | | | | 2] 73.4%
| | NOSIE social competence | 1] 28.5 | | | | 1] 32.0
| | | 2] 29.2 | | | | 2] 31.4
| | NOSIE irritability | 1] 30.9 | | | | 1] 25.7
| | | 2] 32.1 | | | | 2] 26.8
| | AGGR | 1] 10.6 | | | | 1] 5.7
| | | 2] 11.0 | | | | 2] 4.8
| | VAS-ADL | 1] 31.1 | | | | 1] 41.8
| | | 2] 32.5 | | | | 2] 39.9
| | VAS- verbal aggression | 1] 28.5 | | | | 1] 14.7
| | | 2] 30.9 | | | | 2] 15.8
| | VAS-aggressive behaviour | 1] 26.9 | | | | 1] 16.5
| | | 2] 38.4 | | | | 2] 18.3

* SEM

Evidence Table 158. Study results: Imipramine - Paroxetine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Katona, 1998 | ITT Analysis
| 1] Paroxetine 50 mg bid variable change from baseline | [underlined: MADRS] | | | | | 1] -12.6 (10.0) | 3] >0.368
| 2] Imipramine 50 mg bid variable change from baseline | | | | | | 2] -11.8 (10.0)
| 3] Difference between Paroxetine group and Imipramine group | [underlined: CGI severity of Illness] | | | | | 1] -1.3 (1.5) | 3] >0.286
| | | | | | | 2] -1.3 (1.5)
| | CGI improvement Score | | | | | 1] 2.7 (1.5)
| | | | | | | 2] 2.7 (1.6)
| | CSDD | | | | | 1] -8.9 (6.7) | 3] <0.049 favours Paraxetine
| | | | | | | 2] -7.1 (7.5)
| | GBS total score | | | | | 1] -11.7 (18.1) | 3] >0.651
| | | | | | | 2] -12.0 (19.6)

Evidence Table 159. Study results: Loxapine - Haloperidol

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: 10w
Petrie, 1982 | Efficacy Analysis Population
| 1] Placebo | CGIC (marked or moderate improvement) | | | | | 1] 9%
| 2] Haloperidol 10 mg/d (max) | | | | | | 2] 35%
| 3] Loxapine 50 mg/d (max) | | | | | | 3] 32%
| 4] Haloperidol vs baseline | BPRS total | 1] 46.36 | | | | 1] 48.90 | 4] < 0.05
| 5] Loxapine vs baseline | | 2] 46.35 | | | | 2] 39.60 | 5] < 0.05
| 6] Placebo vs Haloperidol change from baseline | | 3] 50.79 | | | | 3] 43.84 | 6] <0.05
| 7] Placebo vs Loxapine change from baseline | | | | | | | 7] <0.05
| | SCAG total | 1] 61.0 | | | | 1] 60.9 | 4] < 0.05
| | | 2] 55.9 | | | | 2] 47.3 | 5] < 0.05
| | | 3] 62.9 | | | | 3] 54.4
| | NOSIE | 1] 157.2 | | | | 1] 151.2 | 5] < 0.05
| | | 2] 184.0 | | | | 2] 192.0
| | | 3] 155.0 | | | | 3] 171.4

Evidence Table 160. Adverse events. Various cholinergic neurotransmitter modifying agents

Adverse events (AE) identified in included studies | ALAPROCLATE Dehlin, 1985 | ANAPSOS Alvarez, 2000 | BMY Cutler, 1993 | CARBAMAZEPINE Olin, 2001 | CARBAMAZEPINE Tariot, 1998 | CITALOPRAM Nyth, 1990 | DIVALPROEX Porsteinsson, 2000 | DIVALPROEX Tariot, 2001b | FLUOXETINE Petracca, 2001 | FLUOXETINE Taragano, 1997 | FLUVOXAMINE Olafsson, 1992 | IMIPRAMINE Reifler, 1989 | LISURIDE Claus, 1998 | LU 25-109 Thal, 2000b | MAPROTILINE Fuchs, 1993 | MINAPRINE Passeri, 1987 | MOCLOBEMIDE Roth, 1996 | NAFTIDROFURYL Moller, 2001 | OLANZEPINE Street, 2000 | PHOSPHATIDYL-SERINE Amaducci, 1988 | PHOSPHATIDYL-SERINE Crook, 1992a | RISPERIDONE Katz, 1999 | SERTRALINE Magai, 2000 | SERTRALINE Lyketsos, 2000 | XANOMELINE Bodick, 1997 | LORAZEPAM (T) ALPRAZOLAM (C) Ancill, 1991 | HALOPERIDOL (T1) OXAZEPAM (T2) DIPHENHYD (T3) Coccaro, 1990 | HALOPERIDOL (T) LOXAPINE (C) Carlyle, 1993 | HALOPERIDOL (T1) LOXAPINE (T2) PLACEBO (C) Petrie, 1982 | 5′-MTHF (T) TRAZODONE (C) Passeri, 1993 | TIAPRIDE (T) MELPERONE (C) Gutzmann, 1997 | HALOPERIDOL (T1), BMT (T2), TRAZODONE (T3) Teri, 2000 | HALOPERIDOL(T1) FLUOXETINE (T2) PLACEBO (C) Auchus, 1997 | CITALOPRAM (T) MIANSERIN (C) Karlsson, 2000 | PERPHENAZINE CITALOPRAM Pollock, 2002 | TIAPRIDE (T1) HALOPERIDOL (T2) PLACEBO (C) Allain, 2000 | HALOPERIDOL (T) RISPERIDONE (C) Chan, 2001 | HALOPERIDOL (T1) RISPERIDONE (T2) PLACEBO (C) De Deyn, 1999 | CITALOPRAM (T1) PERPHENAZINE (T2) PLACEBO Pollock, 2002 | PAROXETINE (T) IMIPRAMINE (C) Katona, 1998 | OLANZEPINE (T) LORAZEPAM (C) Meehan, 2002 | THIORIDAZINE (T1) LOXAPINE (T2) PLACEBO (C) Barnes, 1982
Withdrawn (%) due to AE | T: 0 | T: 7 | T: 24 | T: 0 | T: 15 | T: 24 | T: 7 | T: 22 | T: 6 | T: 58 | T: 18 | T: 15 | T: 0 | T: 30 | T: 2 | T: 0 | T: NR | T: 0 | T: 12 | T: 0 | T: 0 | T: 16^+^ | T: 12 | T: 0 | T: 40^+^ | T: 19 | T1: 10 | T: 20 | T1: 21 | T: 0 | T: 11 | T1: NR | T1: 33 | T: 5 | T:NR | T1: 5 | T: 4 | T1: NR | | T: 18 | T: 0 | T1: 18
| C: 13 | C: 7 | C: 9 | C: 25 | C: 0 | C: 14 | C: 14 | C: 4 | C: 4 | C: 22 | C: 33 | C: 3 | C: 0 | C: 12 | C: 2 | C: 0 | C: NR | C: 0 | C: 4 | C: 0 | C: 0 | C: 12 | C: 14 | C: 0 | C: 35 | C: 11 | T2: 11 | C: 15 | T2: 15 | C: 0 | C: 6 | T2: NR | T2: 0 | C: 9 | C:NR | T2: 17 | C: 7 | T2: NR | | C: 17 | C: 0 | T2: 21
| | | | | | | | | | | | | | | | | | | | | | | | | | | T3: 5 | | C: 5 | | | T3: NR | C: 17 | | | C: 6 | | C: NR | | | | C: 12
AE Checklist (Max 5) | 2 | 3 | 1 | 4 | 4 | 3 | 5 | 5 | 5 | 3 | 2 | 2 | 1 | 1 | 3 | 5 | 2 | 2 | 2 | 3 | 4 | 4 | 5 | 2 | 2 | 4 | 3 | 5 | 5 | 3 | 5 | 2 | 3 | 3 | 2 | 3 | 1 | 1 | | 4 | 3 | 3
None Reported | | | x | | | | | | | | | | | | | | | | | x | x
Balance | x | x | | | x | | | | | | | | | | | x | | | S* | | | | | | | | | | | x | | S* | x
Accidental Injury | | | | | | | | S | | | | | | | | | | | NS* | | | X | | | | | | | | | | | | | | | | NS* | | | NS*
Dizziness | x | x | | | | X | | | X | | | NS | x | x | NS | | NS | | | | | | | | | | | | | | x | NS* | | NS*
Falls | | x | | | NS | | | | | | | | | | | | | | | | | X | | | | | | x | | | | | | | | | | NS*
Behavioral | | x | | | | | | | | | x | | | | | | | | | | | | | | | NS* | | | NS* | | | | | | | x
Agitation | x | | | | | | x | | | | | | | x | | x | NS | | NS* | | | X | x | NS | | NS* | x | | | | x | | | NS* | S* | | | NS* | | | | x
Cardiovascular | | | | | | | x | S | | | | x | | | | | | x | | | | | | | | | | | x | | | | | | | x | | | | | NS* | x
Arrhythmia | | x | | | | NS | | | | | | | | | | | NS | | | | | | | | | | | | | | | | | | | | | | | | NS*
Hypotension | x | | | | S | | | | | | | | | | | | | | | | | | | | | S* | | x | x | | | | | | | x | NS* | | | | | x
Hypertension | | | | | | | | | | | | | | | NS | | NS | | | | | | | | | | | | | | x | | | | | x | | | | | NS* | x
Extrapyramidal | | | | | NS | | | | | | | | | | | | | | | | | X | | | | | x | x | x | | x | S* | | | NS* | S* | S* | | | | NS* | x
Tremor | | | | | | | | | X | | | | | | | | | | | | | | | NS | | | | x | | | | NS* | x | | | x
Gastrointestinal | | | | | NS | | | x | X | | | | | | | | NS | | | | | | | NS | | | | | x | | x
Abdominal pain | | | | | | | | | | | | | | x | | | NS
Constipation | | | | | | | | | X | X | | | | | x | | NS | | | | | | | | | | | x | | | | | | NS* | | x | x
Diarrhea | x | | | x | | | x | | | X | | | | x | | | NS | | | | | | | | | | | | | | | | | | | x
Dyspepsia | | | | | | | | | X | | | | | | | x | | | | | | | | | S* | | | | | | | | | x
Nausea, vomiting | | x | | x | | | x | NS | | X | x | | | x | x | | NS | | | | | | | | S* | | | | | | x | | | NS* | | x | x | | | x
Metabolic/nutritional | | | | | | | | NS | | | | x | | x | | | | | | | | | | | S* | | | | | | x
Eating disorder | | | | | | | | NS | | | | | | x | | | | | NS*
Weight Change | | | | | | | | NS | | | | | | x | NS | | NS | | NS* | | | | | | | | | | | | x
Neurological | | | | | | | x | | | | | | | | | | | | | | | | | | | S* | | | x | | x | | | | NS*
Asthenia | | | | | | | | | | | | | | x | | | | | | | | | | | | | | | | | | | | | | x | | | | x
Psychiatric | x | x | | | | X | | | | | x | | | | x | | | | | | | | | | | | | | | | | | | | | | | | | x
Anxiety | | | | | | | | | | | | x | | | | x | x | | NS* | | | | | | | | | | | | | | x | NS* | | x
Confusion, delirium | x | | | | NS | | x | | X | X | | | | x | | | | | | | | | x | x | | S* | | x | | | | | x | | | | | | | x
Depression | x | | | | | X | | | | | x | | | x | | | | | | | | | | | | | | | | | x | | x
Respiratory | | | | | | | x | | | | | | | | | | | | | | | X | | | | | | | | | | | | | | | | | | x
Cough, cold, infection | | | | | | | | | | | | | | | | | | | NS* | | | X
Rhinitis | | | | | | | | | | | | | | | | | | | | | | X
Other | x | | | | | X | S | NS | X | | | x | | x | x | | NS | x | NS* | | | X | x | | S* | S* | x | x | S* | x | x | NS* | | | | NS* | | | | x | | x
Aberrant hematology | | | | NS | | | NS | S
Fatigue, weakness | | | | | NS | X | x | | | | | | x | x | x | | NS | | | | | | | | | | | | | | x | NS* | | S* | | | | | | | | x
Fever, flu, pneumonia | | | | | NS | | x | | | | | x | | | | | | | NS* | | | X | | | | | | | | | x
Headache | | | | | | | | | | | | | x | x | | x | x | | | | | | | | | | | | | | | | | NS* | | | | | | | NS*
Hepatic abnormality
Muscle/joint disorder | x | | | | | | x | | | | | | | | | | NS
Pain | | | | | | | | | | | | | | | | | | | NS* | | | X | | | S* | | | | | | | | | NS*
Rash, skin disorder | | x | | | NS | X | x | NS | | | | | | | | x | | | NS* | | | X
Sleep disorder | x | | | | NS | X | x | S | | | x | NS | | x | | | NS | | S* | | | X | | | | | | | | | x | | | S* | | x | x | NS* | | x | NS*
Urinary disorder | | | | | NS | | x | NS | | | | | | x | x | | | | | | | X | | | | | | x | | | x | | | x | | x

NR= Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x= Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS*= Reported and tested for statistical differences between two (three) treatment groups

[ ]= Symptom NOT reported in the paper

Evidence Table 161. Key characteristics: Cerebrolysin (CERE)

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports strained
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Bae 2000 | IF | 7 | Placebo | NINCDS | AD | Mild-Mod | 53 | 53 | 71.0y (NR) | 30 ml/d 5 d/w | 4w | ADAS-Cog | No
| | | Cerebrolysin | | | | | | 34% M | | | Katz-ADL
| | | | | | | | | | | | CGIS/C
| | | | | | | | | | | | GDS
| | | | | | | | | | | | Lawton-IADL
| | | | | | | | | | | | MMSE
Panisset 2002 | NI | 8 | Placebo | NINCDS | AD | Probable | 192 | 171 | 74.1y (59–81y) | 30 ml/d 5 d/w | 6m | ADAS-cog | APOE Genotype
| | | Cerebrolysin | | | Mild-Mod | | | 42% Male | | | CIBIC+
| | | | | | | | | 93.5% White | | | MMSE
| | | | | | | | | | | | DAD
| | | | | | | | | | | | CORNELL
| | | | | | | | | | | | PSMS
| | | | | | | | | | | | IADL
| | | | | | | | | | | | Behave-AD
| | | | | | | | | | | | CDR
| | | | | | | | | | | | CMH
| | | | | | | | | | | | CMH
| | | | | | | | | | | | Trail Making Test
Ruether 1994 | NR | 7 | Placebo | DSM-III-R | AD | Mild-Mod | 120 | 120 | 71.5y (NR) | 30 ml 5d/wk | 28d | BF-S | No
Auxiliary: | | | Cerebrolysin | | | | | | 34% M | | | GDS
Ruether 2000 | | | | | | | | | | | | Ham-D
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NAI
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Trail Making
| | | | | | | | | | | | ZVT-G
Ruether 2001 | IF | 8 | Placebo | NINCDS | AD | Probable | 149 | 136 | 73.0y (50–85y) | 30 ml Cere | 16w | ADAS-Cong | MMSE
Auxiliary: | | | Cerebrolysin | ICD I0 | | Mild-Mod | | | 42% M | 70 ml Saline | | ADAS-Noncog
Ruether 2002 | | | | | | | | | | 5d/w | | CGI
| | | | | | | | | | | | MADR-S
| | | | | | | | | | | | NAI
| | | | | | | | | | | | SKT
Xiao 1999 | IF | 6 | Placebo | DSM IV | VaD | Mild-Modly Sev | 148 | 147 | 69.7y (55–85y) | 30 ml/d 5d/wk | 4w | ADL | No
| | | Cerebrolysin | | | | | | 69% M | | | CGI
| | | | | | | | | | | | Ham-D
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NAI
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Trail Making
| | | | | | | | | | | | ZVT
Xiao 2000 | IF | 7 | Placebo | DSM-III-R | AD | Mild-Modly Sev | 157 | 155 | 70.3y (55–85y) | 30 ml 5d/w | 4w | ADL | No
| | | Cerebrolysin | NINCDS | | | | | 50% M | | | CGI
| | | | | | | | | | | | CGI
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NAI
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | ZVT

Evidence Table 162. Study results: Cerebrolysin (CERE)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 4w
Bae, 2000 | ITT Analysis
| 1] Placebo | [underlined: ADAS-Cog] | 1] 33.51 (13.35) | | | | 3] -0.36 (3.59) | 5] 0.02
| 2] CERE 30 ml IV qid | | 2] 32.52 (14.65) | | | | 4] -3.23 (4.75)
| 3] Placebo change from baseline | [underlined: CGIS/C (Improved)] | | | | | 1] 21.1% | 5] 0.01
| 4] CERE change from baseline | | | | | | 2] 61.8%
| 5] CERE vs Placebo change from baseline | MMSE | 1] 14.6 (5.5) | | | | | 5] 0.04
| | | 2] 16.3 (4.8)
| | GDS | 1] 7.1 (3.4) | | | | 3] 0.21 | 5] NS
| | | 2] 6.1 (2.9) | | | | 4] 1.68
| | KATZ ADL | 1] 9.9 (3.2) | | | | | 5] NS
| | | 2] 9.1 (3.4)
| | LAWTON IADL | 1] 25.2 (5.9) | | | | | 5] NS
| | | 25.5 (6.4)

Evidence Table 163. Study results: Cerebrolysin (CERE)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 3m | | Final: (specify) 6m
Panisset, 2002 | OC Analysis | | | | Endpoint 2 months after end of therapy | | 5 months after end of therapy
| 1] Placebo mean change from baseline | [underlined: CIBIC+] | | | 1] 4.29 (0.11)* | 3] 0.033 | 1] 4.46 (0.12)
| 2] CERE 30 ml 5d/w for 4 weeks mean change from baseline | | | | 2] 4.08 (0.10) | | 2] 4.42 (0.12)
| 3] CERE vs. Placebo change from baseline | [underlined: ADAS-Cog] | 1] 23.63 (1.53) | | 1] -0.88 (0.61) | 3] 0.284 | 1] 1.02 (0.69)
| | | 2] 24.20 (1.68) | | 2] 0.04 (0.62) | | 2] 2.83 (0.68)
| | DAD | | | 1] -2.34 (1.4) | 3] 0.680 | 1] -4.08(1.63)
| | | | | 2] -1.54 (1.38) | | 2] -6.04 (1.60)
| | MMSE | 1] 20.93 (0.33) | | 1] 0.17 (0.34) | 3] 0.620 | 1] -0.34 (0.39)
| | | 2] 20.22 (0.34) | | 2] -0.06 (0.34) | | 2] -0.93 (0.38)

Evidence Table 164. Study results: Cerebrolysin (CERE)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 4w
Ruether, 1994 | ITT Analysis
Ruether, 2000 | 1] Placebo | [underlined: ZVT-G] | 1] 184.4 (39.3) | | | | 1] 185.6 (21.5) | 3] <0.05
| 2] CERE 30 ml 5d/w for 4 weeks | | 2] 184.1 (32.4) | | | | 2] 161.5 (22.8) | 4] <0.0001
| 3] CERE 30 ml vs baseline | [underlined: SCAG] | 1] 66.9 (7.5) | | | | 1] 65.8 (6.1) | 3] <0.05
| 4] Cere vs. Placebo change from baseline | | 2] 66.5 (6.5) | | | | 2] 49.8 (5.2) | 4] <0.0001
| | [underlined: CGI % with improvement] | | | | | 1] 20% | 3] 0.0001
| | | | | | | 2] 100% | 4] <0.0001
| | NAI | 1] 48.2 (2.7) | | | | 1] 45.6 (3.3) | 3] <0.05
| | | 2] 48.1 (2.2) | | | | 2] 34.5 (2.1) | 4] NS
| | Bf-S | 1] 44.7 (3.6) | | | | 1] 41.6 (5.7) | 3] <0.05
| | | 2] 43.7 (4.3) | | | | 2] 26.9 (6.7)

Evidence Table 165. Study results: Cerebrolysin (CERE)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 16w Endpoint | | Final: (specify) 28w Follow-up
Ruether 2001 | ITT Analysis
Ruether 2002 | 1] Placebo | [underlined: CGI] | 1] 5.16 (0.07) | | 3] 4.60 (0.11) | 6] .004 | 3] 4.86 (0.12) | 6] <0.024
| 2] CERE 30 ml/d 5d/w for 4 weeks (repeat after 8w washout) | | 2] 5.24 (0.07) | | 4] 4.18 (0.11) | | 4] 4.81 (0.12)
| 3] Placebo change from baseline | [underlined: ADAS-Cog] | 1] 30.21 (1.57) | | 3] 1.1 (0.59) | 5] .001 | 3] 1.6 (0.59) | 5]<0.025
| 4] CERE 30 ml/d change from baseline | | 2] 32.01 (1.44) | | 4] -2.1(0.69) | | 4] 0.0 (0.65) | 6] 0.024
| 5] CERE vs Placebo change from baseline | NAI | | | 3] 0.0 (0.21) | 5] 0.07 | 3] 0.4(0.30) | 5] 0.071
| 6] Mean treatment difference between CERE and Placebo | | | | 4] -0.5 (0.29) | | 4] 0.0 (0.32)
| | ADAS- Noncog | | | 3] -0.2 (0.29) | 6] .003 | 3] 0.9 (0.37) | 5]<0.025
| | | | | 4] -1.2 (0.45) | | 4] -0.1(0.38) | 6] 0.003
| | MADR-S | | | | 5] NS | | 5] 0.102
| | SKT | | | | 5] NS | | 5] 0.161

Evidence Table 166. Study results: Cerebrolysin (CERE)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 2w | | Final: (specify) 4w
Xiao, 1999 | ITT Analysis
| 1] Placebo | [underlined: MMSE] | 1] 20.08 (3.58) | | 1] 21.01 (4.57) | 3] 0.252 | 1] 21.80 (4.17) | 3] 0.028
| 2] CERE30 ml QID 5d/w | | 2] 19.61 (3.31) | | 2] 20.96 (3.74) | | 2] 22.29 (4.19)
| 3] CERE vs Placebo change from baseline | [underlined: CGI improved] | | | 1] 61% | 3] 0.19 | 1] 71% | 3] 0.11
| | | | | 2] 48% | | 2] 73%
| | HAM-D | 1] 8.47 (4.83) | | 1] 7.33 (4.73) | 3] 0.078 | 1] 6.33 (3.94) | 3] 0.179
| | | 2] 9.68 (4.95) | | 2] 7.56 (5.24) | | 2] 6.68 (5.86)
| | SCAG | 1] 43.55(12.23) | | 1] 40.20(11.20) | 3] 0.359 | 1] 36.94(11.63) | 3] 0.767
| | | 2] 44.06(12.16) | | 2] 39.74(11.47) | | 2] 37.00(12.68)
| | ADL | 1] 30.50 (8.25) | | 1] 29.40 (8.82) | 3] 0.429 | 1] 28.34 (8.95) | 3] 0.377
| | | 2] 30.92 (9.05) | | 2] 30.45 (9.82) | | 2] 29.53(10.34)
| | NAI | 1] 45.94 (6.39) | | 1] 45.60 (6.90) | 3] 0.756 | 1] 45.36 (6.92) | 3] 0.355
| | | 2] 46.44 (6.51) | | 2] 45.88 (6.58) | | 2] 45.11 (7.09)
| | ZVT-1 | 1] 182.96 (95.77) | | 1] 166.81 (84.30) | 3] 0.125 | 1] 170.45 (93.54) | 3] 0.017
| | | 2] 204.69 (122.27) | | 2] 165.00 (92.05) | | 2] 159.63 (85.33)
| | ZVT-2 | 1] 177.88 (107.90) | | 1] 166.28 (92.93) | 3] 0.193 | 1] 170.05 (93.86) | 3] 0.016
| | | 2] 209.23 (163.85) | | 2] 170.74 (114.50) | | 2] 159.00 (95.88)

Evidence Table 167. Study results: Cerebrolysin (CERE)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 4w
Xiao, 2000 | ITT Analysis
| 1] Placebo IV | [underlined: CGI % improved] | | | 1] 52% | 3] 0.03 favours placebo | 1] 60% | 3] 0.02
| 2] CERE IV 30 ml qid, 4d/w | | | | 2] 39% | | 2] 72%
| 3] CERE IV vs Placebo change from baseline | [underlined: MMSE] | 1] 19.3 (3.2) | | 1] 20.12(4.16) | 3] 0.417 | 1] 20.57 (4.61) | 3] 0.043
| | | 2] 18.81 (2.32) | | 2] 20.05(3.37) | | 2] 21.26 (4.08)
| | HAM-D | 1] 7.16 (5.02) | | 1] 6.26 (4.48) | 3] 0.403 | 1] 5.56 (4.16) | 3] 0.783
| | | 2] 7.04 (4.93) | | 2] 6.50 (4.63) | | 2] 5.29 (4.97)
| | SCAG | 1] 42.07(12.44) | | 1] 39.73(12.73) | 3] 0.025 | 1] 38.66(12.64) | 3] 0.014
| | | 2] 41.91(11.99) | | 2] 37.87(12.12) | | 2] 35.71(13.48)
| | ADL | 1] 29.48 (7.59) | | 1] 29.30 (7.72) | 3] 0.105 | 1] 28.40 (7.97) | 3] 0.061
| | | 2] 29.73 (7.88) | | 2] 28.77 (8.24) | | 2] 27.23 (9.17)
| | NAI | 1] 46.25 (6.44) | | 1] 46.52 (6.36) | 3] 0.007 | 1] 6.40 (7.02) | 3] 0.003
| | | 2] 46.62 (7.16) | | 2] 45.19 (7.00) | | 2] 43.05 (9.12)
| | ZVT(1) | 1] 204.09 (119.73) | | 1] 198.72 (144.79) | 3] 0.141 | 1] 186.08 (124.78) | 3] 0.023
| | | 2] 217.05 (111.54) | | 2] 189.85 (110.92) | | 2] 173.14 (134.02)
| | ZVT(2) | 1] 208.50 (139.69) | | 1] 196.30 (142.64) | 3] 0.295 | 1] 196.53 (150.97) | 3] 0.071
| | | 2] 210.61 (129.57) | | 2] 189.29 (109.76) | | 2] 173.05 (119.22)

Evidence Table 168. Adverse Events: Cerebrolysin (CERE)

Adverse events (AE) identified in included studies | Bae, 2000 | Panisset, 2002 | Ruether, 1994 | Ruether, 2001 | Xiao, 1999 | Xiao, 2000
Withdrawn (%) due to AE | T: 0 | T: 1 | T: 0 | T: 1 | T: 0 | T: NR
| C: 0 | C: 0 | C: 0 | C: 1 | C: 0 | C: NR
AE Checklist (Max 5) | 5 | 4 | 5 | 4 | 3 | 2
None Reported | X | | X
Balance | | | | X
Accidental Injury | | NS
Dizziness | | NS | | | NS | NS
Falls
Behavioral
Agitation | | | | | NS
Cardiovascular | | NS | | | NS | NS
Arrhythmia | | | | X
Hypotension | | | | | NS | NS
Hypertension | | | | | NS | NS
Extrapyramidal
Tremor | | | | | | NS
Gastrointestinal | | NS | | | | NS
Abdominal pain
Constipation
Diarrhea
Dyspepsia
Nausea, vomiting | | NS | | X
Metabolic/nutritional
Eating disorder
Weight Change | | S
Neurological
Asthenia | | NS
Psychiatric
Anxiety | | S
Confusion, delirium
Depression | | | | | NS
Respiratory
Cough, cold, infection | | | | X
Rhinitis | | | | X
Other | | NS | | X | NS | NS
Aberrant hematology | | NS | | NS
Fatigue, weakness
Fever, flu, pneumonia | | | | X
Headache | | S | | X
Hepatic abnormality
Muscle/joint disorder
Pain | | NS
Rash, skin disorder | | | | | NS
Sleep disorder | | | | | NS | NS
Urinary disorder

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x= Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS*= Reported and tested for statistical differences between two (three) treatment groups

[ ]= Symptom NOT reported in the paper

Evidence Table 169. Key characteristics: Estrogens

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male
| | | | | | | | | Population
Asthana 2001 | PI | 5 | Placebo | NINCDS | AD | Probable | 20 | 20 | 80.0y (61–90y) | 0.10 mg/d | 8w | BMICT | No
| | | 17b-estradiol | | | Mild-Mod | | | 0%M | | | Boston Naming Test
| | | | | | | | | | | | BPRS
| | | | | | | | | | | | BSRT
| | | | | | | | | | | | CIBIC
| | | | | | | | | | | | DPRS
| | | | | | | | | | | | FCMT
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | OMDR
| | | | | | | | | | | | PSMS
| | | | | | | | | | | | SCWIT
| | | | | | | | | | | | Story Recall
| | | | | | | | | | | | Trail-Making Test
| | | | | | | | | | | | Treisman Visual Search
| | | | | | | | | | | | Visual Paired-Associates
Henderson 2000 | IF | 6 | Placebo | NINCDS | AD | Probable | 42 | 36 | 78.0y (NR) | 1.25 mg/d | 16w | ADAS-Cog | No
| | | Conjugated equine estrogens | | | Mild-Mod | | | 0%M | | | ADL
| | | | | | | | | | | | CGIC
| | | | | | | | | | | | CSGDS
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MADRS
| | | | | | | | | | | | Neuropsychological battery
Kyomen 1999 | PI | 8 | Placebo | DSM-III-R | Dementia | Mod-Sev | 15 | 14 | 83.8y (>60y) | 2.5 mg/d | 4w | ABSR | No
Auxiliary: | IS | | Conjugated Equine Estrogens | | | | | | 13%M | | | CSDD
Kyomen 2002 | | | | | | | | | 100% Institution | | | DSSS
| | | | | | | | | | | | Katz ADL scale
| | | | | | | | | | | | OAS (modified)
| | | | | | | | | | | | TSI
Mulnard 2000 | IF | 7 | Placebo | NINCDS | AD | Probable | 120 | 97 | 75.0y (56–91y) | 1.25mg/d | 1y | ADAS-Cog | No
| | | Estrogen | | | Mild-Mod | | | 0%M | | | ADCS-CGIC
| | | | | | | | | | | | ADL
| | | | | | | | | | | | ADL-BDRS
| | | | | | | | | | | | Blessed-D
| | | | | | | | | | | | CDRS
| | | | | | | | | | | | Dependency Scale
| | | | | | | | | | | | DST
| | | | | | | | | | | | EFR
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | HDRS
| | | | | | | | | | | | MAACLR
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NDT
| | | | | | | | | | | | Neuropsychological Battery
| | | | | | | | | | | | Trail-Making Test A
Wang 2000 | IS | 7 | Placebo | NINCDS | AD | Mild-Mod | 50 | 47 | 71.8y (NR) | 1.25mg/d | 12w | BEHAVE-AD | No
| PI | | Premarin | | | | | | 0%M | | | CASI (Chinese)
| | | | | | | | | | | | CDR
| | | | | | | | | | | | CIBIC+
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | HDRS
| | | | | | | | | | | | MMSE-CE
| | | | | | | | | | | | HARS

Evidence Table 170. Study results: Estradiol

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Asthana 2001 | OC Analysis
| 1] Placebo | [underlined: SCWIT] | | | | | 3] 110 (13)* | 5] 0.02
| 2] Estradiol (17-β) | | | | | | 4] 90 (10)*
| 3] Placebo change over baseline | [underlined: BSRT] | | | | | 3] 7.0 (0.8)* | 5] 0.049
| 4] Estrogen change over baseline | | | | | | 4] 8.2 (0.8)*
| 5] Placebo vs estrogen in change from baseline | FCMT | | | | | 3] 22 (2.5)* | 5] 0.03
| | | | | | | 4] 26 (4.0)*
| | CIBIC | | | | | | 5] 0.30
| | DPRS (mood) | | | | | | 5] NS
| | Functional Assessment (PSMS, IADL) | | | | | | 5] NS

* SEM

Evidence Table 171. Study results: Estrogen

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point] (specify) 4w | | Final] (specify) 16w
Henderson 2000 | OC Analysis
| 1] Placebo | [underlined: ADAS-Cog] | | | 3] 1.2 (1.5) | 5] >0.1 | 3] 0.5 (1.7) | 5] >0.1
| 2] Estrogen (unopposed conjugated equine, Premarin) | | | | 4] -0.2 (1.1) | | 4] 1.8 (1.2)
| 3] Placebo change from baseline | CGIC | | | 3] 3.8 (0.1) | 5] >0.1 | 3] 4.2 (0.1) | 5] >0.1
| 4] Estrogen change from baseline | | | | 4] 3.9 (0.1) | | 4] 4.2 (0.2)
| 5] Placebo vs Estrogen change from baseline | ADL/IADL | | | 3] -1.1 (1.1) | 5] >0.1 | 3] 2.9 (1.5) | 5] >0.1
| | | | | 4] 0.3 (0.8) | | 4] 2.9 (1.1)
| | CSGDS | | | 3] 1.2 (0.8) | 5] >0.1 | 3] -0.7 (1.2) | 5] >0.1
| | | | | 4] 0.1 (1.2) | | 4] -1.4 (1.4)
| | MADRS | | | 3] -2.0 (1.2) | 5] >0.1 | 3] 1.1 (1.4) | 5] >0.1
| | | | | 4] -2.6 (1.3) | | 4] 0.2 (1.6)

Evidence Table 172. Study results: Estrogen

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point] (specify) | | Final] (specify) 4w
Kyomen 1999 | OC Analysis
Kyomen, 2002 | 1] Placebo | ABSR | | | | | 3] 4.74 (4.07) | 5] 0.03
| 2] Estrogen (conjugated equine) | | | | | | 4] 2.05 (1.73)
| 3] Placebo change from baseline | CSDD | | | | | 3] -2.17 (4.00) | 5] 0.387
| 4] Estrogen change from baseline | | | | | | 4]- 3.75 (4.17)
| 5] Placebo vs Estrogen in change from baseline | KATZ ADL | | | | | 3] 0.71 (1.71) | 5] 0.677
| | | | | | | 4] 0.41 (1.56)
| | DSSS | 1] 31.7 (9.0) | | | | 1] 31.7 (9.0) | 3] <0.05
| | | 2] 31.6 (8.7) | | | | 2] 19.6 (6.5) | 4] <0.03
| | TSI | | | | | 3] 0.86 (3.24) | 5] 0.143
| | | | | | | 4] -0.71 (3.18)

Evidence Table 173. Study results: Estrogen

REF ID# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12m
| Mulnard 2000 | ITT Analysis
| | 1] Placebo | [underlined: ADCS-CGIC] | | | | | 3] 5.0 (1.1) | 9] 0.46
| | 2] Estrogen | | | | | | 4] 5.1 (0.9) | 10] 0.36
| | 3] Placebo change from baseline | | | | | | 5] 5.2 (0.9) | 11] 0.73
| | 4] Estrogen (0.625mg/d) change from baseline | | | | | | 6] 74% | 12] 0.73
| | 5] Estrogen (1.25mg/d) change from baseline | | | | | | 7] 80%
| | 6] Placebo (worsened %) | | | | | | 8] 80%
| | 7] Estrogen (0.625mg/d, worsened %) | MMSE | | | | | 3] -3.1(4.1) | 9] 0.48
| | 8] Estrogen (1.25mg/d, worsened %) | | | | | | 4] -2.7(3.5) | 10] 0.64
| | 9] Placebo vs estrogen 0.65mg/d change from baseline | | | | | | 5] -2.7(3.9)
| | 10] Placebo vs estrogen 1.25mg/d change from baseline | ADAS-Cog | | | | | 3] 3.6 (4.7) | 9] 0.09
| | 11] Placebo vs estrogen .065mg/d %worse | | | | | | 4] 6.3 (8.7) | 10] 0.32
| | 12] Difference between Place and estrogen 1.25mg/d %worse | | | | | | 5] 4.8 (5.4)
| | | CDRS | | | | | 3] 0.2 (0.4) | 9] 0.03
| | | | | | | | 4] 0.4 (0.7) | 10] 0.01
| | | | | | | | 5] 0.5 (0.6)
| | | ADL-BDRS part 1 | | | | | 3] 1.2 (1.5) | 9] 0.80
| | | | | | | | 4] 1.0 (1.2) | 10] 0.61
| | | | | | | | 5] 1.0 (1.2)
| | | ADL-BDRS part 2 | | | | | 3] 0.8 (1.6) | 9] 0.56
| | | | | | | | 4] 1.0 (1.4) | 10] 0.73
| | | | | | | | 5] 0.92 (1.4)
| | | ADL-Dependency Score | | | | | 3] 0.4 (1.1) | 9] 0.59
| | | | | | | | 4] 0.4 (0.8) | 10] 0.21
| | | | | | | | 5] 0.5 (1.0)
| | | Mood scores(HDRS) | | | | | 3] 0.03 (3.9) | 9] 0.69
| | | | | | | | 4] 0.5 (3.7) | 10] 0.69
| | | | | | | | 5] -1.1 (4.3)
| | | Memory scores (EFR) | | | | | 3] -5.7 (22.4) | 9] 0.08
| | | | | | | | 4]-11.1 (15.2) | 10] 0.41
| | | | | | | | 5] -8.2 (13.2)
| | | Memory scores (NDT) | | | | | 3] -0.9 (3.1) | 9] 0.57
| | | | | | | | 4] -0.9 (3.5) | 10] 0.19
| | | | | | | | 5] -2.1 (2.6)
| | | Attention scores (letter cancellation) | | | | | 3] -1.3 (5.5) | 9] 0.90
| | | | | | | | 4] -0.6 (8.7) | 10] 0.45
| | | | | | | | 5] -2.3 (6.0)
| | | Attention scores Trail-making test-A | | | | | 3] 18.6 (43.4) | 9] 0.89
| | | | | | | | 4] 19.0 (54.2) | 10] 0.98
| | | | | | | | 5] 18.8 (42.8)
| | | Attention scores DST | | | | | 3] -3.9 (6.8) | 9] 0.47
| | | | | | | | 4] -2.4 (6.8) | 10] 0.99
| | | | | | | | 5] -4.5 (8.5)
| | | Language scores (category fluency | | | | | 3] -2.9 (6.6) | 9] 0.06
| | | | | | | | 4] -6.3 (9.0) | 10] 0.13
| | | | | | | | 5] -5.0 (5.7)
| | | Language scores ( letter fluency) | | | | | 3] -1.7 (6.8) | 9] 0.32
| | | | | | | | 4] -3.1 (5.8) | 10] 0.71
| | | | | | | | 5] -2.1 (7.1)
| | | Motor scores (Grooved Pegboard Test | | | | | 3] -5.2 (42.4) | 9] 0.90
| | | | | | | | 4] -0.6 (2.7) | 10] 0.86
| | | | | | | | 5] -5.9 (5.5)
| | | Motor scores(Finger Tapping Test | | | | | 3] 4.0 (9.6) | 9] 0.04
| | | | | | | | 4] -1.3 (10.2) | 10] 0.25
| | | | | | | | 5] 1.7 (6.9)

Evidence Table 174. Study results: Estrogen

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point] (specify) 6w | | Final] (specify)12w
Wang 2000 | ITT Analysis
| 1] Placebo | [underlined: CASI-Total] | | | 3] -0.7 (8.2) | 5] NS | 3] 0.5 (8.2) | 5] NS
| 2] Estrogen (Conjugated, Premarin) | | | | 4] 0.4 (5.2) | | 4] 1.0 (8.0)
| 3] Placebo change from baseline | [underlined: CDR] | | | 3] 0.0 (0.4) | 5] NS | 3] 0.1 (0.4) | 5] NS
| 4] Estrogen change from baseline | | | | 4] 0.0 (0.3) | | 4] 0.0 ±0.4
| 5] Placebo vs Estrogen in change from baseline | [underlined: CIBIC+] | | | 3] -0.2 (0.8) | 5] NS | 3] -0.2 (0.8) | 5] NS
| | | | | 4] -0.2 (0.9) | | 4] -0.2 (1.0)
| | BEHAVE-AD | | | | | 3] -0.8 (5.0) | 5] NS
| | | | | | | 4] -0.4 (3.8)
| | HARS | | | | | 3] 0.4 (2.6) | 5] NS
| | | | | | | 4] -0.8 (4.7)
| | HDRS | | | | | 3] 0.4 (4.8) | 5] NS
| | | | | | | 4] -1.2 (5.8)

Evidence Table 175. Adverse Events: Estrogens

Advgerse events (AE) identified in included studies | Asthana, 2001 | Haenderson, 2000 | Kyomen, 1999 | Mulnard, 2000 | Wang, 2000
Withdrawn (%) due to AE | T: 0 | T: 5 | T: 0 | T: 14 | T: 4
| C: 0 | C: 5 | C: 0 | C: 5 | C: 0
AE Checklist (Max 5) | 1 | 3 | 5 | 3 | 2
None Reported | | | x
Balance
Accidental Injury
Dizziness
Falls | | | | NS
Behavioral
Agitation
Cardiovascular
Arrhythmia
Hypotension
Hypertension | | | | | NS
Extrapyramidal
Tremor
Gastrointestinal
Abdominal pain
Constipation
Diarrhea
Dyspepsia
Nausea, vomiting | | | | | NS
Metabolic/nutritional
Eating disorder
Weight Change
Neurological
Asthenia
Psychiatric | | | | NS
Anxiety
Confusion, delirium
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other | x | x | | NS | S
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia
Headache | | | | | NS
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder | x | | | | NS
Sleep disorder
Urinary disorder

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x= Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 176. Key characteristics: Gingko Biloba

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | #Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male
| | | | | | | | | Population
Kanowski 1996 | PI | 8 | Placebo | DSM-III-R | DAT | Mild-Mod | 216 | 156 | 69.6y (≥55y) | 240 mg/d | 24w | CGI | DAT vs MID
| | | Ginkgo | | MID | | | | 33%M | | | NAB
| | | Biloba (EGb 761) | | | | | | 100% Community | | | MADRS
| | | | | | | | | | | | SKT
Le Bars 1997 | IF | 8 | Placebo | DSM-III-R | AD | Mild-Modly | 327 | 137 | 69.0y (45–90y) | 40 mg tid | 52w | ADAS-Cog | AD vs MID+AD
Auxiliary: | | | Ginkgo | ICD-10 | MID | Sev | | | 46%M | | | CGIC | MMSE
Le Bars 2002 | | | Biloba | | | | | | | | | GERRI
Le Bars 2000
Pors 1998
Maurer 1997 | NR | 6 | Ginkgo | DSM-III-R | DAT | Mild-Mod | 20 | 18 | 64.6y (50–80y) | 240 mg/d | 3m | ADAS-Cog | No
| | | Biloba (Egb761) | NINCDS | PDD | | | | 50%M | | | ADAS-Noncog
| | | | | | | | | | | | CGI
| | | | | | | | | | | | EEG
| | | | | | | | | | | | SKT
| | | | | | | | | | | | Trail Making

Evidence Table 177. Study results: Ginkgo Biloba (EGb761)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Kanowski 1996 | ITT Analysis
| 1] Placebo | [underlined: SKT] | 1] 11.2 (3.4) | | | | 1] 10.4 (4.9) | 7] <0.05
| 2] Ginkgo Biloba (EGb761) 240 mg/d | | 2] 10.2 (3.0) | | | | 2] 8.0 (4.3)
| 3] Placebo probable MID | | 3] 12.2 (3.3) | | | | 3] 11.8 (3.9)
| 4] Ginkgo Biloba probable MID | | 4] 10.9 (3.7) | | | | 4] 9.4 (4.4)
| 5] Placebo probable DAT | | 5] 11.0 (3.4) | | | | 5] 10.1 (5.0)
| 6] Ginkgo Biloba probable DAT | | 6]10.2 (2.8) | | | | 6] 7.6 (4.2)
| 7] Placebo vs. Ginkgo Biloba change from baseline | [underlined: NAB] | 1] 21.1 (3.7) | | | | 1] 20.5 (3.6) | 7] <0.10
| | | 2] 21.0 (3.6) | | | | 2] 20.1 (3.6)
| | | 3] 23.3 (4.0) | | | | 3] 22.3 (3.9)
| | | 4] 21.2 (3.3) | | | | 4] 20.6 (3.3)
| | | 5] 20.7 (3.5) | | | | 5] 20.2 (3.5)
| | | 6] 21.0 (3.7) | | | | 6] 19.9 (3.7)
| | [underlined: CGI(numbers improved compared with baseline)] | 3] 4.8 (0.4) | | | | 1] 42/77 | 7] <0.05
| | | 4] 4.9 (1.0) | | | | 2] 57/79
| | | 5] 4.9 (0.4) | | | | 3] 3.8 (1.0)
| | | 6] 5.0 (0.4) | | | | 4] 3.7 (0.8)
| | | | | | | 5] 4.6 (1.0)
| | | | | | | 6] 4.0 (0.8)
| | MADRS | 1] 16.1 (7.2) | | | | 1] 13.6 (7.3) | 7] NS
| | | 2] 16.5 (6.8) | | | | 2] 13.2 (6.5)

Evidence Table 178. Study results: Ginkgo Biloba (EGb761)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 52w
Le Bars 1997 | ITT Analysis
Le Bars 2002 | 1] Placebo change from baseline AD & MID | [underlined: ADAS-Cog] | | | | | 1] 1.5 | 5] 0.04
Le Bars 2002 | 2] Ginkgo Biloba (EGb761) 40 mg tid change from baseline AD & MID | | | | | | CI (0.4 to2.5) | 6] 0.02
Por 1998 | 3] Placebo change from baseline AD only | | | | | | 2] 0.1
| 4] Ginkgo Biloba (EGb761) 40 mg tid change from baseline AD only | | | | | | CI (-1.8 to1.0)
| 5] Placebo vs Ginkgo Biloba in change from baseline AD & MID | | | | | | 3] 1.5
| 6] Placebo vs Ginkgo Biloba in change from baseline AD only | | | | | | CI (0.3 to 2.6)
| | | | | | | 4]-0.2
| | | | | | | CI (-1.2 to 0.8)
| | [underlined: GERRI] | | | | | 1] 0.08 | 5] 0.004
| | | | | | | CI (0.01 to 0.14) | 6] <0.001
| | | | | | | 2]-0.06
| | | | | | | CI(-0.13 to 0.01)
| | | | | | | 3] 0.09
| | | | | | | CI (0.02 to 0.17)
| | | | | | | 4] -0.09
| | | | | | | CI (-0.16 to -0.02)
| | [underlined: CGIC (Rating mean)] | | | | | 1] 4.2 | 5] 0.77
| | | | | | | CI (4.1–4.3) | 6] 0.21
| | | | | | | 2] 4.2
| | | | | | | CI (4.1–4.4)
| | | | | | | 3] 4.2
| | | | | | | CI (4.1 to 4.4)
| | | | | | | 4] 4.2
| | | | | | | CI (4.1 to 4.4)

Evidence Table 179. Study results: Ginkgo Biloba (EGb761, Tebonin forte)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3m
Maurer 1997 | SKT: ITT Analysis
| Others: OC Analysis
| 1] Placebo | [underlined: SKT] | 1] 18.11 (9.43) | | | | 1]18.89(9.13) | 3] <0.013
| 2] Ginkgo Biloba (EGb761, Tebonin forte) 240 mg/d | | 2] 19.67 (6.31) | | | | 2]16.78(6.87)
| 3] Difference between placebo and Ginkgo Biloba in change from baseline | ADAS-Cog | 1]36.10(15.23) | | | | 1]36.13(15.56) | 3] NS
| 4] Difference between placebo and Ginkgo Biloba in numbers improved | | 2]31.21(12.63) | | | | 2]30.33(14.77)
| | CGI (numbers improved compared with baseline) | | | | | 1] 1/9 | 4] 0.069
| | | | | | | 2] 5/9

Evidence Table 180. Adverse Events: Gingko Biloba

Adverse events (AE) identified in included studies | Kanowski, 1996 | Le Bars, 1997 | Maurer, 1997
Withdrawn (%) due to AE | T:0 | T:6 | T:0
| C:0 | C:6 | C:0
AE Checklist (Max 5) | 4 | 3 | 5
None Reported | | x | x
Balance
Accidental Injury
Dizziness
Falls
Behavioral
Agitation
Cardiovascular
Arrhythmia
Hypotension
Hypertension
Extrapyramidal
Tremor
Gastrointestinal | x
Abdominal pain
Constipation
Diarrhea
Dyspepsia
Nausea, vomiting
Metabolic/nutritional
Eating disorder
Weight Change
Neurological
Asthenia
Psychiatric
Anxiety
Confusion, delirium
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia
Headache | x
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder | S
Sleep disorder
Urinary disorder

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 181. Key characteristics: Idebenone

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Bergamasco 1994 | NR | 6 | Placebo | DSM III | DAT | Mild - Modly Sev Probable | 92 | 83 | 70.0y (55–80y) | 30 mg tid | 90d | BDRS | No
| | | Idebenone | NINCDS | | | | | 47%M | | | GBS
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | Rey's15 Word Test
| | | | | | | | | | | | Rey's A Figure Test
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Token Test
| | | | | | | | | | | | Word Fluency Test
Gutzmann 1998 | NR | 6 | Placebo | DSM-III-R | AD | Mild-Modly Sev | 450 | 379 | 69.9y (58–82y) | 120 mg tid | 12m | ADAS (Cog/NODCOS) | Disease severity
Auxiliary: Weyer 1996 | | | Idebenone | NINCDS | PDD | | | | 34%M | | | Adverse Events
| | | | | | | | | | | | Caregiver observation
| | | | | | | | | | | | CGI
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | ECG
| | | | | | | | | | | | IADL
| | | | | | | | | | | | NOSGER
| | | | | | | | | | | | SKT
Gutzmann 2002 | PI | 7 | Idebenone | NINCDS | AD | Mild-Mod | 203 | 44 | 71.2y (44–90y) | 360 mg/d | 60w | ADAS-Cog | No
| | | Tacrine | DSM-III-R | PDD | | | | 36%M | 160 mg/d | | ADAS-Noncog
| | | | | | | | | 100% White | | | ADAS-Total
| | | | | | | | | 100% Community | | | CGI
| | | | | | | | | | | | CT
| | | | | | | | | | | | EIS
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MRI
| | | | | | | | | | | | NOSGER-IADL
Marigliano 1992 | NR | 7 | Placebo | DSM-III-R | MID | Mild-Mod | 108 | 108 | 73.6y (65–80y) | 45 mg bid | 120d | ECG | No
| | | Idebenone | | | | | | 49%M | | | GBS
| | | | | | | | | 31% Institution | | | HIS
| | | | | | | | | 69% Community | | | HRSD
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Randt Memory Test
| | | | | | | | | | | | Token Test
| | | | | | | | | | | | TP
Weyer 1997 | NR | 5 | Placebo | DSM-III-R | PDD | Mild-Mod | 300 | 247 | 70.0y (54–90y) | 30 mg/d | 6m | ADAS- Total | Disease severity
| | | Idebenone | NINCDS | DAT | | | | 34%M | 90 mg/d | | ADAS-Cog
| | | | | | | | | | | | ADAS-Noncog
| | | | | | | | | | | | CGI
| | | | | | | | | | | | DSS
| | | | | | | | | | | | Greene's Assessment
| | | | | | | | | | | | HAMD
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NAA
| | | | | | | | | | | | NAB
| | | | | | | | | | | | Laboratory tests

Evidence Table 182. Study results: Idebenone

Author Year | Outcomes Measured | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 45d | | Final: (specify) 90d
Bergamasco 1994 | OC Analysis
| 1] Placebo | SCAG total score | 1] 60.00(2.02)* | | 1] 59.20(1.64)* | 4] <0.05 | 1] 57.62(1.70)* | 4] <0.05
| 2] Idebenone 30 mg tid | | 2] 57.10(1.99)* | | 2] 55.24(1.75)* | | 2] 53.00(2.18)* | 5] <0.05
| 3] Placebo difference from baseline | | | | | 4] <0.05 | | 4] <0.05
| 4] Idebenone difference from baseline | Rey's 15 Word Test | 1] 14.07(0.91)* | | 1] 14.95(0.87)* | | 1] 15.24(1.02)*
| 5] Idebenone vs Placebo change from baseline | | 2] 17.31(1.41)* | | 2] 20.14(1.64)* | | 2] 21.28(1.78)* | 5] NS
| | | | | | 4] <0.05
| | TK | 1] 22.84(0.82)* | | 2] 22.79(0.83)* | | 1] 23.22(0.81)* | 3] <0.05
| | | 2] 23.80(0.89)* | | 2] 24.48(0.92)* | | 2] 24.68(0.89)* | 4] <0.05
| | | | | | | | 5] <0.05
| | BDRS | 1] 17.07(1.01)* | | 1] 16.83(1.06)* | | 1] 16.03(1.18)*
| | | 2] 17.50(1.22)* | | 2] 18.12(1.23)* | | 2] 19.17(1.37)*

* SEM

Evidence Table 183. Study results: Idebenone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6m | | Final: (specify) 12m
Gutzman, 1998 | ITT Analysis
Weyer, 1996 | 1] Placebo 90mg | [underlined: ADAS Total] | | | 4] -5.6 (8.2) | 7] <0.0027 | 4] -4.9 (8.5) | 7] 0.0001
| 2] Idebenone 90 mg tid | | | | 5] -7.2 (7.4) | | 5] -7.1 (8.6)
| 3] Idebenone 120 mg tid | | | | 6] -8.4 (8.1) | | 6] -8.8 (9.5)
| 4] Placebo change from baseline | ADAS-Cog | 1] 34.3 ( 9.3) | | 4] -3.4 | 7] <0.001 | 4] -3.0 | 7] <0.0005
| 5] Idebenone 90 mg tid change from baseline | | 2] 35.3 ( 9.3) | | 5] -4.9 | | 5] -5.0
| 6] Idebenone 120 mg tid change from baseline | | 3] 32.7 ( 8.0) | | 6] -6.0 | | 6] -7.0
| 7] Dose trend | CGI | 1] 5.2 ( 0.4) | | | | 1] 63.3 | 7] 0.0000
| | | 2] 5.2 ( 0.5) | | | | 2] 73.4
| | | 3] 5.1 ( 0.4) | | | | 3] 87.3
| | NOSGER-IADL | 1] 16.0 ( 4.8) | | | | 1] 36.7 | 7] 0.0298
| | | 2] 16.0 ( 4.9) | | | | 2] 41.1
| | | 3] 15.3 ( 4.9) | | | | 3] 48.4

Evidence Table 184. Study results: Idebenone-Tacrine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 60 w
Gutzmann 2002 | ITT Analysis
| 1] Idebenone 360 mg d | [underlined: EIS%] | | | | | 1] 28.9% | 3] <0.0001 favours Idebenone
| 2] Tacrine 160 mg d variable | | | | | | 2] 9.0%
| 3] Difference between Idebenone and Tacrine | Rating = -1 | | | | | 1] 54.8%
| | | | | | | 2] 83.8%
| | Rating = 0 | | | | | 1] 16.3%
| | | | | | | 2] 7.1%
| | Rating = 1 | | | | | 1] 13.5%
| | | | | | | 2] 3.0%
| | Rating = 2 | | | | | 1] 8.7%
| | | | | | | 2] 4.0%
| | Rating = 3 | | | | | 1] 6.7%
| | | | | | | 2] 2.0%
| | ADAS-Total | 1] 41.55(16.46) | | | | 1] 34.51(17.43)
| | | 2] 41.52(14.92) | | | | 2] 30.44(16.32)
| | ADAS-Cog | 1] 30.23(11.59) | | | | 1] 26.40(16.67)
| | | 2] 30.93(10.59) | | | | 2] 24.81(14.92) | 3] NS
| | ADAS-Noncog | 1] 11.32 (6.79) | | | | 1] 8.11(7.56)
| | | 2] 10.55(5.86) | | | | 2] 5.63(6.10)
| | CGI-S | 1] 5.22 (0.46) | | | | 1] 4.43 (1.58)
| | | 2] 5.19 (0.44) | | | | 2] 4.53 (1.45) | 3] NS
| | NOSGER- IADL | 1] 13.88(4.43) | | | | 1] 13.13 (5.49)
| | | 2] 13.78(4.55) | | | | 2] 12.5 (6.25) | 3] NS

Evidence Table 185. Study results: Idebenone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 60d | | Final: (specify) 150d
Marigliano 1992 | OC Analysis
| 1] Placebo | RMT- Delayed Recall | 1] 62 | | 1] 59 | 4] <0.04 | 1] 55 | 5] <0.02
| 2] Idebenone 45 mg bid | | 2] 60 | | 2] 64 | | 2] 61
| 3] Placebo change from baseline | RMT- Figure Recognition | 1] 7 | | 1] 6 | 5] <0.05 | 1] 5.5
| 4] Idebenone 45 mg bid change from baseline | | 2] 6.5 | | 2] 6.4 | | 2] 6.5
| 5] Idebenone 45 mg bid vs. placebo | RMT Paired Word- Acquisition | 1] 6 | | 1] 6 | | 1] 2.5 | 5] <0.02
| | | 2] 5.5 | | 2] 5 | | 2] 6
| | GBS Intellectual Functions | 1] 16.5 | | 1] 16 | | 1] 13 | 5] <0.02
| | | 2] 16.5 | | 2] 15 | | 2] 11
| | GBS Motor functions | 1] 7 | | 1] 7 | | 1] 4.5 | 5] <0.05
| | | 2] 7 | | 2] 6 | | 2] 5

Evidence Table 186. Study results: Idebenone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 3m | | Final: (specify) 6m
Weyer, 1997 | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-Total] | | | 1] -1.6 | | 1] -5.7 | 7] 0.037
| 2] Idebenone 30 mg tid change from baseline | | | | 2] -5 | | 2] -5.6 | 8] 0.009
| 3] Idebenone 90 mg tid change from baseline | | | | 3] -6.9 | | 3] -8.0
| 4] Placebo ADAS-Total >20 change from baseline | | | | 4] -6.1 | | 4] -7.0
| 5] Idebenone30 ADAS-Total >20 change from baseline | | | | 5] -6.5 | | 5] -7.6
| 6] Idebenone 90 ADAS-Total >20 change from baseline | | | | 6] -9.5 | | 6] -11.1
| 7] Treatment effect 0 to 6m | ADAS-Cog | | | 1] -3.6 | | 1] -4.5 | 7] 0.031
| 8] Treatment effect 0 to 6m sub-group ADAS-Cog >20 | | | | 2] -3.8 | | 2] -4.4 | 8] 0.006
| | | | | 3] -5.5 | | 3] -6.5
| | | | | 4] -4.8 | | 4] -5.8
| | | | | 5] -5.0 | | 5] -5.9
| | | | | 6] -7.3 | | 6] -8.9
| | ADAS-Noncog | | | 1] -0.9 | | 1] -1.2 | 7] 0.035
| | | | | 2] -1.3 | | 2] -1.9 | 8] 0.014
| | | | | 3] -1.3 | | 3] -2.0
| | | | | 4] -1.5 | | 4] -1.8
| | | | | 5] -1.6 | | 5] -2.2
| | | | | 6] -2.3 | | 6] -3.2
| | CGI % improved | | | | | 1] 67.5 | 7] 0.018
| | | | | | | 2] 72.2 | 8] 0.000
| | | | | | | 3] 81.6
| | | | | | | 4] 47.9
| | | | | | | 5] 66.7
| | | | | | | 6] 88.5

Evidence Table 187. Adverse Events: Idebenone

Adverse events (AE) identified in included studies | Bergamasco, 1994 | Gutzmann, 1998 | Marigliano, 1992 | Weyer, 1997 | IDEBENONE(C) TACRINE (T) Gutzmann, 2002
Withdrawn (%) due to AE | T:4 | T: NR | T: 0 | T: 5 | T: 41
| C: 2 | C: NR | C: 0 | C: 5 | C: 17
AE Checklist (Max 5) | 4 | 1 | 5 | 3 | 3
None Reported
Balance | | | x
Accidental Injury
Dizziness | | x | | NS*
Falls | | | x
Behavioral | x
Agitation
Cardiovascular | | | | x
Arrhythmia | | | x
Hypotension | | NS*
Hypertension
Extrapyramidal
Tremor
Gastrointestinal | | | x | | S*
Abdominal pain | x
Constipation
Diarrhea
Dyspepsia | | | | x
Nausea, vomiting | x | | | x | S*
Metabolic/nutritional
Eating disorder
Weight Change
Neurological | | NS*
Asthenia
Psychiatric
Anxiety | x
Confusion, delirium | | | x
Depression
Respiratory | | x | | NS*
Cough, cold, infection
Rhinitis
Other | | | x
Aberrant hematology | | NS*
Fatigue, weakness
Fever, flu, pneumonia | | x
Headache | | | | x
Hepatic abnormality | | | | NS* | S*
Muscle/joint disorder
Pain | | x
Rash, skin disorder | | | x
Sleep disorder | x
Urinary disorder

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 188. Key characteristics: Oxiracetam

Author Year | Fundling Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Bottini 1992 | PI | 6 | Placebo | DSM III | PDD | NR | 65 | 58 | 71.0y (54–82y) | 800 mg bid | 12w | DSPT | No
| | | Oxiracetam | NINCDS | MID | | | | 43%M | | | QoL
| | | | | Mixed | | | | | | | RPM
| | | | | | | | | | | | RT
| | | | | | | | | | | | TK
| | | | | | | | | | | | WLM
| | | | | | | | | | | | Verbal Fluency
| | | | | | | | | | | | Short Story
Maina 1989 | NR | 6 | Placebo | DSM III | PDD | NR | 289 | 272 | 73.0y (<85y) | 800 mg bid | 12w | BDS | PDD vs MID
| | | Oxiracetam | | MID | | | | 50%M | | | Global Evaluation of efficacy
| | | | | MIXED | | | | | | | IPSE-E
| | | | | | | | | | | | NMICS
| | | | | | | | | | | | IPAX-E
| | | | | | | | | | | | AE
Mangoni 1988 | PI | 6 | Placebo | NINCDS | AD | Probable-Possible | 30 | 30 | 62.0y (52–79y) | 800 mg bid | 24w | IPSC-E | No
| | | Oxiracetam | | | Mild-Mod | | | 67%M | | | LNNB
| | | | | | | | | | | | Sensory motor left scale
| | | | | | | | | | | | Frontal right scale
Rozzini 1992 | NR | 4 | Placebo | DSM-III-R | PDD | Mild-Mod | 110 | 94 | 73.8y (>65y) | 800 mg bid | 26w | AMI | No
Auxiliary: Rozzini 1993 | | | Oxiracetam | | | | | | 34%M | | | BI
| | | | | | | | | | | | BDI
| | | | | | | | | | | | BMDI
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | RT
Villardita 1992 | PI | 6 | Placebo | NINCDS | AD | Mild-Mod | 60 | 60 | 69.8y (52–83y) | 800 mg bid | 90d | ACPT | No
| | | Oxiracetam | DSM III | MID | | | | 60%M | | | BTT
| | | | | | | | | | | | DS
| | | | | | | | | | | | IADL-E
| | | | | | | | | | | | IPSC-E
| | | | | | | | | | | | LAS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | MWF
| | | | | | | | | | | | Rosy's WT

Evidence Table 189. Study results: Oxiracetem

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6w | | Final: (specify) 12w
Bottini 1992 | Completer Analysis
| 1] Placebo | Reaction Time milli second | 1] 783 (634) | | | | 1] 697 (350) | 5] NS
| 2] Oxiracetem 800 mg bid | | 2] 1018 (873) | | | | 2] 996 (1101)
| 3] Placebo vs baseline | Verbal Fluency phonemic | 1] 12.6 (8.21) | | | | 1] 9.8 (7.74) | 5] 0.009
| 4] Oxiracetem vs baseline | | 2] 13.3(12.37) | | | | 2] 14.2 (10.2)
| 5] Oxiracetem vs Placebo | Verbal Fluency semantic | 1] 13.8 (13.0) | | | | 1] 13.0 (7.02) | 5] <0.02
| | | 2] 12.9 (7.31) | | | | 2] 14.7 (7.31)
| | Short Story | 1] 7.8 (12.54) | | | | 1] 6.1 (5.942) | 5] 0.02
| | | 2] 5.2 (6.24) | | | | 2] 9.7 (11.67)
| | RPM | 1] 13.9 (7.34) | | | | 1] 12.7 (6.08) | 5] 0.007
| | | 2] 13.1 (6.15) | | | | 2] 14.5 (6.5)
| | DSPT | 1] 4.3 (0.94) | | | | 1] 4.5 (1.03) | 3] <0.01
| | | 2] 4.2 (0.95) | | | | 2] 4.7 (1.16) | 4] <0.01
| | | | | | | | 5] NS
| | WLM | 1] 4.0 (3.71) | | | | 1] 4.7 (3.97) | 3] <0.01
| | | 2] 3.6 (2.98) | | | | 2] 5.1 (3.73 | 4] <0.01
| | | | | | | | 5] <0.05
| | TK | 1] 22.6 (5.83) | | | | 1] 23.8 (6.16) | 5] NS
| | | 2] 23.3 (6.11) | | | | 2] 23.1 (7.17)
| | Italian QoL | 1] 2.7 (0.55) | | 1] 2.7 (0.54) | | 1] 2.5 (0.62) | 5] <0.001
| | | 2] 2.8 (0.56) | | 2] 3.1 (0.53) | | 2] 3.2 (0.50)

Evidence Table 190. Study results: Oxiracetem

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Maina, 1989 | Per Protocol Analysis
| 1] Placebo | BDS | 1] 10.5 (4.20) | | | | 1] 10.3 (4.54) | 3] <0.01
| 2] Oxiracetem 800 mg bid | | 2] 10.7 (4.25) | | | | 2] 9.0 (4.17)
| 3] Difference between treatments in favor of Oxiracetem | NMICS | 1] 17.3 (7.06) | | | | 1] 17.7 (20.9) | 3] <0.01
| 4] Time by treatment interaction | | 2] 18.4 (7.34) | | | | 2] 20.9 (6.93) | 4] <0.01
| | IPSE-E | 1] 1.9 (0.35) | 3] NS | | | 1] 1.8 (est) | 3] <0.01
| | | 2] 2.0 (0.34) | | | | 2] 1.51 (est)
| | Global evaluation of efficacy | | | | | Good or very good | 3] <0.01
| | | | | | | 1] 21%
| | | | | | | 2] 64%

Evidence Table 191. Study results: Oxiracetem

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 12w | | Final: (specify) 24w
Mangoni 1998 | Completer Analysis
| 1] Placebo | IPSC-E | 1] 2.1 ( 0.75) | 3] NS | 1] 1.94 (est) | | 1] 2.1 (est) | 3] <0.01
| 2] Oxiracetem 800 bid | | 2] 2.3 ( 0.68) | | 2] 1.67 (est) | | 2] 1.75 (est) | 4] <0.001
| 3] Between treatment in favor of Oxiracetem | LNNB | | | | | 3] 7/14 tests | 3] <0.01
| 4] Time by treatment interaction | | | | | | 4] 7/14 tests | 4] <0.01
| | Sensory-motor left scale | | | | | | 4] <0.01
| | Frontal right scale | | | | | | 4] <0.01

Evidence Table 192. Study results: Oxiracetem

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 2m | | Final: (specify) 6m
Rozzini, 1992 | OC Analysis
Rozzini 1993 | 1] Placebo | BI | 1] 94.89 (9.79) | | 1] 94.67(10.02) | | 1] 94.46(10.28) | 4] NS
| 2] Oxiracetem 800 mg bid | | 2] 94.38(10.69) | | 2] 94.17(10.77) | | 2] 93.96(11.32)
| 3] Oxiracetem vs baseline | IADL | 1] 1.52 (1.64) | | 1] 1.57(1.70) | | 1] 1.63 (1.85) | 3] NS
| 4] Placebo vs. Oxiracetam change from baseline | | 2] 1.48 (1.62) | | 2] 1.50 (1.72) | | 2] 1.56 (1.73) | 4] NS
| | MMSE | 1] 21.98 (2.77) | | 1] 22.22(3.01) | 3] <0.05 | 1] 22.04(3.28)
| | | 2] 22.08 (2.78) | | 2] 23.35(3.18) | | 2] 22.71 (3.58
| | RT score | 1] 1.84 (1.95) | | 1] 8.84 (1.79) | 3] <0.05 | 1] 8.85(2.04) | 3] <0.02
| | | 2] 8.67 (2.05) | | 2] 7.64 (2.47) | | 2] 7.54(2.44)
| | BDI | 1] 20.43(14.49) | | 1] 21.04(15.92) | | 1] 22.25(16.82)
| | | 2] 23.79(17.96) | | 2] 20.75(16.21) | | 2] 23.58(16.4)
| | Test of Attention Matrix | 1] 18.83 (8.72) | | 1] 19.39 (7.21) | 3] NS | 1]18.85 (6.92) | 3] NS
| | | 2] 18.46 (9.14) | | 2] 19.27 (8.96) | | 2] 20.31 (8.92)

Evidence Table 193. Study results: Oxiracetem

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 90d
Villardita 1992 | OC Analysis
| 1] Placebo | MMSE | 1] 16.7 (0.8)* | | | | 1] 15.6 (0.8)* | 3] NS
| 2] Oxiracetem 800 mg bid | | 2] 15.5 (0.9)* | | | | 2] 21.6 (1.0)* | 4] <0.01
| 3] Placebo vs baseline | | | | | | | 5] <0.01
| 4] Oxiracetem vs baseline | ACPT | 1] 18.5 (0.8)* | | | | 1] 17.3 (1.0)* | 3] NS
| 5] Oxiracetem vs Placebo | | 2] 17.2 (0.9)* | | | | 2] 21.6 (1.0)* | 4] <0.05
| | | | | | | | 5] <0.05
| | R15WT immediate | 1] 18.8 (1.1)* | | | | 1] 18.4 (1.1)* | 3] NS
| | | 2] 18.5 (1.1)* | | | | 2] 20.6 (1.1)* | 4] <0.05
| | | | | | | | 5] <0.05
| | R15WT delayed | 1] 2.4 (0.3)* | | | | 1] 2.5 (0.2)* | 3] NS
| | | 2] 2.3 (0.3)* | | | | 2] 2.8(0.2)* | 4] <0.05
| | | | | | | | 5] NS
| | DS forward | 1] 4.5 (0.3)* | | | | 1] 4.1 (0.2)* | 5] NS
| | | 2] 4.5 (0.2)* | | | | 2] 4.5 (0.2)*
| | DS backward | 1] 3.1 (0.2)* | | | | 1] 3.1 (0.2)* | 5] NS
| | | 2] 3.0 (0.2)* | | | | 2] 2.9 (0.2)*
| | IPSC-E total | 1] 152.7 (4.1)* | | | | 1] 155.9 (4.2)* | 5] NS
| | | 2] 149.9(4.4)* | | | | 2] 157.6 (5.2)*
| | IADL-E total | 1] 20.9(1.2)* | | | | 1] 19.6 (1.0)* | 3] <0.05
| | | | | | | 2] 26.0 (1.0)* | 4] <0.01
| | | | | | | | 5] <0.01

* SEM

Evidence Table 194. Adverse Events: Oxiracetam

Adverse events (AE) identified in included studies | Bottini, 1992 | Maina, 1989 | Mangoni, 1988 | Rozzini, 1992 | Villardita, 1992
Withdrawn (%) due to AE | T: 6 | T: 2 | T: 0 | T: 4 | T: 0
| C: 0 | C: 2 | C: 0 | C: 9 | C: 0
AE Checklist (Max 5) | 4 | 5 | 5 | 2 | 5
None Reported | | | x
Balance
Accidental Injury
Dizziness | x
Falls
Behavioral
Agitation | | x
Cardiovascular
Arrhythmia
Hypotension
Hypertension
Extrapyramidal | x
Tremor
Gastrointestinal | | | | x
Abdominal pain | x | x | | x
Constipation | | x
Diarrhea
Dyspepsia | | | | x
Nausea, vomiting
Metabolic/nutritional
Eating disorder | x
Weight Change
Neurological
Asthenia
Psychiatric
Anxiety | | | | x | x
Confusion, delirium | | x
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other | x
Aberrant hematology | | NS
Fatigue, weakness
Fever, flu, pneumonia
Headache
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder | x
Sleep disorder | x | | | | x
Urinary disorder | x

NR = Withdrawals due to AE Not Reported

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 195. Key characteristics. Pentoxifylline

Author Year | Fundling Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total Number Randomized | Number Completing Trial | Mean Age (range) | Dose | Treatment Period | Outcomes Measured | Outcomes reports stratified
| | | | | | | | | % Mean (M)
| | | | | | | | | Population
Knezevic 1996 | IF | 6 | Placebo | DSM-III-R | MID | Mild-Mod | 289 | 239 | 69.7y (45–90y) | 1200 mg/d | 9m | GBS | No
| | | Pentoxifylline | | | | | | 56%M | | | MMSE
| | | | | | | | | | | | Neuropsychological
| | | | | | | | | | | | SCAG
Black 1992 | PI | 6 | Placebo | DSM III | MID | Nild-Mod | 64 | 38 | 75.4y (55–98y) | 400 mg tid | 36w | ADAS-Cog | Vascular change vs Discrete strokes
| | | Pentoxifylline | | | | | | 52%M | | | ADAS-Noncog
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MMSE
Ghose 1987 | IF | 6 | Placebo | DSM III | PDD | Mild-Mod | 36 | 28 | 77.0y (60–88y) | 400 mg tid | 12w | Digit Span Test | MID vs PDD
| | | Pentoxifylline | | MID | | | | 50%M | | | DSPT
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | RT
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Shopping list
DRUG VS DRUG
Parnetti 1997 | NR | 5 | Sulodexide | NINDS-AIREN | VaD | Probable | 93 | 86 | 75.0y (65–80y) | 100 mg/d | 6m | GBS | No
| | | Pentoxifylline | | | Mild-Mod | | | 40%M | 1200 mg/d | | Laboratory tests
| | | | | | | | | | | | MMSE

Evidence Table 196. Study results: Pentoxifylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 9m
Knezevic, 1996 | ITT/LOCF Analysis
| 1] Placebo | [underlined: GBS total] | 1] 37.2 (17.2) | | | | 3] 0.0 (13.9) | 5] 0.065
| 2] Pentoxifylline 1200 mg/day | | 2] 37.9 (17.5) | | | | 4] -2.1 (14.7)
| 3] Placebo change from baseline | GBS Intellectual | | | | | 3] 0.0 (7.0) | 5] 0.060
| 4] Pentoxifylline change from baseline | | | | | | 4] –0.9 (7.6)
| 5] Placebo vs Pentoxifylline change from baseline | GBS Motor | | | | | 3] 0.2 (5.0) | 5] 0.275
| | | | | | | 4] 0.0 (9.5)
| | GBS emotional | | | | | 3] 0.3 (2.3) | 5] 0.072
| | | | | | | 4] –0.3 (2.8)
| | MMSE | | | | | | 5] NS
| | SCAG Total | 1] 43.9 (11.8) | | | | 3] –1.9 (9.0) | 5] 0.034
| | | 2] 44.8 (11.7) | | | | 4] –3.1 (10.4)
| | SCAG cognitive | | | | | 3] –0.4 (3.5) | 5] 0.007
| | | | | | | 4] –1.3 (3.6)

Evidence Table 197. Study results: Pentoxifylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 36w
Black 1992 | Efficacy Analysis
| 1] Placebo | [underlined: ADAS-total] | 1] 30.08 | | | | 1] 37.03 | 3] 0.058
| 2] Pentoxifylline 1200 mg/d | | 2] 26.5 | | | | 2] 28.19 | 6] 0.023
| 3] Pentoxifylline Placebo change from baseline | | 4] 29.17 | | | | 4] 34.98 | 9] 0.002
| 4] Placebo Subgroup with vascular damage | | 5] 22.94 | | | | 5] 20.85
| 5] Pentoxifylline subgroup with vascular damage | | 7] 30.77 | | | | 7] 41.99
| 6] Placebo vs Pentoxfylline change from baseline subgroup with vascular damage | | 8] 26.72 | | | | 8] 25.36
| 7] Placebo subgroup with discrete strokes | ADAS-Cog | 1] 25.39 | | | | 1] 30.41 | 3] 0.064
| 8] Pentoxifylline subgroup with discrete strokes | | 2] 21.69 | | | | 2] 23.10 | 6] 0.020
| 9] Placebo vs Pentoxifylline change from baseline subgroup with discrete strokes | | 4] 24.81 | | | | 4] 28.83 | 9] 0.005
| | | 5] 18.34 | | | | 5] 17.11
| | | 7] 25.72 | | | | 7] 33.24
| | | 8] 21.72 | | | | 8] 21.14
| | ADAS-Noncog | 1] 4.69 | | | | 1] 6.63 | 3] 0.23
| | | 2] 4.81 | | | | 2] 5.09 | 6] 0.12
| | | 4] 4.36 | | | | 4] 6.16 | 9] 0.017
| | | 5] 4.60 | | | | 5] 3.73
| | | 7] 5.05 | | | | 7] 8.73
| | | 8] 5.00 | | | | 8] 4.22
| | ADAS without cognitive memory | 1] 7.78 | | | | 1] 10.16 | 3] 0.036
| | | 2] 6.63 | | | | 2] 6.72 | 6] 0.005
| | | 4] 7.20 | | | | 4] 8.96 | 9] 0.001
| | | 5] 5.07 | | | | 5] 3.47
| | | 7] 7.78 | | | | 7] 12.84
| | | 8] 6.00 | | | | 8] 5.28

Evidence Table 198. Study results: Oxpentifylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Ghose, 1987 | Per protocol analysis
| 1] Placebo PDD | [underlined: MMSE] | 1] 19.4 | | | | 1] 20.4 | 7] <0.05
| 2] Placebo MID | | 2] 19.6 | | | | 2] 21.3 | 8] NS
| 3] Oxpentifylline 400 mg tid PDD | | 3] 16.6 | | | | 3] 18.3
| 4] Oxpentifylline 400 mg tid MID | | 4] 16.5 | | | | 4] 20.3
| 5] Placebo all | | 5] 19.9 | | | | 5] 21.3
| 6] Oxpentifylline all | | 6] 16.6 | | | | 6] 19.5
| 7] Oxpentifylline vs Placebo MID | [underlined: SCAG] | 1] 42.1 (14.3) | | | | 1] 37.3 (14.0) | 7] NS
| 8] Oxpentifylline vs Placebo PDD | | 2] 44.1 (16.3) | | | | 2] 39.9 (14.8) | 8] NS
| | | 3] 53.5 (15.6) | | | | 3] 44.3 (13.0)
| | | 4] 43.0 (16.7) | | | | 4] 41.0 (10.4)
| | | 5] 42.1 (14.3) | | | | 5] 37.4 (14.4)
| | | 6] 50 (16) | | | | 6] 43.51 (12.9)
| | DSST | 5] 5.5 (1.4) | | | | 5] 6.2 (1.4) | 7] NS
| | | 6] 5.4 (1.3) | | | | 6] 5.7 (1.2) | 8] NS

Evidence Table 199. Study results: Sulodexide - Pentoxifylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 4m | | Final: (specify) 6m
Parnetti, 1997 | OC Analysis
| 1] Sulodexide 50 mg bid | [underlined: GBS motor impairment] | 1] 1.64 (0.14)* | | 1] 1.58 (0.14)* | 3] <0.01 | 1] 1.54 (0.16)* | 3] <0.01
| 2] Pentoxifylline 400 mg tid | | 2] 1.59 (0.13)* | | 2] 1.53 (0.14)* | | 2] 1.46 (0.17)*
| 3] sulodexide change vs baseline | [underlined: GBS intellectual impairment] | 1] 2.09 (0.09)* | | 1] 1.88 (0.09)* | 3] <0.01 | 1] 1.79 (0.1)* | 3] <0.01
| | | 2] 1.98 (0.08)* | | 2] 1.95 (0.1)* | | 2] 1.87 (0.12)*
| | [underlined: GBS emotional impairmen] | 1] 2.1 (0.12)* | | 1] 1.88 (0.12)* | 3] <0.12 | 1] 1.76 (0.12)* | 3] <0.01
| | | 2] 1.89 (0.1)* | | 2] 1.9 (0.1)* | | 2] 1.75 (0.11)*
| | MMSE | 1] 17.6 (0.4)* | | | | 1] 20 (0.6)*
| | | 2] 18 (0.4)* | | | | 2] 20 (0.4)*

*SEM

Evidence Table 200. Adverse Events. Pentoxifylline

Adverse events (AE) identified in included studies | Black, 1992 | Ghose, 1987 | Knezivic, 1996 | PENTOXIFYLLINE SULODEXIDE Parnetti, 1997
Withdrawn (%) due to AE | T: 22 | T: 12 | T: 0 | T: 7
| C: 25 | C: 6 | C: 0 | C: 6
AE Checklist (Max 5) | 1 | 2 | 3 | 2
None Reported | | | X
Balance
Accidental Injury
Dizziness
Falls
Behavioral
Agitation
Cardiovascular | X | | | X
Arrhythmia
Hypotension
Hypertension
Extrapyramidal
Tremor
Gastrointestinal | X | X
Abdominal pain | | | | X
Constipation
Diarrhea
Dyspepsia
Nausea, vomiting | X | X
Metabolic/nutritional
Eating disorder
Weight Change
Neurological | X
Asthenia | | | | X
Psychiatric
Anxiety
Confusion, delirium
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia
Headache | | | | X
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder
Sleep disorder
Urinary disorder

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 201. Key characteristics: Propentofylline

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male
| | | | | | | | | Population
Marcusson 1997 | NR | 5 | Placebo | DSM-III-R | AD | Mild-Mod | 260 | 187 | 72.4y (NR) | 300 mg tid | 12m | ADAS-Cog | AD vs VaD
| | | Propentofylline | | VaD | | | | %M NR | | | BfS
| | | | | | | | | | | | CGI
| | | | | | | | | | | | DSST
| | | | | | | | | | | | ECG
| | | | | | | | | | | | GBS
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NAA
| | | | | | | | | | | | NAB
| | | | | | | | | | | | SKT
| | | | | | | | | | | | Syndrome Short Test
| | | | | | | | | | | | Zerssen Adjective Mood Scale
Mielke 1996 | IS | 5 | Placebo | DSM-III-R | VaD | Mild-Mod | 30 | 25 | 68.7y (55–79y) | 300 mg tid | 3m | DSST | No
| | | Propentofylline | | | | | | 58%M | | | Fragmented Picture Task
| | | | | | | | | | | | Memory Tasks
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PET
| | | | | | | | | | | | Physiological tests
Mielke 1998 | NR | 5 | Placebo | NINCDS | AD | Probable | 30 | 28 | 64.8y (52–78y) | 300 mg tid | 3m | DSST | No
| | | Propentofylline | DSM-III-R | | Mild-Mod | | | 57%M | | | FAST
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PET
| | | | | | | | | | | | BSRT
| | | | | | | | | | | | SRT-DR
| | | | | | | | | | | | Verbal Fluency
Saletu 1990 | NR | 6 | Placebo | DSM-III-R | Dementia | Mild | 190 | 165 | 68.5y (NR) | 300 mg tid | 12w | Alphabetical Cross-out test | MMSE
Auxiliary: | | | HWA 285 (Propentofylline) | | | | | | 49%M | | | Benton Test
Moller 1994 | | | | | | | | | | | | CGI-CGC
| | | | | | | | | | | | CGI-S
| | | | | | | | | | | | Cognitive Difficulties Scale
| | | | | | | | | | | | CT
| | | | | | | | | | | | DST
| | | | | | | | | | | | EEG
| | | | | | | | | | | | Folstein Mini-Mental State
| | | | | | | | | | | | GBS
| | | | | | | | | | | | Gruenberger Verbal
| | | | | | | | | | | | Memory Test
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | MRI
| | | | | | | | | | | | Pictures of Objects Task and Learning
| | | | | | | | | | | | Trail Making Test

Evidence Table 202. Study results: Propentofylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6m | | Final: (specify) 12m
Marcusson 1997 | ITT Analysis
| 1] Placebo change from baseline | [underlined: GBS] | | | 1] 1.5 (12.5) | 3] 0.003 | 1] 4.5 (15.5) | 3] 0.001
| 2] Propentofylline 300 mg tid change from baseline | | | | 2] -2.2 (11.1) | | 2] -0.4 (14.2)
| 3] Change from baseline in treatment vs placebo | [underlined: CGI item II] | | | 1] -0.4 (2.3) | 3] 0.028 | 1] -0.3 (4.0) | 3] 0.072
| | | | | 2] -1.0 (2.7) | | 2] -1.2 (5.1)
| | [underlined: SKT] | | | 1] -0.4 (3.9) | 3] 0.001 | 1] -0.1 (3.8) | 3] 0.002
| | | | | 2] -1.9 (3.4) | | 2] -1.5 (3.9)
| | CGI item I | | | 1] 0.03 (0.6) | 3] 0.014 | 1] 0.09 (0.7) | 3] 0.004
| | | | | 2] -0.14 (0.6) | | 2] -0.12 (0.8)
| | MMSE | | | 1] 0.4 (3.5) | 3] 0.072 | 1] -0.6 (4.2) | 3] 0.001
| | | | | 2] 0.9 (3.1) | | 2] 0.6 (3.9)
| | DSST | | | 1] -0.5 (6.0) | 3] 0.222 | 1] -0.9 (6.5) | 3] 0.062
| | | | | 2] 0.6 (6.9) | | 2] 1.1 (8.2)
| | NAB | | | 1] 1.1 (3.4) | 3] 0.021 | 1] 6.8 (3.7) | 3] 0.007
| | | | | 2] 0.1 (3.4) | | 2] 0.6 (3.8)
| | NAA | | | 1] -0.3 (4.7) | 3] 0.395 | 1] 0.9 (4.9) | 3] 0.698
| | | | | 2] -0.0(4.3) | | 2] -0.2 (5.1)
| | BfS | | | 1] 0.1 (10.6) | 3] 0.588 | 1] -0.1 (10.1) | 3] 0.893
| | | | | 2] -1.5 (9.4) | | 2] -1.2 (9.9)

Evidence Table 203. Study results: Propentofylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Mielke, 1996 | OC Analysis
| 1] Placebo change from baseline | MMSE | | 3] NS | | | 1] 21.9 (3.1) | 3] <0.1
| 2] Propentofylline 300 mg tid change from baseline | | | | | | 2] 21.4 (3.2)
| 3] Propentofylline 300 mg tid vs Placebo | DSST | | 3] NS | | | 1] 19.6 ( 8.1) | 3] <0.1
| | | | | | | 2] 15.6 ( 7.5)

Evidence Table 204. Study results: Propentofylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3m
Mielke, 1998 | OC Analysis
| 1] Placebo change from baseline | MMSE | 1] 21.3 (3.4) | | | | 1] -1.0 (1.6) | 1] NS
| 2] Propentofylline 300 mg tid change from baseline | | 2] 19.5 (3.5) | | | | 2] -1.4 (3.8) | 2] 0.02
| 3] Change from baseline in treatment vs placebo | | | | | | | 3] NS
| | BSRT | | | | | 1] 0.1 (0.7) | 1] NS
| | | | | | | 2] -0.1 (0.5) | 2] NS
| | | | | | | | 3] NS
| | SRT DR | | | | | 1] 0.4 (1.1) | 1] NS
| | | | | | | 2] 0.5 (1.3) | 2] NS
| | | | | | | | 3] NS
| | DSST | | | | | 1] -2.1 (7.5) | 1] NS
| | | | | | | 2] 3.2 (6.2) | 2] NS
| | | | | | | | 3] <0.06
| | Verbal Fluency | | | | | 1] 0.6 (7.5) | 1] NS
| | | | | | | 2] -1.9 (7.3) | 2] NS
| | | | | | | | 3] NS

Evidence Table 205. Study results: Propentofylline

Author Year | Analysis Groups | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Saletu, 1990 | OC Analysis
Moller 1994 | 1] Placebo | GBS Total | 1] 26.2 (11.1) | 5] 0.1632 | | | 3] -2.5 (10.4) | 3]<0.05
| 2] Propentofylline 300mg tid | | 2] 29.4 (14.8) | | | | 4] -11.6 (11.8) | 4] <0.05
| 3] Placebo change from baseline | | | | | | | 5] 0.0001
| 4] Propentolfylline change from baseline | MMSE | 1] 20.9 (2.3) | 5] 0.8794 | | | 3] 2.3 (4.0) | 3]<0.05
| 5] Placebo vs Propentofylline | | 2] 21.0 (2.7) | | | | 4] 4.2 (3.2) | 4]<0.05
| | | | | | | | 5] 0.0038
| | CGI –S | 1] 5.06 (.71) | 5] 0.619 | | | 3] -0.50 (1.20) | 3] <0.05
| | | 2] 5.19 (.74) | | | | 4] -0.82 (1.00) | 4] <0.05
| | | | | | | | 5] 0.014
| | CGI-CGC | | | | | 3] 4.02 (1.37) | 3] <0.05
| | | | | | | 4] 3.33 (0.97) | 4] <0.05
| | | | | | | | 5] 0.003
| | CGI-efficacy | | | | | 3] 2.70 (1.05) | 3] <0.05
| | | | | | | 4] 2.31 (1.04) | 4] <0.05
| | | | | | | | 5] 0.032
| | 8 Psychometric tests | | | | 5] NS | | 3] 0.05
| | | | | | | | 4] 0.05
| | | | | | | | 5] NS

Evidence Table 206. Adverse Events: Propentofylline

Adverse events (AE) identified in included studies | Marcusson {1984}, 1997 | Mielke {2645}, 1996 | Mielke {1855}, 1998 | Saletu {4169}, 1990
Withdrawn (%) due to AE | T: 12 | T: 0 | T: 8 | T: 0
| C: 8 | C: 0 | C: 0 | C: 13
AE Checklist (Max 5) | 2 | 4 | 2 | 1
None Reported | | X
Balance
Accidental Injury
Dizziness | X | | | X
Falls
Behavioral
Agitation
Cardiovascular
Arrhythmia
Hypotension
Hypertension
Extrapyramidal
Tremor
Gastrointestinal | X | | | X
Abdominal pain | X | | X
Constipation
Diarrhea
Dyspepsia
Nausea, vomiting | X
Metabolic/nutritional
Eating disorder
Weight Change
Neurological
Asthenia
Psychiatric
Anxiety | | | | X
Confusion, delirium
Depression
Respiratory
Cough, cold, infection
Rhinitis
Other
Aberrant hematology
Fatigue, weakness
Fever, flu, pneumonia
Headache | X | | | X
Hepatic abnormality
Muscle/joint disorder
Pain
Rash, skin disorder | | | X
Sleep disorder
Urinary disorder

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Evidence Table 207. Key characteristics: Other agents

Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total # Randomized | # Completing Trial | Mean age (range) | Highest Dose | Treatment Period | Outcomes Measured | Outcome reports stratified
| | | | | | | | | % Male (M)
| | | | | | | | | Population
Senin 1991 | PI | 8 | Placebo | NINCDS | AD | Mild-Mod | 109 | 109 | 72.4y (65–80y) | 750 mg bid | 6m | Blessed-D | No
| | | Aniracetam | | | | | | 44%M | | | Corsi Test
| | | | | | | | | 100% Community | | | Gibson Spiral Maze
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Raven Colored
| | | | | | | | | | | | Progressive Matrices
| | | | | | | | | | | | Rey's 15
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | TP
Ban 1991b | NR | 5 | Placebo | DSM III | PDD | NR | 155 | 148 | 73.0 y (NR) | 200 LRU tid | 12w | SCAG | PDD vs MID
| | | Ateroid | | MID | | | | 56% M | | | HDS
| | | | | SDAT | | | | 30% Community | | | Laboratory tests
| | | | | | | | | 70% Institution
Shrotriya 1996 | IF | 6 | Placebo | NINCDS | AD | Mild-Mod | 69 | 54 | 72.0 y (54–92 y) | 300 mg tid | 12w + 4w washout | ADAS | No
| | | BMY (Nootropic) | DSM-III-R | | | | | 41% M | | | ADAS-Cog
| | | | | | | | | | | | AE
| | | | | | | | | | | | CGI-S
| | | | | | | | | | | | CNTB
| | | | | | | | | | | | MMSE
Cucinotta 1992 | NR | 6 | Placebo | DSM-III-R | VaD | Mild-Mod | 88 | 73 | 74.0 y (NR) | 300 mg bid | 270d | Birren test | No
| | | Buflomedil | | | | | | 47% M | | | CGI
| | | | | | | | | | | | Dementia rating scale
| | | | | | | | | | | | HDS
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Nowlis mood test
| | | | | | | | | | | | SHGRS
Danielczyk 1988 | NR | 8 | Placebo | DSM III | PDD | Mild-Mod | 125 | 117 | 73.8 y (60–90 y) | 0.4 mg/d (Day 1–3) | 8w | Digit span | No
| | | CBM 36–733 (Ergokryptine) | | | | | | 41% M | 0.8 mg/d (Day 4–6) | | Laboratory tests
| | | | | | | | | Community | 1.2 mg/d (Day 7–9) | | Neuropsychological
| | | | | | | | | Institution | 2 mg/d (Day 10-end) | | Battery
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | Psychometric tests
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Trail Making Test
| | | | | | | | | | | | WAIS
Shimada 1994 | NI | 5 | Placebo | DSM-III-R | VaD | NR | 60 | 57 | 78.9 y (NR) | 2.5 g tid | 12w | Global improvement rating | No
| IS | | Choto-san | | | | | | 15% M | | | Hasegawa's dementia scale
| | | | | | | | | 100% Asian | | | Overall safety rating
| | | | | | | | | 77% Cardiovascular | | | Utility rating
| | | | | | | | | 5% Diabetes
| | | | | | | | | 5% Parkinson's
| | | | | | | | | 5% Liver/Renal
Terasawa 1997 | PI | 5 | Placebo | DSM-III-R | VaD | NR | 139 | 119 | 76.6 y (NR) 36 | 7.5 g tid | 12w | HDS-R | No
| | | Choto-san | | | | | | 100% Asian; | | | Various Global Rating Scales
| | | | | | | | | 80% Cardiovascular
| | | | | | | | | 8% Diabetes
| | | | | | | | | 5% Parkinson's
| | | | | | | | | 3% Liver/Renal
Schellenberg 1997 | PI | 5 | Placebo | DSM-III-R | AD | NR | 139 | 92 | 75.0 y (62–85 y) | 400 mg qid | 16w | ADAS | No
| | | Cyclandelate | | | | | | 21% M | | | FIGT
| | | | | | | | | Community | | | MEMT
| | | | | | | | | | | | NCT
| | | | | | | | | | | | NSL
| | | | | | | | | | | | NST
| | | | | | | | | | | | SCAG
Weyer 2000 | PI | 7 | Placebo | DSM-III-R | PDD | Mild-Modly Sev | 196 | 147 | 78.6 y (54–91y) | 800 mg bid | 24w | ADAS-Cog | MMSE ADAS-Cog Treatment Center
| | | Cyclandelate | | VaD | | | | 27% M | | | CGI-C
| | | | | Mixed | | | | Community | | | NOSGER-IADL
Peabody 1986 | NI | 6 | Placebo | DSM III | PDD | Mild-Mod | 14 | NR | NR | 30 μg/d (start) | 3w | BUSCHKE-S&L | No
| IS | | Vasopressin (DAVP) | | | | | | | 180 μg/d | | SCAG
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | POMS
| | | | | | | | | | | | VAMS
Cucinotta 1996 | IF | 6 | Placebo | NINCDS | AD | Mild-Mod | 215 | 155 | 74.0 y (60–85 y) | 5 mg bid (week 1–2) | 1y | AE | No
Auxiliary: | | | Ergokryptine (DEK) | | | | | | 33% M | 10 mg bid (week 3–4) | | GBS
Cucinotta 1998 | | | | | | | | | Italian, Institution | 20 mg bid (until end) | | HAM-D
| | | | | | | | | | | | MDB
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Rey
Treves 1999 | NR | 5 | Placebo | DSM-III-R | VaD | Mild-Mod | 336 | 229 | 74.0 y (>60 y) | 100 mg bid | 16w | MMSE | No
| | | Denbufylline | | AD | | | | 42% M | | | WAIS-DSST
| | | | | MIXED | | | | | | | WAIS-VDC
Crapper-McLachlan 1991 | NI | 7 | Placebo | NINCDS | AD | Probable | 48 | 39 | 63.1y (57–69 y) | 500 mg bid (start) | 2y | VHB | No
| | | DFO | | | | | | 49% M | 125 mg bid (Day17- end) | | Wechsler Adult Intelligence-revised verbal
| | | | | | | | | 100% Community | | | Wechsler Memory Scale
| | | | | | | | | | | | Western Aphasia Battery
Scharf 1999 | NI | 7 | Placebo | DSM IV | AD | Mild-Mod | 41 | 26 | 73.0 y (≥50 y) | 50 mg & 200 μg bid | 25w | ADAS-Cog | No
| IS | | Diclofenac & Misoprostol | | | | | | 44% M | | | ADAS-Noncog
| | | | | | | | | Community | | | ADAS-total
| | | | | | | | | | | | CGIC
| | | | | | | | | | | | GCIC
| | | | | | | | | | | | GDS
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | PSMS
Ban 1991a | IS | 7 | Placebo | DSM III | PDD | Mod-Sev | 155 | 148 | 73.5 y (56–98 y) | 200 LRU tid | 12w | ADL | No
| | | Glycosaminoglycan | | MID | | | | 57% M | | | BPRS
| | | Polysulphate | | | | | | Hispanic, Italian | | | CGI-GI
| | | | | | | | | 30% Community | | | CGI-SI
| | | | | | | | | 70% Institution | | | CT
| | | | | | | | | | | | EEG
| | | | | | | | | | | | EKG
| | | | | | | | | | | | GDS
| | | | | | | | | | | | HDS
| | | | | | | | | | | | HIS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | WMS-RR
Ala 1990 | PI | 5 | Placebo | NINCDS | AD | Mild-Mod | 46 | 42 | 71.0 y (63–79 y) | 100 mg/d | 12w | BCRS | No
| | | GM-1 | | | | | | 39% M | | | Benton Racial Recognition Test
| | | Monosialotetrahexosylgan | | | | | | | | | BPRS
| | | | | | | | | | | | Buschke Selective Reminding Test
| | | | | | | | | | | | Clock drawing
| | | | | | | | | | | | Complex Figure Test
| | | | | | | | | | | | Grooved pegboard test
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | IADL
| | | | | | | | | | | | Letter cancellation
| | | | | | | | | | | | Lipids
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NOSIE
| | | | | | | | | | | | Selective Reminding
| | | | | | | | | | | | Symbol-Digit Modalities test
| | | | | | | | | | | | Verbal fluency
Crook 1992b | NR | 5 | Placebo | NINCDS | AD | Mild-Mod | 29 | 26 | 71.0 y (60–81y) | 0.5 mg/d | 13w | Benton Visual Retention | No
| | | Guanfacine | DSM III | PDD | | | | 45% M | | | CGI variables
| | | | | | | | | Community | | | MMSE
| | | | | | | | | | | | Neuropsychiatric rating scale
| | | | | | | | | | | | WAIS Vocabulary
| | | | | | | | | | | | Wechsler Paired Assoc.
Thompson 1990 | IF | 7 | Placebo | DSM III | PDD | Probable | 80 | 68 | 71.0 y (55–79 y) | 1 mg tid | 24w + 2w washout | GERRI | No
| | | Hydergine-LC | NINCDS | AD | | | | 59% M | | | Ham-D
| | | | | | | | | | | | IPSCE
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | WMS
| | | | | | | | | | | | WAIS-DSST
Van Gool 2001 | NI | 8 | Placebo | NINCDS | AD | Min-Mild | 168 | 155 | 70.6 y (NR) | 400 mg/d if >/= 65 kg | 18m | ADAS-Cog | No
| IS | | Hydroxychloro-quine | | | | | | 42% M | 200 mg/d if </= 65 kg | | CAMDEX
| | | | | | | | | | | | IDDD
| | | | | | | | | | | | RMBPC
Rogers 1993 | NR | 5 | Placebo | NINCDS | AD | Mild-Mod | 44 | 28 | 78.0 y (NR) | 100 mg/d if </= 100 lbs | 6m | ADAS | No
| | | Indomethacin | | | | | | 54% M | 125/d if 101150 lbs | | BNT
| | | | | | | | | Community | 150 mg/d if >/= 150 lbs | | MMSE
| | | | | | | | | | | | TK
Adair 2001 | NI | 7 | Placebo | NINCDS | AD | Mild-Mod | 47 | 43 | NR | 50 mg/kg/d | 6m | ADL | No
| | | N-acetylcysteine | | | | | | Community | | | BNT
| | | | | | | | | | | | CT Scan
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Neuropsychological Battery
Aisen 2002 | NI | 7 | Placebo | DSM III | AD | Probable | 40 | 38 | 74.0 y (NR) | 100 mg bid | 12w | ADAS-Cog | No
| | | Nimesulide | | | | | | 58% M | | | ADL
| | | | | | | | | | | | BPRS
| | | | | | | | | | | | CDR
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | MMSE
Ban 1990 | IS | 7 | Placebo | DSM III | PDD | Mild-Modly Sev | 178 | 175 | 75.4 y (55–95 y) | 90 mg/d | 12w | CBC & platelet count | No
| | | Nimodipine | | MID | | | | 42% M | | | CGI Severity of illness
| | | | | | | | | Italian, | | | CGI-global improvement
| | | | | | | | | 19% Community | | | EEG
| | | | | | | | | 79% Institution | | | GDS
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | HIS
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Neurologic Evaluation
| | | | | | | | | | | | Plutchik Geriatric Rating Scale
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Wechsler Memory Scale
Pantoni 2000a | IF | 6 | Placebo | DSM-III-R | MID | Mild-Mod | 259 | 251 | 74.3 y (45–85 y) | 30 mg tid | 26w | ADL | VaD vs MID
Auxiliary: | | | Nimodipine | | | | | | 47% M | | | CDR
Pantoni 2000 | | | | | | | | | White, Community & Institution | | | CGI
| | | | | | | | | | | | Digit Span
| | | | | | | | | | | | Fuld Object Memory
| | | | | | | | | | | | GBS
| | | | | | | | | | | | IADL
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | RDS
| | | | | | | | | | | | Word Fluency
| | | | | | | | | | | | ZVT-G
Carlson 2001 | IS | 7 | Placebo | DSM-III-R | AD | Probable - Possible | 51 | 42 | 80.7 y (67–96 y) | 75 mg bid | 1y | Benton Visual Retention Test | No
Auxiliary: | | | Nizatidine | NINCDS | VaD | | | | 38% M | | | Boston Naming Test
Breitner 1999 | | | | NINDS-AIREN | | | | | | | | Category Fluency
| | | | | | | | | | | | CERAD
| | | | | | | | | | | | Constructional Praxis
| | | | | | | | | | | | COWA
| | | | | | | | | | | | CPT
| | | | | | | | | | | | IADL
| | | | | | | | | | | | Logical Memory I & 2
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Trail-Making Test
| | | | | | | | | | | | WLM
| | | | | | | | | | | | WMS
| | | | | | | | | | | | WMS-R
Kragh-Sorensen 1986 | NI | 6 | Placebo | DSM III | PDSD | Mild-Mod | 156 | 126 | 82.5 y (>65 y) | 80 mg bid | 28d | GAGS | No
| | | ORG 2766 | | | | | | 23% M | | | Laboratory tests
| | | | | | | | | | | | LPRS
| | | | | | | | | | | | RDS
| | | | | | | | | | | | SCAG
Soininen 1985 | IS | 7 | Placebo | DSM III | AD | Mild-Sev | 77 | 73 | 73.2 y (NR) | 20 mg bid | 6m | AGS-E | No
Auxiliary | | | ORG 2766 | | | | | | 32% M | | | GPI-E
Partanen 1986 | | | | | | | | | Institution | | | LPRS
Soininen 1984 | | | | | | | | | | | | McGBRS
| | | | | | | | | | | | SCAG
Aisen 2000b | NI | 7 | Placebo | NINCDS | AD | Mild-Mod | 138 | 92 | 72.3 y (>50 y) | 20 mg/d (week 1–4) | 1y | ADAS-Cog | No
Auxiliary: | IS | | Prednisone | | | | | | 69% M | 10 mg/d (week 5-end) | | BDRS
Aisen 2000a | | | | | | | | | | | | BPRS
| | | | | | | | | | | | CDR-SB
| | | | | | | | | | | | HAM-D
| | | | | | | | | | | | MMSE
Simmons 2002 | PI | 7 | Placebo | NINCDS | AD | Mild-Mod | 44 | 37 | 68.3 y (60–77 y) | 80 mg/d | 26w | ADAS-cog | MMSE
| IS | | Simvastatin | | | | | | 43% M | | | Laboratory tests
| | | | | | | | | | | | MMSE
Nolan 1991 | NI | 5 | Placebo | NINCDS | AD | Mild-Mod | 15 | 10 | 76.3 y (59–87 y) | 3 g/day | 12m | Boston Naming test | No
| | | Thiamine | | | | | | 33% M | | | CERAD
| | | | | | | | | Community | | | Constructional praxis test
| | | | | | | | | | | | Delayed recall and recognition
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Verbal learning score
| | | | | | | | | | | | Word list learning test
Fischhof 1996 | NR | 5 | Placebo | DSM-III-R | PDD | Mild-Mod | 152 | 142 | Mean NR (50–85 y) | 30 mg bid | 12w | BGP | MID vs DAT
| | | Vincamine | | VaD | | | | % M NR | | | CGI
| | | | | | | | | Institution | | | SCAG
| | | | | | | | | | | | SKT
Croisile 1993 | IF | 4 | Placebo | NINCDS | AD | Mild-Mod | 33 | 30 | 42% M | 8 gr/day per oz | 1y | Aphasia Battery | No
| | | Piracetam | | | | | | Community | | | Blessed A
| | | | | | | | | | | | CT
| | | | | | | | | | | | EEG
| | | | | | | | | | | | Laboratory tests
| | | | | | | | | | | | Logical Digit Span
| | | | | | | | | | | | MADRS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Neuropsychological Battery
Kanowski 1990 | PI | 8 | Placebo | DSM-III-R | AD | Mild-Mod | 313 | 297 | 82.0 y (≥60 y) | 1g tid | 12w | BGP | MID vs DAT
| | | Xantinolnicotinate | | MID | | | | 19% M | | | CGI
| | | | | | | | | | | | NAI
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | Digit Correction Test
| | | | | | | | | | | | Digit Symbol Substitution Test
Thomas 2001 | NR | 7 | Donepezil | NINCDS | AD | Mild-Mod | 60 | 54 | 66.1y (57–78 y) | Donepezil: | 6m | ADAS-cog | No
| | | Vitamin E | | | | | | 44% M | 5 mg/d (1 month) | | CT/MRI
| | | Rivastigmine (open label) | | | | | | | 10 mg/d (until end) | | ERP scalp topography
| | | | | | | | | | Vitamin E: | | GBS
| | | | | | | | | | 2000 IU (fixed) | | GDS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | NPI
| | | | | | | | | | | | WAIS
Taragano 1997 | NR | 7 | Fluoxetine | NINCDS | AD | Mild-Mod | 37 | 25 | 72.0 y (NR) | 10 mg/d | 45d | HAM-D | No
| | | Amitriptyline | DSM III | | | | | 22% M | 25 mg/d | | MMSE
| | | | | | | | | Community, Major depression
Passeri 1993 | NR | 5 | 5′-MTHF (folate) | DSM III-R | AD | Mild-Mod | 96 | 96 | Mean NR (65–94 y) | 50 mg/d | 8w | Blood levels | AD vs MID
| | | Tradozone | | MID | | | | 45% M | 100 mg/d | | HDRS
| | | | | | | | | Depression | | | RVM - immediate recall
| | | | | | | | | | | | RVM - delayed recall
Parnetti 1995 | NR | 6 | Placebo | NINCDS | AD | Mild-Mod | 222 | 214 | 74.9 y (65–85 y) | 10 mg/d | 3m | GBS | No
| | | Posatirelin | | | | | | 34% M | 500 mg/d | | GDS
| | | Citicoline | | | | | | 100% Community | | | HDRS
| | | | | | | | | | | | MMSE
| | | | | | | | | | | | Laboratory tests
Spilich 1996 | PI | 6 | Pyritinol | NINCDS | AD | Mild-Mod | 102 | 100 | 73.0 y (NR) | 600 mg/d | 12w | CETM | No
| | | Hydergine | | | | | | 31% M | 4.5 mg/d | | SCAG
| | | | | | | | | 100% Hispanic
Cucinotta 1988 | PI | 5 | Sulfomuco-polysaccharides | DSM III | MID | Mild-Mod | 30 | 23 | 79.4 y (NR) | 500 LRU | 4w | Blessed-D | No
| | | CDP-choline | | | | | | 27% M | 1000 mg | | Digit-Span
| | | | | | | | | 100% Institution | | | Digit-Symbol
| | | | | | | | | | | | NMS
| | | | | | | | | | | | SCAG
| | | | | | | | | | | | TP
Parnetti 1997 | NR | 5 | Sulodexide | NINDS-AIREN | VaD | Mild-Mod | 93 | 86 | 75.0 y (65–80y) | 100 mg/d | 6m | GBS | No
| | | Pentoxifylline | | | | | | 40% M | 1200 mg/d | | Laboratory tests
| | | | | | | | | Institution | | | MMSE
Sano 1997 | NI | 5 | Placebo | NINCDS | AD | Mod | 341 | 341 | 73.4 y (NR) | Vitamin E | 2y | ADAS-Cog | No
Auxiliary: | IS | | Vitamin E | | | | | | 35% M | 1000 IU bid | | Blessed Dementia Scale
Thal 1996 | | | Selegiline | | | | | | | Selegiline 5 mg bid | | CDR
| | | Selegiline + VitaminE | | | | | | | | | MMSE
| | | | | | | | | | | | Time to end-point (event free survival)

Evidence Table 208. Study results: Aniracetam

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 4m | | Final: (specify) 6m
Senin 1991 | OC Analysis
| 1] Placebo | SCAG total | 1] 48.2 (1.3)* | | 1] 52.2 (1.6)* | 3] <0.01 | 1] 56.5 (2.3) | 3] <0.01
| 2] Aniracetam 1500 mg/d | | 2] 50.5 (0.9)* | | 2] 42.3 (1.5)* | 4] <0.001 | 2] 39.4 (1.5) | 4] <0.001
| 3] Placebo time × baseline | | | | | 5] <0.001 | | 5] <0.001
| 4] Aniracetam time × baseline | Blessed I | 1] 7.2 (0.4)* | | 1] 7.9 (0.4)* | 3] <0.001 | 1] 8.8 (0.5) | 3] <0.001
| 5] Placebo vs. Aniracetam | | 2] 7.9 (0.4)* | | 2] 6.3 (0.5)* | 4] <0.001 | 2] 5.7 (0.5) | 4] <0.001
| | | | | | 5] <0.02 | | 5] <0.001
| | Blessed II | 1] 22.9 (0.5)* | | 1] 21.5 (0.8)* | 3] <0.001 | 1] 20.2 (1) | 3] <0.001
| | | 2] 21.6 (0.6)* | | 2] 24.4 (0.8)* | 4] <0.001 | 2] 26.1 (0.6) | 4] <0.001
| | | | | | 5] <0.01 | | 5] <0.001
| | Toulouse-Pieron (global) | 1] 0.4 (0.1)* | | 1] 0.1 (0.1)* | 3] <0.02 | 1] 0.2 (.01) | 3] <0.02
| | | 2] 0.3 (0.08)* | | 2] 0.7 (0.08)* | 4] <0.02 | 2] 0.8 (.01) | 4] <0.001
| | | | | | 5] <0.001 | | 5] <0.001
| | Rey immediate recall | 1] 18.4 (0.9)* | | 1] 16.2 (0.9)* | 5] <0.001 | 1] 16.2 (1.1) | 3] 0.001
| | | 2] 16.9 (0.9)* | | 2] 20.8 (1)* | | 2] 23.4 (1) | 4] <0.001
| | | | | | | | 5] <0.001
| | Rey delayed recall | 1] 1.9 (0.2)* | | 1] 1.3 (0.2)* | 5] <0.02 | 1] 1.6 (0.3) | 3] <0.001
| | | 2] 1.8 (0.2)* | | 2] 2.6 (0.3)* | | 2] 2.9 (0.4) | 4] <0.001
| | | | | | | | 5] <0.02

* SEM

Evidence Table 209. Study results: Ateroid

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Ban 1991b | OC Analysis
| 1] Placebo | SCAG total | | | | | 1] 17.3 | 3] <0.05
| 2] Ateriod 200LRU tid | | | | | | 2] 24.1
| 3] Ateriod vs Placebo | SCAG cognitive | | | | | 1] 13.0 | 3] <0.05
| | | | | | | 2] 19.2
| | SCAG agitation | | | | | 1] 17.77 | 3] NS
| | | | | | | 2] 25.4
| | SCAG overall impression | | | | | 1] 13.5 | 3] <0.10
| | | | | | | 2] 20.2
| | SCAG depression | | | | | 1] 22.0 | 3] <0.10
| | | | | | | 2] 27.5
| | HDS | | | | | | 3] <0.04

Evidence Table 210. Study results: BMY 21,502

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Shrotrya, 1996 | OC Analysis
| 1] Placebo | [underlined: ADAS-Cog] | 1] 16.2 | 3] 0.81 | | | 4] -0.5 | 3] >0.05
| 2] BMY 21,502 300 mg tid | | 2] 15.1 | | | | 5] -1.5
| 3] BMY 21,502 300 mg tid vs Placebo | [underlined: CGI severity] | 1] 3.49 | 3] 0.11 | | | | 3] NS
| 4] Placebo changes from baseline | | 2] 3.29
| 5] BMY changes from baseline | MMSE | 1] 22.5 | 3] 0.26
| | | 2] 23.5
| | CGI % Improvement | | | | | 1] 28% | 3] >0.05
| | | | | | | 2] 37%

Evidence Table 211. Study results: Buflomedil

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 90d | | Final: (specify) 270d
Cucinotta, 1992 | OC Analysis
| 1] Group I Buflomedil 300mg/ bid 270d | SHGRS | 1] 43.00 | | 1] 37.00 | | 1] 29.00
| 2] Group II Buflomedil 300mg/ bid 180d No treatment 90d | | 2] 35.50 | | 2] 30.50 | | 2] 30.00
| 3] Group III Placebo 90d Buflomedil 300mg bid 180d | | 3] 29.00 | | 3] 25.40 | | 3] 23.75
| 4] Group IV Placebo 90d Buflomedil 300mg/ bid 90d No treatment 90d | | 4] 41.00 | | 4] 39.00 | | 4] 34.00
| | Median Rating scale & Neuro-psychological test scores | 1] 16.00 | | 1] 10.75 | | 1] 6.25
| | | 2] 18.50 | | 2] 16.50 | | 2] 11.50
| | | 3] 21.50 | | 3] 9.50 | | 3] 7.00
| | | 4] 29.00 | | 4] 22.50 | | 4] 22.00
| | Dementia Rating scale | 1] 39.00 | | 1] 28.00 | | 1] 15.25
| | | 2] 22.50 | | 2] 18.50 | | 2] 17.50
| | | 3] 27.00 | | 3] 22.00 | | 3] 15.75
| | | 4] 37.25 | | 4] 30.25 | | 4] 28.00
| | Birren test | 1] 1.19 | | 1] 1.64
| | | 2] 1.38 | | 2] 2.50
| | | 3] 1.83 | | 3] 1.93
| | | 4] 1.27 | | 4] 1.50
| | Nowlis Mood test | 1] 13.38 | | 1] 12.12
| | | 2] 13.17 | | 2] 12.00
| | | 3] 15.83 | | 3] 12.50
| | | 4] 15.50 | | 4] 15.75
| | Clinical Global Impression | 1] 025 | | 1] 0.82 | | 1]1.33
| | | 2] 0.00 | | 2] 1.00 | | 2] 0.67
| | | 3] 0.00 | | 3] 0.12 | | 3] 0.67
| | | 4] 0.03 | | 4] 0.05 | | 4] 0.00

Evidence Table 212. Study results: CBM 36–733 (Ergokryptine)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 8w
Danielczyk, 1997 | OC Analysis
| 1] Placebo | SCAG- Overall Impression | 1] 5.0 | | | | 1] 5.0 | 3] 0.016
| 2] CBM 36–733 2.0 mg/df | | 2] 5.0 | | | | 2] 4.0
| 3] Differences between groups | SCAG-Cognitive Dysfunction | 1] 18.0 | | | | 1] 17.0 | 3] 0.276
| | | 2] 16.0 | | | | 2] 15.0
| | SCAG-Interpersonal Relationship | 1] 12.0 | | | | 1] 11.0 | 3] 0.421
| | | 2] 10.0 | | | | 2] 8.0
| | SCAG-Apathy | 1] 14.0 | | | | 1] 14.0 | 3] 0.011
| | | 2] 15.0 | | | | 2] 13.0
| | SCAG- Affect | 1] 10.0 | | | | 1] 10.0 | 3] 0.385
| | | 2] 9.0 | | | | 2] 8.0
| | SCAG- Somatic Dysfunction | 1] 8.0 | | | | 1] 7.0 | 3] 0.679
| | | 2] 7.0 | | | | 2] 7.0
| | Psychometric Test Battery-tests with significant difference | | | | | 2/9

Evidence Table 213. Study results: Choto-san

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 8w | | Final: (specify) 12w
Shimada 1994 | OC Analysis
| 1] Placebo | Global Improvement rating (% improved) | | | 1] 19% | 3] <0.01 | 1] 23% | 3] <0.01
| 2] Choto-san 2.5g tid | | | | 2] 61% | | 2] 71%
| 3] Difference between Placebo and Choto-san | Utility rating (% useful) | | | | | 1] 25% | 3] <0.01
| 4] Choto-san vs baseline | | | | | | 2] 78%
| | Global improvement
| | -subjective symptoms | | | 1] 12% | 3] <0.01 | 1] 21% | 3] <0.01
| | | | | 2] 59% | | 2] 55%
| | -neurological symptoms | | | 1] 13% | 3] NS | 1] 25% | 3] NS
| | | | | 2] 5% | | 2] 14%
| | -psychiatric symptoms | | | 1] 12% | 3] <0.01 | 1] 24% | 3] <0.01
| | | | | 2] 58% | | 2] 58%
| | Disturbance in daily living | | | 1] 12% | | 1] 19% | 3] <0.05
| | | | | 2] 29% | | 2] 38%
| | Hasegawa dementia | 1] 15 (3.84) | 4] NS | 1] 16 (5.82) | 4] <0.01 | 1] 17 (5.97) | 4] <0.01
| | | 2] 15 (3.76 | | 2] 18 (4.79) | | 2] 19 (5.71)

Evidence Table 214. Study results: Choto-san

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 8w | | Final: (specify) 12w
Terasawa 1997 | OC Analysis
| 1] Placebo | Global severity rating %improved | | | 1] 42.9% | 3] 0.001 | 1] 48.4% | 3] <0.001
| 2] Choto-san 2.5g tid | | | | 2] 70.9% | | 2] 34.4%
| 3] difference between Placebo and Choto-san | HDS-R | | | 1] 17.3(5.3) | 3] NS | 1] 17.4(6.0) | 3] NS
| | | | | 2] 18.0(6.4) | | 2] 19.3(6.6)
| | Utility Rating (% Useful) | | | | | 1] 33% | 3] <0.001
| | | | | | | 2] 44%

Evidence Table 215. Study results: Cyclandelate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 8w | | Final: (specify) 16w
Schellenberg 1997 | ITT Analysis
| 1] Placebo | SCAG | 1] 44.0 (39.0, 53.0) | | 1] 36.0 (28.0, 53.0) | | 1] 38.0 (29.0, 67.0) | 3] 0.0004
| 2] Cyclandelate 1,600 mg d | | 2] 39.0 (35.0, 51.0) | | 2] 33.0 (28.0, 38.0) | | 2] 32.0 (26.0, 37.0)
| 3] Cyclandelate vs. placebo | ADAS | 1] 24.0 (15.0, 39.0) | | 1] 20.0 (13.0, 34.0) | | 1] 17.0 (11.0, 42.0) | 3] 0.0006
| | | 2] 20.0 (14.0, 37.0) | | 2] 17.0 (9.0, 22.0) | | 2] 16.0 (8.0, 20.0)
| | NCT | 1] 16.5 (8.0, 35.0) | | 1] 25.8 (10.8, 51.2) | | 1] 34.9 (11.4, 52.8) | 3] >0.2
| | | 2] 20.2 (10.2, 32.2) | | 2] 37.2 (22.6, 54.0) | | 2] 26.4 (19.4, 53.4)
| | NST | 1] 39.0 (19.0, 59.0) | | 1] 50.0 (23.0, 65.0) | | 1] 54.0 (27.0, 65.0) | 3] 0.0051
| | | 2] 48.0 (27.0, 57.0) | | 2] 56.0 (39.0, 68.0) | | 2] 59.5 (36.0, 66.0)
| | FIGT | 1] 14.5 (7.0, 34.0) | | 1] 25.5 (11.0, 45.0) | | 1] 30.0 (11.0, 45.0) | 3] >0.2
| | | 2] 22.0 (13.0, 34.0) | | 2] 33.5 (18.0, 49.0) | | 2] 31.5 (18.0, 45.0)
| | MEMT | 1] 17.0 (12.0, 19.0) | | 1] 18.0 (14.0, 19.0) | | 1] 18.0 (15.0, 19.0) | 3] >0.2
| | | 2] 18.0 (14.0, 19.0) | | 2] 18.0 (17.0, 19.0) | | 2] 18.0 (16.0, 19.0)
| | NSL | 1] 53.0 (45.0, 61.0) | | 1] 51.0 (38.0, 63.0) | | 1] 55.0 39.0, 69.0) | 3] .000002
| | | 2] 49.0 (43.0, 58.0) | | 2] 41.0 36.0, 50.0) | | 2] 41.0 (27.0, 49.0)

Evidence Table 216. Study results: Cyclandelate

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Weyer, 2000 | ITT Analysis
| 1] Placebo change from baseline | [underlined: ADAS-Cog% responders < -10 points] | | | | | 1] 12.8% | 3] NS
| 2] Cyclandelate 800 mg bid change from baseline | | | | | | 2] 18.6%
| 3] Difference between Placebo and Cyclandelate in change from baseline | [underlined: NOSGER-IADL % responders < -5 points] | | | | | 1] 5.3% | 3] NS
| | | | | | | 2] 10.3%
| | [underlined: CGI-C % responders at least minimal improvement] | | | | | 1] 51.1% | 3] NS
| | | | | | | 2] 58.8%
| | ADAS-Cog | | | | | 1] -1.5 (7.4) | 3] 0.320
| | | | | | | 2] -2.7 (8.8)
| | NOSGER-IADL | | | | | 1] -0.2 (2.7) | 3] 0.181
| | | | | | | 2] -0.6 (3.9)

Evidence Table 217. Study results: Desamino-D-Arginine-Vasapressin (DDAVP)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 3w
Peabody 1986 | OC Analysis
| 1] Placebo | HAM-D | 1] 4.4 (4.6) | | | | 1] 3.6 (2.8) | 3] 0.02
| 2] DDAVP 45mg qid | | 2] 3.2 (3.6) | | | | 2] 4.5 (3.9)
| 3] DDAVP vs Placebo | SCAG affect | 1] 4.1 (1.3) | | | | 1] 4.4 (1.2) | 3] 0.01
| | | 2] 4.6 (1.8) | | | | 2] 4.7 (2.6)
| | SCAG interpersonal | 1] 4.8 (1.2) | | | | 1] 4.5 (0.4) | 3] 0.02
| | | 2] 4.6 (1.0) | | | | 2] 5.0 (1.5)
| | SCAG 19 (overall) | 1] 4.4 (0.7) | | | | 1] 4.5 (0.6) | 3] 0.06
| | | 2] 3.4 (1.0) | | | | 2] 3.3 (1.1)
| | SCAG total | 1] 36 (5) | | | | 1] 35 (3) | 3] NS
| | | 2] 29 (6) | | | | 2] 30 (65)
| | Buschke total recall | 1] 6.1 (1.8) | | | | 1] 5.8 (2.0) | 3] NS
| | | 2] 7.4 (2.1) | | | | 2] 7.7 (2.5)
| | POMS Vigor | 1] 55 (9) | | | | 1] 56 (9) | 3] NS
| | | 2] 59 (7) | | | | 2] 63 (6)
| | POMS Fatigue | 1] 42 (5) | | | | 1] 44 (6) | 3] NS
| | | 2] 42 (5) | | | | 2] 41 (5)
| | POMS Depression | 1] 37 (4) | | | | 1] 37 (3) | 3] NS
| | | 2] 38 (5) | | | | 2] 38 (5)

Evidence Table 218. Study results: Dihydroergokryptine (DEK)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 6m | | Final: (specify) 12m
Cucinotta, 1996 | Endpoint Analysis
Cucinotta, 1998 | 1] Placebo | [underlined: GBS Factor 1] | 1] 8.7 ( 4.4) | | 1] 9.4 ( 4.4) | | 1] 10.5 ( 4.8) | 3] 0.000
| 2] DEK 20mg bid | | 2] 9.6 ( 4.3) | | 2] 8.4 ( 4.2) | | 2] 8.0 ( 4.8)
| 3] DEK 20mg bid vs Placebo | [underlined: GBS Factor 2] | 1] 5.2 ( 6.0) | | 1] 5.4 ( 6.2) | | 1] 7.2 ( 7.7) | 3] 0.001
| | | 2] 4.9 ( 5.7) | | 2] 4.1 ( 4.6) | | 2] 3.8 ( 4.7)
| | [underlined: GBS Factor 3] | 1] 3.5 ( 2.7) | | 1] 3.1 ( 2.3) | | 1] 3.0 ( 2.8) | 3] 0.229
| | | 2] 3.3 ( 2.4) | | 2] 2.7 ( 2.3) | | 2] 2.5 ( 2.3)
| | [underlined: GBS Factor 4] | 1] 13.1 ( 7.5) | | 1] 13.5 ( 7.8) | | 1] 15.3 ( 7.5) | 3] 0.000
| | | 2] 12.6 ( 7.6) | | 2] 11.1 ( 6.7) | | 2] 10.3 ( 6.7)
| | MMSE | 1] 19.6 ( 2.6) | 3] 0.645 | | | 1] 8% reduction | 3] <0.001
| | | 2] 19.7 ( 2.6) | | | | 2] same mean
| | HAM-D | 1] 9.1 ( 4.9) | 3] 0.621
| | | 2] 9.4 ( 4.7)
| | REY Test Immediate Recall | 1] 14.4 ( 7.0) | | 1] 12.2 ( 7.2) | | 1] 11.7 ( 7.0) | 3] 0.022
| | | 2] 14.3 ( 7.9) | | 2] 14.2 ( 8.3) | | 2] 14.5 ( 8.1)
| | REY Test Delayed Recall | 1] 3.0 ( 2.9) | | 1] 3.0 ( 3.0) | | 1] 2.4 ( 2.7) | 3] 0.044
| | | 2] 3.4 ( 2.5) | | 2] 3.8 ( 3.4) | | 2] 4.0 ( 3.7)
| | GBS-C | 1] 4.7 (2.8) | | 1] 4.9 (3.3) | | 1] 5.4 (3.3) | 3] 0.004
| | | 2] 4.9 (5.7) | | 2] 4.1 (2.6) | | 2] 3.6 (2.6)
| | GBS - M | 1] 5.2 (6.0) | | 1] 5.4 (6.2) | | 1] 7.2 (7.7) | 3] 0.001
| | | 2] 4.9 (5.7) | | 2] 4.1 (4.6) | | 2] 3.8 (4.7)
| | GBS - I | 1] 18.8 (8.9) | | 1] 19.8 (8.8) | | 1] 22.3 (8.9) | 3] 0.000
| | | 2] 19.1 (9.2) | | 2] 16.8 (8.2) | | 2] 16.6 (9.0)

Evidence Table 219. Study results: Denbufylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 16w
Treves, 1999 | OC Analysis
| 1] Placebo | [underlined: MMSE] | 1] 17.3 (4.2) | | | | 1] 16.9 (5.1) | 6] 0.7
| 2] Denbufylline 25 mg bid | | 2] 18.4 (4.6) | | | | 2] 19.5 (6)
| 3] Denbufylline 50 mg bid | | 3] 18.6 (4.7) | | | | 3] 19.1 (5.7)
| 4] Denbufylline 100 mg bid | | 4] 18.2 (4.8) | | | | 4] 19.1 (5.5)
| 5] Denbufylline Overall doses | | 5] 18.4 (4.7) | | | | 5] 19.3 (5.7)
| 6] Treatment effect vs Placebo | [underlined: DSST] | 1] 6.6 (6.8) | | | | 1] 7.1 (7.1) | 6] NS
| | | 2] 7.2 (6.5) | | | | 2] 9.4 (9)
| | | 3] 8.5 (8.6) | | | | 3] 9.7 (8.6)
| | | 4] 7.5 (5.4) | | | | 4] 8.3 (7.6)
| | | 5] 7.7 (6.9) | | | | 5] 9.2 (8.5)
| | WAIS-voc | 1] 28.9 (15.5) | | | | 1] 26.1 (16) | 6] NS
| | | 2] 28.8 (17.2) | | | | 2] 30.9 (19.6)
| | | 3] 26.6 (17.1) | | | | 3] 29.4 (19.3)
| | | 4] 27.7 (16.1) | | | | 4] 29.6 (19.4)
| | | 5] 27.7 (16.8) | | | | 5] 30.0 (19.4)

Evidence Table 220. Study results: Desferrioxamine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 18m
Crapper McLachlan 1991 | OC Analysis
| 1] Placebo slope of change from baseline | [underlined: VHB] | 1] -1.717 (1.689) | | | | 1] -0.866 (0.932) | 3] 0.0375
| 2] Desferrioxamine 500 mg BID slope of change from baseline
| 3] Difference from baseline between Desferrioxamine and Placebo

Evidence Table 221. Study results: Diclofenac and Misoprostol (D/M)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 25w
Scharf 1999 | ITT Analysis
| 1] Placebo | [underlined: ADAS-cog] | | | | | 3] 1.93 (5.55) | 5] 0.571
| 2] Diclofenac 50mg and Misoprostol 200μg (D/M) | | | | | | 4] 0.25 (4.50)
| 3] Placebo mean change from baseline | [underlined: GDS] | | | | | 3] 0.57 (0.51) | 5] 0.384
| 4] D/M group mean change from baseline | | | | | | 4] 0.35 (0.49)
| 5] mean treatment differences placebo vs. D/M | [underlined: CGIC] | | | | | 3] 4.57 (0.51) | 5] 0.340
| | | | | | | 4] 4.29 (0.69)
| | MMSE | | | | | 3] -0.86 (3.21) | 5] 0.237
| | | | | | | 4] 0.41 (2.69)
| | ADAS-noncog | | | | | 3] 1.36 (3.93) | 5] 0.319
| | | | | | | 4] -0.59 (3.89)
| | ADAS- Total | | | | | 3] 3.24 (8.85) | 5] 0.125
| | | | | | | 4] -0.75 (1.34)
| | IADL | | | | | 3] 1.86 (2.03) | 5] 0.161
| | | | | | | 4] 0.06 (2.95)
| | PSMS | | | | | 3] 0.21 (0.89) | 5] 0.340
| | | | | | | 4] 0.53 (1.84)
| | CGIC-C Caregiver rated | | | | | 3] 4.79 (1.05) | 5] 0.768
| | | | | | | 4] 4.47 (1.01)

Evidence Table 222. Study results: Glycoaminoglycan

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Ban, 1991a | OC Analysis
| 1] Placebo | CGI- SI | 1] 4.6 (0.69) | | | | 1] 4.0 (0.89) | 3] <0.18
| 2] Glycoaminoglycan polysulphate 200 LRU tid | | 2] 4.6 (0.63) | | | | 2] 3.7 (0.77)
| 3] Improvement in scores Glycoaminoglycan polysulphate 200 LRU tid vs. placebod | CGI -GI | 1] 3.8 (0.41) | | | | 1] 3.5 (0.71) | 3] <0.001
| | | 2] 3.7 (0.71) | | | | 2] 3.0 (0.78)
| | BPRS | 1] 31.4 (11.75) | | | | 1] 25.2 (10.73) | 3] <0.01
| | Total scores | 2] 28.9 (12.12) | | | | 2] 20.6 (10.52)
| | ADL | 1] 32.9 (9.10) | | | | 1] 32.2 (9.11) | 3] <0.16
| | | 2] 33.0 (9.77) | | | | 2] 30.5 (9.57)
| | SCAG | 1] 56.6 (10.66) | | | | 1] 46.8 (11.78) | 3] <0.05
| | | 2] 56.1 (13.47) | | | | 2] 42.6 (12.72)
| | MMSE | 1] 14.3 (4.64) | | | | 1] 16.2 (5.16) | 3] <0.04
| | | 2] 14.9 (4.93) | | | | 2] 18.2 (6.01)
| | GDS | 1] 4.8 (0.77) | | | | 1] 4.4 (0.95) | 3] <0.50
| | | 2] 4.8 (0.72) | | | | 2] 4.3 (0.93)
| | HDS | 1] 11.8 (3.87) | | | | 1] 11.1(4.28) | 3] <0.04
| | | 2] 12.1 (3.98) | | | | 2] 10.6 (4.53)
| | WMS-RR | 1] 5.9 (3.98) | | | | 1] 5.9 (4.79) | 3] <0.081
| | PAL | 2] 6.8 (4.7) | | | | 2] 7.7 (4.93)
| | Logical Memory | 1] 1.4 (1.42) | | | | 1] 1.5 (1.46) | 3] <0.18
| | | 2] 1.8 (1.54) | | | | 2] 2.1 (2.01)
| | Immediate Recall | 1] 1.5 (1.38) | | | | 1] 1.3 (1.24) | 3] <0.03
| | | 2] 1.6 (1.55) | | | | 2] 2.0 (2.01)
| | Delayed Recall | 1] 0.5 (.22) | | | | 1] 0.8 (.36) | 3] NS
| | | 2] 0.8 (.23) | | | | 2] 1.1 (.31)

Evidence Table 223. Study results: Monosialotetrahexosylgan (GM-1)

REF ID# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | | Baseline | | Mid-Point: (specify) 12w | | Final: (specify) 24w
| Ala 1990 | OC Analysis
| | 1] Placebo | HAM-D | 1] 7.04 (4.01) | | 1] 6.61 (4.19) | | 1] 6.43 (2.90) | 3] NS
| | 2] GM-1 100mg IM d | | 2] 5.58 (4.07) | | 2] 5.79 (4.61) | | 2] 7.21 (4.20) | 4] >0.05
| | 3] Placebo vs. GM-1 | | | | | | | 5]>0.05
| | 4] Placebo change from baseline | PSM | 1] 8.13 (1.63) | | 1] 8.09 (1.76) | | 1] 9.22 (2.39) | 3] NS
| | 5] GM-1 change from baseline | | 2] 8.32 (1.42) | | 2] 8.16 (1.80) | | 2] 9.42 (2.67) | 4] 0.032
| | | | | | | | | 5] 0.049
| | | IADL | 1] 17.1 (3.2) | | 1] 17.4 (3.5) | | 1] 18.4 (3.6) | 3] NS
| | | | 2] 18.5 (3.7) | | 2] 19.5 (4.1) | | 2] 20.6 (4.7) | 4] 0.012
| | | | | | | | | 5] 0.027
| | | BPRS | 1] 8.65 (5.47) | | 1] 8.65 (6.32) | | 1] 9.22 (4.00) | 3] NS
| | | Total score | 2] 6.42 (3.81) | | 2] 8.74 (7.49) | | 2] 9.79 (6.33) | 4] >0.05
| | | | | | | | | 5] 0.024
| | | NOSIE | 1] 178 (26) | | 1] 177 (28) | | 1] 169 (32) | 3] NS
| | | Total score | 2] 184 (15) | | 2] 184 (21) | | 2] 173 (28) | 4] 0.031
| | | | | | | | | 5] 0.036
| | | MMSE | 1] 17.5 (3.2) | | 1] 17.7 (4.4) | | 1] 17.0 (4.9) | 3] NS
| | | | 2] 17.5 (3.3) | | 2] 18.3 (4.0) | | 2] 16.5 (4.5)
| | | BCRS | 1] 19.7 (3.3) | | 1] 18.9 (2.7) | | 1] 19.6 (3.2) | 3] NS
| | | | 2] 19.7 (2.4) | | 2] 19.2 (2.6) | | 2] 20.3 (2.9)
| | | Complex figure -copy accuracy | 1] 10.8 (7.2) | | 1] 10.7 (6.9) | | 1] 9.8 (6.2) | 3] NS
| | | | 2]11.6 (7.4) | | 2] 10.6 (6.5) | | 2] 10.7 (7.3)
| | | Verbal fluency | 1] 25.1 (9.6) | | 1] 26.0 (10.3) | | 1] 23.6 (9.4) | 3] NS
| | | | 2] 25.6 (11.1) | | 2] 24.4 (11.2) | | 2] 22.4 (10.0)
| | | Selective reminding- Retrieval | 1] 7.30 (6.96) | | 1] 6.35 (6.11) | | 1] 9.52 (9.40) | 3] NS
| | | | 2] 9.58 (8.31) | | 2] 8.42 (5.69) | | 2] 8.95 (6.79)
| | | Symbol digit | 1] 11.9 (11.1) | | 1] 13.9 (10.8) | | 1] 13.8 (10.5) | 3] NS
| | | | 2] 14.6 (8.3) | | 2] 15.8 (6.3) | | 2] 10.6 (7.4) | 5] 0.017
| | | 8 other cognitive tests | | | | | | 3] NS

Evidence Table 224. Study results: Guanfacine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 13w
Crook, 1992b | ITT Analysis
| 1] Placebo | CGI | | | | | | 5] <.05
| 2] Guanfacine .5mg/d | Wechsler Paired Associates | 1] 6.54 (2.04) | | | | 3] 6.08 (1.77)
| 3] Placebo change from baseline | | 2] 6.90 (2.94) | | | | 4] 4.97 (2.72)
| 4] Guanfacine .5mg/d change from baseline | Benton Visual Retention- Number Correct | 1] 2.69 (1.49) | | | | 3] 2.15 (1.57)
| 5] Guanfacine .5mg/d change from baseline relative to placebo | | 2] 3.20 (1.66) | | | | 4] 1.67 (1.18)
| | Benton Visual Retention- Errors | 1] 15.31 (4.48) | | | | 3] 15.69 (5.06) | 5] <.03
| | | 2] 12.73 (6.22) | | | | 4] 17.80 (4.28)

Evidence Table 225. Study results: Hydergine-LC

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
Thompson 1990 | OC Population
| 1] Placebo change from baseline | WAIS DSST | | | | | 1] 1.76(1.64)* | 3] <0.01
| 2] Hydergine-LC 1mg tid change from baseline | | | | | | 2] 8.85(2.07)*
| 3] Placebo vs Hydergine-LC change from baseline | WMS-Logical | | | | | 1] -0.02(0.23)* | 3] >0.30
| | | | | | | 2] -0.21(0.23)*
| | WMS-Visual | | | | | 1] -0.07(0.12)* | 3] >0.50
| | | | | | | 2] -0.10(0.10)*
| | GERRI | | | | | 1] 0.04(0.07)* | 3] <0.02
| | | | | | | 2] -0.23(0.09)*
| | IPSCE | | | | | 1] -0.11(1.36)* | 3] >0.50
| | | | | | | 2] -1.43(1.65)*
| | HAM-D | | | | | 1] 0.46(0.45)* | 3] >0.50
| | | | | | | 2] 0.39(0.39)*
| | SCAG | | | | | 1] -3.60(1.35)* | 3] >0.50
| | | | | | | 2] -2.37(1.69)*

* SEM

Evidence Table 226. Study results: Hydroxychloroquine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 9m | | Final: (specify) 18m
Van Gool, 2001 | ITT Analysis
| 1] Placebo | [underlined: IDDD] | 1] 10.9 (7.0) | 3] NS | 1] 15.9 (9.2) | 3] NS | 1] 21.3 (10.5) | 3] NS
| 2] Hydroxchloroquine 200 or 400 mg QID | | 2] 11.6 (7.1) | | 2] 17.0 (10.0) | | 2] 22.6 (11.4)
| 3] Difference between Placebo and Hydroxchloroquine | ADAS-Cog | 1] 17.6 (9.1) | 3] NS | 1] 20.0 (9.70) | 3] NS | 1] 25.7 (14.3) | 3] NS
| | | 2] 18.0 (9.4) | | 2] 21.7 (12.8) | | 2] 26.4 (14.9)
| | RMBPC | 1] 27.8 (10.8) | 3] NS | 1] 30.2 (11.7) | 3] NS | 1] 34.2 (12.4) | 3] NS
| | | 2] 28.6 (11.0) | | 2] 32.0 (11.5) | | 2] 36.3 (12.0)

Evidence Table 227. Study results: Indomethacin

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Rogers 1993 | Completer Analysis
| 1] Placebo % change from baseline | ADAS | | | | | 1] -13.3 (5.6)* | 3] 0.061
| 2] Indomethacin 150mg/d % change from baseline | | | | | | 2] 1.4 (4.9)*
| 3] Difference between Placebo and Indomethacin change from baseline | MMSE | | | | | 1] -13.4 (4.4)* | 3] 0.069
| | | | | | | 2] -0.9 (4.8)*
| | BNT | | | | | 1] -6.6 (5.5)* | 3] 0.120
| | | | | | | 2] 4.4 (3.7)*
| | TK | | | | | 1] -0.4 ( 2.9)* | 3] 0.773
| | | | | | | 2] 0.5 ( 1.0)*
| | Overall all tests | | | | | 1] -8.4 (2.3)* | 3] <0.003
| | | | | | | 2] 1.3 (1.8)*

* SEM

Evidence Table 228. Study results: N-acetylcysteine (NAC)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 3m | | Final: (specify) 6m
Adair 2001 | ITT Analysis
| 1] Placebo | [underlined: MMSE] | 1] 18.0 (3.6) | | 1] 17.5 (3.6) | 3] 0.056 | 1] 16.8 (4.6) | 3] NS
| 2] NAC 50 mg/kg/d | | 2] 19.8 (3.7) | | 2] 20.5 (4.7) | | 2] 19.8 (5.3)
| 3] Difference between Placebo and NAC | [underlined: ADL] | 1] 16.2 (5.0) | | 1] 18.5 (4.3) | | 1] 20.1 (4.9) | 3] NS
| | | 2] 14.2 (4.3) | | 2] 15.2 (4.7) | | 2] 16.1 (5.0)
| | BNT | 1] 18.9 (6.5) | | 1] 19.6 (6.0) | | 1] 18.0 (6.9) | 3] NS
| | | 2] 20.9 (5.6) | | 2] 21.1 (5.3) | | 2] 21.2 (6.2)

Evidence Table 229. Study results: Nimesulide

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
Aisen 2001 | ITT Analysis
| 1] Placebo | MMSE | 1] 22.7 (1.0)* | 6] 0.54
| 2] Nimesulide 100mg bid | | 2] 21.8 (1.1)
| 3] Placebo change from baseline | ADAS-Cog | 1] 21.4 (2.6)* | 6] 0.59 | | | 3] -0.5 (1.0)* | 5] 0.49
| 4] Nimesulide change from baseline | | 2] 19.8 (1.5)* | | | | 4] 0.9 (1.0)*
| 5] Nimesulide change from baseline relative to placebo | CDR -SB | 1] 4.6 (0.5)* | 6] 0.91 | | | 3] 0.2 (0.3)* | 5] 0.70
| 6] Placebo vs Nimesulide | | 2] 4.7 (0.7)* | | | | 4] 0.7(0.3)*
| | ADL | 1] 3.8 (0.5)* | 6] 0.34 | | | 3] -0.3 (0.2)* | 5] 0.73
| | | 2] 3.3 (.03)* | | | | 4] -0.2 (0.3)*
| | HAM-D | 1] 3.8 (0.8)* | 6] 0.52 | | | 3] 1.0 (0.6)* | 5] 0.30
| | | 2] 4.6 (0.8)* | | | | 4] -0.2 (0.9)*
| | BPRS | 1] 29.6 (1.4)* | 6] 0.59 | | | 3] 0.4 (0.9)* | 5] 0.99
| | | 2] 28.5 (1.5)* | | | | 4] 0.4 (1.4)*

* SEM

Evidence Table 230. Study results: Nimodipine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 90d
Ban, 1990 | OC Analysis
| 1] Placebo | CGI-SI | 1] 3.8 (1.44) | | | | 1] 3.6 (1.3) | 3] <0.018
| 2] Nimodipine 30 mg bid | | 2] 3.8 (1.51) | | | | 2] 3.2 (1.28)
| 3] Nimodipine 30 mg bid vs. placebo | CGI-GI | 1] 3.7 (0.59) | | | | 1] 3.3 (.86) | 3] <0.001
| | | 2] 3.3 (0.77) | | | | 2] 2.7 (0.86)
| | HAM-D total | 1] 13.1 (6.20) | | | | 1] 12.1 (6.42) | 3] <0.001
| | | 2] 14.4(7.67) | | | | 2] 10.4 (5.63)
| | MMSE total | 1] 18.4 (5.57) | | | | 1] 19.2 (5.74) | 3] <0.001
| | | 2] 17.6 (5.47) | | | | 2] 21.0 (5.14)
| | GDS total | 1] 4.0 (.79) | | | | 1] 3.8 (.90) | 3] <0.001
| | | 2] 4.1 (.83) | | | | 2] 3.5 (.85)
| | SCAG total | 1] 53.0 (14.40) | | | | 1] 46.9 (14.47) | 3] <0.001
| | | 2] 57.5 (15.70) | | | | 2] 44.8 (12.79)
| | PLUTCHIK | 1] 19.2 (7.14) | | | | 1] 17.6 (6.26) | 3] <0.013
| | Total | 2] 20.3 (6.87) | | | | 2] 16.9 (7.41)
| | WMS | 1] 74.9 (16.67) | | | | 1] 80.7 (19.07) | 3] <0.001
| | | 2] 71.6 (13.19) | | | | 2] 85.4 (18.72)

Evidence Table 231. Study results: Nimodipine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: | | Final: 26w
Pantoni, 2000a | ITT Analysis
| 1] Placebo change from baseline | [underlined: GBS total] | 1] 0.85 (0.55) | | | | 1] 0.23 (0.49) | 3] 0.67
| 2] Nimodipine 90 mg/d change from baseline | | 2] 0.88 (0.58) | | | | 2] 0.85 (0.55)
| 3] Placebo vs Nimodipine change from baseline | [underlined: GBS-i] | 1] 1.06 (0.65) | | | | 1] 0.25 (0.58) | 3] 0.60
| | | 2] 1.13 (0.73) | | | | 2] 0.21 (0.64)
| | CDR | | | | | 1] 1.16 (0.55) | 3] 0.67
| | | | | | | 2] 1.12 (0.60)
| | MMSE | 1] 21.46 (4.24) | | | | 1] -0.83 (3.29) | 3] 0.94 favours placebo
| | | 2] 21.24 (4.07) | | | | 2] -0.87 (3.66) | 3] 0.35
| | CGI (item 1) | | | | | 1] 0.14 (0.61)
| | | | | | | 2] 0.21 (0.57)
| | CGI (item 2) | | | | | 1] 4.02 (1.06) | 3] 0.95 favours placebo
| | | | | | | 2] 4.02 (0.99) | 3] 0.67
| | FOM (total recall) | | | | | 1] -2.56 (5.53)
| | | | | | | 2] -2.28 (6.54)
| | IADL | | | | | 1] 0.14 (0.39) | 3] 0.41
| | | | | | | 2] 0.11 (0.32)

Evidence Table 232. Study results: Nizatidine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12m
Carlson, 2002 | ITT Analysis
Breitner, 1999 | 1] Placebo change from baseline | COWA Letter fluency | | | | | 1] 1.4 | 3] 0.460
| 2] Nizatidine 75 mg bid change from baseline | | | | | | 2] -0.2
| 3] Difference between placebo and Nizatidine change from baseline | Category Fluency | | | | | 1] 0.5 | 3] 0.611
| | | | | | | 2] 2.0
| | Boston Naming test | | | | | 1] 1.4 | 3] 0.231
| | | | | | | 2] 0.6
| | WMS Immediate Recall | | | | | 1] 0.4 | 3] 0.147
| | | | | | | 2] 2.1
| | WMS Delayed Recall | | | | | 1] -0.8 | 3] 0.087
| | | | | | | 2] 0.9
| | Word List Immediate Recall | | | | | 1] 1.8 | 3] 0.413
| | | | | | | 2] 2.1
| | Word list Delayed Recall | | | | | 1] 0.3 | 3] 0.916
| | | | | | | 2] 0.3
| | Constructional Praxis test | | | | | 1] 1.6 | 3] 0.704
| | | | | | | 2] 1.9
| | Constructional Praxis, recall IADL | | | | | 1] 1.1 | 3] 0.224
| | | | | | | 2] 0.3

Evidence Table 233. Study results: ACTH4-9 (Org 2766)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 4w
Kragh-Sorensen 1986 | OC Analysis
| 1] Org 2766 5 mg vs Placebo | GAGS | | | | | | 1] <0.05
| 2] Org 2766 20 mg vs Placebo | SCAG total | | | | | | 1] <0.01
| 3] Org 2766 40 mg vs Placebo | | | | | | | 2] <0.09
| 4] Org 2766 80 mg vs Placebo | | | | | | | 3] <0.01
| | | | | | | | 4] <0.01
| | LPRS | | | | | | 4] <0.05

Evidence Table 234. Study results: ACTH 4-9 (Org 2766)

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 6m
Soininen 1985 | OC Analysis
| 1] Placebo vs ACTH 4-9 (Org 2766) | SCAG | | | | | 1] 0.8 CI (-6.8 to 5.1) | 1] NS
Partanen 1986 | | AGS-E | | | | | 1] -0.2 CI (-3.1 to 2.7) | 1] NS
| | LPRS | | | | | 1] 1.2 CI (-3.4 to 5.8) | 1] NS
Soininen 1984 | | McGBRS | | | | | 1] -0.0 CI (-2.4 to 2.4) | 1] NS
| | GPI-E | | | | | 1] -0.1 CI (-3.8 to 3.7) | 1] NS

Evidence Table 235. Study results: Prednisone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 1y
Aisen 2000b | ITT Analysis
Aisen 2000a | 1] Placebo change from baseline | [underlined: ADAS-Cog] | | | | | 1] 6.3 (6.4) | 3] 0.16
| 2] Prednisone 20 mg decreasing change from baseline | | | | | | 2] 8.2 (7.8)
| 3] Difference between Placebo and Prednisone in change from baseline | CDR-SB | | | | | 1] 2.2 (1.8) | 3] 0.07
| | | | | | | 2] 2.9 (2.5)
| | BDRS | | | | | 1] 1.7 (1.9) | 3] 0.60
| | | | | | | 2] 1.7 (2.1)
| | HAM-D | | | | | 1] 0.7 (3.6) | 3] 0.25
| | | | | | | 2] 1.7 (4.5)
| | BPRS | | | | | 1] 2.0 (6.6) | 3] 0.003
| | | | | | | 2] 5.4 (8.2)

Evidence Table 236. Study results: Simvastatin

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 26w
Simons 2002 | OC Analysis
| 1] Placebo | MMSE | 1] 17.1 (4.9) | | | | 1] 14.4 (5.6) | 3] <0.05
| 2] Simvastatin 80 mg/d | | 2] 17.8 (5.0) | | | | 2] 17.2 (4.8) | 4] NS
| 3] Placebo change from baseline | | | | | | | 5] <0.02
| 4] Simvastatin change from baseline | ADAS-cog | 1] 33.2 (11.3) | | | | 3] 3.4 (7.0) | 3] NS
| 5] Simvastatin vs. Placebo | | 2] 29.4 (10.4) | | | | 4] 4.1 (6.5) | 4] NS
| | | | | | | | 5] NS

Evidence Table 237. Study results: Thiamine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6m | | Final: (specify) 12m
Nolan, 1990 | Completers Analysis
| 1] Lactose placebo | [underlined: MMSE] | 1] 16.0 (5.7) | | 1] 16.4 (7.7) | 3] <.05 | 1] 14.6 (7.09) | 3] <0.05
| 2] Thiamine 3 g/ d | | 2] 16.6 (5.73) | | 2] 13.4 (7.2) | | 2] 10.4 (9.13)
| 3] Change from baseline across groups | Verbal Learning Score | | | | | | 3] <0.05
| | BNT | | | | | | 3]<0.05

Evidence Table 238. Study results: Vincamine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 6w | | Final: (specify) 12w
Fischhof 1996 | OC Population
| 1] Placebo DAT | CGI | 1] 5.0 (0.3) | | | 5] <0.05 | 1] 4.6 (0.8)
| 2] Placebo MID | | 2] 4.9 (0.4) | | | | 2] 4.9 (0.7)
| 3] Vincamine 30 mg/d DAT | | 3] 5.0 (0.0) | | | | 3] 2.8 (1.0)
| 4] Vincamine 30 mg/d MID | | 4] 5.0 (0.2) | | | | 4] 3.7 (1.1)
| 5] Vincamine vs Placebo | CGI Total Improvement | | | | | 6] 25% | 5] <0.05
| 6] All Placebo | | | | | | 7] 72% | 8] <0.05
| 7] All Vincamine | | | | | | | 9] <0.05
| 8] Placebo vs Vincamine DAT | CGI Worse | | | | | 6] 7%
| 9] Placebo vs Vincamine MID | | | | | | 7] 3%
| | SCAG | 1] 69.0 (7.4) | | | 5] <0.05 | 1] 67.9 (8.0)
| | | 2] 70.1 (6.5) | | | | 2] 68.1 (7.5)
| | | 3] 68.8 (7.2) | | | | 3] 62.1 (8.5)
| | | 4] 68.3 (7.0) | | | | 4] 63.4 (6.7)
| | BGP Need for help | 1] 15.0 (9.1) | | | | 1] 14.2 (9.0)
| | | 2] 12.5 (9.0) | | | | 2] 12.3 (8.7)
| | | 3] 12.3 (8.8) | | | | 3] 10.4 (8.8)
| | | 4] 12.9 (9.1) | | | | 4] 11.0 (8.3)
| | SKT | 1] 17.5 (3.3) | | | 5] <0.05 | 1] 17.5 (3.6)
| | | 2] 17.6 (2.8) | | | | 2] 17.2 (3.1)
| | | 3] 17.8 (2.6) | | | | 3] 14.8 (4.4)
| | | 4] 18.1 (2.6) | | | | 4] 14.8 (4.4)

Evidence Table 239. Study results: Piracetam

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12m
Croisile 1993 | OC Analysis
| 1] Placebo | MMSE | 1] 19.31(3.32) | | | | 1] 16.4(6.60) | 3] <0.05
| 2] Piracetam 8g/d | | 2] 19.21 (3.98) | | | | 2] 18.10(5.70) | 4] NS
| 3] Placebo difference from baseline | | | | | | | 5] NS
| 4] Piracetam difference from baseline | MADRS | 1] 5.75(3.45) | | | | 1] 7.88(5.68) | 3] NS
| 5] Placebo vs Piracetam | | 2] 9.50(6.82) | | | | 2] 10.14(7.61) | 4] NS
| | | | | | | | 5] NS
| | Blessed A | 1] 4.28(3.34) | | | | 1] 7.72(5.47) | 3] <0.01
| | | 2] 4.96(3.72) | | | | 2] 6.46(4.51) | 4] <0.05
| | | | | | | | 5] NS
| | Aphasia Battery | 1] 1.76(1.94) | | | | 1] 6.15(7.68) | 3] <0.01
| | | 2] 1.67(1.75) | | | | 2] 3.41(4.88) | 4] NS
| | | | | | | | 5] NS
| | Logical Digit Span | 1] 14.69(4.21) | | | | 1] 10.88(6.16) | 3] <0.05
| | | 2] 12.36(4.65) | | | | 2] 11.50(5.37) | 4] NS
| | | | | | | | 5] NS

Evidence Table 240. Study results: Xantinolnicotinate

REF ID# | Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | | Baseline | | Mid-Point: (specify) | | Final: (specify) 12w
| Kanowski 1990 | OC Population
| | 1] Placebo SDAT subgroup | [underlined: CGI] | | | | | 1] 5.6 | 5] <0.001
| | 2] Xantinolnicotinate 1g tid SDAT subgroup | | | | | | 2] 4.6 | 6] <0.002
| | 3] Placebo MID subgroup | | | | | | 3] 5.3 | 7] <0.001
| | 4] Xantinolnicotinate 1g tid MID subgroup | | | | | | 4] 4.5 | 8] <0.001
| | 5] difference between Placebo and Xantinolnicotinate SDAT subgroup | SCAG Decrease in mean value | | | | | 1] 2.1% | 5] <0.0001
| | 6] difference between Placebo and Xantinolnicotinate MID subgroup | | | | | | 2] 10.1% | 6] <0.0002
| | 7] Xantinolnicotinate SDAT change from baseline | | | | | | 3] 1.7%
| | 8] Xantinolnicotinate MID change from baseline | | | | | | 4] 9.8%
| | | BGP | | | | | | 5] NS
| | | | | | | | | 6] NS
| | | Digit Connection Test | | | | | | 5] <0.001
| | | | | | | | | 6] <0.001
| | | Digit Symbol Substitution test | | | | | | 5] <0.01
| | | | | | | | | 6] <0.03

Evidence Table 241. Study results: Donepezil (DPZ) - Vitamin E

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 3m | | Final: (specify) 6m
Thomas 2001 | OC Analysis
| 1] DPZ 10 mg d | WAIS | 1] 72 (2.0)* | | 1] 74 (2.0)* | | 1] 75 (2.0)* | 3] 0.15
| 2] Vitamin E 2,000 IU | | 2] 72 (2.0)* | | 2] 72 (2.0)* | | 2] 71 (2.1)* | 4] 0.43
| 3] change from baseline with DPZ | MMSE | 1] 16 (0.5)* | | 1] 16 (0.6)* | 5] <0.001 favors DZP | 1] 16 (0.5)* | 3] 0.06
| 4] change from baseline with Vitamin E | | 2] 16 (0.5)* | | 2] 15 (0.5)* | | 2] 15 (0.6)* | 4] 0.07
| 5] DPZ vs Vitamin E change from baseline | | | | | | | 5] <0.001 favors DPZ
| | ADAS-cog | 1] 33.34 (2.7)* | | 1] 31.55 (2.7)* | | 1] 31.84 2.7)* | 3] <0.001
| | | 2] 33.45 (2.6)* | | 2] 36.09 (2.8)* | | 2] 39.07 (2.7)* | 4] <0.01
| | NPI | 1] 21.9 (0.5)* | | | | 1] 16.8 (0.2)*
| | | 2] 21.9 (0.5)* | | | | 2] 22.8 (1.2)*

* SEM

Evidence Table 242. Study results: Fluoxetine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 30d | | Final: (specify) 45d
Taragano 1997 | OC Analysis
| 1] Fluoxetine 10 mg/d | Ham-D | 1] 25.3 (3.8) | 3] 0.10 | 1] 19.3 (3.2) | 3] 0.10 | 1] 16.7 (2.9) | 3] 0.10
| 2] Amitriptyline 25 mg/d | | 2] 26.3 (4.0) | | 2] 17.8 (2.5) | | 2] 15.6 (3.2)
| 3] Between treatments | MMSE | 1] 20.0 (3.2) | 3] 0.10 | | | 1] 21.4 (2.9) | 3] 0.10
| | | 2] 18.8 (4.2) | | | | 2] 21.5 (3.5)

Evidence Table 243. Study results: 5′-MTHF - Trazodone

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 4w | | Final: (specify) 8w
Passeri 1992 | OC Analysis
| 1] 5′-MTHF 50 mg/d | HDRS | 1] 23 (5) | | 1] 20(6) | 3] <0.01 | 1] 18 (6) | 3] <0.01
| 2] Trazodone 100mg/d | | 2] 23 (3) | | 2] 21 (4) | 4] <0.05 | 2] 19 (5) | 4] <0.01
| 3] 5′-MTHF change from baseline | | 5] 23 (5) | | 5] 21 (6) | 7] <0.01 | 5] 18 (6) | 7] <0.01
| 4] Trazodone change from baseline | | 6] 23 (4) | | 6] 21 (5) | 8] <0.01 | 6] 19 (6) | 8] <0.01
| 5] 5′-MTHF subgroup AD | | 9] 21 (5) | | 9] 17 (7) | | 9] 18 (5) | 11] <0.01
| 6] Trazodone subgroup AD | | 10] 23 (3) | | 10] 22 (2) | | 10] 20 (3)
| 7] 5′-MTHF change from baseline subgroup AD | RVM immediate recall | 1] 20 (7) | | | | 1] 23 (8) | 3] <0.01
| 8] Trazodone change from baseline subgroup AD | | 2] 22 (9) | | | | 2] 22 (9) | 7] <0.01
| 9] 5′-MTHF subgroup MID | | 5] 20 (7) | | | | 5] 23 (7)
| 10] Trazodone subgroup MID | | 6] 22 (9) | | | | 6] 22 (8)
| 11] Trazodone change from baseline subgroup MID | | 9] 20 (8) | | | | 9] 22 (7)
| | | 10] 20 (8) | | | | 10] 22 (11)
| | RVM delayed recall | 1] 2 (2) | | | | 1] 3 (2)
| | | 2] 3 (2) | | | | 2] 3 (2)
| | | 5] 3 (2) | | | | 5] 3 (2)
| | | 6] 3 (2) | | | | 6] 3 (2)
| | | 9] 2 (2) | | | | 9] 3 (2)
| | | 10] 4 (2) | | | | 10] 3 (2)

Evidence Table 244. Study results: Citicoline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 45 d | | Final: (specify) 90 d
Parnetti 1994 | OC Population
| 1] Placebo (Ascorbic Acid 100 mg/d) | [underlined: GBS] Emotional impairment | 1] 1.9 (1.0) | | 1] 1.8 (1.0) | | 1] 1.9 (1.0) | 4] NS
| 2] Citicoline 500 mg/d | | 2] 1.9 (1.0) | | 2] 1.9 (1.1) | | 2] 1.7 (1.0) | 5] NS
| 3] Posatirelin 10 mg/d | | 3] 1.9 (1.2) | | 3] 1.7 (1.0) | | 3] 1.6 (0.9) | 6] <0.025
| 4] Ascorbic Acid change from baseline | [underlined: GBS] Impaired orientation & memory | 1] 2.2 (0.9) | | 1] 2.1 (1.0) | | 1] 2.1 (1.1) | 4] NS
| 5] Citicoline change from baseline | | 2] 2.2 (1.0) | | 2] 2.1 (1.0) | | 2] 2.1 (1.0) | 5] NS
| 6] Posatirelin change from baseline | | 3] 2.1 (1.0) | | 3] 2.0 (1.0) | | 3] 1.8 (1.0) | 6] NS
| 7] Posatirelin vs Citicoline change from baseline | | | | | | | 7] 0.038 favors Posatirelin
| | [underlined: GBS] Impaired ability | 1] 1.2 (0.8) | | 1] 1.3 (0.8) | | 1] 1.3 (0.9) | 4] NS
| | ADL | 2] 1.4 (1.1) | | 2] 1.3 (1.0) | | 2] 1.4 (1.0) | 5] NS
| | | 3] 1.2 (1.0) | | 3] 1.1 (1.0) | | 3] 1.1 (1.0) | 6] <0.025
| | [underlined: GBS] Depression / Anxiety | 1] 1.5 (0.9) | | 1] 1.5 (0.9) | | 1] 1.4 (0.9) | 4] NS
| | | 2] 1.5 (0.8) | | 2] 1.5 (0.9) | | 2] 1.4 (0.9) | 5] NS
| | | 3] 1.6 (1.1) | | 3] 1.5 (1.0) | | 3] 1.4 (0.9) | 6] NS
| | | | | | | | 7] 0.031 favors Posatirelin
| | [underlined: GBS] Impaired attention & motivation | 1] 2.2 (0.9) | | 1] 2.1 (0.9) | | 1] 2.1 (1.0) | 4] NS
| | | 2] 2.1 (1.0) | | 2] 2.0 (1.0) | | 2] 1.9 (1.0) | 5] NS
| | | 3] 2.1 (1.1) | | 3] 1.9 (0.9) | | 3] 1.8 (0.8) | 6] <0.025
| | [underlined: GBS] Intellectual impairment | 1] 2.2 (0.8) | | 1] 2.1 (0.9) | | 1] 2.1 (1.0) | 5] <0.025
| | | 2] 2.1 (0.9) | | 2] 2.0 (0.9) | | 2] 2.0 (0.9) | 7] 0.037 favors Posatirelin
| | | 3] 2.0 (0.9) | | 3] 1.9 (0.9) | | 3] 1.8 (0.8)
| | [underlined: GBS] Motor impairment | 1] 1.2 (0.8) | | 1] 1.3 (0.8) | | 1] 1.3 (0,9) | 5] <0.025
| | | 2] 1.4 (1.1) | | 2] 1.3 (1.0) | | 2] 1.4 (1.0)
| | | | | 3] 1.1 (1.0) | | 3] 1.1 (1.0)
| | MMSE | 1] 16.4 (2.7) | | | | 1] 17.1 (4.1) | 4] NS
| | | 2] 16.5 (2.6) | | | | 2] 17.6 (3.9) | 5] NS
| | | 3] 16.6 (2.5) | | | | 3] 17.8 (3.4) | 6] NS
| | HDRS | 1] 13.0 (5.0) | | | | 1] 11.4 (4.9) | 4] NS
| | | 2] 11.4 (4.9) | | | | 2] 11.3 (5.2) | 5] NS
| | | 3] 12.6 (5.0) | | | | 3] 11.1 (5.3) | 6] NS

Evidence Table 245. Study results: Pyritinol - Hydergine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P value | Result Value | P value | Result Value | P value
| | | Baseline | | Mid-Point: (specify) 6w | | Final: (specify) 12w
Spilich 1996 | OC Analysis
| 1] Pyritinol 600 mg/d | SCAG | 1] 27.0 | | 1] 22.5 | 3] 0.14 | 1] 16.5 | 3] 0.008 favors Pyritinol
| 2] Hydergine 4.5 mg/d | | 2] 28.0 | | 2] 25.0 | | 2] 22.0
| 3] Between drugs vs baseline | CETM | 1] 13.0 | | 1] 17.0 | | 1] 19.8 | 4] <0.001
| 4] Pyritinol change from baseline | | 2] 14.8 | | 2] 17.8 | | 2] 17.0 | 5] <0.002
| 5] Hydergine change from baseline

Evidence Table 246. Study results: Sulfomucopolysaccharides - Cytidine Diphosphocholine

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 2w | | Final: (specify) 4w
Cucinotta 1987 | OC Analysis
| 1] Sulphomucopolysaccharides 500 units | SCAG | 1] 35.35(1.32)* | | 1] 32.28(1.28)* | | 1] 31.61(1.94)* | 3] <0.05 favors Sulphomucopolysaccharides
| 2] CDP-choline 1.0g | | 2] 36.00(1.55)* | | 2] 35.00(1.38)* | | 2] 35.58(1.56)*
| 3] difference between Sulphomucopolysaccharides and CDP-choline | NMS | 1] 16.71(0.59)* | | 1] 16.14(0.54)* | | 1] 15.45(0.66)* | 3] <0.02 favors Sulphomucopolysaccharides
| | | 2] 17.93(0.56)* | | 2] 17.80(0.49)* | | 2] 18.08(0.71)*
| | Digit Symbol | 1] 44.66(6.84)* | | | | 1] 65.77(9.46)* | 3] <0.05 favors Sulphomucopolysaccharides
| | | 2] 47.41(4.99)* | | | | 2] 52.00(6.44)*
| | Digit Span | 1] 6.72 (0.33)* | | | | 1] 6.90 (0.34)* | 3] NS
| | | 2] 5.91 (0.42)* | | | | 2] 6.25 (0.44)*

* SEM

Evidence Table 247. Study results: Sulodexide - Pentoxifylline

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 4m | | Final: (specify) 6m
Parnetti, 1997 | OC Analysis
| 1] Sulodexide 50 mg bid | [underlined: GBS motor impairment] | 1] 1.64 (0.14)* | | 1] 1.58 (0.14)* | 3] <0.01 | 1] 1.54 (0.16)* | 3] <0.01
| 2] Pentoxifylline 400 mg tid | | 2] 1.59 (0.13)* | | 2] 1.53 (0.14)* | | 2] 1.46 (0.17)*
| 3] sulodexide change vs baseline | [underlined: GBS intellectual impairment] | 1] 2.09 (0.09)* | | 1] 1.88 (0.09)* | 3] <0.01 | 1] 1.79 (0.1)* | 3] <0.01
| | | 2] 1.98 (0.08)* | | 2] 1.95 (0.1)* | | 2] 1.87 (0.12)*
| | [underlined: GBS emotional impairmen] | 1] 2.1 (0.12)* | | 1] 1.88 (0.12)* | 3] <0.12 | 1] 1.76 (0.12)* | 3] <0.01
| | | 2] 1.89 (0.1)* | | 2] 1.9 (0.1)* | | 2] 1.75 (0.11)*
| | MMSE | 1] 17.6 (0.4)* | | | | 1] 20 (0.6)*
| | | 2] 18 (0.4)* | | | | 2] 20 (0.4)*

* SEM

Evidence Table 248. Study results: Selegiline - Vitamin E

Author Year | Analysis Groups | Outcomes Measured | Result Value | P Value | Result Value | P Value | Result Value | P Value
| | | Baseline | | Mid-Point: (specify) 10m | | Final: (specify) 20m
Sano 1997 | ITT Analysis
Thal 1996 | 1] Placebo | [underlined: Event-free survival] | | | 1] 79% | | 1] 40% | 5] 0.077
| 2] Vitamin E 1000IU bid | | | | 2] 86% | | 2] 51% | 6] 0.087
| 3] Selegeline 5mg bid | | | | 3] 60% | | 3] 60% | 7] 0.21
| 4] Vitamin E 1000IU bid + Selegiline 5mg bid | | | | 4] 80% | | 4] 49%
| 5] Vitamin E 1000IU bid vs Placebo from baseline | Event-free survival with MMSE as covariate | | | | | | 5] 0.001
| 6] Selegeline 5mg bid vs Placebo from baseline | | | | | | | 6] 0.012
| 7] Vitamin E 1000IU bid + Selegiline 5mg bid vs Placebo from baseline | | | | | | | 7] 0.049

Evidence Table 249. Adverse Events: Other agents

Adverse events (AE) indentified in included studies | ANIRACETAM Senin, 1991 | ATEROID Ban, 1991b | BMY 21, 502 Shrotriya, 1996 | CBM 36-733 Danielczyk, 1988 | CHOTO-SAN Shimada, 1994 | CHOTO-SAN Terasawa, 1997 | DEK Cucinotta, 1996 | VASOPRESSIN (DDAVP) Peabody, 1986 | DENBUFYLLINE Treves, 1999 | NIMODIPINE Ban, 1990 | NIMODIPINE Pantoni, 2000a | NIZATIDINE Carlson, 2002 | ORG 2766 Soinninen, 1985 | ORG 2766 Kragh-Sorensen, 1986 | PIRACETAM Croisile, 1993 | THIAMINE Nolan, 1991 | BUFLOMEDIL Cucinotta, 1992 | CYCLANDELATE Weyer, 2000 | CYCLANDELATE Schellenberg, 1997 | GUANFACINE Crook, 1992b | HYDERGINE Spilich, 1996 | HYDERGINE Thompson, 1990 | VINCAMINE Fischhof, 1996 | XANITOLNICOTINATE Kanowski, 1990 | PENTOXIFYLLINE Parnetti, 1997 | N-ACETYLCYSTEINE Adair 2001 | GM-1 Ala, 1990 | LYCOSAMINO GLYCAN-OLYSULPHATE Ban, 1991a | DESFERRIOXAMINE Crapper, McLachlan, 1991 | SIMVASTATIN Simmons, 2002 | POSATIRELIN Parnetti, 1995 | 5′-MTHF (T) TRADOZONE (C) Passeri, 1993 | PREDNISONE Aisen, 2000b | NIMESULIDE Aisen, 2002 | DICLOFENAC ISOPROSTOL Scharf, 1999 | INDOMETHACIN Rogers, 1993 | HYDROXY-CHLOROQUINE Van Gool, 2001 | FLUOXETINE AMITRIPTYLINE Taragano, 1997 | SULFOMUCOPOLYSACCHARIDE S CDP-CHOLINE Cucinotta, 1988 | DONEPEZIL Thomas, 2001 | SELEGILINE VITAMIN E Sano, 1997
Withdrawn (%) due to AE | T: 0 | T: 1 | T:24 | T: 3 | T: 3 | T: 7 | T: 4 | T: 0 | T:21 | T: 1 | T: 0 | T: NR | T:0 | T:NR | T: 0 | T:0 | T:NR | T: 7 | T: 9 | T: 0 | T: | T: 0 | T:NR | T: 0 | T: 7 | T: 0 | T:10 | T: 1 | T: 0 | T: 8 | T: 0 | T: 0 | T:0 | T:5 | T:46 | T:42 | T:0 | T: 58 | T: | T: 0 | T:0
| C: 0 | C: 2 | C: 9 | C: 5 | C: 0 | C: 3 | C: 2 | C: 0 | C: 16 | C: 0 | C: 0 | C:NR | C:0 | C:NR | C:0 | C:0 | C:NR | C: 6 | C: 6 | C: 0 | C: | C: 0 | C:NR | C: 0 | C:6 | C:0 | C: 0 | C:4 | C: 0 | C:0 | C:0 | C: 0 | C:0 | C:5 | C: 6 | C:30 | C:0 | C:22 | C: | C: 0 | C:0
AE Checklist (Max 5) | 3 | 2 | 3 | 4 | 3 | 2 | 3 | 2 | 2 | 5 | 4 | 3 | 2 | 5 | 3 | 0 | 1 | 3 | 3 | 0 | 4 | 1 | 3 | 3 | 2 | 2 | 3 | 5 | 3 | 2 | 4 | 3 | 3 | 5 | 2 | 2 | 0 | 3 | | 3 | 1
None Reported | | | | | | | | | | | | | | x | | x | x | | | x | | | | | | | | | | | | | | | | | | | | X
Balance | | | | | | | | | x | | | | | | | | | | | | | | x | x | | | | | | | | x | | | | | | | | | S*
Accidental Injury
Dizziness | | | x | x | | | | | | | | | | | | | | | | | | | | x | | X | | | | | | | | X
Falls | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | S*
Behavioral | x | | | | | | | | | | | | | | | | | | | | | | | | | X | | | | | | | | X | X | X
Agitation | | | | | | | x | | | | | | | | | | | | | | | | | | | | X | | | | X
Cardiovascular | x | x | | NS | | | x | | | NS | NS | x | | | | | | | | | x | | | | X | | X | X | | | | | | | | | | | | | NS*
Arrhythmia | | | x | x | | | x | | | NS | | | | | | | | | | | | | | | | | | | | | X
Hypotension | | | | | | | x | | | NS | | | | | | | | | | | | | x
Hypertension | | | | NS | | x
Extrapyramidal | | | | | | | | | | | x | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | NS*
Tremor | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | X
Gastrointestinal | | x | | | | | x | | | NS | x | | | | x | | | | x | | | | | | | | | X | | | | | | X | | X | | | | | NS*
Abdominal pain | x | | | | | | | | | | | | | | | | | | | | | | | | X | | | | | | | | | S | X
Constipation | | | | | | | | | | | | | | | x | | | | | | | | | | | | | X | | | | | X | S | | | | X
Diarrhea | | | | | | x | x | | | NS | | | | | | | | | x | | | | x | | | X | | | | | | | | | | | | X
Dyspepsia | | | x | | | x | x | | x | | | | | | | | | | | | | | | | | | | | | | X
Nausea, vomiting | x | | | | | | x | | x | NS | | | | | | | | | x | | | | x | x | | | | | | | | | | X | | | X | X
Metabolic/nutritional | | | | | | x | | | | | | | | | | | | x | | | | | | | | X | | X
Eating disorder | | | | | | | | | | NS | | | | | | | | | | | | | | | | | | | X
Weight Change | | | | | | | | | | | | | NS | | NS | | | | | | | | | | | | | | X
Neurological | | x | x | x | | x | | | x | | S | x | | | | | | | | | | | | | | | | | | | | | | | | X | | | | | NS*
Asthenia | | | | | | | | | | | | | | | | | | | | | | | | | X
Psychiatric | | | | | | | | | | | x
Anxiety | | | x | x | | | x | | | | | | | | | | | | | | | | x
Confusion, delirium | | | x | | | | x | x | | | | | | | | | | | | | | | | x | | | X | | | | X | | | | | | | X
Depression | | | | | | | | | | | | | | | | | | | x
Respiratory | | | | x | | | | | x | | x
Cough, cold, infection
Rhinitis | | | x
Other | | | x | | | | x | | x | | x | | | | | | | | x | | | x | | x | | X | | X | | X | X | x | S | | | X | X | | | | S*
Aberrant hematology | | | | | x | | | | | | x | | S | | NS | | | | | | | | | | | | | | | | | | | X | X
Fatigue, weakness | | | | | | | | | | | | | | | | | | | | | | | | x | | X
Fever, flu, pneumonia | | | | | | x
Headache | | | x | | | | x | | | NS | | | | | | | | | x | | | | | x | X | X | X | | | | X | | X | | | X | X
Hepatic abnormality | x | | x | | | x | | | | | | | | | | | | | | | | | | | | | | | | | | | S | X | X
Muscle/joint disorder | | | | | | | | | | | | | | | | | | | | | | | | | | X | | | | X
Pain | | | | | | | x | | | | | | | | | | | | | | | | | | | | X
Rash, skin disorder | | | | | | | x | | | | x | | | | | | | | | | | | | x | | X | X | | | | X | | | S | | | | | | | NS*
Sleep disorder | x | | | | | | | | | NS | | | | | | | | | | | | | x | | | X | X | | | | X
Urinary disorder | | | | x | | x | x | | x | | x | | | | | | | x | | | | | | | | | X | | | | X | | S | X

NR = Withdrawals due to AE Not Reported;

+ = Dose response effect on AE

x = Reported adverse event/side effect but not tested for significant differences between groups

S or NS = Reported and tested for statistical differences between placebo and treatment group

S* or NS* = Reported and tested for statistical differences between two (three) treatment groups

[ ] = Symptom NOT reported in the paper

Guide to the Results Tables

The results from all of the studies have been recorded in the following tables, which have been organized according to the intervention used in the trial. There are three sections:

1. Cholinergic neurotransmitter modifying agents (CNMA)
2. Non-cholinergic neurotransmitter/neuropeptide modifying agents (NCNNM)
3. Other pharmacological agents (OTHER)

Within each category, the results for drugs with three or more trials included are grouped together and presented in alphabetical order by drug name. There is a table showing the characteristics of the all of the studies using the drug. This table is followed by a separate table for each of the studies using that drug which shows the detailed results reported. These detailed tables are followed by a table containing adverse event information about each of the studies using that particular drug. Where there are only one or two trials included which use a drug, the tables for these studies are grouped together as various in tables as described above.

Following is a list of all of the drugs found in this review and the section in which they can be found. The drugs are ordered alphabetically within their section.

INTERVENTION | DRUG GROUP
5′-MTHF (FOLATE) | OTHER
ALAPROCLATE | NCNNM
ALPRAZOLAM | NCNNM
AMITRIPTYLINE | OTHER
ANAPSOS | NCNNM
ANIRACETAM | CNMA
ANTAGONIC STRESS | CNMA
ATEROID | OTHER
BMT | OTHER
BMY(NOOTROPIC) | NCNNM
BUFLOMEDIL | OTHER
CARBAMAZEPINE | CNMA
CARNITINE | CNMA
CEREBROLYSIN | OTHER
CHOTO-SAN (HERB) | OTHER
CITALOPRAM | NCNNM
CITICOLINE | OTHER
CYCLANDELATE | OTHER
DENBUFYLLINE | OTHER
DESFERRIOXAMINE (DFO) | OTHER
DICLOFENAC/MISOPROSTOL | OTHER
DIPHENHYDRAMINE | NCNNM
DIVALPROEX | NCNNM
DONEPEZIL | CNMA
EPTASTIGMINE | CNMA
ERGOKRYPTINE DEK (DIHYDROERGOKRYPTINE) | OTHER
ESTROGENS | OTHER
FLUOXETINE | NCNNM
FLUVOXAMINE | NCNNM
GALANTAMINE | CNMA
GINKO BILOBA | OTHER
GLYCOSAMINOGLYCAN POLYSULFATE | OTHER
GUANFACINE | OTHER
HALOPERIDOL | NCNNM
HUPERZINE-A | CNMA
HYDERGINE | OTHER
HYDROXYCHLOROQUINE | OTHER
IDEBENONE | OTHER
IMIPRAMINE | NCNNM
INDOMETHACIN | OTHER
LINOPIRIDINE | CNMA
LISURIDE | NCNNM
LORAZEPAM | NCNNM
LOXAPINE | NCNNM
LU25-109 | NCNNM
MAPROTILINE | NCNNM
MECLOFENOXATE | CNMA
MELPERONE | NCNNM
MEMANTINE | NCNNM
METRIFONATE | CNMA
MIANSERIN | NCNNM
MINAPRINE | NCNNM
MOCLOBEMIDE | NCNNM
MONOSIALOTETRAHEXOSYLGANGLIOSIDE (GM1) | OTHER
N-ACETYLCYSTEINE NAC | OTHER
NAFTIDROFURYL | NCNNM
NICERGOLINE | CNMA
NIMESULIDE (NSAID) | OTHER
NIMODIPINE | OTHER
NIZATIDINE | OTHER
NOOTROPIC | OTHER
OLANZAPINE | NCNNM
ORG 2766 | OTHER
OXAZEPAM (Benzodiazapine) | NCNNM
OXIRACETAM | OTHER
PAROXETINE | NCNNM
PENTOXYFYLLINE | OTHER
PERPHENAZINE | NCNNM
PHOSPHATIDYLSERINE | NCNNM
PHYSOSTIGMINE | CNMA
PIRACETAM | OTHER
POSATIRELIN | CNMA
PREDNISONE | OTHER
PROPENTOFYLLINE | OTHER
PYRITINOL | OTHER
RISPERIDONE | NCNNM
RIVASTIGMINE | CNMA
SABELUZOLE | CNMA
SELEGILINE (DEPRENYL) | NCNNM
SERTRALINE | NCNNM
SIMVASTATIN | OTHER
SULFOMUCOPOLYSACCHARIDES | OTHER
SULODEXIDE | OTHER
TACRINE | CNMA
THIAMINE | OTHER
THIORIDAZINE | NCNNM
TIAPRIDE | NCNNM
TRAZODONE | NCNNM
VASOPRESSIN (DDAVP) | OTHER
VELNACRINE | CNMA
VINCAMINE | OTHER
VITAMIN E | OTHER
XANOMELINE | NCNNM
XANTINOLNICOTINATE | OTHER