# Appendix B Forms

[underlined: USING THE FORM]

a. Be sure to fill in the [underlined: DM ID#], the [underlined: Name of the First Author] and [underlined: Your Initials] in the three boxes at the top right of the form.
b. If a paper should be excluded, fill in the “EXCLUDE” box and fill in the box for the reason for exclusion that occurs first in the list of 7 reasons for exclusion.
c. The boxes for “KEEP ANYWAY as SPECIAL' or "should check for full article” can also be checked if it is an excluded article but may be useful to our review as background or clarification of it appears to be a companion paper for another report that is likely in our review.
d. If you choose to exclude the paper, the details for included papers do not need to be filled in.
e. If a paper should be included, fill in the “INCLUDE” box and fill in the information for ONLY TWO of the subsequent categories listed: Diagnosis of interest and Treatments randomized. Ignore Population analyzed, Outcomes reported and Other........we may use them later for grouping.
f. If you are not sure if a paper qualifies for inclusion and want it to be looked at by our clinicians or methodologists, mark “CONSULTATION REQUIRED”
g. If a paper is excluded because the Dementia population is not defined by DSM, NINCDS OR ICD-10 criteria, save it for consultation and mark "population' beside the Consultation Required box.

EXCLUDING ARTICLES

1. Complete report must be in English to be included. If there is only an English abstract, exclude the article.
2. Only full reports will be included. If the article is a letter, comment, editorial, news, abstract, proceedings of a meeting or any other brief description, exclude the article. If it seems that the study would otherwise be included, check the box “Should check for full article”.
3. All dementia populations will be accepted at this stage if they are documented by DSM III, DSM III-R, DSM IV, NINCDS-ADRDA, ICD-9, ICD-10. The population studied may include those with mild cognitive impaired (MCI), cognitive impairment, not Dementia (CIND), cognitive loss, not Dementia (CLOND). If the author cites the article by McKhann as the criteria for diagnosis, it can be included because that is the criteria for NINCDS.
4. Articles included should look at treatment of disease, cognition, behaviour, or quality of life, time to deterioration, depression, falls etc. Exclude if outcomes reported are ONLY neurophysiologic or neuroimaging (eg EEG)
5. Exclude if not a report of a randomized controlled trial.
6. Outcomes reported should be for subjects with Dementia. If the entire population does not have Dementia, only data sub-grouped for Dementia will be examined. Exclude if there are no outcomes of interest reported for specifically Dementia subjects.
7. Any previously unmentioned, compelling reason to exclude the study should be specified.

[underlined: INCLUDING ARTICLES]

1. If you are unclear about whether the diagnosis is an included one, mark the referral box and pass along for a consult. If entire population is demented, mark boxes for all specific diagnoses included in [underlined: study outcomes]. If not all of population is demented, mark boxes for all specific diagnoses included in subgroup analysis of outcomes. If diagnosis is not listed as a choice, but is an included diagnosis, specify on line provided.
2. Specify treatments if they were randomly provided to the dementia population.

[underlined: DETAIL ABOUT DISEASE TERMS (terms from the literature search)]

NOT

- Not normal or healthy volunteers
- Not general population of elderly persons
- Not selected for depression (some may have dementia but not all)…BUT… If subgroup analysis may have been done, it should be marked “Retrieve”.

INCLUDE

- Alzheimer's disease by DSM, NINCDS OR ICD
- Dementia defined by DSM, NINCDS OR ICD
- MCI - mild cognitive impairment
- CIND - cognitive impairment, not Dementia
- CLOND - cognitive loss, not Dementia

*Keep articles aside in a group if the intervention is directed toward the caregiver or caregiver/patient dyad.

[image]

[image]

Table A Key Characteristics

REF ID # | Author Year | Funding Source | Quality Score | Interventions | Criteria for Diagnosis | Diagnosis | Disease Severity | Total Number Randomized | Number Completing Trial | Mean age (range) % Male (M) Population | Highest Dose | Treatment Period | Outcomes Measured | Outcome reports stratified by patient characteristic

GUIDE TO DATA EXTRACTION TABLE

REF ID # | Enter number written on top of first page of article.
Author / Year | Enter last name of first author on one line and year of publication on the second line.
Funding Source | Enter one of the following codes: IF (Industry Funded) PI (Partially funded by Industry) IS (Industry provided Supplies) NI (Non-Industry funding source) NR (not reported) Use more than one code if necessary.
Quality score | Enter the Modified Jadad score for Alzheimer's Disease (out of 8 points)
Interventions | Enter name of drugs used in trial. Use the most commonly recognized name (eg use Tacrine instead of generic name). If more than one drug is used, put one on each line. If a dose response trial is reported, treat as one drug at the highest dose. If placebo is used, enter as first drug.
Criteria for Diagnosis | Indicate what criteria were used for diagnosis. It should be one of NINCDS, DSMIII, DSMIII-R, DSMIV, ICD-10
Diagnosis | Enter all dementia diagnoses included in the trial.
PDD = PRIMARY DEGENERATIVE DEMENTIA
MID = MULTI- INFARCT DEMENTIA
AD = DAT = SDAT = ALZHEIMER'S DEMENTIA
MIXED
VaD = VASCULAR DEMENTIA
DEMENTIA
Disease Severity | Use the descriptive terms as used in the paper.
Total Number randomized | Give the number in all groups that were initially randomized.
Number completing trial | Give the number in all groups that completed the treatment. If ITT population is given, report also.
Mean age (range) | Enter whatever information is given in paper for whole population
% Male (M) | Compute this figure if possible for those randomized at baseline
Population | Give any special inclusion criteria (or existing factor in population) which may affect the external validity (eg comorbid disorders, race, setting)
Highest Dose | Give the dose per day. If the dose was titrated up to individual doses, give the highest dose used and enter details of titration on the second line.
| Record as reported in paper - make sure to note if dose is by weight or a set amount and report how often given (preferably by day).
Treatment Period | This should be the length of time for which the subjects received drug treatment. Use the longest period if there is more than one. Note here if there is an open extension
Outcomes Measured | List all of the tests reported. If a battery of psychological tests were done, list the name of the battery.
| If physical tests are reported (e.g. blood tests, scans) list in very general terms (e.g. blood levels, EEG).
Outcome reports stratified by patient characteristic | Enter a Y if any of the data is reported in any way and is stratified by any patient characteristic (e.g. gender, age, race, genotype, education) and describe what the characteristic is. Otherwise, enter N.

Table B Evidence Results

DRUG
REF ID # | Author Year | Analysis Groups | Test Used | Result Value | P Value | Result Value | P Value | Result Value | P value
| | | | Baseline | | Mid-Point: (specify) | | Final: (specify) 24w
| | | | Baseline | | Mid-Point: (specify) | | Final: (specify)

GUIDE TO DATA EXTRACTION TABLE B

REF ID # | Enter number written on top of first page of article.
Author / Year | Enter last name of first author on one line and year on the second line
Analysis groups and | Use one line for each intervention that will be reported on. Number them as follows (1] 2] 3] )
Interventions | Make the Control condition # 1 and Drug treatment conditions # 2 and so forth.
| If results are reported as change or relationship between baseline and later time-points or between placebo and drug conditions, these will be added as additional Analysis Groups (e.g. [ 3] Baseline vs 28w Placebo) would be entered as the third Analysis Group and would be for the score that reports the change in value between the one at baseline and the one at 28 weeks for the placebo group. The Analysis Group [ 5] Placebo vs Tacrine 28w) would be the fifth Analysis Group and be used for the score that reports the change in value between the placebo condition and the drug condition at 28 weeks.
| If subgroup analysis has been reported, an Analysis Group can be created to report the results.
| For Analysis Groups that refer to the drug used, enter the name of drug used in trial. Use the most commonly recognized name (eg use Tacrine instead of generic name). If more than one drug is used, put one on each line. If variable dosing is used within an arm, report the higher dose. Put the Placebo condition first in the list
Test Used | List all psychological and functional tests used that have extractable data (cognition, behavior, functional, global). Do not report on physiological measurements such as blood levels. Enter the primary outcomes first in the list and bold the font on the test name.
Baseline, Mid-Point, Final | Enter number of hours, days, weeks, months, years from baseline measurement to current measurement. Use abbreviations (h = hours, d = days, w = weeks, m = months, y = years)
| If more than 3 time points given, use the most central one for Time 2.
Result Values | Enter the value for Mean ± Standard Deviation for each arm for each time-point for each test. If Standard Error is used, use an *.
| If % is used, enter the % sign after the value.
| If the test consists of subsections (eg a battery that also reports the total), just use the total score unless a sub-score is a primary outcome.
| Give P value if provided. If no P value available, but CI reported, put CI in P value column.

Overall Summary Table Interpretation

SC | = statistically significant CHANGE at the alpha = 0.05
| = based on the PRIMARY outcomes (no need to specify as 1° because this is the default). If the paper does not specify primary or secondary ASSUME primary for all reported outcomes
| = report secondary outcomes ONLY when there is NO primary variable for that domain AND indicate with (2°) in front of the result code
| = based on the ITT analyses results ONLY; if ITT results were not reported in the paper, then indicate with an asterick (*) located behind the result code (i.e. NS*)
| = this change is ONLY relative to placebo (within group findings are reported in Table B..so not necessary to recapitulate this in summary table)
| = in those instances where there is A PRIORI hypotheses for subgroup analyses and there are statistical results reported, then indicate with a symbol (i.e. # or ^) that the subgroup analyses were SC or NS and specify with respect to what factor (i.e. Vascular dementia versus not, or gender, etc)
NS | = not statistically significant effect for primary or secondary outcomes (some additional domains are tested with the secondary outcomes)
NT | = outcomes were not tested reflecting in this domain
MX | = mixed results for two primary outcomes (i.e one was significant and the other variable was not significant) and do not represent a SUBGROUP analysis
| = indicates that two measures within the same domain show conflicting results (one outcome is significant and the other is not significant)

Reporting Safety information in Randomized controlled trials (Ioannidis and Lau, 2002)

DOMAIN recommendation Ioannidis and Lau | OUR QUESTION | STATUS
FREQUENCY of WITHDRAWALS due to adverse events (AE) | Do the authors specify the number of patients withdrawn from the study due to AE per study arm and per type of AE that caused withdrawal | Y | N
| | Unclear
| | Y | N
| | Unclear
FREQUENCY of AE (can be stated as a count or as a proportion for either CLINICAL AE or LABORATORY-DEFINED TOXICITY) | Do the authors provide the number of AE with respect to severity (reference to a known scale of toxicity such as mild, moderate, severe, life threatening or grades 1 to 3, etc) per study arm and per type of specific AE (i.e. diarrhea, headache, etc) | Y | N
| | Unclear
| | Y | N
| | Unclear
Was the recording of the AE (i.e. surveillance) ACTIVE or PASSIVE | [underlined: Is the surveillance ACTIVE (actively monitor the presence of absence of AE during the study…do not rely on methods that are PASSIVE (sometimes called spontaneous reporting)] | Y | N
| | Unclear
Describe a SCHEDULE for collection of safety info | Optional
| 1) Do the authors specify the schedule for collection of safety information?
FREQUENCY of SERIOUS AE (i.e. results in death, requires inpatient hospitalization, persistent or significant disability or is life threatening, WHO 2001) | Are exact numbers for high-grade (serious and life threatening) clinical AE laboratory toxicity reported. | Y | N
| | Unclear
SEVERITY of each AE (i.e. mild, moderate, or severe headache) | Have each of the AE been reported with respect to a severity continuum (i.e. mild diarrhea, severe headache, etc) ? | Y | N
| Have some of the AE been reported with respect to a severity grade? | Unclear
| | Optional:
| | Y | N
| | Unclear
Description of UNUSUAL or NOT PREVIOUSLY RECORDED AE | Has a detailed description of cases of unusual or not previously recorded AE effects been presented? | Y | N
| | Unclear
STANDARDIZED SCALES used to capture AE. | Do the authors report the use of widely known, standardized scales for AE? | Y | N
| Specify scale: | Unclear
| If the scale is new, do the authors provide definitions for the grades of severity | Optional:
| | Y | N
| | Unclear
Identify specific SAFETY TESTS or QUESTIONNAIRES used for data collection | Do the authors identify specific safety tests or questionnaires used for data collection | Y | N
| | Unclear

THRESHOLD SCORING for ADVERSE EVENTS:

1. Scoring:
  - YES = 1
  - NO = 0
  - Unclear = consult with other rater to reach consensus
2. For the first 3 questions a MINIMUM score of 3 is required to proceed to the subsequent 5 questions
3. If all patients were accounted for (i.e. no withdrawals), then we assume a score of 2 for the WITHDRAWAL due to AE question
4. If no mention of serious (see definition) is mentioned in the paper, then we will ASSUME that they were NOT monitored (rather than not reported)