# Appendix A Search strategies

## Database: Cochrane Central Register of Controlled Trials <4th Quarter 2002> on OVID

Search strategy executed on February 3, 2003

Same search executed on February 4th, 2003 on the online version of the Cochrane Library for the new references <1st Quarter 2003>:

1. (mild cognitive impairment or MCI).tw.
2. ((cognitive impairment not dementia) or CIND).tw.
3. ((cognitive loss not dementia) or CLOND).tw.
4. Delirium, Dementia, Amnestic, Cognitive Disorders/
5. exp Amnesia/
6. Cognition Disorders/
7. exp Dementia/
8. exp tauopathies/
9. dement:.tw.
10. Alzheimer:.tw.
11. Huntington disease/
12. Lewy: ajd8 bod:.tw.
13. ((cognit: or memory or mental:) adj8 (decli: or impair: or los: or deteriorat:)).tw.
14. (chronic adj8 cerebrovascular).tw.
15. supra-nuclear palsy.tw.
16. (normal pressure hydrocephalus adj8 shunt:).tw.
17. benign senescent forgetfulness.tw.
18. (cerebr: adj8 deteriorat:).tw.
19. cerebr: ajd8 insufficien:.tw.
20. (confusion: or confused).tw.
21. (pick: adj8 disease).tw.
22. (creutzfeldt: or JCD: or CJD:).tw.
23. (Huntington: or Huntingdon).tw.
24. Binswanger:.tw.
25. brain atrophy.tw.
26. exp Cerebral Amyloid Angiopathy/
27. neurofibrillary tangles/
28. senile plaques/
29. neuropil threads/
30. spongiform encephalopathy.tw.
31. exp Hypothyroidism/
32. neurosyphilis/
33. exp amyloid beta-protein/ not (Down syndrome/ or trisomy 21.tw.)
34. (CADISIL or cerebral autosomal dominant ischemia with subcortical leukoencephalopathy).tw.
35. (corticobasil ganglionic degeneration or cortical basal degeneration or corticabasal ganglionic degeneration).tw.
36. multisystem atrophy.tw.
37. exp alcohol amnestic disorder/
38. (alcohol adj3 amnestic).tw.
39. or/1–38

Database: Pre-MEDLINE, MEDLINE on OVID

Search strategy executed on February 4, 2003

1. randomized controlled trial.pt.
2. controlled clinical trial.pt.
3. controlled clinical trials/
4. (clinical trials, phase II or clinical trials, phase III or clinical trials, phase IV or multicenter studies).sh.
5. random allocation.sh.
6. double blind method.sh.
7. cross-over studies.sh.
8. single-blind method.sh.
9. clinical trial.pt.
10. (clin: adj25 trial:).ti,ab.
11. ((singl: or doubl: or trebl: or tripl:) adj25 (blind: or mask:)).ti,ab.
12. placebos.sh.
13. placebo:.ti,ab.
14. random:.ti,ab.
15. or/1–14
16. comparative study.sh.
17. exp evaluation studies/
18. follow up studies.sh.
19. prospective studies.sh.
20. or/16–19
21. (tu or th).xs.
22. treatment outcome/
23. exp therapeutics/
24. or/21–23
25. 20 and 24
26. 15 or 25
27. (mild cognitive impairment or MCI).tw.
28. ((cognitive impairment not dementia) or CIND).tw.
29. ((cognitive loss not dementia) or CLOND).tw.
30. exp dementia/
31. exp tauopathies/
32. (dement: or alzheimer:).tw.
33. amentia.tw.
34. frontotemporal lobar degeneration.tw.
35. hiv-associated cognitive motor complex.tw.
36. encephalopathy, aids.tw.
37. encephalopathy, hiv.tw.
38. mesulam syndrome.tw.
39. progressive nonfluent aphasia.tw.
40. binswanger disease.tw.
41. binswanger encephalopathy.tw.
42. leukoencephalopathy, subcortical.tw.
43. subcortical arteriosclerotic encephalopathy.tw.
44. chronic progressive subcortical encephalopathy.tw. or alcohol amnestic disorder/ or alcohol induced disorders, nervous system/ or (alcohol adj3 amnestic).tw. or (alcohol adj2 dysmestic).tw. or (ethanol adj3 nervous system disorders).tw. or ethyl alcohol abuse neurologic syndromes.tw.
45. (lewy: bod: adj8 disease).tw.
46. brain atrophy, circumscribed lobar.tw.
47. (pick: adj8 disease).tw.
48. exp amyloid beta-protein/ not (down syndrome/ or trisomy 21.tw.)
49. exp cerebral amyloid angiopathy/
50. neurofilament proteins/
51. tau proteins/
52. neurofibrillary tangles/
53. neuropil threads/
54. senile plaques/
55. (Corticobasil ganglionic degeneration or cortical basal degeneration or cortica).tw.
56. (CADISIL or Cerebral autosomal dominant ischemia with subcortical leukoencephalopathy).tw.
57. Multisystems atrophy.tw.
58. huntington disease/
59. hydrocephalus, normal pressure/
60. Creutzfeldt-Jakob syndrome/
61. spongiform encephalopathy.tw.
62. (cjd or jcd).tw.
63. Creutzfeldt-Jakob disease.tw.
64. spongiform encephalopathy.tw.
65. exp Hypothyroidism/
66. exp Vitamin B 12 Deficiency/
67. exp Neurosyphilis/
68. or/27–67
69. 26 and 68
70. animal.sh.
71. 69 not 70
72. not (comment or editorial or news or letter).pt.
73. and eng.la.
74. limit 73 to yr=1998-2003

Database: EMBASE <1996 to 2003 Week 5> on OVID

Search strategy executed on February 6, 2003

1. (mild cognitive impairment or MCI).tw.
2. ((cognitive impairment not dementia) or CIND).tw.
3. ((cognitive loss not dementia) or CLOND).tw.
4. exp dementia/
5. (dement: or alzheimer:).tw.
6. amentia.tw.
7. frontotemporal lobar degeneration.tw.
8. hiv-associated cognitive motor complex.tw.
9. encephalopathy, aids.tw.
10. encephalopathy, hiv.tw.
11. mesulam syndrome.tw.
12. progressive nonfulent aphasia.tw.
13. binswanger disease.tw.
14. binswanger encephalopathy.tw.
15. leukoencephalopathy, subcortical.tw.
16. subcortical arteriosclerotic encephalopathy.tw.
17. chronic progressive subcortical encephalopathy.tw.
18. exp Korsakoff psychosis/ or exp Wernicke Korsakoff syndrome/
19. (alcohol adj3 amnestic).tw.
20. (alcohol adj2 dysmnestic).tw.
21. (ethanol adj3 nervous system disorders).tw.
22. ethyl alcohol abuse neurologic syndromes.tw.
23. (Lewy: bod: adj8 disease).tw.
24. brain atrophy, circumscribed lobar.tw.
25. (Pick: adj8 disease).tw.
26. exp brain atrophy/ or exp brain cortex atrophy/ or exp brain degeneration/ or exp corticobasal degeneration/ or exp lewy body/ or exp neurofibrillary tangle/ or exp neuropil thread/ or exp organic brain syndrome/
27. exp amyloid beta-protein/ not (exp Down syndrome/ or trisomy 21.tw.)
28. exp Vascular Amyloidosis/
29. exp Neurofilament Protein/
30. Tau Protein/
31. Neurofibrillary Tangle/
32. Neuropil Thread/
33. Senile Plaque/
34. (corticobasil ganglionic degeneration or cortical basal degeneration or corticobasal degeneration).tw.
35. (CADISIL or Cerebral autosomal dominant ischemia with subcortical leukoencephalopathy).tw.
36. multisystems atrophy.tw.
37. Normotensive Hydrocephalus/
38. Creutzfeldt Jakob Disease/
39. exp Brain Spongiosis/
40. spongiform encephalopathy.tw.
41. (CJD or JCD).tw.
42. Creutzfeldt-Jakob disease.tw.
43. exp Hypothyroidism/
44. Cyanocobalamin Deficiency/
45. Neurosyphilis/
46. or/1–45
47. multicenter study/ or phase 2 clinical trial/ or phase 3 clinical trial/ or phase 4 clinical trial/ or randomized controlled trial/ or exp postmarketing surveillance/
48. randomization/
49. crossover procedure/ or double blind procedure/ or experimental design/ or latin square design/ or parallel design/ or single blind procedure/
50. (clin: adj25 trial:).ti,ab.
51. ((singl: or doubl: or trebl: or tripl:) adj25 (blin: or mask:)).ti,ab.
52. Placebo/
53. placebo:.ti,ab.
54. random:.ti,ab.
55. exp comparative study/ or exp drug comparison/
56. exp “evaluation and follow up”/
57. longitudinal study/ or major clinical study/ or prospective study/
58. or/47–54
59. or/55–57
60. (tu or th).fs.
61. exp treatment outcome/
62. exp therapy/
63. or/60–62
64. 59 and 63
65. 58 or 64
66. 65 and 46
67. exp animal/
68. 66 not 67
69. 68 not (comment or editorial or news or letter or conference paper).pt.
70. limit 69 to English language
71. limit 70 to yr=1998-2003

Database: AMED (Allied and Complementary Medicine) <1985 to February 2003> on OVID

Search strategy executed on March 4, 2003

1. exp clinical trials/ or double blind method/ or random allocation/
2. clinical trial.pt.
3. (clin: adj25 trial:).ti,ab.
4. ((singl: or doubl: or trebl: or tripl:) adj25 (blind or mask:)).ti,ab.
5. placebos.sh.
6. placebo:.ti,ab.
7. random:.ti,ab.
8. or/1–7
9. (mild cognitive impairment or MCI).tw.
10. ((cognitive impairment not dementia) or CIND).tw.
11. ((cognitive loss not dementia) or CLOND).tw.
12. exp dementia/
13. (dement: or Alzheimer:).tw.
14. amentia.tw.
15. frontotemporal lobar degeneration.tw.
16. hiv-associated cognitive motor complex.tw.
17. (encephalopathy, aids or encephalopathy, hiv).tw.
18. mesulam syndrome.tw.
19. progressive nonfluent aphasia.tw.
20. binswanger disease.tw.
21. binswanger encephalopathy.tw.
22. leukoencephalopathy, subcortical.tw.
23. subcortical arteriosclerotic encephalopathy.tw.
24. chronic progressive subcortical encephalopathy.tw.
25. (alcohol adj3 amnestic).tw.
26. (alcohol adj2 dysmnestic).tw.
27. (ethanol adj3 nervous system disorders).tw.
28. ethyl alcohol abuse neurologic syndromes.tw.
29. (Lewy: bod: adj8 disease).tw.
30. brain atrophy, circumscribed lobar.tw.
31. (Pick: adj8 disease).tw.
32. (corticobasil ganglionic degeneration or cortical basal degeneration or cortica).tw.
33. (CADISIL or cerebral autosomal dominant ischemia with subcortical leukoencephalopathy).tw.
34. Multisystems atrophy.tw.
35. spongiform encephalopathy.tw.
36. (cjd or Jcd).tw.
37. Creutzfeldt-Jakob disease.tw.
38. hypothyroidism/
39. or/9–38
40. 8 and 39
41. 40 not (comment or editorial or news or letter).pt.
42. 41 and English.lg.

Database: CINAHL <1982 to February Week 3 2003> on OVID

Search strategy executed on March 5, 2003

1. crossover design/ or empirical research/ or experimental studies/ or exp clinical trials/ or community trials/ or factorial design/ or quantitative studies/
2. clinical trial.pt.
3. (clin: adj25 trial:).ti,ab.
4. ((singl: or doubl: or trebl: or tripl:) adj25 (blind: or mask:)).ti,ab.
5. Placebos/
6. placebo:.ti,ab.
7. random:.ti,ab.
8. Study Design/
9. or/1–8
10. (mild cognitive impairment or MCI).tw.
11. ((cognitive impairment not dementia) or CIND).tw.
12. ((cognitive loss not dementia) or CLOND).tw.
13. exp Dementia/
14. (dement: or Alzheimer:).tw.
15. amentia.tw.
16. frontotemporal lobar degeneration.tw.
17. hiv-associated cognitive motor complex.tw.
18. (encephalopathy, aids or encephalopathy, hiv).tw.
19. mesulam syndrome.tw.
20. progressive nonfulent aphasia.tw.
21. Binswanger disease.tw.
22. Binswanger encephalopathy.tw.
23. leukoencephalopathy, subcortical.tw.
24. (chronic progressive subcortical encephalopathy or (alcohol adj3 amnestic) or (alcohol adj2 dysmestic) or (ethanol adj3 nervous system disorders) or ethyl alcohol abuse neurologic syndromes).tw.
25. Lewy body disease.tw.
26. brain atrophy, circumscribed lobar.tw.
27. Pick: disease.tw.
28. (corticobasil ganglionic degeneration or cortical basal degeneration or cortica).tw.
29. (CADASIL or cerebral autosomal dominant ischemia with subcortical leukoencephalopathy).tw.
30. multisystems atrophy.tw.
31. Huntington's Disease/
32. Creutzfeldt-Jakob Syndrome/
33. spongiform encephalopathy.tw.
34. (cjd or jcd).tw.
35. Creutzfeldt-Jakob disease.tw.
36. spongiform encephalopathy.tw.
37. exp Hypothyroidism/
38. Neurosyphilis/
39. or/10–38
40. 9 and 39
41. 40 not (editorial or letter or proceedings).pt.
42. limit 41 to English

Database: Ageline <1978 to December 2002> on SILVERPLATTER

Search strategy executed on March 6, 2003

#1 randomized controlled trials in DE

#2 controlled clinical trials in de

#3 random allocation

#4 controlled clinical trial*

#5 randomized controlled trial*

#6 random allocation

#7 double blind method

#8 single blind method

#9 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8

#10 clinical trial*

#11 (clin* near trial*) in TI

#12 (clin* near trial*) in AB

#13 (singl* or doubl* or trebl* or tripl*) near (blind* or mask*)

#14 (#13 in TI) or (#13 in AB)

#15 placebo*

#16 Placebo* in TI

#17 placebo* in AB

#18 random* in TI

#19 random* in AB

#20 research design

#21 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20

#22 mild cognitive impairment

#23 (cognitive impairment and dementia) or CIND

#24 (cognitive loss not dementia) or CLOND

#25 (explode 'Dementia-' in DE) or (explode 'Early-Onset-Dementia' in DE) or (explode 'Vascular-Dementia' in DE)

#26 dement* or alzheimer*

#27 amentia*

#28 frontotemporal lobar degeneration

#29 hiv-associated cognitive motor complex

#30 aids associated encephalopathy

#31 hiv associated encephalopathy

#32 mesulam syndrome

#33 progressive nonfluent aphasia

#34 binswanger disease

#35 binswanger encephalopathy

#36 leukoencephalopathy subcortical

#37 subcortical arteriosclerotic encephalopathy

#38 chronic progressive subcortical encephalopthy

#39 alcohol near amnestic

#40 alcohol amnestic disorder

#41 alcohol induced disorders

#42 alcohol near dysmnestic

#43 ethanol near nervous system disorders

#44 lewy* bod* near disease

#45 ethyl alcohol abuse neurologic syndromes

#46 brain atrophy lobar

#47 Pick* near disease*

#48 cerebral amyloid angiopathy

#49 neurofilament protein*

#50 tau protein*

#51 neurofibrillary tangles

#52 neuropil threads

#53 senile plaque*

#54 corticobasil ganglionic degeneration or cortical basal degeneration or cortica

#55 cadisil

#56 cerebral autosomal dominant ischemia with subcortical leukoencephalopathy

#57 multisystems atrophy

#58 explode 'Huntingtons-Disease' in DE

#59 normal pressure hydrocephalus

#60 Creutzfeldt-Jakob syndrome

#61 spongiform encephalopathy

#62 cjd or jcd

#63 Creutzfeldt-Jakob disease

#64 hypothyroidism

#65 vitamin b12 deficiency

#66 neurosyphilis

#67 #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 or #52 or #53 or #54 or #55 or #56 or #57 or #58 or #59 or #60 or #61 or #62 or #63 or #64 or #65 or #66

#68 #67 and #21

* #69 #68 and (DT=JOURNAL-ARTICLE)

Database: PsychINFO <1967 TO 2002/12> on SILVERPLATTER

Search strategy executed on March 7, 2003

#1 randomized controlled trial in PT

#2 controlled clinical trial in PT

#3 controlled clinical trials

#4 random allocation

#5 (clinical trial*) in DE,SU

#6 (random allocation) in DE,SU

#7 (double blind method) in DE,SU

#8 (cross-over studies) in DE,SU

#9 (single-blind method) in DE,SU

#10 (clinical trial) in PT

#11 ((clin* near trial*)) in TI

#12 (placebo*) in DE,SU

#13 (placebo*) in TI

#14 (random*) in TI

#15 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14

#16 mild cognitive impairment

#17 MCI

#18 (cognitive impairment not dementia) or CIND

#19 (cognitive loss not dementia) or CLOND

#20 (explode 'AIDS-Dementia-Complex' in DE) or (explode 'Alzheimers-Disease' in DE) or (explode 'Dementia-with-Lewy-Bodies' in DE) or (explode 'Dementia-' in DE) or (explode 'General-Paresis' in DE) or (explode 'Multi-Infarct-Dementia' in DE) or (explode 'Presenile-Dementia' in DE) or (explode 'Senile-Dementia' in DE) or (explode 'Vascular-Dementia' in DE)

#21 dement* or Alzheimer*

#22 amentia

#23 HIV-associated cognitive motor complex

#24 encephalopathy aids

#25 encephalopathy hiv

#26 mesulam syndrome

#27 progressive nonfluent aphasia

#28 binswanger disease

#29 binswanger encephalopathy

#30 leukoencephalopathy subcortical

#31 subcortical arteriosclerotic encephalopathy

#32 chronic progressive subcortical encephalopathy

#33 alcohol near amenstic

#34 alcohol near dysmnestic

#35 ethanol near (nervous system disorders)

#36 ethyl alcohol abuse neurologic syndromes

#37 lewy* bod* near disesase

#38 brain atrophy circumscribed lobar

#39 Pick* near disease

#40 cerebral amyloid angiopathy

#41 (neurofilament proteins) in DE,SU

#42 (tau proteins) in DE,SU

#43 (neurofibrillary tangles) in DE,SU

#44 (neuropil threads) in DE,SU

#45 (senile plaque*) in DE,SU

#46 (corticobasil ganglionic degeneration) or (cortical basal degeneration)

#47 cadisil or (cerebral autosomal dominant ischemia with subcortical leukoencephalopathy) (0 records)

#48 multisystems atrohpy (0 records)

#49 'Huntingtons-Disease' in DE (883 records)

#50 hydrocephalus normal pressure (140 records)

#51 'Creutzfeldt-Jakob-Syndrome' in DE (109 records)

#52 spongiform encephalopathy (39 records)

#53 cjd or jcd (80 records)

#54 Creutzfeldt-Jakob disease (183 records)

#55 explode 'Hypothyroidism-' in DE (260 records)

#56 explode 'Neurosyphilis-' in DE (39 records)

#57 vitamin B12 deficien* (50 records)

#58 frontotemporal lobar degeneration (15 records)

#59 #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 or #52 or #53 or #54 or #55 or #56 or #57 or #58 (27527 records)

#60 #15 and #59 (338 records)

* #61 #60 and (LA=ENGLISH) and (PO=HUMAN) (322 records)