# Appendixes

Appendix A Search strategies

Appendix B Forms

Appendix C Evidence tables

Appendix D Peer review

Appendix E. Outcome Measures

Appendix F. List of excluded studies