# Listing of Excluded Studies

1 A battle cry for biomedicine. Nat Med. Nov 2001;7(11):1163. Does not address regionalization.
2 After September 11. N Engl J Med. Nov 15 2001;345(20):1490. Opinion or editorial.
3 Ahmad S H. Hurricane Andrew: a Texas physician helps out. Tex Med. Jan. 1993;89(1):8-9. Does not address regionalization. [pmid: 8420033].
4 Alexander J P, Chapman L E, Pallansch M A, Stephenson W T, Torok T J, Anderson L J. Coxsackievirus B2 infection and aseptic meningitis: a focal outbreak among members of a high school football team. J Infect Dis. May. 1993;167(5):1201-1205. Does not address regionalization. [pmid: 8387565].
5 Altman GB. Bioterrorism's invisible threats: heightened awareness will help nurses identify real and suspected bioterrorism. Nurs Manage. Jan 2002;33(1):43, 45–47. Does not address regionalization.
6 Analyzing your vulnerability to hazards. Jt Comm Perspect. Dec 2001;21(12):8–9. Does not address regionalization.
7 Anderson G V Jr, Feliciano D V. The Centennial Olympic Park bombing: Grady's response. J Med Assoc Ga. Jan. 1997;86(1):42-46. Does not address regionalization. [pmid: 9029886].
8 Annas GJ. Bioterrorism and public health law. JAMA. Dec 4 2002;288(21):2685–2686; author reply 2686–2687. Does not describe bioterrorism-relevant response task.
9 Annas G J. Bioterrorism, public health, and civil liberties. N Engl J Med. Apr 25. 2002;346(17):1337-1342. Does not describe bioterrorism-relevant response task. [pmid: 11973377].
10 Annas G J. Bioterrorism, public health, and human rights. Health Aff. Nov-Dec. 2002;21(6):94-97. Does not describe bioterrorism-relevant response task.
11 Anteau C M, Williams L A. The Oklahoma Bombing: Lessons Learned. Crit Care Nurs Clin North Am. Jun. 1997;9(2):231-236. Does not address regionalization. [pmid: 9214891].
12 Arnold J L. Disaster medicine in the 21st century: future hazards, vulnerabilities, and risk. Prehospital Disaster Med. Jan-Mar. 2002;17(1):3-11. Does not address regionalization. [pmid: 12357562].
13 Artenstein A W, Neill M A, Opal S M. Bioterrorism and physicians. Ann Intern Med. Oct 1. 2002;137(7):626. Opinion or editorial. [pmid: 12353968].
14 Aseptic meningitis in a high school football team - Ohio. MMWR Morb Mortal Wkly Rep. Jan 9 1981;29(52):631–637. Does not address regionalization.
15 Aseptic meningitis--New York State and United States, weeks 1–36, 1991. MMWR Morb Mortal Wkly Rep. Nov 15 1991;40(45):773–775. Does not address regionalization.
16 ASHP statement on the role of health-system pharmacists in counterterrorism. Am J Health Syst Pharm. Feb 1 2002;59(3):282–283. Does not address regionalization.
17 Atlas R M. Bioterriorism: from threat to reality. Annu Rev Microbiol. 2002;56:167-185. Does not address regionalization. [pmid: 12142472].
18 Atlas R M. Public health. National security and the biological research community. Science. Oct 25. 2002;298(5594):753-754. Does not address regionalization. [pmid: 12399568].
19 Atlas R M. Responding to the threat of bioterrorism: a microbial ecology perspective--the case of anthrax. Int Microbiol. Dec. 2002;5(4):161-167. Does not address regionalization. [pmid: 12497181].
20 Atlas R M. The medical threat of biological weapons. Crit Rev Microbiol. 1998;24(3):157-168. Does not address regionalization. [pmid: 9800098].
21 Aubrey L. The hard lessons of September. Mod Healthc. Jan 28. 2002;32(4):50. Opinion or editorial. [pmid: 11859551].
22 Augustine J. Silent assassin. Managing exposure incidents of unknown origin. J Emerg Med Serv JEMS. Apr. 2002;27(4):36-40. Does not address regionalization. [pmid: 11968570].
23 Austin P C, Mamdani M M, Jaakkimainen L, Hux J E. Trends in drug prescriptions among elderly residents of Ontario in the weeks after September 11, 2001. JAMA. Aug 7. 2002;288(5):575-577. Does not address regionalization. [pmid: 12150668].
24 Barclay L. Combat Medicine in Iraq, Part 1: An Expert Interview with Col. Cliff Cloonan, MD. Medscape Medical News, 2003. Does not address regionalization.
25 Baron R C, Hatch M H, Kleeman K, MacCormack J N. Aseptic meningitis among members of a high school football team. An outbreak associated with echovirus 16 infection. JAMA. Oct 8. 1982;248(14):1724-1727. Does not address regionalization. [pmid: 7120592].
26 Bartlett J G, Inglesby T V Jr, Borio L. Management of anthrax. Clin Infect Dis. Oct 1. 2002;35(7):851-858. Does not address regionalization. [pmid: 12228822].
27 Bates N, Asgari-Jirhandeh N. Bioterrorism. Emerg Nurse. Dec-2002 Jan 2001;9(8):21–25. Does not address regionalization.
28 Bayer R, Colgrove J. Bioterrorism, public health, and the law. Health Aff. Nov-Dec. 2002;21(6):98-101. Does not describe a bioterrorism-relevant response task.
29 Bayer R, Colgrove J. Public health vs. civil liberties. Science. Sep 13. 2002;297(5588):1811. Does not describe a bioterrorism-relevant response task. [pmid: 12228702].
30 Beaton R D, Johnson L C. Instrument development and evaluation of domestic preparedness training for first responders. Prehospital Disaster Med. Jul-Sep. 2002;17(3):119-125. Does not address regionalization. [pmid: 12627914].
31 Becker C. 20/20 hindsight. Months after anthrax claimed the lives of several Americans, hospitals review their reaction to the event--and plan for future crises. Mod Healthc. Feb 25 2002;32(8):8–9, 12. Does not address regionalization.
32 Becker C. Ready, willing and able. Providers united to treat the victims of terrorism, but they wanted more patients. Mod Healthc. Sep 17 2001;31(38):4–5, 28. Does not address regionalization.
33 Becker C. ‘We have survived, and we're stronger’. During the year since America's trauma of Sept. 11, New York hospitals--and healthcare organizations nationwide--have taken the painful lessons to heart. Mod Healthc. Sep 2. 2002;32(35):22-26. Does not address regionalization. [pmid: 12298356].
34 Becker R, Smith M, Maier J. Are hospitals focusing enough on disaster readiness?. Hosp Health Netw. Jul. 2002;76(7):30. Does not address regionalization. [pmid: 12136713].
35 Bellamy R J, Freedman A R. Bioterrorism. QJM. Apr. 2001;94(4):227-234. Does not address regionalization. [pmid: 11294966].
36 Benedek D M, Holloway H C, Becker S M. Emergency mental health management in bioterrorism events. Emerg Med Clin North Am. May. 2002;20(2):393-407. Does not address regionalization. [pmid: 12120485].
37 Benjamin G. Ensuring the health of Maryland's citizens: the 2002 legislative agenda. Md Med. Winter 2002;3(1):42–43. Does not address regionalization.
38 Benjamin GC. Bioterrorism and the public health. Md Med. Spring 2000;1(2):24–26. Opinion or editorial.
39 Benjamin G C. Managing terror. Public health officials learn lessons from bioterrorism attacks. Physician Exec. Mar-Apr. 2002;28(2):80-83. Does not address regionalization. [pmid: 11957420].
40 Benjamin G C. Smallpox vaccine policy: the national debate. Physician Exec. Sep-Oct. 2002;28(5):64-66. Does not address regionalization. [pmid: 12416388].
41 Bentley J. The front line. Local hospitals will be the first to respond to a terrorist attack--and they intend to be ready. Hosp Health Netw. Nov 2001;75(11):84, 84. Does not address regionalization.
42 Berkowitz B. Public health nursing practice: aftermath of September 11, 2001. Online J Issues Nurs. 2002;7(3):5. Does not address regionalization. [pmid: 12410635].
43 Berlin B. Targeting bioterrorism. N J Med. Oct. 1999;96(10):29-31. Opinion or editorial. [pmid: 10570631].
44 Berod T, Chan-ou-Teung F. Pharmacist's role in rescue efforts after plane crash in Indian Ocean. Am J Health Syst Pharm. May 1. 1997;54(9):1110. Does not address regionalization. [pmid: 9143661].
45 Bioterrorism alleging use of anthrax and interim guidelines for management--United States, 1998. MMWR Morb Mortal Wkly Rep. Feb 5 1999;48(4):69–74. Does not address regionalization.
46 Blendon R J, DesRoches C M, Benson J M, Herrmann M J, Taylor-Clark K, Weldon K J. The public and the smallpox threat. N Engl J Med. Jan 30. 2003;348(5):426-432. Opinion or editorial. [pmid: 12496352].
47 Block SM. The Growing Threat of Biological Weapons. American Scientist. Jan-Feb 2001;89(1). Does not address regionalization.
48 Boatright J R. The threat of terrorism--can our emergency medical systems ever be prepared?. J Emerg Nurs. Dec. 2002;28(6):552-555. Does not address regionalization. [pmid: 12509735].
49 Bobo N. Smallpox vaccine--do school nurses know how to respond?. Nasnewsletter. Sep. 2002;17(5):14-15. Does not address regionalization. [pmid: 12298227].
50 Boin A, van Duin M, Heyse L. Toxic fear: the management of uncertainty in the wake of the Amsterdam air crash. J Hazard Mater. Dec 14. 2001;88(23):213-234. Does not address regionalization. [pmid: 11679195].
51 Boni C E, Earls E A. Hospital preparedness for acts of bioterrorism: an assessment of emergency preparedness plans of hospitals in Rhode Island. Med Health R I. Jun. 2001;84(6):199. Does not address regionalization. [pmid: 11434149].
52 Borg MA, Tieck WC, Jr. Responding to anthrax. J Dent Technol. Nov-Dec 2001;18(8):12–14, 28. Does not address regionalization.
53 Borio L, Frank D, Mani V, et al. Death due to bioterrorism-related inhalational anthrax: report of 2 patients. JAMA. Nov 28. 2001;286(20):2554-2559. Does not address regionalization. [pmid: 11722269].
54 Bowen G S, Fisher M C, DeForest A, Thompson C M Jr, Kleger B, Friedman H. Epidemic of meningitis and febrile illness in neonates caused by ECHO type 11 virus in Philadelphia. Pediatr Infect Dis. Sep-Oct. 1983;2(5):359-363. Does not address regionalization. [pmid: 6634464].
55 Bozeman WP, Dilbero D, Schauben JL. Biologic and chemical weapons of mass destruction. Emerg Med Clin North Am. Nov 2002;20(4):975–993, xii. Does not address regionalization.
56 Bozzette S A, Boer R, Bhatnagar V, et al. A model for a smallpox-vaccination policy. N Engl J Med. Jan 30. 2003;348(5):416-425. Does not address regionalization. [pmid: 12496353].
57 Bradley R N. Health care facility preparation for weapons of mass destruction. Prehosp Emerg Care. Jul-Sep. 2000;4(3):261-269. Does not address regionalization. [pmid: 10895923].
58 Brechtel K. Andrew's aftermath. Am J Nurs. Nov. 1992;92(11):16. Does not address regionalization. [pmid: 1485619].
59 Breithaupt H. Responding to bioterrorism. EMBO Rep. Dec. 2001;2(12):1053. Does not address regionalization. [pmid: 11743010]. [pmcid: 1084174].
60 Brewer R D, Morris P D, Cole T B. Hurricane-related emergency department visits in an inland area: an analysis of the public health impact of Hurricane Hugo in North Carolina. Ann Emerg Med. Apr. 1994;23(4):731-736. Does not address regionalization. [pmid: 8161040].
61 Briggs B. Hospitals recheck: are they ready for anything?. Health Data Manag. Dec. 2001;9(12):42-44. Does not address regionalization. [pmid: 11794994].
62 Broad WJ. Anthrax, Virulence. ProMED-mail. April 7, 2003. Does not address regionalization.
63 Brocato CE, Miller GT. The next agent of terror? Understanding smallpox & its implications for prehospital crews. J Emerg Med Serv JEMS. Mar 2002;27(3):44–50, 52-45. Does not address regionalization.
64 Brook I, Gorman R, Johnson M W. Outbreak of meningococcal disease in a family. South Med J. Jul. 1980;73(7):902-903. Does not address regionalization. [pmid: 7384853].
65 Brook I. The prophylaxis and treatment of anthrax. Int J Antimicrob Agents. Nov. 2002;20(5):320-325. Does not address regionalization. [pmid: 12431866].
66 Brookmeyer R, Blades N. Prevention of inhalational anthrax in the U.S. outbreak. Science. Mar 8. 2002;295(5561):1861. Does not address regionalization. [pmid: 11884746].
67 Brown D. Medicine and the media: a case study. Pharos Alpha Omega Alpha Honor Med Soc. Summer 1984;47(3):2–7. Does not address regionalization.
68 Bruckbauer S. Congress considers stockpiling potassium iodide. J Natl Cancer Inst. Jan 16. 2002;94(2):86. Does not address regionalization. [pmid: 11792744].
69 Bryan J L, Fields H F. An ounce of prevention is worth a pound of cure-shoring up the public health infrastructure to respond to bioterrorist attacks. Am J Infect Control. Dec. 1999;27(6):465-467. Does not address regionalization. [pmid: 10586147].
70 Bullard T B, Strack G, Scharoun K. Emergency department security: a call for reassessment. Health Care Manag. Sep. 2002;21(1):65-73. Does not address regionalization.
71 Burda A M, Sigg T. Pharmacy preparedness for incidents involving weapons of mass destruction. Am J Health Syst Pharm. Dec 1. 2001;58(23):2274-2284. Does not address regionalization. [pmid: 11763806].
72 Burkle F M Jr. Mass casualty management of a large-scale bioterrorist event: an epidemiological approach that shapes triage decisions. Emerg Med Clin North Am. May. 2002;20(2):409-436. Does not address regionalization. [pmid: 12132490].
73 Bush GW. Remarks of Project Bioshield, 2003. Does not address regionalization.
74 Bush L M, Abrams B H, Beall A, Johnson C C. Index case of fatal inhalational anthrax due to bioterrorism in the United States. N Engl J Med. Nov 29. 2001;345(22):1607-1610. Does not address regionalization. [pmid: 11704685].
75 Butler R. International leadership in the control of biological weapons. Public Health Rep. 2001;116(Suppl 2):53-58. Does not address regionalization. [pmid: 11880673]. [pmcid: 1497274].
76 Calhoun P, Plymale I. Hurricane Andrew reverses natural order: the helpers need help. Part I. Fund Raising Manage. Feb. 1993;23(12):27-32. Does not address regionalization. [pmid: 10123821].
77 Cangemi CW. Occupational response to terrorism. AAOHN J. Apr 2002;50(4):190–196; quiz 197–198. Does not address regionalization.
78 Caroline N L, Adom M D. EMS response to a terrorist attack. Emerg Med Serv. Sep-Oct. 1978;7(5):34-37. Does not address regionalization. [pmid: 10240014].
79 Carpenter D. When privacy and terror collide. Hosp Health Netw. Dec. 2001;75(12):32. Does not address regionalization. [pmid: 11803938].
80 Cartter M L. Night of two town meetings. Emerg Infect Dis. Oct. 2002;8(10):1175-1176. Does not address regionalization. [pmid: 12405129].
81 Catizone CA. Survey of Pharmacy Law. Park Ridge, IL: National Association of Boards of Pharmacy; 2002. Does not address regionalization.
82 Chaffee M, Conway-Welch C, Stephens V. Bioterrorism in the United States: take it seriously. Am J Nurs. Nov 2001;101(11):59, 61. Opinion or editorial.
83 Charatan F. Anthrax blamed as two postal workers die in United States. BMJ. Oct 27. 2001;323(7319):951. Does not address regionalization. [pmid: 11679374].
84 Check E. Fight against terror ‘needs science institute’. Nature. Jun 27. 2002;417(6892):887. Does not address regionalization. [pmid: 12087368].
85 Check E. US urged to provide smallpox vaccines for emergency crews. Nature. Jun 20. 2002;417(6891):775-776. Does not address regionalization. [pmid: 12075304].
86 Chemical and Biological Incident Response Force. Available at: http://www.globalsecurity.org/military/agency/usmc/cbirf.html, 2003. Does not address regionalization.
87 Chen F M, Hickner J, Fink K S, Galliher J M, Burstin H. On the front lines: family physicians' preparedness for bioterrorism. J Fam Pract. Sep. 2002;51(9):745-750. Does not address regionalization. [pmid: 12366891].
88 Christen HT, Denney JP, Maniscalco PM, Rubin DL. Terrorism. Part III--Response procedures for terrorist/tactical violence incidents. J Emerg Med Serv JEMS. Jan 1999;24(1):58–64, 66. Does not address regionalization.
89 Cieslak T J, Christopher G W, Kortepeter M G, et al. Immunization against potential biological warfare agents. Clin Infect Dis. Jun. 2000;30(6):843-850. Does not address regionalization. [pmid: 10880299].
90 Citarella B B, Marble M J, Mueller C J. Home care & hospice's role in response to a bioterrorist event. Caring. Jan. 2002;21(1):36-39. Does not address regionalization. [pmid: 11813647].
91 Clark N. A joint labor-management health and safety model: Lessons learned at the World Trade Center Emergency Project. Am J Ind Med. Dec. 2002;42(6):553-554. Does not address regionalization. [pmid: 12439884].
92 Cohen H W, Gould R M, Sidel V W. Bioterrorism initiatives: public health in reverse?. Am J Public Health. Nov. 1999;89(11):1629-1631. Does not address regionalization. [pmid: 10553378]. [pmcid: 1509000].
93 Cohen H W, Sidel V W, Gould R M. Preparedness for bioterrorism?. N Engl J Med. Nov 8. 2001;345(19):1423-1424. Does not address regionalization. [pmid: 11794178].
94 Cohen J, Enserink M. Public health. Rough-and-tumble behind Bush's smallpox policy. Science. Dec 20. 2002;298(5602):2312-2316. Does not address regionalization. [pmid: 12493889].
95 Cohen J, Marshall E. Bioterrorism. Vaccines for biodefense: a system in distress. Science. Oct 19. 2001;294(5542):498-501. Does not address regionalization. [pmid: 11641476].
96 Cohen J. Bioterrorism. Blocking smallpox: a second defense. Science. Oct 19. 2001;294(5542):500. Does not address regionalization. [pmid: 11641477].
97 Coignard B. Bioterrorism preparedness and response in European public health institutes. Euro Surveill. Nov. 2001;6(11):159-166. Does not address regionalization. [pmid: 11891386].
98 Coile R C Jr. U.S. hospitals, physicians playing “catch-up” on bioterrorism. Russ Coiles Health Trends. Dec. 2001;14(2):2-3. Opinion or editorial. [pmid: 11765713].
99 Cole L A. Risks of publicity about bioterrorism: anthrax hoaxes and hype. Am J Infect Control. Dec. 1999;27(6):470-473. Does not address regionalization. [pmid: 10586149].
100 Coleman E A. Smallpox in the ED. Am J Nurs. Sep. 2002;102(9):11. Does not address regionalization. [pmid: 12394009].
101 Colmers J M, Fox D M. The politics of emergency health powers and the isolation of public health. Am J Public Health. Mar. 2003;93(3):397-399. Does not address regionalization. [pmid: 12604480]. [pmcid: 1447751].
102 Cono J, Casey C G, Bell D M. Smallpox vaccination and adverse reactions. Guidance for clinicians. MMWR Recomm Rep. Feb 21. 2003;52(RR-4):1-28. Does not address regionalization. [pmid: 12617510].
103 Conrad D A. Coordinating patient care services in regional health systems: the challenge of clinical integration. Hosp Health Serv Adm. 1993;38(4):491-508. Does not describe bioterrorism-relevant response task. [pmid: 10130609].
104 Cordero J F. The epidemiology of disasters and adverse reproductive outcomes: lessons learned. Environ Health Perspect. 1993;101(Suppl 2):131-136. Does not describe bioterrorism-relevant response task. [pmid: 8243383]. [pmcid: 1519923].
105 County Public Health Preparedness. Washington, D.C.: National Association of Counties. Does not describe bioterrorism-relevant response task.
106 Crombie H D. Pasteur returns. Conn Med. Nov. 2001;65(11):689-690. Does not address regionalization. [pmid: 11766555].
107 Cross J T Jr, Altemeier W A 3rd. A pediatrician's view. Skin manifestations of bioterrorism. Pediatr Ann. Jan. 2000;29(1):7-9. Does not address regionalization. [pmid: 10941763].
108 Currie M. Smallpox nursing in Britain, Part II: Nursing care and nurse training. Int Hist Nurs J. 2001;6(2):59-65. Does not address regionalization. [pmid: 12143444].
109 Darling R G, Catlett C L, Huebner K D, Jarrett D G. Threats in bioterrorism. I: CDC category A agents. Emerg Med Clin North Am. May. 2002;20(2):273-309. Does not address regionalization. [pmid: 12120480].
110 Davis S. Engineering a terrorism defense. Health Facil Manage. Dec. 2001;14(12):14-17. Does not address regionalization. [pmid: 11799786].
111 Deaton H L, Hensley J. Taking the terror out of transport. Am J Nurs. Jun. 1990;90(6):58-60. Does not address regionalization. [pmid: 2346185].
112 Dee L G. Lessons learned from Hurricane Andrew. J Am Vet Med Assoc. Oct 1. 1993;203(7):986-988. Does not address regionalization. [pmid: 8226267].
113 DeJohn P. Innovation, cooperation keys to terror response. Hosp Mater Manage. Dec 2002;27(12):1, 9–10. Does not address regionalization.
114 Demuth JL. Countering Terrorism: Lessons Learned from Natural and Technological Disasters. Washington, D.C.: National Academy of Science; March 1, 2002. Does not address regionalization.
115 Dennis D T, Inglesby T V, Henderson D A, et al. Tularemia as a biological weapon: medical and public health management. JAMA. Jun 6. 2001;285(21):2763-2773. Does not address regionalization. [pmid: 11386933].
116 Dewan P K, Fry A M, Laserson K, et al. Inhalational anthrax outbreak among postal workers, Washington, D.C., 2001. Emerg Infect Dis. Oct. 2002;8(10):1066-1072. Does not address regionalization. [pmid: 12396917].
117 Diaz P S. The epidemiology and control of invasive meningococcal disease. Pediatr Infect Dis J. Jul. 1999;18(7):633-634. Does not address regionalization. [pmid: 10440442].
118 Donnellan C. New law funds nursing's role in bioterrorism response. The ANA establishes the National Nurses Response Team. Am J Nurs. Aug. 2002;102(8):23. Does not address regionalization. [pmid: 12394032].
119 Downs K E. Training requirements and opportunities in planning responses to bioterrorism. Am J Health Syst Pharm. Jul 15. 2002;59(14):1331-1332. Does not address regionalization. [pmid: 12132558].
120 Dull P M, Wilson K E, Kournikakis B, et al. Bacillus anthracis aerosolization associated with a contaminated mail sorting machine. Emerg Infect Dis. Oct. 2002;8(10):1044-1047. Does not address regionalization. [pmid: 12396913].
121 Elliott B. Bioterrorism, physician education, and the Internet. Del Med J. Dec. 2001;73(12):479-482. Does not address regionalization. [pmid: 11771483].
122 Ellis J M Jr. Medical care at the Super Bowl. J Med Assoc Ga. Jun. 2000;89(2):32-37. Does not address regionalization. [pmid: 10887746].
123 Emergency Health Powers Act. Richman K, trans. 2001-02 Regular Session ed; 2002. Does not address regionalization.
124 Emergency Plan for the Dock Sud Area, Port of Bs As City. Buenos Aires: Municipality of Buenos Aires; January 2001. Does not address regionalization.
125 Enserink M. Biosafety labs. The war on bioterror moves west. Science. Feb 7. 2003;299(5608):814. Does not address regionalization. [pmid: 12574601].
126 Enserink M. Fort Detrick. On biowarfare's frontline. Science. Jun 14. 2002;296(5575):1954-1956. Does not address regionalization. [pmid: 12065815].
127 Etzioni A. Public health law: a communitarian perspective. Health Aff. Nov-Dec. 2002;21(6):102-104. Does not address regionalization.
128 Evans G. Bioterrorism watch. Traumatized health care providers may need stress counseling in horrific aftermath of bioterror attack. Hosp Peer Rev. May 2002;27(5):suppl 1–3. Does not address regionalization.
129 Evans G. Bioterrorism Watch: Clinicians Must Be Voice of Reason, Reassurance Now That Bioterrorism Battle Has Been Joined. ED Manag. Nov 2001;13(11):suppl 1–4, suppl 1. Does not address regionalization.
130 Evans G. Clinicians must be voice of reason, reassurance now that bioterrorism battle has been joined. Hosp Case Manag. Dec 2001;9(12):suppl 1–3. Does not address regionalization.
131 Evans R G, Crutcher J M, Shadel B, Clements B, Bronze M S. Terrorism from a public health perspective. Am J Med Sci. Jun. 2002;323(6):291-298. Does not address regionalization. [pmid: 12074484].
132 Feigin R D, Baker C J, Herwaldt L A, Lampe R M, Mason E O, Whitney S E. Epidemic meningococcal disease in an elementary-school classroom. N Engl J Med. Nov 11. 1982;307(20):1255-1257. Does not address regionalization. [pmid: 6813733].
133 Fenstersheib M. Alleged Anthrax Exposure: Guidelines for Physicians. San Jose, CA; 2001. Does not address regionalization.
134 Fidler D P. The malevolent use of microbes and the rule of law: legal challenges presented by bioterrorism. Clin Infect Dis. Sep 1. 2001;33(5):686-689. Does not address regionalization. [pmid: 11486291].
135 Fierer J, Kirkland T. Questioning CDC's “select agent” criteria. Science. Jan 4. 2002;295(5552):43. Does not address regionalization. [pmid: 11780643].
136 Flahault A, Dias-Ferrao V, Chaberty P, Esteves K, Valleron A J, Lavanchy D. FluNet as a tool for global monitoring of influenza on the Web. JAMA. Oct 21. 1998;280(15):1330-1332. Does not address regionalization. [pmid: 9794312].
137 Flatow I. Current efforts to monitor for bioterrorism. National Public Radio. January 31, 2003. Does not address regionalization.
138 Flemmer M. Saboteurs in our salad?. Am J Gastroenterol. Feb. 1998;93(2):278-279. Opinion or editorial. [pmid: 9468264].
139 Fox J L. US anti-bioterror efforts swiftly expanding. Nat Biotechnol. Dec. 2001;19(12):1091. Does not address regionalization. [pmid: 11731763].
140 Fox J L. US expands anti-bioterrorist measures. Nat Biotechnol. Nov. 2001;19(11):998-1000. Does not address regionalization. [pmid: 11689831].
141 Foy H M, Nolan C M, Allan I D. Epidemiologic aspects of M. pneumoniae disease complications: a review. Yale J Biol Med. Sep-Dec. 1983;56(56):469-473. Does not address regionalization. [pmid: 6382821].
142 Franz D R, Zajtchuk R. Biological terrorism: understanding the threat, preparation, and medical response. Dis Mon. Feb. 2000;46(2):125-190. Does not address regionalization. [pmid: 10742828].
143 From the Centers for Disease Control and Prevention. Additional options for preventive treatment for exposed persons to inhalational anthrax. JAMA. Feb 6. 2002;287(5):579. Does not address regionalization. [pmid: 11838446].
144 From the Centers for Disease Control and Prevention. Interim guidelines for investigation of and response to Bacillus anthracis exposures. JAMA. Nov 28. 2001;286(20):2540-2541. Does not address regionalization. [pmid: 11763848].
145 From the Centers for Disease Control and Prevention. Investigation of bioterrorism-related anthrax, 2001. JAMA. Dec 5. 2001;286(21):2662-2663. Does not address regionalization. [pmid: 11787482].
146 From the Centers for Disease Control and Prevention. Outbreak of aseptic meningitis--Whiteside County, Illinois, 1995. JAMA. Apr 23–30. 1997;277(16):1272-1273. Does not address regionalization. [pmid: 9109455].
147 From the Centers for Disease Control and Prevention. Public health dispatch: update: cutaneous anthrax in a laboratory worker-Texas, 2002. JAMA. Jul 24–31. 2002;288(4):444. Does not address regionalization. [pmid: 12141318].
148 From the Centers for Disease Control and Prevention. Recommendations for antimicrobial prophylaxis for children and breastfeeding mothers and treatment of children with anthrax. JAMA. Dec 5. 2001;286(21):2663-2664. Does not address regionalization. [pmid: 11763855].
149 From the Centers for Disease Control and Prevention. Risk for meningococcal disease associated with the Hajj 2001. JAMA. Mar 21. 2001;285(11):1438. Does not address regionalization. [pmid: 11336047].
150 From the Centers for Disease Control and Prevention. Update: Assessment of risk for meningococcal disease associated with the Hajj 2001. JAMA. Apr 18. 2001;285(15):1956. Does not address regionalization. [pmid: 11336047].
151 From the Centers for Disease Control. Aseptic meningitis--New York State and United States, weeks 1–36, 1991. JAMA. Dec 18. 1991;266(23):3267. Does not address regionalization. [pmid: 1960819].
152 Gadus A, Koverman R B. Guarding your hospital from terrorism: the Cleveland Clinic Foundation plan. J Healthc Prot Manage. 1985;1(2):99-104. Does not address regionalization. [pmid: 10272292].
153 Gallo R J, Campbell D. Bioterrorism: challenges and opportunities for local health departments. J Public Health Manag Pract. Jul. 2000;6(4):57-62. Does not address regionalizaiton. [pmid: 10977614].
154 Garrett L. Responding to the nightmare of bioterrorism. Responsive Community. Winter 2001;12(1):88–93. Does not address regionalization.
155 Garrett L. The collapse of global public health and why it matters for New York. J Urban Health. Jun. 2001;78(2):403-409. Does not describe a bioterrorism-relevant response task. [pmid: 11419592].
156 Garrett L. Understanding media's response to epidemics. Public Health Rep. 2001;116(Suppl 2):87-91. Does not address regionalization. [pmid: 11880679]. [pmcid: 1497272].
157 Garrett L C, Magruder C, Molgard C A. Taking the terror out of bioterrorism: planning for a bioterrorist event from a local perspective. J Public Health Manag Pract. Jul. 2000;6(4):1-7. Does not address regionalization. [pmid: 10977608].
158 Gaunt P N. Audit in infection control--data analysis and infections in the intensive care unit. J Hosp Infect. Aug. 1993;24(4):291-300. Does not address regionalization. [pmid: 8104988].
159 Geiger H J. Terrorism, biological weapons, and bonanzas: assessing the real threat to public health. Am J Public Health. May. 2001;91(5):708-709. Does not address regionalization. [pmid: 11344875]. [pmcid: 1446684].
160 Gensheimer K F, Fukuda K, Brammer L, Cox N, Patriarca P A, Strikes R A. Preparing for pandemic influenza: the need for enhanced surveillance. Vaccine. May 15. 2002;20(Suppl 2):S63-65. Does not address regionalization. [pmid: 12110262].
161 Gerberding J L. Faster… but fast enough? Responding to the epidemic of severe acute respiratory syndrome. N Engl J Med. May 15. 2003;348(20):2030-2031. Does not address regionalization. [pmid: 12672880].
162 Gewolb J. Bioterrorism. Labs tighten security, regardless of need. Science. Nov 16. 2001;294(5546):1437. Does not address regionalization. [pmid: 11711648].
163 Gilmore JS. First Annual Report to the President and the Congress of the Advisory Panel to Assess Domestic Response Capabilities for Terrorism Involving Weapons of Mass Destruction: Advisory Panel to Assess Domestic Response Capabilities for Terrorism Involving Weapons of Mass Destruction; December 15 1999. Does not address regionalization.
164 Giordano B P. Hurricanes Andrew and Iniki are still with us. Aorn J. Nov. 1992;56(5):829-830. Does not address regionalization. [pmid: 1444341].
165 Giovachino M, Carey N. Modeling the consequences of bioterrorism response. Mil Med. Nov. 2001;166(11):925-930. Does not address regionalization. [pmid: 11725318].
166 Global Epidemic Detection and Response. World Health Organization. Available at: http://www.who.int/emc/surveillindex.html. Accessed March 1, 2003. Does not address regionalization.
167 Gold R. Epidemiology of meningococcal disease in light of recent Hajj-associated outbreaks. Clin Infect Dis. Mar 15. 2003;36(6):684-686. Does not address regionalization. [pmid: 12627351].
168 Goldman B. Spectator events: medical preparation a must. CMAJ. Jan 15. 1988;138(2):164-165. Does not address regionalization. [pmid: 3334930]. [pmcid: 1267559].
169 Gonzales J. A Report from the Front Lines: Safeguarding America's Communities from Terrorism: National Association of Counties. Does not address regionalization.
170 Gordon J A. Casualty evacuation in the Rhodesian terrorist war. S Afr Med J. Nov 12. 1977;52(21):856-860. Does not address regionalization. [pmid: 609961].
171 Gordon SM. The threat of bioterrorism: a reason to learn more about anthrax and smallpox. Cleve Clin J Med. Nov-Dec 1999;66(10):592–595, 599–600. Does not address regionalization.
172 Gostin L O. Law and ethics in a public health emergency. Hastings Cent Rep. Mar-Apr. 2002;32(2):9-11. Does not address regionalization. [pmid: 12360777].
173 Gourlay M, Siwek J. Resources in the war against bioterrorism. Am Fam Physician. Nov 15 2001;64(10):1676, 1678. Does not address regionalization.
174 Grabenstein J D. Public and patient concerns in catastrophic circumstances. Am J Health Syst Pharm. May 15. 2002;59(10):923-925. Does not address regionalization. [pmid: 12040729].
175 Grady D, Altman LK. Experts See Gains and Gaps in Planning for Terror Attack. New York Times. March 25, 2003. Does not address regionalization.
176 Greaves I. Terrorism--new threats, new challenges?. J R Army Med Corps. Jun. 2001;147(2):142-146. Does not address regionalization. [pmid: 11464404].
177 Greenberg M I, Jurgens S M, Gracely E J. Emergency department preparedness for the evaluation and treatment of victims of biological or chemical terrorist attack. J Emerg Med. Apr. 2002;22(3):273-278. Does not address regionalization. [pmid: 11932091].
178 Greene J, Gardner E, Lutz S. Andrew pounds states, hospitals. Mod Healthc. Aug 31. 1992;22(35):2-3. Does not address regionalization. [pmid: 10122212].
179 Greene J, Weissenstein E. Hospitals mounting efforts to aid Andrew-hit hospitals. Mod Healthc. Sep 7. 1992;22(36):4. Does not address regionalization. [pmid: 10121634].
180 Greene J. Atlanta hospitals nimbly respond to Olympics emergency. Mod Healthc. Aug 5. 1996;26(32):2-3. Does not address regionalization. [pmid: 10158973].
181 Greene J. Hospitals learn lessons from Andrew. Mod Healthc. Aug 30. 1993;23(35):6. Opinion or editorial. [pmid: 10127950].
182 Gresham R. Going … going … gone? Federal Emergency Management Agency. Emerg Med Serv. Jan. 1994;23(1):42-52. Does not address regionalization. [pmid: 10131244].
183 Gunter E W. Biological and environmental specimen banking at the Centers for Disease Control and Prevention. Chemosphere. May. 1997;34(910):1945-1953. Does not address regionalization. [pmid: 9159897].
184 Guynn J B Jr. Disaster imminent--Hurricane Hugo. Hosp Pharm. Apr. 1990;25(4):325-328. Does not address regionalization. [pmid: 10104388].
185 Hagstad D. Emergency: Bioterrorism. Am J Nurs. Dec. 2000;100(12):33-35. Does not address regionalization. [pmid: 11202782].
186 Haines J D, Pitts K, Crutcher J M. Medical response to bioterrorism: are we prepared?. J Okla State Med Assoc. May. 2000;93(5):187-196. Does not address regionalization. [pmid: 10826225].
187 Hall S D, Herbold J, England E C. Food for thought: the use of hazard and critical control point analysis to assess vulnerability of food to terrorist attack in deployment locations. Mil Med. Dec. 2002;167(12):1006-1011. Does not address regionalization. [pmid: 12502176].
188 Hamburg M A. Bioterrorism: responding to an emerging threat. Trends Biotechnol. Jul. 2002;20(7):296-298. Does not address regionalization. [pmid: 12062974].
189 Hamer J. Response to ski lift disaster by rural Canadian clinic. J Emerg Nurs. Apr. 1997;23(2):142-147. Does not address regionalization. [pmid: 9216286].
190 Hampson G V, Cook S P, Frederiksen S R. Operation Bali assist. Med J Aust. Dec 2–16. 2002;177(1112):620-623. Does not address regionalization. [pmid: 12463980].
191 Harling R, Twisselmann B, Asgari-Jirhandeh N, et al. Deliberate releases of biological agents: initial lessons for Europe from events in the United States. Euro Surveill. Nov. 2001;6(11):166-171. Does not address regionalization. [pmid: 11891387].
192 Harris R D, Grabenstein J D. What I need to know about anthrax today. J Ky Med Assoc. Dec. 2001;99(12):528-532. Opinion or editorial. [pmid: 11787310].
193 Harris R D. Medical log: forward command Thredbo. Med J Aust. Dec 1–15. 1997;167(1112):627-629. Does not address regionalization. [pmid: 9418807].
194 Hart C A, Beeching N J. Prophylactic treatment of anthrax with antibiotics. BMJ. Nov 3. 2001;323(7320):1017-1018. Does not address regionalization. [pmid: 11691746]. [pmcid: 1121531].
195 Harty-Golder B. How do labs report bioterrorism agents?. MLO Med Lab Obs. Oct. 2002;34(10):19. Does not address regionalization. [pmid: 12385172].
196 Harvey P. The impact of coordinated care: Eyre region, South Australia 1997-1999. Aust J Rural Health. Apr. 2001;9(2):69-73. Does not describe bioterrorism-relevant response task. [pmid: 11259959].
197 Hayward M. Management issues surrounding the United Kingdom health services' ability to deal effectively with major incidents involving bioterrorism. J Nurs Manag. May. 2003;11(3):197-207. Does not address regionalization. [pmid: 12694367].
198 Health Care Response to Bioterrorism: … What it is … What you can do; June 5, 2000; San Francisco, CA. Does not address regionalization.
199 Henderson D A. About the First National Symposium on Medical and Public Health Response to Bioterrorism. Emerg Infect Dis. July-August. 1999;5(4):491. Opinion or editorial. [pmid: 10458947].
200 Henderson D A. Bioterrorism as a public health threat. Emerg Infect Dis. Jul-Sep. 1998;4(3):488-492. Does not address regionalization. [pmid: 9716981].
201 Henderson DA. Bioterrorism. Int J Clin Pract Suppl. Dec 2000(115):32–36. Does not address regionalization.
202 Henretig F. Biological and chemical terrorism defense: a view from the “front lines” of public health. Am J Public Health. May. 2001;91(5):718-720. Does not address regionalization. [pmid: 11344878]. [pmcid: 1446658].
203 Henretig F M, Cieslak T J, Kortepeter M G, Fleisher G R. Medical management of the suspected victim of bioterrorism: an algorithmic approach to the undifferentiated patient. Emerg Med Clin North Am. May. 2002;20(2):351-364. Does not address regionalization. [pmid: 12120483].
204 Herrmann J, Smith J L. Hospitals continue struggle with hurricane aftermath. Health Syst Rev. Nov-Dec. 1992;25(6):13-16. Does not address regionalization. [pmid: 10122845].
205 Herrmann J. Investor-owned hospitals respond to Andrew's devastation. Health Syst Rev. Sep-Oct 1992;25(5):6, 16. Does not address regionalization.
206 Hilleman M R. Overview: cause and prevention in biowarfare and bioterrorism. Vaccine. Aug 19. 2002;20(2526):3055-3067. Does not address regionalization. [pmid: 12163257].
207 Hoard M L, Williams J M, Helmkamp J C, Furbee P M, Manley W G, Russell F K. Preparing at the local level for events involving weapons of mass destruction. Emerg Infect Dis. Sep. 2002;8(9):1006-1007. Does not address regionalization. [pmid: 12194786].
208 Hodge JG, Jr. Bioterrorism law and policy: critical choices in public health. J Law Med Ethics. Summer 2002;30(2):254–261. Does not address regionalization.
209 Hogan D E, Waeckerle J F, Dire D J, Lillibridge S R. Emergency department impact of the Oklahoma City terrorist bombing. Ann Emerg Med. Aug. 1999;34(2):160-167. Does not address regionalization. [pmid: 10424916].
210 Holdstock D. Bioterrorism and the Biological Weapons Convention--the wider context. Med Confl Surviv. Apr-Jun. 2002;18(2):107-109. Does not address regionalization. [pmid: 12044021].
211 Holdsworth G M, Breathnach A, Asboe D, et al. Controlled management of public relations following a public health incident. J Public Health Med. Sep. 1999;21(3):251-254. Does not address regionalization. [pmid: 10528951].
212 Holsenbeck L S. Joint Task Force Andrew: the 44th Medical Brigade mental health staff officer's after action review. Mil Med. Mar. 1994;159(3):186-191. Does not address regionalization. [pmid: 8041460].
213 Horton HH, Misrahi JJ, Matthews GW, Kocher PL. Critical biological agents: disease reporting as a tool for determining bioterrorism preparedness. J Law Med Ethics. Summer 2002;30(2):262–266. Does not address regionalization.
214 Hubalek Z. European experience with the West Nile virus ecology and epidemiology: could it be relevant for the New World?. Viral Immunol. 2000;13(4):415-426. Does not address regionalization. [pmid: 11192288].
215 Hudson P J, Vogt R L, Heun E M, et al. Evidence for school transmission of Neisseria meningitidis during a Vermont outbreak. Pediatr Infect Dis. Mar-Apr. 1986;5(2):213-217. Does not address regionalization. [pmid: 3081880].
216 Huerta M, Balicer R D, Leventhal A. SWOT analysis: strengths, weaknesses, opportunities and threats of the Israeli Smallpox Revaccination Program. Isr Med Assoc J. Jan. 2003;5(1):42-46. Does not address regionalization. [pmid: 12592958].
217 Hurlburt EL, Jones AR. Blood Bank Inventory Control. 1963:126–133. Does not address regionalization.
218 Huycke M M. Smallpox in the post-eradication era. J Okla State Med Assoc. Nov. 2002;95(11):725-728. Does not address regionalization. [pmid: 12471737].
219 Hyams K C, Murphy F M, Wessely S. Responding to chemical, biological, or nuclear terrorism: the indirect and long-term health effects may present the greatest challenge. J Health Polit Policy Law. Apr. 2002;27(2):273-291. Does not address regionalization. [pmid: 12043900].
220 In the wake of Hurricane Hugo's devastation, Charleston nurses are picking up the pieces. Am J Nurs. Nov 1989;89(11):1535, 1556. Does not address regionalization.
221 Inglesby T V, Henderson D A, Bartlett J G, et al. Anthrax as a biological weapon: medical and public health management. Working Group on Civilian Biodefense. Jama. May 12. 1999;281(18):1735-1745. Does not address regionalization. [pmid: 10328075].
222 Inglesby T V, O'Toole T, Henderson D A. Preventing the use of biological weapons: improving response should prevention fail. Clin Infect Dis. Jun. 2000;30(6):926-929. Does not address regionalization. [pmid: 10880302].
223 Irizarry A, Heitman B, Segarra M. Lessons learned from Hurricane Andrew. Nurse Pract. Dec 1992;17(12):18, 25. Does not address regionalization.
224 Jacobs L M, Ramp J M, Breay J M. An emergency medical system approach to disaster planning. J Trauma. Mar. 1979;19(3):157-162. Does not address regionalization. [pmid: 458880].
225 James JS. SARS Web information. AIDS Treat News. Apr 4 2003(390):6. Does not address regionalization.
226 Jernigan D B, Raghunathan P L, Bell B P, et al. Investigation of bioterrorism-related anthrax, United States, 2001: epidemiologic findings. Emerg Infect Dis. Oct. 2002;8(10):1019-1028. Does not address regionalization. [pmid: 12396909].
227 Jezierski M. Emergency nurses' response to Hurricane Andrew's devastation in southern Florida. J Emerg Nurs. Aug. 1993;19(4):370-371. Does not address regionalization. [pmid: 8350563].
228 Johnson D E. Hospitals are more ready for bioterrorism. Health Care Strateg Manage. Nov. 2001;19(11):2-3. Does not address regionalization. [pmid: 11799890].
229 Johnson R T, Irani D N. West Nile virus encephalitis in the United States. Curr Neurol Neurosci Rep. Nov. 2002;2(6):496-500. Does not address regionalization. [pmid: 12359102].
230 Jones J, Terndrup T E, Franz D R, Eitzen E M Jr. Future challenges in preparing for and responding to bioterrorism events. Emerg Med Clin North Am. May. 2002;20(2):501-524. Does not address regionalization. [pmid: 12120489].
231 Jones JW, Kiefe CI. Anthrax attacks and practice patterns: a learning opportunity for health care systems. Qual Manag Health Care. Spring 2002;10(3):31–39. Does not address regionalization.
232 Jones S. Heroes of Hurricane Andrew. Nursing. Mar. 1993;23(3):6. Opinion or editorial. [pmid: 8446321].
233 Jortani S A, Snyder J W, Valdes R Jr. The role of the clinical laboratory in managing chemical or biological terrorism. Clin Chem. Dec. 2000;46(12):1883-1893. Does not address regionalization. [pmid: 11106318].
234 Josefson D. Toll of anthrax cases reaches 15. BMJ. Nov 3. 2001;323(7320):1022. Does not address regionalization. [pmid: 11691753].
235 Josefson D. US fear of bioterrorism spreads as anthrax cases increase. BMJ. Oct 20. 2001;323(7318):883. Does not address regionalization. [pmid: 11668122].
236 Kampmier C H. Decontamination details. Suggested considerations for hospital ED decon rooms. Health Facil Manage. Nov. 2001;14(11):28-31. Does not address regionalization. [pmid: 11759194].
237 Katzman S. Preparing for the worst. The USA and Japan's preparations for a terrorist attack with chemical or biological weapons. EMBO Rep. Nov. 2000;1(5):387-389. Does not address regionalization. [pmid: 11258475]. [pmcid: 1083769].
238 Keating TP, Nesmith AW, Jr. Material management's role in disaster planning. J Healthc Mater Manage. Aug-Sep 1990;8(6):40, 42, 44–46. Does not address regionalization.
239 Keim M, Kaufmann A F. Principles for emergency response to bioterrorism. Ann Emerg Med. Aug. 1999;34(2):177-182. Does not address regionalization. [pmid: 10424919].
240 Kemp C. Bioterrorism: introduction and major agents. J Am Acad Nurse Pract. Nov. 2001;13(11):483-491. Does not address regionalization. [pmid: 11930512].
241 Kenar L, Karayilanoglu T, Kose S. Laboratory conditions and safety in a chemical warfare agent analysis and research laboratory. Mil Med. Aug. 2002;167(8):628-633. Does not address regionalization. [pmid: 12188231].
242 Kennedy E M. National leadership in confronting bioterrorism: 2. Public Health Rep. 2001;116(Suppl 2):116-118. Opinion or editorial. [pmid: 11880684]. [pmcid: 1497282].
243 Kerr G W, Wilkie S C, McGuffie C A. Medical cover at Scottish football matches: have the recommendations of the Gibson Report been met?. Br J Sports Med. Aug. 1999;33(4):274-275. Does not address regionalization. [pmid: 10450484].
244 Kerruish T. Media could be used to better effect than inducing fear. BMJ. Jan 12. 2002;324(7329):115. Opinion or editorial. [pmid: 11786467].
245 Kilic Y A, Agalar F A, Kunt M, Cakmakci M. Prospective, double-blind, comparative fast-tracking trial in an academic emergency department during a period of limited resources. Eur J Emerg Med. 1998;5(4):403-406. Does not address regionalization. [pmid: 9919444].
246 Kirtley J C. Success during these trying times. J Am Pharm Assoc. Jan-Feb. 2002;42(1):6-7. Does not address regionalization.
247 Kitler M E, Gavinio P, Lavanchy D. Influenza and the work of the World Health Organization. Vaccine. May 15. 2002;20(Suppl 2):S5-14. Does not address regionalization. [pmid: 12110248].
248 Kizer K W. Lessons learned in public health emergency management: personal reflections. Prehospital Disaster Med. Oct-Dec. 2000;15(4):209-214. Opinion or editorial. [pmid: 11227611].
249 Klinkenberg M. Defense tech. Training for terror. Sci Am. Sep. 2002;287(3):28-29. Does not address regionalization. [pmid: 12197097].
250 Kohane I S. The contributions of biomedical informatics to the fight against bioterrorism. J Am Med Inform Assoc. Mar-Apr. 2002;9(2):116-119. Does not address regionalization. [pmcid: 344565]. [pmid: 11861623].
251 Koplan J P, Falk H, Green G. Public health lessons from the Bhopal chemical disaster. JAMA. 1990;264(21):2795-2796. Does not address regionalization. [pmid: 2232066].
252 Kortepeter M G, Cieslak T J, Eitzen E M. Bioterrorism. J Environ Health. Jan-Feb. 2001;63(6):21-24. Does not address regionalization. [pmid: 11381472].
253 Kraut A, Mullan F, Riegelman R, Etzioni A. Public health in the age of bioterrorism. Responsive Community. Spring 2002;12(2):59–70. Does not address regionalization.
254 Kron S, Mendlovic S. Mental health consequences of bioterrorism. Isr Med Assoc J. Jul. 2002;4(7):524-527. Does not address regionalization. [pmid: 12120464].
255 Krueger G P. Psychological and performance effects of chemical-biological protective clothing and equipment. Mil Med. Dec. 2001;166(12 Suppl):41-43. Does not address regionalization. [pmid: 11778430].
256 Kuhr S, Hauer J M. Intergovernmental preparedness and response to potential catastrophic biological terrorism. J Public Health Manag Pract. Jul. 2000;6(4):50-56. Does not address regionalization. [pmid: 10977613].
257 Kwik G, Fitzgerald J, Inglesby T, O'Toole T. Biosecurity: Responsible Stewardship of Bioscience in an Age of Catastrophic Terrorism. Biosecurity and Bioterrorism: Biodefense Strategy, Science, and Practice. 2003;1(1). Does not address regionalization.
258 Lamb A. Biological weapons: the facts not the fiction. Clin Med. Nov-Dec. 2001;1(6):502-504. Does not address regionalization. [pmid: 11792093].
259 Landrigan P J. Health consequences of the 11 September 2001 attacks. Environ Health Perspect. Nov. 2001;109(11):A514-515. Does not address regionalization. [pmid: 11713006].
260 Lane H C, Fauci A S. Bioterrorism on the home front: a new challenge for American medicine. JAMA. Nov 28. 2001;286(20):2595-2597. Does not address regionalization. [pmid: 11722275].
261 Lane H C, Montagne J L, Fauci A S. Bioterrorism: a clear and present danger. Nat Med. Dec. 2001;7(12):1271-1273. Opinion or editorial. [pmid: 11726956].
262 Lanser E G. America under attack: ACHE affiliates respond. Healthc Exec. Mar-Apr. 2002;17(2):12-18. Does not address regionalization. [pmid: 11892451].
263 Laughrun G M. Preparing your hospital to respond to a terrorist attack. Am J Health Syst Pharm. Jul 15. 2002;59(14):1329-1330. Does not address regionalization. [pmid: 12132557].
264 LeDuc J W, Becher J. Current status of smallpox vaccine. Emerg Infect Dis. Jul-Aug. 1999;5(4):593-594. Does not address regionalization. [pmid: 10458973].
265 LeDuc J W, Damon I, Relman D A, Huggins J, Jahrling P B. Smallpox research activities: U.S. interagency collaboration, 2001. Emerg Infect Dis. Jul. 2002;8(7):743-745. Does not address regionalization. [pmid: 12095449].
266 Levenson D. CDC: be alert to symptoms associated with bioterrorism. Rep Med Guidel Outcomes Res. Nov 1 2001;12(21):1–2, 5. Does not address regionalization.
267 Lewicki G. Fiery plane crash finds Little Rock hospitals ready to handle influx of media and public attention. Profiles Healthc Mark. Sep-Oct. 1999;15(5):44-45. Does not address regionalization. [pmid: 10621480].
268 Li T S, Buckley T A, Yap F H, Sung J J, Joynt G M. Severe acute respiratory syndrome (SARS): infection control. Lancet. Apr 19. 2003;361(9366):1386. Does not address regionalization. [pmid: 12711488].
269 Lichtveld M, Hodge JG, Jr., Gebbie K, Thompson FE, Jr., Loos DI. Preparedness on the frontline: what's law got to do with it? J Law Med Ethics. Fall 2002;30(3 Suppl):184–188. Does not address regionalization.
270 Lightfoot N, Wale M, Spencer R, Nicoll A. Appropriate responses to bioterrorist threats. BMJ. Oct 20. 2001;323(7318):877-878. Does not address regionalization. [pmid: 11668117]. [pmcid: 1121424].
271 Logan-Henfrey L. Mitigation of bioterrorist threats in the 21st century. Ann N Y Acad Sci. 2000;916:121-133. Does not address regionalization. [pmid: 11193612].
272 Lord E J. Exercises involving an act of biological or chemical terrorism: what are the psychological consequences?. Mil Med. Dec. 2001;166(12 Suppl):34-35. Does not address regionalization. [pmid: 11778427].
273 Lorin H G, Kulling P E. The Bhopal tragedy--what has Swedish disaster medicine planning learned from it?. J Emerg Med. 1986;4(4):311-316. Does not address regionalization. [pmid: 3794283].
274 Lovern E. Sketchy isn't best. Hospitals fault feds for poor anthrax guidance. Mod Healthc. Oct 29. 2001;31(44):8. Does not address regionalization. [pmid: 11765371].
275 Lynch M. Grace under pressure. Drills become reality during California's 'quake and Hurricane Hugo. Adm Radiol. Nov 1989;8(11):66–69, 71. Does not address regionalization.
276 Lyons K. Is your hospital prepared to treat hundreds of victims of a terrorist attack? J Healthc Prot Manage. Winter 1999;16(1):20–24. Does not address regionalization.
277 Mac Sheoin T. Bhopal: a bibliography. Int J Health Serv. 1986;16(3):441-468. Does not address regionalization. [pmid: 3525436].
278 Malakoff D. Bioterrorism. Security rules leave labs wanting more guidance. Science. Feb 21. 2003;299(5610):1175. Does not address regionalization. [pmid: 12595669].
279 Management of asymptomatic pregnant or lactating women exposed to anthrax. Int J Gynaecol Obstet. Jun 2002;77(3):293–295. Does not address regionalization.
280 Marghella PD. Medical planning considerations in consequence management. Front Health Serv Manage. Fall 2002;19(1):15–23. Does not address regionalization.
281 Mark McClellan, FDA commissioner, on antibioterror initiative. Boston Globe. March 23, 2003. Opinion or editorial.
282 Marmar C R, Weiss D S, Metzler T J, Delucchi K L, Best S R, Wentworth K A. Longitudinal course and predictors of continuing distress following critical incident exposure in emergency services personnel. J Nerv Ment Dis. Jan. 1999;187(1):15-22. Does not address regionalization. [pmid: 9952249].
283 Marmar C R, Weiss D S, Metzler T J, Ronfeldt H M, Foreman C. Stress responses of emergency services personnel to the Loma Prieta earthquake Interstate 880 freeway collapse and control traumatic incidents. J Trauma Stress. Jan. 1996;9(1):63-85. Does not address regionalization. [pmid: 8750452].
284 Marshall E. Bioterrorism. DOD retreats on plan for anthrax vaccine. Science. Jul 21. 2000;289(5478):382-383. Does not address regionalization. [pmid: 10939944].
285 Mason D J. Anthrax and the voice of reason. Am J Nurs. Dec. 2001;101(12):7. Does not address regionalization. [pmid: 12585054].
286 Massey R U. Anthrax. Conn Med. Nov. 2001;65(11):693. Opinion or editorial. [pmid: 11766556].
287 Matthews GW, Benjamin G, Mills SP, Parmet W, Misrahi JJ. Legal preparedness for bioterrorism. J Law Med Ethics. Fall 2002;30(3 Suppl):52–56. Does not address regionalization.
288 Mayer T A, Bersoff-Matcha S, Murphy C, et al. Clinical presentation of inhalational anthrax following bioterrorism exposure: report of 2 surviving patients. JAMA. Nov 28. 2001;286(20):2549-2553. Does not address regionalization. [pmid: 11722268].
289 McCally M, Garg A, Oleskey C. The challenges of emerging illness in urban environments: an overview. J Urban Health. Jun. 2001;78(2):350-358. Does not address regionalization. [pmid: 11419585].
290 McCarthy M. Anthrax attack in the USA. Lancet Infect Dis. Dec. 2001;1(5):288-289. Does not address regionalization. [pmid: 11871791].
291 McDonnell S, Hlady W G. In the wake of Hurricane Andrew. JAMA. Jun 21. 1995;273(23):1832-1833. Does not address regionalization. [pmid: 7776494].
292 McFee R B. Adolescent health and terrorism--the role of the adolescent medicine specialist. J Adolesc Health. May. 2002;30(5):300-301. Does not address regionalization. [pmid: 11996777].
293 McFee R B. Preparing for an era of weapons of mass destruction (WMD). Are we there yet? Why we should all be concerned. Part 1. Vet Hum Toxicol. Aug. 2002;44(4):193-199. Does not address regionalization. [pmid: 12136963].
294 Meltzer M I, Damon I, LeDuc J W, Millar J D. Modeling potential responses to smallpox as a bioterrorist weapon. Emerg Infect Dis. Nov-Dec. 2001;7(6):959-969. Does not address regionalization. [pmid: 11747722].
295 Miara-Rezutek K, Montoya K, Cross M. When disaster strikes, is your lab prepared?. MLO Med Lab Obs. Jan. 1995;27(1):24-27. Does not address regionalization. [pmid: 10139547].
296 Milsten A. Hospital responses to acute-onset disasters: a review. Prehospital Disaster Med. Jan-Mar. 2000;15(1):32-45. Does not address regionalization. [pmid: 11066840].
297 Ministries of Health and national surveillance institutes around the world. World Health Organization. Available at: http://www.who.int/emc/surveill/mohglobal.html. Does not address regionalization.
298 Mitka M. Bioterror Exercise Tests Agencies' Mettle. JAMA. June 11. 2003;289(22):2927-2928. Does not address regionalization. [pmid: 12799390].
299 Mohle-Boetani J C, Matkin C, Pallansch M, et al. Viral meningitis in child care center staff and parents: an outbreak of echovirus 30 infections. Public Health Rep. May-Jun. 1999;114(3):249-256. Does not address regionalization. [pmid: 10476994]. [pmcid: 1308476].
300 Moles T M. Emergency medical services systems and HAZMAT major incidents. Resuscitation. Oct. 1999;42(2):103-116. Does not address regionalization. [pmid: 10617329].
301 Molitor L. Coping, caring, and heroism in the wake of Hurricane Andrew. J Emerg Nurs. Jun. 1993;19(3):37A-42A. Does not address regionalization. [pmid: 8510376].
302 Moore M, Baron R C, Filstein M R, et al. Aseptic meningitis and high school football players. 1978 and 1980. JAMA. Apr 15. 1983;249(15):2039-2042. Does not address regionalization. [pmid: 6300476].
303 Moreno JD. Bioethics after the terror. Am J Bioeth. Winter 2002;2(1):60–64. Does not address regionalization.
304 Morse A. Bioterrorism preparedness for local health departments. J Community Health Nurs. Winter 2002;19(4):203–211. Does not address regionalization.
305 Mott J A, Treadwell T A, Hennessy T W, et al. Call-tracking data and the public health response to bioterrorism-related anthrax. Emerg Infect Dis. Oct. 2002;8(10):1088-1092. Does not address regionalization. [pmid: 12396921].
306 Mullin S. Public health and the media: the challenge now faced by bioterrorism. J Urban Health. Mar. 2002;79(1):12. Does not address regionalization. [pmid: 11937610].
307 Munro I, Brennan M. Lessons of Chernobyl. BMJ. Jan 25. 1992;304(6821):254-255. Does not describe bioterrorism-relevant response task. [pmid: 1739813].
308 Murlidhar V. The Bhopal tragedy. Natl Med J India. 1994;7(3):150-151. Does not describe bioterrorism-relevant response task. [pmid: 8069212].
309 Murray V, Goodfellow F. Mass casualty chemical incidents--towards guidance for public health management. Public Health. Jan. 2002;116(1):2-14. Does not address regionalization. [pmid: 11896630].
310 NACo's Call to Action for President Bush, Congress and the American People: National Association of Counties. Does not address regionalization.
311 Navas E. Problems associated with potential massive use of antimicrobial agents as prophylaxis or therapy of a bioterrorist attack. Clin Microbiol Infect. Aug. 2002;8(8):534-539. Does not address regionalization. [pmid: 12197876].
312 Nestor A, Aviles A I, Kummerle D R, Barclay L P, Rey J A. Pharmaceutical services at a medical site after Hurricane Andrew. Am J Hosp Pharm. Sep. 1993;50(9):1896-1898. Does not address regionalization. [pmid: 8135236].
313 Nicoll A. Health services in the detection of and defence against bioterrorism. Hosp Med. Sep. 2002;63(9):519. Does not address regionalization. [pmid: 12357850].
314 Nierengarten M B. Positive response to US smallpox vaccine policy. Lancet Infect Dis. Feb. 2003;3(2):60. Does not address regionalization. [pmid: 12560175].
315 Noah D L, Huebner K D, Darling R G, Waeckerle J F. The history and threat of biological warfare and terrorism. Emerg Med Clin North Am. May. 2002;20(2):255-271. Does not address regionalization. [pmid: 12120479].
316 Noah D L, Sobel A L, Ostroff S M, Kildew J A. Biological warfare training. Infectious disease outbreak differentiation criteria. Ann N Y Acad Sci. 1999;894:37-43. Does not address regionalization. [pmid: 10681967].
317 Nolte K B, Yoon S S, Pertowski C. Medical examiners, coroners, and bioterrorism. Emerg Infect Dis. Sep-Oct. 2000;6(5):559-560. Does not address regionalization. [pmid: 10998392].
318 Nomura A, Takahashi T. The practical aspects of quality assurance in Good Laboratory Practice studies in an emergency situation. Qual Assur. Dec. 1995;4(4):366-373. Does not address regionalization. [pmid: 8890369].
319 Norcross E D, Elliott B M, Adams D B, Crawford F A. Impact of a major hurricane on surgical services in a university hospital. Am Surg. Jan. 1993;59(1):28-33. Does not include regionalization. [pmid: 8480928].
320 Nordberg M. Terrorism's bloody trail. Learning tragic lessons in scene safety from the Israelis. Emerg Med Serv. Aug 1996;25(8):70–74, 81. Does not address regionalization.
321 North C S, Pfefferbaum B. Research on the mental health effects of terrorism. JAMA. Aug 7. 2002;288(5):633-636. Does not address regionalization. [pmid: 12150676].
322 Notice of Emergency Rulemaking: California Department of Health Services. Does not address regionalization.
323 Nuclear, biological, and chemical decontamination. Jt Comm Perspect. Dec 2001;21(12):20–21. Does not address regionalization.
324 Nunn S. The future of public health preparedness. J Law Med Ethics. Fall 2002;30(3 Suppl):202–209. Does not address regionalization.
325 Obstacles to biodefence. Nature. Sep 5 2002;419(6902):1. Does not address regionalization.
326 O'Connell K P, Menuey B C, Foster D. Issues in preparedness for biologic terrorism: a perspective for critical care nursing. AACN Clin Issues. Aug. 2002;13(3):452-469. Does not address regionalization. [pmid: 12151997].
327 Orient JM. Bioterrorism and public health law. JAMA. Dec 4 2002;288(21):2686; author reply 2686–2687. Does not address regionalization.
328 Osterholm M T. Bioterrorism: media hype or real potential nightmare?. Am J Infect Control. Dec. 1999;27(6):461-462. Does not address regionalization. [pmid: 10586145].
329 O'Toole T, Mair M, Inglesby T V. Shining light on “Dark Winter”. Clin Infect Dis. Apr 1. 2002;34(7):972-983. Does not address regionalization. [pmid: 11880964].
330 Outbreak of invasive pneumococcal disease in a jail--Texas, 1989. MMWR Morb Mortal Wkly Rep. Nov 3 1989;38(43):733–734. Does not address regionalization.
331 Pallentino J. Terrorism response resources for clinicians. Fla Nurse. Dec. 2001;49(4):4-6. Does not address regionalization. [pmid: 12080532].
332 Parry J. WHO issues global alert on respiratory syndrome. BMJ. Mar 22. 2003;326(7390):615. Does not address regionalization. [pmid: 12649215].
333 Patrick D M. The race to outpace severe acute respiratory syndrome (SARS). CMAJ. May 13. 2003;168(10):1265-1266. Does not address regionalization. [pmcid: 154183]. [pmid: 12743070].
334 Pavlin J A, Gilchrist M J, Osweiler G D, Woollen N E. Diagnostic analyses of biological agent-caused syndromes: laboratory and technical assistance. Emerg Med Clin North Am. May. 2002;20(2):331-350. Does not address regionalization. [pmid: 12120482].
335 Pavlin J A. Epidemiology of bioterrorism. Emerg Infect Dis. Jul-Aug. 1999;5(4):528-530. Does not address regionalization. [pmid: 10458958].
336 Perrotta D M, Ascher M S, Layton M. Bioterrorism initiatives: public health support. Am J Public Health. Aug. 2000;90(8):1327-1328. Does not address regionalization. [pmid: 10937024]. [pmcid: 1446343].
337 Persell DJ, Arangie P, Young C, et al. Preparing for bioterrorism: category A agents. Nurse Pract. Dec 2001;26(12):12–15, 19–24, 27; quiz 28–19. Does not address regionalization.
338 Pesik N, Keim M, Sampson T R. Do US emergency medicine residency programs provide adequate training for bioterrorism?. Ann Emerg Med. Aug. 1999;34(2):173-176. Does not address regionalization. [pmid: 10424918].
339 Pesik N, Keim M E, Iserson K V. Terrorism and the ethics of emergency medical care. Ann Emerg Med. Jun. 2001;37(6):642-646. Does not address regionalization. [pmid: 11385335].
340 Peterson L R, Hamilton J D, Baron E J, et al. Role of clinical microbiology laboratories in the management and control of infectious diseases and the delivery of health care. Clin Infect Dis. Feb 15. 2001;32(4):605-611. Does not address regionalization. [pmid: 11181125].
341 Petsko GA. Winter, plague and pestilence. Genome Biol. 2001;2(11). Opinion or editorial.
342 Pile JC, Longworth DL. Bioterrorism: what practicing physicians can do. Cleve Clin J Med. Dec 2001;68(12):998, 1000. Does not address regionalization.
343 Piotrowski J. Diplomatic immunity. Smallpox safeguard for healthcare workers plagued by logistical issues. Mod Healthc. Jul 29. 2002;32(30):32-33. Does not address regionalization. [pmid: 12195666].
344 Piotrowski J. Smallpox, big worries. Preparing medical-response teams is easier said than done, according to healthcare providers across the nation. Mod Healthc. Jan 6 2003;33(1):6–7, 12–13, 11. Does not address regionalization.
345 Poe B M. Expanding disaster preparedness to include bioterrorism. Am J Health Syst Pharm. May 15. 2002;59(10):926-927. Does not address regionalization. [pmid: 12040730].
346 Poland S. Key players in crisis planning, response, and prevention. Nasnewsletter. Jan. 2003;18(1):25-26. Does not address regionalization. [pmid: 12613188].
347 Polgreen PM, Helms C. Vaccines, biological warfare, and bioterrorism. Prim Care. Dec 2001;28(4):807–821, vii. Does not address regionalization.
348 Polyak C S, Macy J T, Irizarry-De La Cruz M, et al. Bioterrorism-related anthrax: international response by the Centers for Disease Control and Prevention. Emerg Infect Dis. Oct. 2002;8(10):1056-1059. Does not address regionalization. [pmid: 12396915].
349 Poupard JA, Miller LA. Biological Warfare. Encyclopedia of Microbiology. Vol 1. 2nd ed: Academic Press; 2000. Does not address regionalization.
350 Powers MJ. Deterring Terrorism with CBRN Weapons: Developing a Conceptual Framework: CBACI; February 2001. Does not address regionalization.
351 Preparing the Nation: A Policy Summit on Bioterrorism. Paper presented at: Preparing the Nation: A Policy Summit on Bioterrorism, 2003; Washington, D.C. Does not address regionalization.
352 President Details Project BioShield. Available at: http://www.whitehouse.gov/news/releases/2003/02/20030203.html. Accessed March 12, 2003. Does not address regionalization.
353 bioterrorism: the role of Fort Detrick since 1970. WMJ. 2002;101(2):20–24. Does not address regionalization.
354 Program in Brief: State and Local Infrastructure. Centers for Disease Control and Prevention. Available at: http://bt.cdc.gov, 2003. Does not address regionalization.
355 Public Health Threats and Emergencies Act of 2000. Frist B, Kennedy E, trans. 106th Congress, Second session ed; 2000. Does not address regionalization.
356 Radetsky M S, Istre G R, Johansen T L, et al. Multiply resistant pneumococcus causing meningitis: its epidemiology within a day-care centre. Lancet. Oct 10. 1981;2(8250):771-773. Does not address regionalization. [pmid: 6116903].
357 Rapid health needs assessment following hurricane Andrew--Florida and Louisiana, 1992. MMWR Morb Mortal Wkly Rep. Sep 18 1992;41(37):685–688. Does not address regionalization.
358 Ratzan S C. Real risks: the need for health leadership and security. J Health Commun. Oct-Dec. 2001;6(4):295-296. Does not address regionalization. [pmid: 11783664].
359 Rawlings M. From ‘ground zero’. Health Facil Manage. Dec. 2001;14(12):18-21. Does not address regionalization. [pmid: 11799787].
360 Ready T. Bioterrorism threat becomes reality. Nat Med. Nov. 2001;7(11):1167. Does not address regionalization. [pmid: 11689863].
361 Reardon TF. EMS and disaster planning for the Winter Olympics. Emerg Med Serv. Nov-Dec 1979;8(6):88–90, 92, 199. Does not address regionalization.
362 Red Cross: Field Delegations. International Federation of Red Cross and Red Crescent Societies. Accessed November 12, 2002. Does not address regionalization.
363 Reissman S. EMS at the Democratic National Convention. J Emerg Med Serv JEMS. Nov. 1993;18(11):58-59. Does not address regionalization. [pmid: 10129834].
364 Revel J P. Meeting psychological needs after Chernobyl: the Red Cross experience. Mil Med. 2001;166(12 Suppl):19-20. Does not address regionalization. [pmid: 11778421].
365 Revised environment of care standards for the Comprehensive Accreditation Manual for Hospitals (CAMH). Jt Comm Perspect. 2001;21(12):suppl 2 p. following 20. Does not address regionalization.
366 Rice S K, Heinl R E, Thornton L L, Opal S M. Clinical characteristics, management strategies, and cost implications of a statewide outbreak of enterovirus meningitis. Clin Infect Dis. Apr. 1995;20(4):931-937. Does not address regionalization. [pmid: 7795097].
367 Richards C F, Burstein J L, Waeckerle J F, Hutson H R. Emergency physicians and biological terrorism. Ann Emerg Med. Aug. 1999;34(2):183-190. Does not address regionalization. [pmid: 10424920].
368 Richards E P. Collaboration between public health and law enforcement: the constitutional challenge. Emerg Infect Dis. Oct. 2002;8(10):1157-1159. Does not address regionalization. [pmid: 12396932].
369 Richmond C. The plain lawyer's guide to bioterrorism. Med Leg J. 2001;69(Pt 4):182-183. Does not address regionalization. [pmid: 11887760].
370 Richmond J Y, Nesby-O'Dell S. Biosecurity for animal facilities and associated laboratories. Lab Anim (NY). Jan. 2003;32(1):32-35. Does not address regionalization. [pmid: 12509785].
371 Risk for meningococcal disease associated with the Hajj 2001. MMWR Morb Mortal Wkly Rep. Feb 16 2001;50(6):97–98. Does not address regionalization.
372 Roffey R, Lantorp K, Tegnell A, Elgh F. Biological weapons and bioterrorism preparedness: importance of public-health awareness and international cooperation. Clin Microbiol Infect. Aug. 2002;8(8):522-528. Does not address regionalization. [pmid: 12197874].
373 Roffey R, Tegnell A, Elgh F. Biological warfare in a historical perspective. Clin Microbiol Infect. Aug. 2002;8(8):450-454. Does not address regionalization. [pmid: 12197867].
374 Rogers F J, Apsey D, Kantor K, Hann E, Dienst S. Medical preparedness: Chernobyl as a model for southeastern Michigan. JAMA. Aug 7. 1987;258(5):609. Does not address regionalization. [pmid: 3612979].
375 Rose J B. Environmental ecology of Cryptosporidium and public health implications. Annu Rev Public Health. 1997;18:135-161. Does not address regionalization. [pmid: 9143715].
376 Rose M A, Larrimore K L. Knowledge and awareness concerning chemical and biological terrorism: continuing education implications. J Contin Educ Nurs. Nov-Dec. 2002;33(6):253-258. Does not address regionalization. [pmid: 12442873].
377 Rosenfield A, Morse S S, Yanda K. September 11: the response and role of public health. Am J Public Health. Jan. 2002;92(1):10-11. Does not address regionalization. [pmid: 11772747]. [pmcid: 1447374].
378 Rosenfield R L, Bernardo L M. Pediatric implications in bioterrorism, part II: postexposure diagnosis and treatment. Int J Trauma Nurs. Oct-Dec. 2001;7(4):133-136. Does not address regionalization. [pmid: 11707769].
379 Rosenthal TC. Rural bioterrorism: are we exempt? J Rural Health. Winter 2003;19(1):5–6. Does not address regionalization.
380 Rosling L, Rosling M. Pneumonia causes panic in Guangdong province. BMJ. Feb 22. 2003;326(7386):416. Does not address regionalization. [pmid: 12595377].
381 Ryan J M, Sibson J, Howell G. Assessing injury severity during general war. Will the Military Triage system meet future needs?. J R Army Med Corps. Feb. 1990;136(1):27-35. Does not address regionalization. [pmid: 2319500].
382 Saathoff G, Everly GS, Jr. Psychological challenges of bioterror: containing contagion. Int J Emerg Ment Health. Fall 2002;4(4):245–252. Does not address regionalization.
383 Sachs E M. The bubonic man. Lessons from a bioterrorism incident. Emerg Med Serv. Aug. 2000;29(8):43-44. Does not address regionalization. [pmid: 11186485].
384 Samadani AM. A physician's notes for community education in bioterrorism. WMJ. 2002;101(2):10–11, 36. Opinion or editorial.
385 Scharoun K, van Caulil K, Liberman A. Bioterrorism vs. health security--crafting a plan of preparedness. Health Care Manag. Sep. 2002;21(1):74-92. Does not address regionalization.
386 Senate HELP Committee Approves Bush's Project Bioshield, But Not Compensation Method for Smallpox Vaccine. Kaiser Daily Health Policy Report. March 20, 2003. Does not address regionalization.
387 Sepkowitz K A. Anthrax and anthrax anxiety: Sverdlovsk revisited. Int J Infect Dis. 2001;5(4):178-179. Does not address regionalization. [pmid: 11962347].
388 Shadel B N, Clements B, Arndt B, Rebmann T, Evans R G. What we need to know about bioterrorism preparedness: results from focus groups conducted at APIC 2000. Am J Infect Control. Dec. 2001;29(6):347-351. Does not address regionalization. [pmid: 11743480].
389 Shah N D, Vermeulen L C, Santell J P, Hunkler R J, Hontz K. Projecting future drug expenditures--2002. Am J Health Syst Pharm. Jan 15. 2002;59(2):131-142. Does not address regionalization. [pmid: 11826567].
390 Shahi S K, Ranga S, Gupta P. Bioterrorism. Indian J Pathol Microbiol. Oct. 2001;44(4):391-392. Does not address regionalization. [pmid: 12035346].
391 Shalala D E. Bioterrorism: how prepared are we?. Emerg Infect Dis. Jul-Aug. 1999;5(4):492-493. Opinion or editorial. [pmid: 10458948].
392 Shannon M, Burstein J, Mandl K, Fleisher G. Usage of a web-based decision support tool for bioterrorism detection. Am J Emerg Med. Jul. 2002;20(4):384-385. Does not address regionalization. [pmid: 12098202].
393 Shapira S C, Shemer J, Oren M. Hospital management of a bioterror event. Isr Med Assoc J. Jul. 2002;4(7):493-494. Does not address regionalization. [pmid: 12120457].
394 Shapiro D S, Schwartz D R. Exposure of laboratory workers to Francisella tularensis despite a bioterrorism procedure. J Clin Microbiol. Jun. 2002;40(6):2278-2281. Does not address regionalization. [pmcid: 130659]. [pmid: 12037110].
395 Sharp T W, Brennan R J, Keim M, Williams R J, Eitzen E, Lillibridge S. Medical preparedness for a terrorist incident involving chemical or biological agents during the 1996 Atlanta Olympic Games. Ann Emerg Med. Aug. 1998;32(2):214-223. Does not address regionalization. [pmid: 9701305].
396 Sheaffer S L, Manasse H R. The new realities of practice in a post-9/11 world. Am J Health Syst Pharm. Aug 15. 2002;59(16):1553-1558. Does not address regionalization. [pmid: 12185832].
397 Shepard C W, Soriano-Gabarro M, Zell E R, et al. Antimicrobial postexposure prophylaxis for anthrax: adverse events and adherence. Emerg Infect Dis. Oct. 2002;8(10):1124-1132. Does not address regionalization. [pmid: 12396927].
398 Sheppa C M, Stevens J, Philbrick J T, Canada M. The effect of a class IV hurricane on emergency department operations. Am J Emerg Med. Sep. 1993;11(5):464-467. Does not address regionalization. [pmid: 8363682].
399 Sherman F T. Old biological threats. Geriatrics. Dec. 2001;56(12):11. Does not address regionalization. [pmid: 11766557].
400 Sidel V W, Cohen H W, Gould R M. Good intentions and the road to bioterrorism preparedness. Am J Public Health. May. 2001;91(5):716-718. Does not address regionalization. [pmid: 11344877]. [pmcid: 1446690].
401 Siegelson H J. Preparing for terrorism and hazardous material exposures. Health Forum J. Jan-Feb. 2001;44(1):32-35. Does not address regionalization. [pmid: 11225556].
402 Siegrist DW. Advanced Technology to Counter Biological Terrorism. Holon, Israel: Potomac Institute for Policy Studies; March 18, 1998. Does not address regionalization.
403 Silber SH, Oster N, Simmons B, Garrett C. Y2K medical disaster preparedness in New York City: confidence of emergency department directors in their ability torespond. Prehospital Disaster Med. Apr-Jun 2001;16(2):88–94; discussion 94-85. Does not address regionalization.
404 Silvagni A J, Levy L A, McFee R B. Educating health professionals, first responders, and the community about bioterrorism and weapons of mass destruction. J Am Osteopath Assoc. Sep. 2002;102(9):491-499. Does not address regionalization. [pmid: 12361182].
405 Silver R C, Holman E A, McIntosh D N, Poulin M, Gil-Rivas V. Nationwide longitudinal study of psychological responses to September 11. JAMA. Sep 11. 2002;288(10):1235-1244. Does not address regionalization. [pmid: 12215130].
406 Silverman M A, Weston M, Llorente M, Beber C, Tam R. Lessons learned from Hurricane Andrew: recommendations for care of the elderly in long-term care facilities. South Med J. Jun. 1995;88(6):603-608. Does not address regionalization. [pmid: 7777873].
407 Silverston P P. Development of an emergency services system--the Israeli example. Injury. Nov. 1979;11(2):99-100. Does not address regionalization. [pmid: 521161].
408 Siwicki B. Hospitals, chapters weather Hurricane Andrew. Healthc Financ Manage. Nov 1992;46(11):72, 74. Does not address regionalization.
409 Smallpox Emergency Personnel Protection Act of 2003; 2003. Does not address regionalization.
410 Smallpox vaccine. Pediatrics. Oct 2002;110(4):841–845. Does not address regionalization.
411 Smith E L. Highlights from the annual scientific assembly: weapons of mass destruction: organized medicine's role in the national response to terrorism. South Med J. Dec. 2001;94(12):1223-1229. Does not address regionalization. [pmid: 11811866].
412 Sobel J, Khan A S, Swerdlow D L. Threat of a biological terrorist attack on the US food supply: the CDC perspective. Lancet. Mar 9. 2002;359(9309):874-880. Does not address regionalization. [pmid: 11897303].
413 Socher M M. NBC Delta: special training beyond HAZMAT in the USA. Resuscitation. Oct. 1999;42(2):151-153. Does not address regionalization. [pmid: 10617334].
414 SoRelle R. Physicians, nurses, paramedics, medics, and hospitals respond to tragedies in New York and DC. Circulation. Sep 25. 2001;104(13):E9030. Does not address regionalization. [pmid: 11571264].
415 Southwick G J, Pethick A J, Thalayasingam P, Vijayasekaran V S, Hogg J J. Australian doctors in Bali: the initial medical response to the Bali bombing. Med J Aust. Dec 2–16. 2002;177(1112):624-626. Does not address regionalization. [pmid: 12463981].
416 Spectre of the Bhopal disaster. Am J Public Health. 1987;77(7):878–879. Does not address regionalization.
417 Spencer R C, Lightfoot N F. Preparedness and response to bioterrorism. J Infect. Aug. 2001;43(2):104-110. Does not address regionalization. [pmid: 11676515].
418 Srivatsa L P. The Bhopal tragedy. J Toxicol Clin Exp. 1987;7(1):47-49. Does not address regionalization. [pmid: 3598918].
419 Stamm B H. Terrorism risks in rural and frontier America. Their importance to the successful functioning of urban America makes rural and frontier areas ripe targets for terrorism. IEEE Eng Med Biol Mag. Sep-Oct. 2002;21(5):100-111. Does not address regionalization. [pmid: 12405063].
420 Stamp G L. Hurricane Andrew: the importance of coordinated response. J Am Vet Med Assoc. Oct 1. 1993;203(7):989-992. Does not address regionalization. [pmid: 8226268].
421 Steinhauer R, Bauer J. The emergency management plan. RN. Jun. 2002;65(6):40-46. Does not address regionalization. [pmid: 12087598].
422 Stephenson J. Smallpox vaccine program launched amid concerns raised by expert panel, unions. JAMA. Feb 12. 2003;289(6):685-686. Does not address regionalization. [pmid: 12585929].
423 Sumaya C V, Corman L I. Enteroviral meningitis in early infancy: significance in community outbreaks. Pediatr Infect Dis. May-Jun. 1982;1(3):151-154. Does not address regionalization. [pmid: 7145728].
424 Summary of the executive session on emergency preparedness and the pharmaceutical supply chain. Am J Health Syst Pharm. Feb 1 2002;59(3):247–253. Does not address regionalization.
425 Taha M K, Achtman M, Alonso J M, et al. Serogroup W135 meningococcal disease in Hajj pilgrims. Lancet. Dec 23–30. 2000;356(9248):2159. Does not address regionalization. [pmid: 11191548].
426 Teeter D S. Bioterrorism preparedness: answers for the health-system pharmacist. Am J Health Syst Pharm. May 15. 2002;59(10):928-930. Does not address regionalization. [pmid: 12040731].
427 Temte J. Response to bioterrorism. Screening for agents of bioterrorism increases terror. BMJ. Feb 9. 2002;324(7333):363. Does not address regionalization. [pmid: 11858180].
428 Thal E R, Riggs L M Jr. Community planning for medical support of a national political convention. J Trauma. Jun. 1988;28(6):799-803. Does not address regionalization. [pmid: 3385824].
429 Tharratt R S, Case J T, Hird D W. Perceptions of state public health officers and state veterinarians regarding risks of bioterrorism in the United States. J Am Vet Med Assoc. Jun 15. 2002;220(12):1782-1787. Does not address regionalization. [pmid: 12092950].
430 The Global Infectious Disease Threat and Its Implications for the United States: Central Intelligence Agency; January 2000. Does not address regionalization.
431 The public health implications of the Bhopal disaster. Report to the Program Development Board, American Public Health Association. Bhopal Working Group. Am J Public Health. 1987;77(2):230–236. Does not describe bioterrorism-relevant response task.
432 Thompson T G. Service in the front lines for America. Hosp Outlook. Nov-Dec. 2001;4(8):7. Does not address regionalization. [pmid: 11806342].
433 Tieman J. Hospitals review plans in wake of latest threats. Mod Healthc. Nov 18. 2002;32(46):10-11. Does not address regionalization. [pmid: 12545614].
434 Totenhofer R I, Kierce M. It's a disaster: emergency departments' preparation for a chemical incident or disaster. Accid Emerg Nurs. Jul. 1999;7(3):141-147. Does not address regionalization. [pmid: 10693383].
435 Traynor K. CDC has anthrax, smallpox vaccination guidelines available. Am J Health Syst Pharm. Nov 1 2001;58(21):2008, 2011. Does not address regionalization.
436 Treadwell T A, Koo D, Kuker K, Khan A S. Epidemiologic clues to bioterrorism. Public Health Rep. Mar-Apr. 2003;118(2):92-98. Does not address regionalization. [pmid: 12690063]. [pmcid: 1497515].
437 Trotter G. Of terrorism and healthcare: jolting the old habits. Camb Q Healthc Ethics. Fall 2002;11(4):411–414. Does not address regionalization.
438 Trumpp C E, Karasic R. Management of communicable diseases in day care centers. Pediatr Ann. Mar. 1983;12(3):219-229. Does not address regionalization. [pmid: 6343986].
439 Tucker JB. Chemical/Biological Terrorism: Coping with a New Threat. Politics and the Life Sciences. September 1996. Does not address regionalization.
440 Turnbull P C. Current status of immunization against anthrax: old vaccines may be here to stay for a while. Curr Opin Infect Dis. Apr. 2000;13(2):113-120. Does not address regionalization. [pmid: 11964777].
441 U.S. Fire Administration. Federal Emergency Management Agency. Available at: www.usfa.fema.gov. Accessed August 7, 2002. Does not address regionalization.
442 United States Better Prepared Now to Deal with Bioterrorist Attacks, But Improvement Still Needed, Experts Say. Henry J. Kaiser Family Foundation. March 25. Available at: www.kaisernetwork.org. Accessed March 25,, 2003. Does not address regionalization.
443 Update: assessment of risk for meningococcal disease associated with the Hajj 2001. MMWR Morb Mortal Wkly Rep. Mar 30 2001;50(12):221–222. Does not address regionalization.
444 Update: Investigation of bioterrorism-related anthrax and adverse events from antimicrobial prophylaxis. MMWR Morb Mortal Wkly Rep. Nov 9 2001;50(44):973–976. Does not address regionalization.
445 Update: Investigation of bioterrorism-related anthrax and interim guidelines for clinical evaluation of persons with possible anthrax. MMWR Morb Mortal Wkly Rep. Nov 2 2001;50(43):941–948. Does not address regionalization.
446 Update: Investigation of bioterrorism-related anthrax and interim guidelines for exposure management and antimicrobial therapy, October 2001. MMWR Morb Mortal Wkly Rep. Oct 26 2001;50(42):909–919. Does not address regionalization.
447 Update: Investigation of bioterrorism-related anthrax, 2001. MMWR Morb Mortal Wkly Rep. Nov 16 2001;50(45):1008–1010. Does not address regionalization.
448 Update: Investigation of bioterrorism-related anthrax--Connecticut, 2001. MMWR Morb Mortal Wkly Rep. Dec 7 2001;50(48):1077–1079. Does not address regionalization.
449 Update: investigation of bioterrorism-related inhalational anthrax--Connecticut, 2001.MMWR Morb Mortal Wkly Rep. Nov 30 2001;50(47):1049–1051. Does not address regionalization.
450 Updated recommendations for antimicrobial prophylaxis among asymptomatic pregnant women after exposure to Bacillus anthracis.MMWR Morb Mortal Wkly Rep. Nov 2 2001;50(43):960. Does not address regionalization.
451 Van Koevering M. Congress approves bioterrorism bill. Healthplan. Jul-Aug 2002;43(4):8–10, 12. Does not address regionalization.
452 Varkey P, Poland G A, Cockerill F R, Smith T F, Hagen P T. Confronting bioterrorism: physicians on the front line. Mayo Clin Proc. Jul. 2002;77(7):661-672. Does not address regionalization. [pmid: 12108604].
453 Venkatesh S, Memish Z A. Bioterrorism--a new challenge for public health. Int J Antimicrob Agents. Feb. 2003;21(2):200-206. Does not address regionalization. [pmid: 12615387].
454 Vlahov D, Galea S, Frankel D. New York City, 2001: reaction and response. J Urban Health. Mar. 2002;79(1):2-5. Does not address regionalization. [pmid: 11937606].
455 Waeckerle J F, Lillibridge S R, Burkle F M Jr, Noji E K. Disaster medicine: challenges for today. Ann Emerg Med. Apr. 1994;23(4):715-718. Does not address regionalization. [pmid: 8161037].
456 Waeckerle J F, Seamans S, Whiteside M, et al. Executive summary: developing objectives, content, and competencies for the training of emergency medical technicians, emergency physicians, and emergency nurses to care for casualties resulting from nuclear, biological, or chemical incidents. Ann Emerg Med. Jun. 2001;37(6):587-601. Does not address regionalization. [pmid: 11385327]. [pmcid: 152387].
457 Wagner M M. The space race and biodefense: lessons from NASA about big science and the role of medical informatics. J Am Med Inform Assoc. Mar-Apr. 2002;9(2):120-122. Does not address regionalization. [pmcid: 344566]. [pmid: 11861624].
458 Wain H J, Grammer G G, Stasinos J J, Miller C M. Meeting the patients where they are: consultation-liaison response to trauma victims of the Pentagon attack. Mil Med. Sep. 2002;167(9 Suppl):19-21. Does not address regionalization. [pmid: 12363131].
459 Walsh M. Smallpox: the disease and strategies for its control. Nurs Times. Dec 17-2003 Jan 6 2002;98(51):26–27. Does not address regionalization.
460 Wardrope J, Ryan F, Clark G, Venables G, Crosby A C, Redgrave P. The Hillsborough tragedy. BMJ. Nov 30. 1991;303(6814):1381-1385. Does not address regionalization. [pmid: 1760607]. [pmcid: 1671592].
461 Web survey. October results: are we prepared? Mod Healthc. Dec 3 2001;31(49):33. Does not address regionalization.
462 Weill H. Disaster at Bhopal: the accident, early findings and respiratory health outlook in those injured. Bull Eur Physiopathol Respir. 1987;23(6):587-590. Does not describe bioterrorism-relevant response task. [pmid: 3453752].
463 Weir E. Anthrax: of bison and bioterrorism. CMAJ. Sep 5. 2000;163(5):608. Opinion or editorial. [pmcid: 80494]. [pmid: 11006776].
464 Weir E. Anthrax: walking the fine line between precaution and panic. CMAJ. Nov 27. 2001;165(11):1528. Opinion or editorial. [pmcid: 81687]. [pmid: 11762587].
465 What the survey process expects of your organization. Jt Comm Perspect. Dec 2001;21(12):6–7. Does not address regionalization.
466 White DE. A terrorism response plan for hospital security and safety officers. J Healthc Prot Manage. Winter 2002;18(1):15–23. Does not address regionalization.
467 White SR, Henretig FM, Dukes RG. Medical management of vulnerable populations and co-morbid conditions of victims of bioterrorism. Emerg Med Clin North Am. May 2002;20(2):365–392, xi. Does not address regionalization.
468 Who We Are: History of Blood Banking. America's Blood Centers. Available at: http://www.americasblood.org/index.cfm?fuseaction=display.showpage&pageID=30. Accessed January 15, 2003. Does not address regionalization.
469 Williams B. Bioterrorism: are we prepared?. Tenn Med. Nov. 2001;94(11):413-417. Does not address regionalization. [pmid: 11709894].
470 Williams C L, Lee A C, Curran A S. Prevention of meningitis in a day-care center: management of an outbreak of Haemophilus influenzae type b. Prev Med. Mar. 1987;16(2):261-268. Does not address regionalization. [pmid: 3588566].
471 Williams J L, Noviello S S, Griffith K S, et al. Anthrax postexposure prophylaxis in postal workers, Connecticut, 2001. Emerg Infect Dis. Oct. 2002;8(10):1133-1137. Does not address regionalization. [pmid: 12396928].
472 Wyatt H W. The role and responsibility of the media in the event of a bioterrorist act. J Public Health Manag Pract. Jul. 2000;6(4):63-67. Does not address regionalization. [pmid: 10977615].
473 Wyss K, Lorenz N. Decentralization and central and regional coordination of health services: the case of Switzerland. Int J Health Plann Manage. 2000;15(2):103-114. Does not describe bioterrorism-relevant response task. [pmid: 11009945].
474 Yang W. Severe acute respiratory syndrome (SARS): infection control. Lancet. Apr 19. 2003;361(9366):1386-1387. Does not address regionalization. [pmid: 12711489].
475 Young D. Experience with disaster yields lessons in preparedness. Am J Health Syst Pharm. Oct 1 2002;59(19):1812, 1814–1816. Does not address regionalizaiton.
476 Zimbardo PG. The Political Psychology of Terrorist Alarms. Stanford, CA: Stanford University; March 3 2003. Does not address regionalization.
477 Zipes D P. President's page: fighting terrorism: our role as physicians. J Am Coll Cardiol. Feb 20. 2002;39(4):739-740. Opinion or editorial. [pmid: 11849877].