# References and Included Studies

1 Roosevelt E. In a letter to journalist Martha Gellhorn, dated April 5, 1938. In: Lash JP, ed. Eleanor and Franklin; 1971:ch. 47.
2 Kanof ME. Severe Acute Respiratory Syndrome: Established Infectious Disease Control Measures Helped Contain Spread, But a Large-Scale Resurgence May Pose Challenges. Washington: United States General Accounting Office; July 30 2003. GAO-03-1058T.
3 Bravata DM, McDonald K, Owens DK, et al. Bioterrorism Preparedness and Response: Use of Information Technologies and Decision Support Systems (Evidence Report/Technology Assessment No. 59). Rockville, MD: Prepared by the UCSF-Stanford Evidence-based Practice Center under Contract No. 290-97-0013 for the Agency for Healthcare Research and Quality; June 2002.
4 Wetter D C, Daniell W E, Treser C D. Hospital preparedness for victims of chemical or biological terrorism. Am J Public Health. May. 2001;91(5):710-716. [pmid: 11344876]. [pmcid: 1446687].
5 English J F. Overview of bioterrorism readiness plan: a template for health care facilities. Am J Infect Control. 1999;27(6):468-469. [pmid: 10586148].
6 Bioterrorism readiness plan--a template for healthcare facilities. Association for Professionals in Infection Control and Epidemiology Inc. and Centers for Disease Control and Prevention. ED Manag. 1999;11(11):suppl 1–16.
7 Proceedings of the National Symposium on Medical and Public Health Response to Bioterrorism. Arlington, Virginia, USA. February 16–17, 1999. Emerg Infect Dis. 1999;5(4):491–592.
8 Layton M. Bioterrorism Preparedness Checklist - Local Public Health Agency Perspective. Paper presented at: Informal Discussions on Strengthening National Preparedness and Response to Biological Weapons; 6–8 March 2002, 2002; Rome.
9 Manning FJ, Goldfrank L, eds. Preparing for Terrorism: Tools for Evaluating the Metropolitan Medical Response System Program. Washington, D.C.: National Academy Press; 2002. Institute of Medicine: Board on Health Science Policy.
10 Helget V, Smith P W. Bioterrorism preparedness: a survey of Nebraska health care institutions. Am J Infect Control. Feb. 2002;30(1):46-48. [pmid: 11852417].
11 Treat K N, Williams J M, Furbee P M, Manley W G, Russell F K, Stamper C D Jr. Hospital preparedness for weapons of mass destruction incidents: an initial assessment. Ann Emerg Med. Nov. 2001;38(5):562-565. [pmid: 11679869].
12 Hick J L, Leitheiser A. Integrated planning for disaster. A model for Minnesota hospitals. Minn Med. Aug. 2002;85(8):44-47. [pmid: 12199030].
13 Case G G, West B M, McHugh C J. Hospital preparedness for biological and chemical terrorism in central New Jersey. N J Med. Nov. 2001;98(11):23-33. [pmid: 11771336].
14 The Hospital Emergency Incident Command System: San Mateo County Department of Health Services; June 1998.
15 California Hospital Bioterrorism Response Planning Guide: California Department of Health Services; 2002.
16 Analyzing your vulnerability to hazards. Jt Comm Perspect. Dec 2001;21(12):8–9.
17 What the survey process expects of your organization. Jt Comm Perspect. Dec 2001;21(12):6–7.
18 Using JCAHO standards as a starting point to prepare for an emergency. Jt Comm Perspect. Dec 2001;21(12):4–5.
19 Developing practical emergency management education programs. Jt Comm Perspect. Dec 2001;21(12):3.
20 Responding effectively in the midst of a natural emergency. Jt Comm Perspect. Dec 2001;21(12):22–23.
21 Nuclear, biological, and chemical decontamination. Jt Comm Perspect. Dec 2001;21(12):20–21.
22 The need for a national bioterrorism response. Jt Comm Perspect. Dec 2001;21(12):2.
23 Caring for our own. Jt Comm Perspect. Dec 2001;21(12):19, 23.
24 Talking to each other in a crisis. Jt Comm Perspect. Dec 2001;21(12):16–17.
25 The power of preparation. Jt Comm Perspect. Dec 2001;21(12):13–15.
26 Managing people and resources effectively. Jt Comm Perspect. Dec 2001;21(12):12, 18.
27 Preparing for a mass casualty event. Jt Comm Perspect. Dec 2001;21(12):10–11.
28 Joint Commission zeroes in on disaster plans: is yours up to par? ED Manag. Feb 2002;14(2):13–15; suppl 11–13.
29 Hospital Preparedness for Mass Casualties. Chicago: American Hospital Association; March 8–9 2000.
30 Bentley J D. Hospital preparedness for bioterrorism. Public Health Rep. 2001;116(Suppl 2):36-39. [pmid: 11880669]. [pmcid: 1497267].
31 Training of Clinicians for Public Health Events Relevant to Bioterrorism Preparedness. Rockville, MD: Agency for Healthcare Research and Quality; January 2002. AHRQ Publication No. 02-E011.
32 Halm E A, Lee C, Chassin M R. Is volume related to outcome in health care? A systematic review and methodologic critique of the literature. Ann Intern Med. Sep 17. 2002;137(6):511-520. [pmid: 12230353].
33 Elliott D C, Rodriguez A. Cost effectiveness in trauma care. Surg Clin North Am. Feb. 1996;76(1):47-62. [pmid: 8629202].
34 Mullins R J, Veum-Stone J, Helfand M, et al. Outcome of hospitalized injured patients after institution of a trauma system in an urban area. JAMA. Jun 22–29. 1994;271(24):1919-1924. [pmid: 8201736].
35 Mullins RJ, Veum-Stone J, Hedges JR, et al. Influence of a statewide trauma system on location of hospitalization and outcome of injured patients. J Trauma. Apr 1996;40(4):536–545; discussion 545-536.
36 Mullins RJ, Mann NC, Hedges JR, Worrall W, Jurkovich GJ. Preferential benefit of implementation of a statewide trauma system in one of two adjacent states. J Trauma. Apr 1998;44(4):609–616; discussion 617.
37 Mullins R J, Mann N C. Population-based research assessing the effectiveness of trauma systems. J Trauma. Sep. 1999;47(3 Suppl):S59-66. [pmid: 10496613].
38 Nathens A B, Maier R V. The relationship between trauma center volume and outcome. Adv Surg. 2001;35:61-75. [pmid: 11579818].
39 Okumura T, Suzuki K, Fukuda A, et al. The Tokyo subway sarin attack: disaster management, Part 1: Community emergency response. Acad Emerg Med. Jun. 1998;5(6):613-617. [pmid: 9660289].
40 What is CERT? CERT Los Angeles. July 21. Available at: www.cert-la.com/WhatIsCert.htm. Accessed September 4, 2003.
41 Noji E K. Progress in disaster management. Lancet. May 21. 1994;343(8908):1239-1240. [pmid: 7910269].
42 Noji E K. The public health consequences of disasters. Prehospital Disaster Med. Oct-Dec. 2000;15(4):147-157. [pmid: 11227602].
43 Noji E K. Advances in disaster medicine. Eur J Emerg Med. 2002;9(2):185-191. [pmid: 12131648].
44 Maniscalco PM, Christen HT. Understanding Terrorism and Managing the Consequences. Upper Saddle River, NJ: Prentice Hall; 2001.
45 Maniscalco P M, Christen H T. EMS incident management: emergency medical logistics. Emerg Med Serv. Jan. 1999;28(1):49-52. [pmid: 10345883].
46 Richey SK. Operational Command and Control of Federal Domestic Emergency Response Operations. Newport, R.I.: Naval War College; May 16 2000.
47 Ganeshan R, Harrison TP. An Introduction to Supply Chain Management. Department of Management Science and Information Systems, Penn State University. May 22. Available at: http://silmaril.smeal.psu.edu/misc/supply_chain_intro.html. Accessed December 16, 2002.
48 Burns LR, ed. The Health Care Value Chain: Producers, Purchasers, and Providers. San Francisco: Jossey-Bass; 2002.
49 Robeson JF, Copacino WC, eds. The Logistics Handbook. New York: The Free Press; 1994.
50 Lin G, Ettl M, Buckley S, et al. Extended-Enterprise Supply-Chain Management at IBM Personal Systems Group and Other Divisions. Interfaces. Jan-Feb. 2000;30(1):7-25.
51 Arntzen B C, Brown G C, Harrison T P, Trafton L L. Global Supply Chain Management at Digital Equipment Corporation. Interfaces. January-February. 1995;25(1):69-93.
52 Davis EW. General Electric TSBO (A): Purchasing and Just-in-Time. Charlottesville, VA: Darden Graduate School of Business Administration, University of Virginia; 1983.
53 Mohammed A. Polaroid Corporation: European Distribution System. Boston, MA: Harvard Business School; June 26 1995.
54 Sery S, Presti V, Shobrys D E. Optimization Models for Restructuring BASF North America's Distribution System. Interfaces. May-June. 2001;31(3):55-65.
55 Graves SC, Willems SP. Optimizing Strategic Safety Stock Placement in Supply Chains. Manufacturing and Service Operations Management. Winter 2000;2(1):68–83.
56 Nahmias S. Supply Chain Management. Production and Operations Analysis. 4th ed. Boston: McGraw-Hill; 2001.
57 Cheng F, Ettl M, Yao DD. Inventory-Service Optimization in Configure-to-Order Systems. Manufacturing and Service Operations Management. Spring 2002;4(2):114–132.
58 Lee H L, Billington C. The Evolution of Supply-Chain-Management Models and Practice at Hewlett-Packard. Interfaces. September-October. 1995;25(5):42-63.
59 Ernst R, Kamrad B. Evaluation of supply chain structures through modularization and postponement. European Journal of Operational Research. 2000;124:495-510.
60 Brown A O, Lee H L, Petrakian R. Xilinx Improves its Semiconductor Supply Chain Using Product and Process Postponement. Interfaces. July-August. 2000;30(4):65-80.
61 Thonemann U W, Brandeau M L. Optimal Commonality in Component Design. Operations Research. Jan-Feb. 2000;48(1):1-19.
62 Inglesby T V. Observations from the Top Off exercise. Public Health Rep. 2001;116(Suppl 2):64-68. [pmid: 11880675].
63 Gehman HW, Barry JL, Deal DW, et al. Columbia Accident Investigation Board. Washington, D.C.: National Aeronautics and Space Administration; August 2003.
64 Dembek Z, Myers M, Carley K, Hadler J. Connecticut Hospital Admissions Syndromic Surveillance. J Urban Health. June 1. 2003;80(Suppl 1):i121-122.
65 Lober W B, Karras B T, Wagner M M, et al. Roundtable on bioterrorism detection: information system-based surveillance. J Am Med Inform Assoc. Mar-Apr. 2002;9(2):105-115. [pmcid: 344564]. [pmid: 11861622].
66 DoD Global Emerging Infections System: Partnering in the Fight Against Emerging Infections: Global Emerging Infections System; 2000.
67 Lombardo J, Burkom H, Elbert E, et al. A Systems Overview of the Electronic Surveillance System for the Early Notification of Community-Based Epidemics (ESSENCE II). J Urban Health. Jun. 2003;80(Suppl 1):I32-I42. [pmid: 12791777].
68 Platt R, Bocchino C, Caldwell B, et al. Syndromic surveillance using minimum transfer of identifiable data: the example of the national bioterrorism syndromic surveillance demonstration program. J Urban Health. Jun. 2003;80(Suppl 1):I25-I31. [pmid: 12791776].
69 Mostashari F, Fine A, Das D, Adams J, Layton M. Use of ambulance dispatch data as an early warning system for communitywide influenzalike illness, New York City. J Urban Health. Jun. 2003;80(Suppl 1):I43-I49. [pmid: 12791778].
70 Chapman W W, Allegra J, Rothman J. Syndromic Surveillance from Free-Text Triage Chief Complaints. J Urban Health. June 1. 2003;80(Suppl 1):i120.
71 Teich J M, Wagner M M, Mackenzie C F, Schafer K O. The informatics response in disaster, terrorism, and war. J Am Med Inform Assoc. Mar-Apr. 2002;9(2):97-104. [pmcid: 344563]. [pmid: 11861621].
72 Miller B, Kassenborg H, Dunsmuir W, et al. Syndromic Surveillance for Bioterrorism: a System for Rapid Detection of Influenzalike Illness and Bioterrorism-Related Outbreaks. J Urban Health. June 1. 2003;80(Suppl 1):i117.
73 Lober W B, Trigg L J, Karras B T, et al. Syndromic surveillance using automated collection of computerized discharge diagnoses. J Urban Health. Jun. 2003;80(Suppl 1):I97-I106. [pmid: 12791784].
74 Bravata D M, Rahman M M, Luong N, Divan H A, Cody S H. A Comparison of Syndromic Incidence Data Collected by Triage Nurses in Santa Clara County with Regional Infectious Disease Data. J Urban Health. June 1. 2003;80(Suppl 1):i122.
75 Lazarus R, Kleinman K P, Dashevsky I, DeMaria A, Platt R. Using automated medical records for rapid identification of illness syndromes (syndromic surveillance): the example of lower respiratory infection. BMC Public Health. 2001;1(1):9. [pmcid: 60002]. [pmid: 11722798].
76 Brillman J C, Joyce E L, Forslund D W, et al. The Biosurveillance Analysis, Feedback, Evaluation, and Response (B-SAFER) System. J Urban Health. June 1. 2003;80(Suppl 1):i119-120.
77 Eidson M. “Neon needles” in a haystack: the advantages of passive surveillance for West Nile virus. Ann N Y Acad Sci. Dec. 2001;951:38-53. [pmid: 11797803].
78 Zaric GS, Bravata DM, McDonald KM, Owens DK. Regionalization of Syndromic Surveillance for Bioterrorism. In press.
79 Zaric GS, Bravata DM, Holty JE, et al. Modeling the Logistics of Responding to a Large Scale Anthrax Attack in the United States. Med Decis Making. In press.
80 Karabakal N, Gunal A, Ritchie W. Supply-Chain Analysis at Volkswagen of America. Interfaces. July-August. 2000;30(4):46-55.
81 Hahn C K, Duplaga E A, Hartley J L. Supply-Chain Synchronization: Lessons from Hyundai Motor Company. Interfaces. July-August. 2000;30(4):32-45.
82 Rao U, Scheller-Wolf A, Tayur S. Development of a Rapid-Response Supply Chain at Caterpillar. Operations Research. March-April. 2000;48(2):189-204.
83 Lee HL, Hoyt DB. Lucent Technologies: Global Supply Chain Management. Stanford, CA: Graduate School of Business, Stanford University; January 2001.
84 Chen E, Enna A, Jordan S, et al. Instill Corporation: Improving the Foodservice Industry Supply Chain. Stanford, CA: Graduate School of Business, Stanford University; February 2000.
85 Takeda Y, Matsuo H. ECR: a “fresh” look from Japan. ECR Journal. Winter 2002;2(2):17–27.
86 Lockamy A. Supply-Chain Excellence for Accelerated Improvement. Interfaces. July-August. 2000;30(4):22-31.
87 Ghemawat P, Neueno JL. ZARA: Fast Fashion. Boston, MA: Harvard Business School; April 1 2003.
88 LFM Scheduling and Logistics Control. LFM Research Group 3. June 16, 2000. Available at: http://web.mit.edu/lfmrg3/www/. Accessed September 26, 2003.
89 Gostin L O, Sapsin J W, Teret S P, et al. The Model State Emergency Health Powers Act: planning for and response to bioterrorism and naturally occurring infectious diseases. JAMA. Aug 7. 2002;288(5):622-628. [pmid: 12150674].
90 Gostin L O. Public health law in an age of terrorism: rethinking individual rights and common goods. Health Aff. Nov-Dec. 2002;21(6):79-93.
91 Lopez W. West Nile virus in New York City. Am J Public Health. Aug. 2002;92(8):1218-1221. [pmid: 12144970].
92 Lopez W. New York City and state legal authorities related to syndromic surveillance. J Urban Health. Jun. 2003;80(Suppl 1):I23-I24. [pmid: 12791775].
93 Barbera J, Macintyre A, Gostin L, et al. Large-scale quarantine following biological terrorism in the United States: scientific examination, logistic and legal limits, and possible consequences. JAMA. Dec 5. 2001;286(21):2711-2717. [pmid: 11730447].
94 Knouss R F. National disaster medical system. Public Health Rep. 2001;116(Suppl 2):49-52. [pmid: 11880672]. [pmcid: 1497270].
95 Pretto E A Jr, Safar P. National medical response to mass disasters in the United States. Are we prepared?. JAMA. Sep 4. 1991;266(9):1259-1262. [pmid: 1870252].
96 Kizer K W, Cushing T S, Nishimi R Y. The Department of Veterans Affairs' role in Federal Emergency Management. Ann Emerg Med. Sep. 2000;36(3):255-261. [pmid: 10969234].
97 Angus D C, Pretto E A, Abrams J I, et al. Epidemiologic assessment of mortality, building collapse pattern, and medical response after the 1992 earthquake in Turkey. Disaster Reanimatology Study Group (DRSG). Prehospital Disaster Med. 1997;12(3):222-231. [pmid: 10187018].
98 Babb J, Downs K. Fighting back: pharmacists' roles in the federal response to the September 11 attacks. J Am Pharm Assoc. Nov-Dec. 2001;41(6):834-837.
99 Streger MR. The structure and role of DMAT teams. Emerg Med Serv. Apr 2000;29(4):57–58, 60, 70.
100 Hogan J, Rega P, Forkapa B. A civilian-sponsored DMAT: a community's collaboration among three hospitals. J Emerg Nurs. Jul-Aug. 1990;16(4):245-247. [pmid: 2385055].
101 Rodenbeck S E. The needs of a disaster medical assistance team for environmental support services. Mil Med. Jan. 1990;155(1):12-13. [pmid: 2106633].
102 Charbonneau R. Kosova relief efforts at Fort Dix, New Jersey: one DMAT nurse's experience. J Emerg Nurs. Oct. 1999;25(5):51a-52a. [pmid: 10508451].
103 Lewis-Rakestraw L. Response of the New Mexico Disaster Medical Assistance Team in St. Croix after Hurricane Hugo. J Emerg Nurs. Jun. 1991;17(3):162-164. [pmid: 1921040].
104 Henderson A K, Lillibridge S R, Salinas C, Graves R W, Roth P B, Noji E K. Disaster medical assistance teams: providing health care to a community struck by Hurricane Iniki. Ann Emerg Med. Apr. 1994;23(4):726-730. [pmid: 8161039].
105 National Disaster Medical System; medical manpower component establishment--Health Resources and Services Administration, HHS. Notice. Fed Regist. Apr 20. 1988;53(76):12994-12995. [pmid: 11659025].
106 Roth P B, Gaffney J K. The federal response plan and disaster medical assistance teams in domestic disasters. Emerg Med Clin North Am. May. 1996;14(2):371-382. [pmid: 8635413].
107 Sacra J C, Murphy M. Oklahoma City and Tulsa Metropolitan Medical Response System. J Okla State Med Assoc. Apr. 2002;95(4):281-285. [pmid: 11957849].
108 Macintyre A G, Christopher G W, Eitzen E Jr, et al. Weapons of mass destruction events with contaminated casualties: effective planning for health care facilities. JAMA. Jan 12. 2000;283(2):242-249. [pmid: 10634341].
109 Gostin LO, Hodge JG. Turning Point: Collaborating for a New Century in Public Health. State Public Health Law Assessment Report: Turning Point Public Health Statute Modernization National Excellence Collaborative, Turning Point National Program Office, University of Washington; April 1 2002.
110 Executive Summary: Smallpox Response Plan: Centers for Disease Control and Prevention; December 6 2002.
111 Green CB. The Role of Air Force Aeromedical Evacuation in Support of Military Operations. Washington, D.C.: United States Senate, Armed Services Committee; March 13 2002.
112 Winslow F, Walmsley J. Metropolitan Medical Strike Team Systems: Responding to the Medical Demands of WMD/NBC Events. In: Farazmand A, ed. Encyclopedia Handbook of Crisis and Emergency Management: Marcel Dekker, Inc.; 2001.
113 Heinrich J. Homeland Security: New Department Could Improve Coordination but Transferring Control of Certain Public Health Programs Raises Concerns. Washington, D.C.: United States General Accounting Office; July 16 2002.
114 Heinrich J. Homeland Security: New Department Could Improve Biomedical R&D Coordination but May Disrupt Dual-Purpose Efforts. Washington, D.C.: United States General Accounting Office; July 2002.
115 Heinrich J. Homeland Security: New Department Could Improve Coordination but May Complicate Public Health Priority Setting. Washington, D.C.: United States General Accounting Office; June 25 2002.
116 Walker DM. Homeland Security: Challenges and Strategies in Addressing Short- and Long-Term National Needs. Washington, D.C.: Committee on the Budget, House of Representatives; November 7 2001.
117 Federal Response Plan. Washington, D.C.: Federal Emergency Management Agency; 1992.
118 A Nation Prepared: Federal Emergency Management Agency Strategic Plan, Fiscal Years 2003-2008. Washington, D.C.: Federal Emergency Management Agency; 2002.
119 HRSA Annual Report. Washington, D.C.: HRSA; 2001.
120 Bioterrorism: Information Technology Strategy Could Strengthen Federal Agencies' Abilities to Respond to Public Health Emergencies. Washington, D.C.: General Accounting Office; May 2003. GAO-03-139.
121 Gebicke ME. Combating Terrorism: Use of National Guard Response Teams is Unclear. Washington, D.C.: United States General Accounting Office; May 1999.
122 Mughal M. Biological Weapons Improved Response Program. Arlington, V.A.: U.S. Army Soldier and Biological Chemical Command Department of Defense; April 30 2001.
123 Mughal M. Biological Weapons Response Template and Decision Tree. Arlington, V.A.: U.S. Army Soldier and Biological Chemical Command Department of Defense; April 30 2001.
124 A Mass Casualty Care Strategy for Biological Terrorism Incidents: Preparedness Program by the Department of Defense; May 1 2001.
125 CDC's Mission. Centers for Disease Control and Prevention. August 12. Available at: http://www.cdc.gov/aboutcdc.htm#mission. Accessed August 19, 2003.
126 Alabama Public Health Areas. Alabama Department of Public Health. August 15. Available at: http://www.alapubhealth.org/cancer/Public_Health_Area.htm. Accessed September 9, 2003.
127 Texas Public Health Regions. Texas Department of Health. May. Available at: http://www.tdh.state.tx.us/state.htm. Accessed September 9, 2003.
128 NDMS: Catastrophic Care for the Nation. Department of Health and Human Services. Available at: ndms.hhs.gov/NDMS/About_Teams. Accessed August 8, 2002.
129 About Teams. National Disaster Medical System. Available at: http://ndms.dhhs.gov/NDMS/About_Teams/about_teams.html. Accessed August 8, 2002.
130 Frequently Asked Questions. National Disaster Medical System. Available at: http://www.ndms.dhhs.gov/NDMS/FAQ/faq.html. Accessed August 8, 2002.
131 DMAT CA-1. Orange County Disaster Medical Assistance Team CA-1, Inc. Available at: http://dmatca-1.org. Accessed August 8, 2002.
132 NDMS and DMAT. Office of Emergency Preparedness. Available at: http://oep.osophs.dhhs.gov/dmat/about/ndms.html. Accessed August 8, 2002.
133 Metropolitan Medical Response System (MMRS): Program Overview. Department of Homeland Security. Available at: http://mmrs.hhs.gov/PublicDocs/08-12-03_MMRS_Final_Briefing.ppt. Accessed August 25, 2003.
134 Homeland Security Act of 2002. United States Congress. Available at: http://www.dhs.gov/interweb/assetlibrary/hr_5005_enr.pdf. Accessed September 2, 2003.
135 DHS Organization; DHS Agencies; Who will be part of the new department? Department of Homeland Security. Available at: http://www.dhs.gov/dhspublic/display?theme=13. Accessed September 9, 2003.
136 Map of Veterans Health Administration. Department of Verterans Affairs. Available at: http://www.va.gov/sta/guide/map.asp?divisionid=1. Accessed August 25, 2003.
137 Terrorism Incident Annex, Federal Response Plan: Federal Emergency Management Agency; April 1999.
138 Babb J, Tosatto R, Hayslett J. Disaster planning and emergency preparedness: lessons learned. J Am Pharm Assoc. Sep-Oct. 2002;42(5 Suppl 1):S50-51.
139 Hsu EB, Jenckes MW, Catlett CL, et al. Training of Hospital Staff to Repond to a Mass Casualty Event. Rockville, MD: Agency for Healthcare Research and Quality; in press. Contract No. 290-02-0018.
140 AHRQ Bioterrorism Preparedness Research Portfolio. Agency for Healthcare Research and Quality. June 2003. Available at: http://www.ahrq.gov/research/bioterport.htm. Accessed October 13, 2003.
141 Bioterrorism and Emergency Preparedness. Health Resources and Services Administration. Available at: http://www.hrsa.gov/bioterrorism.htm. Accessed October 13, 2003, 2003.
142 The Future of the Public's Health in the 21st Century. Washington, D.C.: National Academies Press; 2002.
143 Local Public Health Agency Infrastructure: A Chartbook: National Association of County and City Health Officials; October 2001.
144 Mertz E, Finocchio L. A Snapshot of California's Local Public Health Departments. San Francisco, CA: Center for California Health Workforce Studies at the University of California, San Francisco; June 1999.
145 Managing the Unexpected: Four Case Study Reports. Washington, D.C.: U.S. Medicine Institute for Health Studies, Executive Leadership Program 2002; 2002.
146 Freund LW. Allowing Access to the Selected Reserve for Domestic Disaster Relief Operations. Carlisle Barracks, P.A.: U.S. Army War College; April 7 1997.
147 Spiese MG. The National Guard and WMD Homeland Defense: School of Advanced Military Studies; May 21 1998.
148 Chase DW. Reviewing the Role of the Army National Guard in the Twenty-First Century. Fort Leavenworth, K.S.: School of Advanced Military Studies United States Army Command and General Staff College; January 2 2001.
149 Update: Investigation of anthrax associated with intentional exposure and interim public health guidelines, October 2001. MMWR Morb Mortal Wkly Rep. Oct 19 2001;50(41):889–893.
150 Maillard J M, Fischer M, McKee K T Jr, Turner L F, Cline J S. First case of bioterrorism-related inhalational anthrax, Florida, 2001: North Carolina investigation. Emerg Infect Dis. 2002;8(10):1035-1038. [pmid: 12396911].
151 Update: investigation of bioterrorism-related inhalational anthrax--Connecticut, 2001. MMWR Morb Mortal Wkly Rep. Nov 30 2001;50(47):1049–1051.
152 Holty JE, Bravata DM, Wilhelm ER, et al. Systematic review of inhalational anthrax in the U.S.: 1900 to 2001. Manuscript under review.
153 Plotkin S A, Brachman P S, Utell M, Bumford F H, Atchison M M. An epidemic of inhalation anthrax, the first in the twentieth century: I. Clinical features. Am J Med. Jan. 2002;112(1):4-13. [pmid: 11812400].
154 Hupert N, Bearman G M, Mushlin A I, Callahan M A. Accuracy of screening for inhalational anthrax after a bioterrorist attack. Ann Intern Med. Sep 2. 2003;139(5 Pt 1):337-345. [pmid: 12965942].
155 Jernigan J A, Stephens D S, Ashford D A, et al. Bioterrorism-related inhalational anthrax: the first 10 cases reported in the United States. Emerg Infect Dis. Nov-Dec. 2001;7(6):933-944. [pmid: 11747719].
156 Perkins B A, Popovic T, Yeskey K. Public health in the time of bioterrorism. Emerg Infect Dis. Oct. 2002;8(10):1015-1018. [pmid: 12396908].
157 Lane H C, Fauci A S. Bioterrorism on the home front: a new challenge for American medicine. JAMA. Nov 28. 2001;286(20):2595-2597. [pmid: 11722275].
158 Developments in Anthrax Scare. Kansas City Star. September 27, 2001.
159 New World Coming: American Security in the 21st Century. US Commission on National Security for the 21st Century. September. Available at: www.nssg.gov. Accessed August 12, 2003.
160 Young S. Expert: Government gets ‘D’ on anthrax response. Cable News Network. November 7, 2001. Available at: http://www.cnn.com/2001/HEALTH/conditions/11/06/bioterrorism.conference/index.html. Accessed August 31, 2003.
161 GAO Congressional Report; Bioterrorism: Preparedness varied across state and local jurisdictions. Washington, D.C.: Government Accounting Office; 2003.
162 Gursky E, Laglesby T V, O'Toole T. Anthrax 2001: observations on the medical and public health response. Biosecurity Bioterrorism. 2003;1(2):97-110.
163 Guidelines for Surveillance and Control of Anthrax in Humans and Animals. World Health Organization. June. Available at: http://www.who.int/emc. Accessed August 12, 2003.
164 Cieslak T J, Eitzen E M Jr. Clinical and epidemiologic principles of anthrax. Emerg Infect Dis. Jul-Aug. 1999;5(4):552-555. [pmid: 10458964].
165 Barbera J A, Macintyre A G. The reality of the modern bioterrorism response. Lancet. Dec. 2002;360(Suppl):s33-34. [pmid: 12504495].
166 Falkenrath RA. US Domestic Preparedness and the Complex Threat of Bioterrorism. Paper presented at: Second National Symposium on Medical and Public Health Response to Bioterrorism; November 28, 2000.
167 Dalton PA. Combating Terrorism: Intergovernmental Cooperation in the Development of a National Strategy to Enhance State and Local Preparedness. Washington, D.C.: General Accounting Office; April 2 2002. GAO-02-550T.
168 Heinrich J. Bioterrorism: Review of Public Health Preparedness Programs. Washington, D.C.: United States General Accouting Office; October 10 2001.
169 Bioterrorism: Federal Research and Preparedness Activities. Washingon, D.C.: United States General Accounting Office; September 2001.
170 Public Health Emergency Response: The CDC Role. Centers for Disease Control and Prevention. October 14. Available at: www.bt.cdc.gov/DocumentsApp/ImprovingBioDefense/ImprovingBioDefense.asp. Accessed August 22, 2003.
171 HHS initiative prepares for possible bioterrorism threat. Department of Health and Human Services. August 16. Available at: www.hhs.gov/news/2001press/01fsbioterrorism.html. Accessed August 21, 2003.
172 Lillibridge SR. Restructuring government for homeland security: nuclear/biological/chemical threats. Washington, D.C. December 15 2001.
173 Heller M B, Bunning M L, France M E, et al. Laboratory response to anthrax bioterrorism, New York City, 2001. Emerg Infect Dis. Oct. 2002;8(10):1096-1102. [pmid: 12396923].
174 Scardaville M. Homeland Security, Strengthening Capabilities to Protect America. Issues 2003: The Policymaker's Briefing Book: The Heritage Foundation; 2003.
175 CDC's Public Health Emergency Preparedness and Response: How to Handle Anthrax and Other Biological Agents. Centers for Disease Control and Prevention. October 12. Available at: www.bt.cdc/DocumentsApp/Anthrax/10122001Handle/10122001Handle.asp. Accessed August 21, 2003.
176 CDC's Programs in Brief: Epidemic Information Exchange (Epi-X). Centers for Disease Control and Prevention. February. Available at: www.cdc.gov/programs/research5.pdf. Accessed August 21, 2003.
177 Casani J, Matuszak D L, Benjamin G C. Under Siege: One State's Perspective of the Anthrax Events of October/November 2001. Biosecurity and Bioterrorism. 2003;1(1):43-45. [pmid: 15040214].
178 Thompson TG. Fighting Bioterrorism Together. Paper presented at: US Conference of Mayors; October 24, 2001; Washington, D.C.
179 Dodge WR. Regional Emergency Preparedness Compacts: Safeguarding the Nation's Communities. March. Available at: www.regionalstewardship.org/Documents/REPCSReports.pdf. Accessed August 25, 2003.
180 Davis LM, Blanchard JC. Are Local Health Responders Ready for Biological and Chemical Terrorism? Santa Monica, C.A.: RAND; 2002.
181 Haffer A S, Rogers J R, Montello M J, Frank E C, Ostroff C. 2001 anthrax crisis in Washington, D.C.: clinic for persons exposed to contaminated mail. Am J Health Syst Pharm. Jun 15. 2002;59(12):1189-1192. [pmid: 12073860].
182 Presidential Decision Directive/NSC-63 (PDD-63). Critical Infrastructure Protection. Available at: www.fas.org/irp/offdocs/pdd/pdd_63.htm. Accessed August 25, 2003.
183 CDC Reports Second Anthrax Case Found in Florida. U.S. Department of State. October 7. Available at: http://usinfo.state.gov/topical/pol/terror/01100901.htm. Accessed August 26, 2003.
184 Butler J C, Cohen M L, Friedman C R, Scripp R M, Watz C G. Collaboration between public health and law enforcement: new paradigms and partnerships for bioterrorism planning and response. Emerg Infect Dis. Oct. 2002;8(10):1152-1156. [pmid: 12396931].
185 American Anthrax Outbreak 2001. UCLA Department of Epidemiology School of Public Health. Available at: www.ph.ucla.edu/epi/bioter/detect/antdetect_intro.html. Accessed August 26, 2003.
186 President Decision Directive 39 (PDD-39). Federal Response Plan: Notice of Change. Federal Emergency Management Agency. Available at: www.fas.org/irp/offdocs/pdd39_frp.htm. Accessed August 25, 2003.
187 About FEMA. Federal Emergency Management Agency. Available at: www.fema.gov/nwz01/nz01_92.shtm. Accessed August 26, 2001.
188 2001 Disaster Activity. Federal Emergency Management Agency. August 21. Available at: www.fema.gov/library/diz01.shtm. Accessed August 26, 2003.
189 Biological and chemical terrorism: strategic plan for preparedness and response. Recommendations of the CDC Strategic Planning Workgroup. MMWR Recomm Rep. Apr 21 2000;49(RR-4):1–14.
190 The Public Health Response to Biological and Chemical Terrorism: Interim Planning Guidance for State and Public Health Officials. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. July. Available at: www.slu.edu/colleges/sph/csbei/bioterrorism/key-references/government.htm. Accessed August 25, 2003.
191 CDC's Bioterrorism Preparedness and Response Core Capacity Project 2001. Centers for Disease Control and Prevention. Available at: www.bt.cdc.goc/Documents/CoreCapacity082801.pdf. Accessed August 14, 2003.
192 Caldwell MC. The Local Role in Homeland Security. Washington, D.C.: US Senate Committee on Governmental Affairs; December 11 2001.
193 Executive Summary: New Jersey Department of Health and Senior Services Cooperative Agreement (CA) Application. Health Resources and Services Administration (HRSA) Bioterrorism (BT) Hospital Preparedness Program. Available at: www.state.nj/health/er/hrsaexecsumbt.pdf. Accessed August 22, 2003.
194 Allan S. The Challenges of Local Preparedness for Bioterrorism and Other Emergencies. NACCHO Exchange. 2002;1(1):2-5.
195 Providing a Framework for Public Health Bioterrorism Preparedness: Public Health Workforce, Collaboration, and Infrastructure Issues. CIDRAP. May 17. Available at: http://www.cidrap.umn.edu/cidrap/center/mission/papers/btworkforce.html. Accessed August 22, 2003.
196 Koplan J. CDC's strategic plan for bioterrorism preparedness and response. Public Health Rep. 2001;116(Suppl 2):9-16. [pmid: 11880662]. [pmcid: 1497264].
197 Strategic National Stockpile. Centers for Disease Control and Prevention. August 11, 2003. Available at: http://www.bt.cdc.gov/stockpile/index.asp. Accessed August 27, 2003.
198 National Pharmaceutical Stockpile. Centers for Disease Control and Prevention. Available at: www.bt.cdc.gov/DocumentsApp/NationalStockpile/national_pharmaceutical_stockpile.pdf. Accessed August 27, 2003.
199 Surge Capacity: Is it Time to Move Beyond ‘Just-in-Time’? US Medicine Institute for Health Studies. June 1, 2002. Available at: www.usminstitute.org/jun02surgeagenda.html. Accessed August 13, 2003.
200 Terriff C M, Tee A M. Citywide pharmaceutical preparation for bioterrorism. Am J Health Syst Pharm. Feb 1. 2001;58(3):233-237. [pmid: 11217178].
201 Benson B, McKinney P. Selecting & Stocking Antidotes to Biological/Chemical Agents. Paper presented at: Texas Society of Hospital Pharamcists Annual Meeting; April 7, 2003.
202 Reissman D B, Steinberg E B, Magri J M, Jernigan D B. The Anthrax Epidemiologic Tool Kit: an Instrument for Public Health Preparedness. Biosecurity and Bioterrorism. 2003;1(2):1-6. [pmid: 15040209].
203 Thompson J. Public Health Responds to the Spotlight on Bioterrorism. Northwest Public Health. 2002(Spring/Summer):6–9.
204 Thompson T G. Preparing for bioterrorism. Anesthesiology. Oct. 2002;97(4):776-777. [pmid: 12357139].
205 Montello M J, Ostroff C, Frank E C, Haffer A S, Rogers J R. 2001 anthrax crisis in Washington, D.C.: pharmacists' role in screening patients and selecting prophylaxis. Am J Health Syst Pharm. Jun 15. 2002;59(12):1193-1199. [pmid: 12073861].
206 Shepard C W, Soriano-Gabarro M, Zell E R, et al. Antimicrobial postexposure prophylaxis for anthrax: adverse events and adherence. Emerg Infect Dis. Oct. 2002;8(10):1124-1132. [pmid: 12396927].
207 Jernigan D B, Raghunathan P L, Bell B P, et al. Investigation of bioterrorism-related anthrax, United States, 2001: epidemiologic findings. Emerg Infect Dis. Oct. 2002;8(10):1019-1028. [pmid: 12396909].
208 Bioterrorism: Summary of Issues and Recommendations. University of Texas' Southwestern Medical Foundation. October. Available at: www.swmed.edu/home_pages/news/handout.htm. Accessed July 5, 2003.
209 Hsu V P, Lukacs S L, Handzel T, et al. Opening a bacillus anthracis-containing envelope, Capitol Hill, Washington, D.C.: the public health response. Emerg Infect Dis. Oct. 2002;8(10):1039-1043. [pmid: 12396912].
210 First Responders Combat Bio-Terrorism: A Satellite and Web-Based Broadcast: National Association of Counties; 2002.
211 Fraser MR, Fisher VS. Elements of Effective Bioterrorism Preparedness: A Planning Primer for Local Public Health Agencies. Washington, D.C.: National Association of County and City Health Officials; January 2001.
212 Camus A. The Plague. New York: Vintage International; 1948.
213 Heymann DL. Hot spots in a wired world: World Health Organization surveillance of emerging and re-emerging infectious diseases: Global Outbreak Alert and Response Network.
214 There are two sides to biodefence. Nature. Apr 10 2003;422(6932):545.
215 Rosett C. The Red Plague: How communism gave us SARS. Wall Street Journal. May 14, 2003.
216 ProMED-mail. Severe acute respiratory syndrome - worldwide (03): alert. ProMED-mail. March 16, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
217 Fine A, Layton M. Lessons from the West Nile viral encephalitis outbreak in New York City, 1999: implications for bioterrorism preparedness. Clin Infect Dis. Jan 15. 2001;32(2):277-282. [pmid: 11170918].
218 Schoch-Spana M. Implications of pandemic influenza for bioterrorism response. Clin Infect Dis. Dec. 2000;31(6):1409-1413. [pmid: 11096011].
219 Update 53 - Situation in Singapore and Hong Kong, interpretation of “areas with recent local transmission”. World Health Organization. Available at: http://www.who.int/csr/sars/archive/2003_05_12/en/. Accessed May 12, 2003.
220 Breiman RF, Evans MR, Preiser W, et al. Role of China in the Quest to Define and Control Severe Acute Respiratory Syndrome. Emerg Infect Dis. Sept 2003.
221 Enserink M. Infectious diseases. WHO wants 21st-century reporting regs. Science. May 2. 2003;300(5620):717-718. [pmid: 12730564].
222 Ashraf H. China finally throws full weight behind efforts to contain SARS. Although SARS claims more lives everyday worldwide, all eyes are on China as it tries to contain the largest outbreak. Lancet. 2003;361(9367):1439. [pmid: 12727402].
223 Parry J. Containment of SARS depends on how it is handled in China. BMJ. May 10. 2003;326(7397):1004. [pmid: 12742917].
224 Update 95 - SARS: Chronology of a serial killer. World Health Organization. Available at: http://www.who.int/csr/don/2003_07_04/en. Accessed August 11, 2003.
225 Parry J. WHO praises China's control measures for SARS. BMJ. Jun 21. 2003;326(7403):1350. [pmid: 12816809].
226 ProMED-mail. SARS - WORLDWIDE (136): CASES. ProMED-mail. June 5 2003.
227 Twu S J, Chen T J, Chen C J, et al. Control measures for severe acute respiratory syndrome (SARS) in Taiwan. Emerg Infect Dis. Jun. 2003;9(6):718-720. [pmid: 12781013].
228 Crupi R S, Asnis D S, Lee C C, Santucci T, Marino M J, Flanz B J. Meeting the challenge of bioterrorism: lessons learned from West Nile virus and anthrax. Am J Emerg Med. Jan. 2003;21(1):77-79. [pmid: 12563588].
229 Chapman L E, Khabbaz R F. Etiology and epidemiology of the Four Corners hantavirus outbreak. Infect Agents Dis. Oct. 1994;3(5):234-244. [pmid: 7866656].
230 SARS death rate rising. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/05/01/sars/index.html. Accessed May 12, 2003.
231 Stohr K. A multicentre collaboration to investigate the cause of severe acute respiratory syndrome. Lancet. May 17. 2003;361(9370):1730-1733. [pmid: 12767752].
232 Cyranoski D. Health labs focus on mystery pneumonia. Nature. Mar 20. 2003;422(6929):247. [pmid: 12646882].
233 Enserink M, Vogel G. Infectious diseases. Deferring competition, global net closes in on SARS. Science. 2003;300(5617):224-225. [pmid: 12690153].
234 ProMED-mail. SARS - worldwide (42): WHO historical overview. ProMED-mail. April 11, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
235 Roueche B. A Man From Mexico.Eleven Blue Men: and Other Narratives of of Medical Detection. Boston, MA: Little, Brown; 1953.
236 White D J. Vector surveillance for West Nile virus. Ann N Y Acad Sci. Dec. 2001;951:74-83. [pmid: 11797806].
237 HHS Teleconference on Smallpox Policy. Atlanta, GA: Centers for Disease Control and Prevention; December 14 2002.
238 Hospitals in China battle SARS burden. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/05/05/sars/index.html. Accessed May 12, 2003.
239 Altman LK. Behind the Mask, The Fear of SARS. New York Times. June 24, 2003;D: 1, 6.
240 ProMED-mail. SARS - WORLDWIDE (04): ETIOLOGY. ProMED-mail. March 25 2003.
241 Drazen J M, Campion E W. SARS, the Internet, and the Journal. N Engl J Med. May 15. 2003;348(20):2029. [pmid: 12748319].
242 O'Hara J A 3rd. West Nile virus: success of public health response underlines failure of the system. J Urban Health. Jun. 2001;78(2):392-395. [pmid: 11419590].
243 ProMED-mail. SARS - worldwide (90): background. ProMED-mail. May 3, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
244 Severe acute respiratory syndrome (SARS): Status of the outbreak and lessons for the immediate future. Geneva: World Health Organization; May 20 2003.
245 Lee N, Hui D, Wu A, et al. A major outbreak of severe acute respiratory syndrome in Hong Kong. N Engl J Med. May 15. 2003;348(20):1986-1994. [pmid: 12682352].
246 Charatan F. Explosion of internet advertisements for protection against SARS. BMJ. 2003;326(7395):900. [pmid: 12714464].
247 Solid response to SARS-almost. Nat Med. 2003;9(5):479.
248 Parry J. SARS shows no sign of coming under control. BMJ. Apr 19. 2003;326(7394):839. [pmid: 12702606].
249 Tsang K W, Ho P L, Ooi G C, et al. A cluster of cases of severe acute respiratory syndrome in Hong Kong. N Engl J Med. May 15. 2003;348(20):1977-1985. [pmid: 12671062].
250 Poutanen S M, Low D E, Henry B, et al. Identification of severe acute respiratory syndrome in Canada. N Engl J Med. May 15. 2003;348(20):1995-2005. [pmid: 12671061].
251 Vogel G. SARS outbreak. Modelers struggle to grasp epidemic's potential scope. Science. Apr 25. 2003;300(5619):558-559. [pmid: 12714711].
252 Tsui PT, Kwok ML, Yuen H, Lai ST. Severe Acute Respiratory Syndrome: Clinical Outcomes and Prognostic Correlates. Emerg Infect Dis. Sept 2003.
253 Drazen J M. SARS--looking back over the first 100 days. N Engl J Med. Jul 24. 2003;349(4):319-320. [pmid: 12878735].
254 Chotani R A, LaPorte R E, Linkov F, Dodani S, Ahmed D, Ibrahim K M. Just-in-time lectures: SARS. Lancet. Jun 7. 2003;361(9373):1996. [pmid: 12801780].
255 State and Local Health Official Epidemic SARS Checklist: Association of State and Territorial Health Officials; June 3 2003.
256 Dwosh H A, Hong H H, Austgarden D, Herman S, Schabas R. Identification and containment of an outbreak of SARS in a community hospital. CMAJ. May 27. 2003;168(11):1415-1420. [pmcid: 155957]. [pmid: 12771070].
257 Chan-Yeung M. Severe acute respiratory syndrome: a lesson in infectious disease. Int J Tuberc Lung Dis. May. 2003;7(5):407-408. [pmid: 12757037].
258 Health official: SARS teaching world about outbreaks. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/05/01/sars.conference/index.html. Accessed May 12, 2003.
259 Bray M. Living in the midst of a killer virus. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/03/28/hk.virus/index.html. Accessed May 12, 2003.
260 SARS infecting economies. Cable News Network. Accessed May 12, 2003.
261 Mass SARS quarantine in Beijing. Cable News Network. Available at: http://www.cnn.com/2003/WORLD/asiapcf/east/04/25/sars/index.html. Accessed May 12, 2003.
262 WHO sends virus team to S. China. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/04/02/sars/index.html. Accessed May 12, 2003.
263 WHO reaches virus epicenter. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/04/03/sars/index.html. Accessed May 12, 2003.
264 Mystery illness on the move. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/03/17/mystery.disease/index.html. Accessed May 12, 2003.
265 How Vietnam beat the bug. Cable News Network. Available at: http://www.cnn.com/2003/WORLD/asiapcf/east/04/28/sars.vietnam/index.html. Accessed May 12, 2003.
266 WHO targets SARS ‘super spreaders’. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/04/06/sars/index.html. Accessed May 12, 2003.
267 Health Agency: SARS pandemic can be avoided. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/04/27/sars.pandemic/index.html. Accessed May 12, 2003.
268 Asia adopts SARS war plan. Cable News Network. Available at: http://www.cnn.com/2003/WORLD/asiapcf/east/04/29/sars.wrap/index.html. Accessed May 12, 2003.
269 Timeline: SARS outbreak. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/04/24/timeline.sars/index.html. Accessed May 12, 2003.
270 SARS relapses stump doctors. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/05/03/sars.mutate/index.html. Accessed May 12, 2003.
271 WHO confirms SARS more deadly. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/05/09/sars/index.html. Accessed May 12, 2003.
272 CDC chief: Vigilance needed to contain SARS. Cable News Network. Available at: http://www.cnn.com/2003/HEALTH/05/05/cnna.gerberding/index.html. Accessed May 12, 2003.
273 ProMED-mail. SARS - WORLDWIDE (137): CASES. ProMED-mail. June 6 2003.
274 ProMED-mail. SARS - worldwide (41): overview. ProMED-mail. April 11, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
275 ProMED-mail. SARS - worldwide (28): overview. ProMED-mail. April 3, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
276 ProMED-mail. SARS - worldwide (14): overview. ProMED-mail. March 27, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
277 ProMED-mail. SARS - worldwide (10): infectious disease perspectives. ProMED-mail. March 26, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
278 ProMED-mail. Severe acute respiratory syndrome - worldwide (02): alert. ProMED-mail. March 15, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
279 ProMED-mail. SARS - worldwide (06): WHO press briefing. ProMED-mail. March 25, 2003. Available at: http://www.promedmail.org. Accessed May 12, 2003.
280 Koch MG. Epidemiological considerations about 3 months with SARS. ProMED-mail. 2003.
281 Key Developments Concerning SARS. New York Times. May 12, 2003.
282 Shenon P. U.S. Approves Force in Detaining Possible SARS Carriers. New York Times. May 7, 2003.
283 Arnold W. Military Hardware is Adapted to Fight SARS. New York Times. May 12, 2003.
284 Emanuel EJ. Preventing the Next SARS. New York Times. May 12, 2003.
285 4 Major Shanghai Hotels Close Over SARS. New York Times. May 12, 2003.
286 Altman LK. Lessons of AIDS, Applied to SARS. New York Times. May 6, 2003.
287 Eckholm E. The SARS Epidemic: Epidemic; China Admits Underreporting Its SARS Cases. New York Times. April 21, 2003.
288 Altman LK. W.H.O. Urges More Detailed SARS Reports. New York Times. May 3, 2003.
289 Broder JM. Agressive Steps Help U.S. Avoid SARS Brunt. New York Times. May 5, 2003.
290 China SARS Cases Stabilize, WHO Urges Caution. New York Times. May 12, 2003.
291 SARS Cases in China Pass 5,000. New York Times. May 12, 2003.
292 Krauss C. W.H.O. Restores Toronoto to SARS List After Surge in Cases. New York Times. May 26, 2003.
293 SARS Shuts Toronto School, 6,400 in Quarantine. New York TImes. May 28, 2003.
294 Bradsher K, Campbell C. New Travel Alert is Issued for Toronto. New York Times. May 24, 2003.
295 Toronto Braces for SARS Outbreak as Taiwan Reports 12 More Deaths. Wall Street Journal. May 25, 2003.
296 Heinzl M. Toronto Appoints 4 Hospitals to Handle SARS Patients. Wall Street Journal. May 28, 2003.
297 Cherney E. Toronto's 2nd SARS Outbreak Triggers a Mass Quarantine. Wall Street Journal. May 27, 2003.
298 Chang L, Pottinger M. Health Body Says Chinese Data on SARS ‘Reflect Huge Efforts’. Wall Street Journal. June 12, 2003.
299 Canada Fears New Outbreak With 4 Suspected SARS Cases. Wall Street Journal. May 22, 2003.
300 Possible New Cases of SARS Virus May Put Canada Back on WHO List. Wall Street Journal. May 23, 2003.
301 Playing Politics with SARS. Wall Street Journal. May 28, 2003.
302 Update 83 - One hundred days into the outbreak. World Health Organization. Available at: http://www.who.int/csr/don/2003_06_18/en. Accessed August 11, 2003.
303 The operational response to SARS. World Health Organization. Available at: http://www.who.int/csr/sars/goarn2003_4_16/en/. Accessed May 12, 2003.
304 Epidemic curves - Severe Acute Respiratory Syndrome (SARS). World Health Organization. Available at: http://www.who.int/csr/sars/epicurve/epiindex/en/. Accessed May 12, 2003.
305 Gensheimer K F, Fukuda K, Brammer L, Cox N, Patriarca P A, Strikes R A. Preparing for pandemic influenza: the need for enhanced surveillance. Vaccine. May 15. 2002;20(Suppl 2):S63-65. [pmid: 12110262].
306 Update 89 - What happens if SARS returns? World Health Organization. June 26, 2003. Available at: http://www.who.int/csr/don/2003_06_26/en/print.html. Accessed September 10, 2003.
307 Mac Kenzie W R, Hoxie N J, Proctor M E, et al. A massive outbreak in Milwaukee of cryptosporidium infection transmitted through the public water supply. N Engl J Med. 1994;331(3):161-167. [pmid: 7818640].
308 MacKenzie W R, Schell W L, Blair K A, et al. Massive outbreak of waterborne cryptosporidium infection in Milwaukee, Wisconsin: recurrence of illness and risk of secondary transmission. Clin Infect Dis. 1995;21(1):57-62. [pmid: 7578760].
309 Puech M C, McAnulty J M, Lesjak M, Shaw N, Heron L, Watson J M. A statewide outbreak of cryptosporidiosis in New South Wales associated with swimming at public pools. Epidemiol Infect. 2001;126(3):389-396. [pmid: 11467796].
310 Brookhart M A, Hubbard A E, van der Laan M J, Colford J M Jr, Eisenberg J N. Statistical estimation of parameters in a disease transmission model: analysis of a Cryptosporidium outbreak. Stat Med. Dec 15. 2002;21(23):3627-3638. [pmid: 12436460].
311 Dietz V, Vugia D, Nelson R, et al. Active, multisite, laboratory-based surveillance for Cryptosporidium parvum. Am J Trop Med Hyg. Mar. 2000;62(3):368-372. [pmid: 11037779].
312 Griffin R J, Dunwoody S, Zabala F. Public reliance on risk communication channels in the wake of a cryptosporidium outbreak. Risk Anal. Aug. 1998;18(4):367-375. [pmid: 9775446].
313 Cicirello H G, Kehl K S, Addiss D G, et al. Cryptosporidiosis in children during a massive waterborne outbreak in Milwaukee, Wisconsin: clinical, laboratory and epidemiologic findings. Epidemiol Infect. Aug. 1997;119(1):53-60. [pmid: 9287944].
314 Quiroz E S, Bern C, MacArthur J R, et al. An outbreak of cryptosporidiosis linked to a foodhandler. J Infect Dis. Feb. 2000;181(2):695-700. [pmid: 10669357].
315 Sharp S E, Suarez C A, Duran Y, Poppiti R J. Evaluation of the Triage Micro Parasite Panel for detection of Giardia lamblia, Entamoeba histolytica/Entamoeba dispar, and Cryptosporidium parvum in patient stool specimens. J Clin Microbiol. Jan. 2001;39(1):332-334. [pmcid: 87724]. [pmid: 11136793].
316 McDonald A C, Mac Kenzie W R, Addiss D G, et al. Cryptosporidium parvum-specific antibody responses among children residing in Milwaukee during the 1993 waterborne outbreak. J Infect Dis. May 1. 2001;183(9):1373-1379. [pmid: 11294669].
317 Gostin L O, Lazzarini Z, Neslund V S, Osterholm M T. Water quality laws and waterborne diseases: Cryptosporidium and other emerging pathogens. Am J Public Health. Jun. 2000;90(6):847-853. [pmid: 10846499]. [pmcid: 1446258].
318 Altman L K. Uncommon Parasite Tied to Ills in Milwaukee. New York Times. April 9. 1993;A:15.
319 Guerrant R L. Cryptosporidiosis: an emerging, highly infectious threat. Emerg Infect Dis. Jan-Mar. 1997;3(1):51-57. [pmid: 9126444].
320 Brillman J C, Sklar D P, Davis K D, Beamsely A. Hantavirus: emergency department response to a disaster from an emerging pathogen. Ann Emerg Med. Sep. 1994;24(3):429-436. [pmid: 8080140].
321 Butler J C, Peters C J. Lessons learned from the hantaviruses and other hemorrhagic fever viruses. Am J Med Sci. Jan. 1996;311(1):55-59. [pmid: 8571987].
322 Berkelman R L. Emerging infectious diseases in the United States, 1993. J Infect Dis. Aug. 1994;170(2):272-277. [pmid: 8035009].
323 Foucar K, Nolte K B, Feddersen R M, et al. Outbreak of Hantavirus pulmonary syndrome in the southwestern United States. Response of pathologists and other laboratorians. Am J Clin Pathol. Apr. 1994;101(4 Suppl 1):S1-5. [pmid: 8154449].
324 Sands L, Kioski C, Komatsu K. Hantavirus in the southwestern United States: epidemiology of an emerging pathogen. J Am Osteopath Assoc. Dec. 1993;93(12):1279-1285. [pmid: 8307808].
325 Morrison Y Y, Rathbun R C. Hantavirus pulmonary syndrome: the Four Corners disease. Ann Pharmacother. Jan. 1995;29(1):57-65. [pmid: 7711347].
326 Allen T J Vt. Man Diagnosed with Virus Spread by Mice. Boston Globe. April 21. 2000;B:7.
327 Slama T G, Zon R. Fatal hantavirus pulmonary syndrome in Indiana. N Engl J Med. Apr 7. 1994;330(14):1010. [pmid: 8121443].
328 Hughes J M, Peters C J, Cohen M L, Mahy B W. Hantavirus pulmonary syndrome: an emerging infectious disease. Science. Nov 5. 1993;262(5135):850-851. [pmid: 8235607].
329 Horgan J. The no-name virus. Questions linger after the four corners outbreak. Sci Am. Dec. 1994;271(6):34-36. [pmid: 7809594].
330 Horgan J. Were four corners victims biowar casualties?. Sci Am. Nov. 1993;269(5):16. [pmid: 8235553].
331 Noji E K, Miller G L. Emergency department response to a disaster from an emerging pathogen. Ann Emerg Med. Sep. 1994;24(3):512-514. [pmid: 8080147].
332 Myers F. Hunting down hantavirus. Nursing. May. 2002;32(5):56-57. [pmid: 12035655].
333 Steier K J, Clay R. Hantavirus pulmonary syndrome (HPS): report of first case in Louisiana. J Am Osteopath Assoc. Dec. 1993;93(12):1286-1289. [pmid: 8307809].
334 From the Centers for Disease Control and Prevention. Update: hantavirus disease--southwestern United States, 1993. JAMA. Aug 25. 1993;270(8):934. [pmid: 8345637].
335 Wenzel R P. A new hantavirus infection in North America. N Engl J Med. Apr 7. 1994;330(14):1004-1005. [pmid: 8121440].
336 Duchin J S, Koster F T, Peters C J, et al. Hantavirus pulmonary syndrome: a clinical description of 17 patients with a newly recognized disease. The Hantavirus Study Group. N Engl J Med. Apr 7. 1994;330(14):949-955. [pmid: 8121458].
337 Morse S S. Hantaviruses and the hantavirus outbreak in the United States. A case study in disease emergence. Ann N Y Acad Sci. Dec 15. 1994;740:199-207. [pmid: 7840450].
338 Simonsen L, Dalton M J, Breiman R F, et al. Evaluation of the magnitude of the 1993 hantavirus outbreak in the southwestern United States. J Infect Dis. Sep. 1995;172(3):729-733. [pmid: 7658065].
339 Wells R M, Young J, Williams R J, et al. Hantavirus transmission in the United States. Emerg Infect Dis. Jul-Sep. 1997;3(3):361-365. [pmid: 9284382].
340 Calisher C H. West Nile virus in the New World: appearance, persistence, and adaptation to a new econiche--an opportunity taken. Viral Immunol. 2000;13(4):411-414. [pmid: 11192287].
341 Bignall J. Hantaviruses: the rodents take revenge. Lancet. Jun 17. 1995;345(8964):1564. [pmid: 7791447].
342 Bonn D. Hantaviruses: an emerging threat to human health?. Lancet. Sep 12. 1998;352(9131):886. [pmid: 9742991].
343 From the Centers for Disease Control and Prevention. Infectious diseases update: outbreak, hantavirus infection--southwestern United States, 1993. JAMA. Jul 7. 1993;270(1):25. [pmid: 8510287].
344 From the Centers for Disease Control and Prevention. Update: hantavirus infection--United States, 1993. JAMA. Jul 28 1993;270(4):429, 432.
345 Bremner J A. Hantavirus infections and outbreaks in 1993. Commun Dis Rep CDR Rev. Jan 7. 1994;4(1):R5-9. [pmid: 7509239].
346 Levy H, Simpson S Q. Hantavirus pulmonary syndrome. Am J Respir Crit Care Med. Jun. 1994;149(6):1710-1713. [pmid: 8004332].
347 Schreiner G E. Hanta is coming. Artif Organs. May. 1996;20(5):451-454. [pmid: 8725626].
348 Siegel B. Meningitis outbreak: Mother Nature sends a scary message.Med Econ. Aug 21 1995;72(16):173–174, 177–180, 185–176 passim.
349 Osterholm M T. How to vaccinate 30,000 people in three days: realities of outbreak management. Public Health Rep. 2001;116(Suppl 2):74-78. [pmid: 11880677].
350 Aguilera J F, Perrocheau A, Meffre C, Hahne S. Outbreak of serogroup W135 meningococcal disease after the Hajj pilgrimage, Europe, 2000. Emerg Infect Dis. Aug. 2002;8(8):761-767. [pmid: 12141959].
351 Krause G, Blackmore C, Wiersma S, Lesneski C, Gauch L, Hopkins R S. Mass vaccination campaign following community outbreak of meningococcal disease. Emerg Infect Dis. Dec. 2002;8(12):1398-1403. [pmid: 12498654].
352 De Wals P, De Serres G, Niyonsenga T. Effectiveness of a mass immunization campaign against serogroup C meningococcal disease in Quebec. JAMA. Jan 10. 2001;285(2):177-181. [pmid: 11176810].
353 Prevention and control of meningococcal disease. Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR Recomm Rep. Jun 30. 2000;49(RR-7):1-10. [pmid: 11106289].
354 Meningococcal disease prevention and control strategies for practice-based physicians (Addendum: recommendations for college students). Committee on Infectious Diseases. Pediatrics. Dec. 2000;106(6):1500-1504. [pmid: 11099614].
355 Diaz P S. The epidemiology and control of invasive meningococcal disease. Pediatr Infect Dis J. Jul. 1999;18(7):633-634. [pmid: 10440442].
356 Makras P, Alexiou-Daniel S, Antoniadis A, Hatzigeorgiou D. Outbreak of meningococcal disease after an influenza B epidemic at a Hellenic Air Force recruit training center. Clin Infect Dis. Sep 15. 2001;33(6):e48-50. [pmid: 11512107].
357 Vogel G. Bacterial meningitis. Appeal to thwart deadly outbreak. Science. Oct 11. 2002;298(5592):339. [pmid: 12376673].
358 Baltimore R S, Jenson H B. Meningococcal vaccine: new recommendations for immunization of college freshmen. Curr Opin Pediatr. Feb. 2001;13(1):47-50. [pmid: 11176243].
359 Shehab S, Keller N, Barkay A, Leitner L, Leventhal A, Block C. Failure of mass antibiotic prophylaxis to control a prolonged outbreak of meningococcal disease in an Israeli village. Eur J Clin Microbiol Infect Dis. Nov. 1998;17(11):749-753. [pmid: 9923513].
360 Rosenstein N, Levine O, Taylor J P, et al. Efficacy of meningococcal vaccine and barriers to vaccination. JAMA. Feb 11. 1998;279(6):435-439. [pmid: 9466635].
361 Hume SE. Mass voluntary immunization campaigns for meningococcal disease in Canada: media hysteria. JAMA. Apr 1 1992;267(13):1833–1834, 1837–1838.
362 Outbreak of aseptic meningitis--Whiteside County, Illinois, 1995. MMWR Morb Mortal Wkly Rep. Mar 14 1997;46(10):221–224.
363 Weinstein I. An Outbreak of Smallpox in New York City. American Journal of Public Health. November 1947.
364 Albert M R, Ostheimer K G, Breman J G. The last smallpox epidemic in Boston and the vaccination controversy, 1901-1903. N Engl J Med. Feb 1. 2001;344(5):375-379. [pmid: 11172172].
365 Albert M R, Ostheimer K G, Liewehr D J, Steinberg S M, Breman J G. Smallpox manifestations and survival during the Boston epidemic of 1901 to 1903. Ann Intern Med. Dec 17. 2002;137(12):993-1000. [pmid: 12484715].
366 Cherry B, Trock S C, Glaser A, et al. Sentinel chickens as a surveillance tool for West Nile virus in New York City, 2000. Ann N Y Acad Sci. Dec. 2001;951:343-346. [pmid: 11797795].
367 Klein C, Kimiagar I, Pollak L, et al. Neurological features of West Nile Virus infection during the 2000 outbreak in a regional hospital in Israel. J Neurol Sci. 2002;200(12):63-66. [pmid: 12127678].
368 Asnis D S, Conetta R, Teixeira A A, Waldman G, Sampson B A. The West Nile Virus outbreak of 1999 in New York: the Flushing Hospital experience. Clin Infect Dis. Mar. 2000;30(3):413-418. [pmid: 10722421].
369 Covello V T, Peters R G, Wojtecki J G, Hyde R C. Risk communication, the West Nile virus epidemic, and bioterrorism: responding to the communication challenges posed by the intentional or unintentional release of a pathogen in an urban setting. J Urban Health. Jun. 2001;78(2):382-391. [pmid: 11419589].
370 Nedry M, Mahon CR. West Nile virus: an emerging virus in North America. Clin Lab Sci. Winter 2003;16(1):43–49.
371 Campbell G L, Marfin A A, Lanciotti R S, Gubler D J. West Nile virus. Lancet Infect Dis. Sep. 2002;2(9):519-529. [pmid: 12206968].
372 Marfin A A, Gubler D J. West Nile encephalitis: an emerging disease in the United States. Clin Infect Dis. Nov 15. 2001;33(10):1713-1719. [pmid: 11595987].
373 Petersen L R, Roehrig J T. West Nile virus: a reemerging global pathogen. Emerg Infect Dis. Jul-Aug. 2001;7(4):611-614. [pmid: 11585520].
374 Tyler K L. West Nile virus encephalitis in America. N Engl J Med. Jun 14. 2001;344(24):1858-1859. [pmid: 11407349].
375 Nash D, Mostashari F, Fine A, et al. The outbreak of West Nile virus infection in the New York City area in 1999. N Engl J Med. Jun 14. 2001;344(24):1807-1814. [pmid: 11407341].
376 Shieh W J, Guarner J, Layton M, et al. The role of pathology in an investigation of an outbreak of West Nile encephalitis in New York, 1999. Emerg Infect Dis. Jul-Aug. 2000;6(4):370-372. [pmid: 10905969].
377 Enserink M. Groups race to sequence and identify New York virus. Science. Oct 8. 1999;286(5438):206-207. [pmid: 10577182].
378 Outbreak of West Nile-like viral encephalitis--New York, 1999. MMWR Morb Mortal Wkly Rep. Oct 1 1999;48(38):845–849.
379 Update: Surveillance for West Nile virus in overwintering mosquitoes--New York, 2000. MMWR Morb Mortal Wkly Rep. Mar 10 2000;49(9):178–179.
380 Komar N. West Nile virus surveillance using sentinel birds. Ann N Y Acad Sci. Dec. 2001;951:58-73. [pmid: 11797805].
381 Kauffman E B, Bernard K A, Jones S A, Maffei J, Ngo K, Kramer L D. West Nile virus laboratory surveillance program: cost and time analysis. Ann N Y Acad Sci. Dec. 2001;951:351-353. [pmid: 11797797].
382 Cannon C E, Pavlin J A, Vaeth M F, et al. Department of Defense West Nile virus surveillance. Ann N Y Acad Sci. Dec. 2001;951:340-342. [pmid: 11797794].
383 Nolen R S. Multistate surveillance system in place for West Nile virus. J Am Vet Med Assoc. Jan 1. 2000;216(1):11. [pmid: 10638307].
384 Mostashari F, Bunning M L, Kitsutani P T, et al. Epidemic West Nile encephalitis, New York, 1999: results of a household- based seroepidemiological survey. Lancet. 2001;358(9278):261-264. [pmid: 11498211].
385 Ford-Jones E L, Fearon M, Leber C, et al. Human surveillance for West Nile virus infection in Ontario in 2000. CMAJ. Jan 8. 2002;166(1):29-35. [pmcid: 99223]. [pmid: 11800244].
386 Gotham I J, Eidson M, White D J, et al. West Nile virus: a case study in how NY State Health Information infrastructure facilitates preparation and response to disease outbreaks. J Public Health Manag Pract. Sep. 2001;7(5):75-86. [pmid: 11680034].
387 Flahault A, Dias-Ferrao V, Chaberty P, Esteves K, Valleron A J, Lavanchy D. FluNet as a tool for global monitoring of influenza on the Web. JAMA. Oct 21. 1998;280(15):1330-1332. [pmid: 9794312].
388 Kitler M E, Gavinio P, Lavanchy D. Influenza and the work of the World Health Organization. Vaccine. May 15. 2002;20(Suppl 2):S5-14. [pmid: 12110248].
389 Preventing Emerging Infectious Diseases: A Strategy for the 21st Century. Overview of the Updated CDC plan. MMWR Recomm Rep. Sep 11. 1998;47(RR-15):1-14. [pmid: 9751113].
390 Schoch-Spana M. “Hospital's full-up”: the 1918 influenza pandemic. Public Health Rep. 2001;116(Suppl 2):32-33. [pmid: 11880667].
391 Chan P K. Outbreak of avian influenza A(H5N1) virus infection in Hong Kong in 1997. Clin Infect Dis. 2002;34(Suppl 2):S58-64. [pmid: 11938498].
392 Besselaar T G, Schoub B D, Blackburn N K. Impact of the introduction of A/Sydney/5/97 H3N2 influenza virus into South Africa. J Med Virol. Dec. 1999;59(4):561-568. [pmid: 10534742].
393 Nichol K L, Lind A, Margolis K L, et al. The effectiveness of vaccination against influenza in healthy, working adults. N Engl J Med. Oct 5. 1995;333(14):889-893. [pmid: 7666874].
394 LeDuc J W. WHO program on emerging virus diseases. Arch Virol Suppl. 1996;11:13-20. [pmid: 8800794].
395 Goddard N L, Joseph C A, Zambon M, Nunn M, Fleming D, Watson J M. Influenza surveillance in England and Wales: October 1999 to May 2000. Commun Dis Public Health. Dec. 2000;3(4):261-266. [pmid: 11280255].
396 Schoub B D, Johnson S, McAnerney J, Blackburn N K. Benefits and limitations of the Witwatersrand influenza and acute respiratory infections surveillance programme. S Afr Med J. Oct. 1994;84(10):674-678. [pmid: 7839255].
397 Takahashi H, Fujii H, Shindo N, Taniguchi K. Evaluation of the Japanese school health surveillance system for influenza. Jpn J Infect Dis. Feb. 2001;54(1):27-30. [pmid: 11326126].
398 Olson J G. School absenteeism during an outbreak of B/Hong Kong/5/72-like influenze virus in Taipei, Taiwan. Southeast Asian J Trop Med Public Health. Dec. 1980;11(4):429-434. [pmid: 7221685].
399 Riddiough M A, Sisk J E, Bell J C. Influenza vaccination. JAMA. Jun 17. 1983;249(23):3189-3195. [pmid: 6406691].
400 Saxen H, Virtanen M. Randomized, placebo-controlled double blind study on the efficacy of influenza immunization on absenteeism of health care workers. Pediatr Infect Dis J. Sep. 1999;18(9):779-783. [pmid: 10493337].
401 Kelly H, Murphy A, Leong W, et al. Laboratory-supported influenza surveillance in Victorian sentinel general practices. Commun Dis Intell. Dec. 2000;24(12):379-383. [pmid: 11225381].
402 Nettleman M D, White T, Lavoie S, Chafin C. School absenteeism, parental work loss, and acceptance of childhood influenza vaccination. Am J Med Sci. Mar. 2001;321(3):178-180. [pmid: 11269793].
403 Carrat F, Flahault A, Boussard E, Farran N, Dangoumau L, Valleron A J. Surveillance of influenza-like illness in France. The example of the 1995/1996 epidemic. J Epidemiol Community Health. Apr. 1998;52(Suppl 1):32S-38S. [pmid: 9764269].
404 Rocchi G, De Felici A, Ragona G, Pelosio A, Muzzi A. Influenza activity in metropolitan Rome, Italy, during the cold-weather months of 1976-1977. Dev Biol Stand. Jun 1–3. 1977;39:425-428. [pmid: 604126].
405 Patriarca P A, Arden N H, Koplan J P, Goodman R A. Prevention and control of type A influenza infections in nursing homes. Benefits and costs of four approaches using vaccination and amantadine. Ann Intern Med. Nov. 1987;107(5):732-740. [pmid: 3116900].
406 Owens S R. Being prepared. Preparations for a pandemic of influenza. EMBO Rep. Dec. 2001;2(12):1061-1063. [pmid: 11743013]. [pmcid: 1084177].
407 Noymer A, Garenne M. The 1918 Influenza Epidemic's Effect on Sex Differentials in Mortality in the United States. Population and Development Review. September 2000;26(3).
408 Gorman S. Smallpox Vaccine Logistics: Distribution, Storage, and Security. Atlanta, GA: Centers for Disease Control and Prevention; December 2002.
409 Meltzer MI, Mason J, Washington ML, Freye R. Maxi-Vac 1.0: A manual to aid state and local-level public health officials plan, prepare and practice for large scale smallpox vaccination (Beta test version). Atlanta, GA: Centers for Disease Control and Prevention, U.S. Department of Health and Human Services; December 3 2002.
410 Review of the Centers for Disease Control and Prevention's Smallpox Vaccination Progam Implementation; Letter Report #1. Washington, D.C.: Committee on Smallpox Vaccination Program Implementation, Institute of Medicine; 2003.
411 Smallpox Vaccination: Vaccination Method and Reactions. Atlanta, GA: Centers for Disease Control and Prevention; February 2003.
412 Wharton M, Strikas R A, Harpaz R, et al. Recommendations for using smallpox vaccine in a pre-event vaccination program. Supplemental recommendations of the Advisory Committee on Immunization Practices (ACIP) and the Healthcare Infection Control Practices Advisory Committee (HICPAC). MMWR Recomm Rep. Apr 4. 2003;52(RR-7):1-16. [pmid: 12710832].
413 ProMED-mail. Smallpox Vaccination, Adverse Events - USA (09). ProMED-mail. March 29 2003.
414 ProMED-mail. Smallpox Vaccination, Adverse Events - USA (10). ProMED-mail. April 3 2003.
415 ProMED-mail. Smallpox Vaccination, Adverse Events - USA (08). ProMED-mail. March 27 2003.
416 ProMED-mail. Smallpox Vaccination, Adverse Events - USA (07). ProMED-mail. March 16 2003.
417 ProMED-mail. Smallpox Vaccination, Adverse Events - USA (03). ProMED-mail. March 6 2003.
418 ProMED-mail. Smallpox Vaccination, Adverse Events - USA. ProMED-mail. March 1 2003.
419 ProMED-mail. Smallpox Vaccination, Adverse Events - USA (02). ProMED-mail. March 1 2003.
420 ProMED-mail. Smallpox Vaccination, Adverse Events - USA (05). ProMED-mail. March 10 2003.
421 Vaccine Information Statement, Smallpox Vaccine: What You Need to Know. Atlanta, GA: Centers for Disease Control and Prevention; January 16 2003.
422 Evaluating Patients for Smallpox. Atlanta, GA: Centers for Disease and Prevention.
423 New York City Department of Health and Mental Hygiene Will Begin Voluntary Smallpox Vaccination Program in January 2003 to Establish Strategic Reserve of Health and Public Health Response Teams. New York City, NY: New York City Department of Health and Mental Hygiene; December 13 2002.
424 Public Willingness to Be Vaccinated Against Smallpox Depends on Whether or Physicians Choose to Get Vaccinated and Whether Deaths Result from Early Waves of Vaccination. Cambridge, MA: Harvard School of Public Health; December 19 2002.
425 Smallpox: Public Health Department, Santa Clara Valley Health and Hospital System.
426 CDC Initial Review of State Smallpox Vaccination Plans Complete. Atlanta, GA: Centers for Disease Control and Prevention; December 12 2002.
427 CDC Smallpox Vaccination Update. Atlanta, GA: Centers for Disease Control and Prevention; January 17 2003.
428 Gerberding J. CDC Efforts in Implementing a Smallpox Vaccination Program: Committee on Health, Education, Labor and Pensions; January 30 2003.
429 Smallpox Vaccine Adverse Events Among Civilians - United States, January 24–February 18, 2003. MMWR. February 21 2003.
430 Maldonado Y A. Current controversies in vaccination: vaccine safety. JAMA. Dec 25. 2002;288(24):3155-3158. [pmid: 12495396].
431 Cohen J. Bioterrorism. Smallpox vaccinations: how much protection remains?. Science. Nov 2. 2001;294(5544):985. [pmid: 11691969].
432 Rosenthal S R, Merchlinsky M, Kleppinger C, Goldenthal K L. Developing new smallpox vaccines. Emerg Infect Dis. Nov-Dec. 2001;7(6):920-926. [pmid: 11747717].
433 Schraeder T L, Campion E W. Smallpox vaccination--the call to arms. N Engl J Med. Jan 30. 2003;348(5):381-382. [pmid: 12496350].
434 Ashraf H. China finally throws full weight behind efforts to contain SARS. Lancet. Apr 26. 2003;361(9367):1439. [pmid: 12727402].
435 Mostashari F, Hartman J. Syndromic Surveillance: a Local Perspective. J Urban Health. June 1. 2003;80(Suppl 1):i1-i7. [pmid: 12892064].
436 Kearney P A, Terry L, Burney R E. Outcome of patients with blunt trauma transferred after diagnostic or treatment procedures or four-hour delay. Ann Emerg Med. Aug. 1991;20(8):882-886. [pmid: 1854073].
437 Calisher C H, Root J J, Mills J N, Beaty B J. Assessment of ecologic and biologic factors leading to hantavirus pulmonary syndrome, Colorado, U.S.A. Croat Med J. Jun. 2002;43(3):330-337. [pmid: 12035141].
438 California Disaster and Civil Defense Master Mutual Aid Agreement: State of California; November 15 1950.
439 Norris F H. Disasters in urban context. J Urban Health. Sep. 2002;79(3):308-314. [pmid: 12200499].
440 Executive Summary: Capability Assessment for Readiness.
441 Noji E K. Disaster epidemiology and disease monitoring. J Med Syst. Apr. 1995;19(2):171-174. [pmid: 7602249].
442 Noji E K. Disaster epidemiology: challenges for public health action. Ann Ig. Jan-Feb. 2002;14(1 Suppl 1):97-102. [pmid: 12162140].
443 Santa Clara County Local Fire Service and Rescue Mutual Aid Plan. Santa Clara County Fire Department. Accessed August 7, 2002.
444 Emergency Managers Mutual Aid Plan: Office of Emergency Services; November 1997.
445 Emergency Management Assistance Compact: National Emergency Management Association; 2003.
446 Emergency Management Assistance Compact. 57th Legislature, 2001 Regular Session ed; 2001.
447 Bullock J. The Emergency Management Assistance Compact: Creating a Network of Management in Times of Emergency. 2000.
448 Freedberg SJ. No Disaster This Compact Can't Handle. National Journal. April 6, 2002: 1002.
449 Dieffenbach RJ. Help is just a state away. State Government News, 1998: 28–31.
450 Davis G, Jones D. Mutual Aid Specialist Committee: Findings and Recommendations: Governor's Office of Emergency Services; November 30 1998.
451 Rivera R. A Plan for Mutual Aid: El Paso, Texas and Juarez, Chihuahaua. El Paso, TX: Applied Research Project for the Executive Fire Officer Program, National Fire Academy; 1995.
452 Community Emergency Response Team: Overview. Emergency Management Institute, Federal Emergency Management Agency. Available at: training.fema.gov/emiweb/CERT/overview.asp. Accessed September 4, 2003.
453 Henderson D A. The looming threat of bioterrorism. Science. Feb 26. 1999;283(5406):1279-1282. [pmid: 10037590].
454 Favero GT. Flexibility of the Incident Command System to Response to Domestic Terrorism. Monterrey, CA, Naval Postgraduate School; 1999.
455 Kaplan E H, Craft D L, Wein L M. Emergency response to a smallpox attack: the case for mass vaccination. Proc Natl Acad Sci U S A. Aug 6. 2002;99(16):10935-10940. [pmcid: 125076]. [pmid: 12118122].
456 Barton D, Bodiwala G G. Assessment of a triage label system during a major incident exercise. Prehospital Disaster Med. Oct-Dec. 1991;6(4):473-476. [pmid: 10149686].
457 Liu S, Quenemoen L E, Malilay J, Noji E, Sinks T, Mendlein J. Assessment of a severe-weather warning system and disaster preparedness, Calhoun County, Alabama, 1994. Am J Public Health. Jan. 1996;86(1):87-89. [pmid: 8561251]. [pmcid: 1380369].
458 Shenon P. Report Finds Threat Alerts In Color Code Baffle Public. New York Times. August 10, 2003.
459 Homeland Security Presidential Directive 3; 2002.
460 American Red Cross Homeland Security Advisory System Recommendations for Individuals, Families, Neighborhoods, Schools, and Businesses. American Red Cross. Available at: http://www.redcross.org/services/disaster/beprepared/hsas.html. Accessed January 16, 2003.
461 Hoene C, Baldassare M, Brennan C. Cities Taking on Security Responsibilities Amid Increasing Economic and Fiscal Concerns. Washington, D.C.: The National League of Cities; 2002.
462 Petty L. Survey: Cities Fear Biological, Chemical Attacks. Cable News Network. Available at: http://www.cnn.com/2002/US/09/06/prepared.cities.survey/index.html. Accessed January 16, 2003.
463 Nara Y, Parikh RN. Decision Making and Resource Management During Emergencies - A Comparison of US and Japanese Models. Buffalo, NY: Assocation on Employment Practices and Principles; October 15 1999.
464 Threats and Protection: Advisory System, Homeland Security Advisory System, Understanding the Homeland Security Advisory System. Department of Homeland Security. Available at: http://www.dhs.gov/dhspublic/display?theme=29. Accessed September 9, 2003.
465 The Emergency Alert System. Federal Communications Commission. Available at: http://www.fcc.gov/eb/easfact.html. Accessed September 10, 2003.
466 What is EAS? California Office of Emergency Services. Available at: http://eas.oes.ca.gov/Pages/whatseas.htm. Accessed September 10, 2003.
467 Report and Order and Further Notice of Proposed Rule Making. Washington, D.C.: Federal Communications Commission; December 9 1994.
468 Booth M. Aviation Disasters: Unique Disasters Demand Unique Responses. American Red Cross. Available at: http://www.redcross.org/news/ds/trans/030115Airteam.html. Accessed January 16, 2003.
469 Chan E. Medecins Sans Frontieres experience in the provision of health care in complex settings. Hong Kong Med J. Feb. 2003;9(1):67. [pmid: 12547962].
470 Dorozynski A. Medecins Sans Frontieres: 20 years old. BMJ. Dec 21–28. 1991;303(6817):1591-1592. [pmid: 1773181]. [pmcid: 1676227].
471 Evans D W. Malaria, malnutrition and MSF. Medecins Sans Frontieres. Med J Aust. Dec 3–17. 2001;175(1112):575-576. [pmid: 11837845].
472 Hakewill P A. Doctoring beyond frontiers. Med J Aust. Dec 1–15. 1997;167(1112):618-621. [pmid: 9418805].
473 Hill O. Medecins Sans Frontieres: mission impossible?. Pract Midwife. Jul-Aug. 2002;5(7):40-44. [pmid: 12123192].
474 Ostroff SM. Management of the National Pharmaceutical Stockpile Program and Public Health Response to the Threat of Bioterrorism; Testimony of Stephen Ostroff, M.D., Associate Director for Epidemiologic Science, CDC's National Center for Infectious Diseases, before the Committee on Government Reform; Subcommittee on National Security, Veterans Affairs and International Relations; U.S. House of Representatives. Washington, D.C.: Centers for Disease Control and Prevention; 2000.
475 Malone M, Christen H, Maniscalco PM. The U.S. Marine Corps: a consequence response partner. Emerg Med Serv. Aug 2000;29(8):33–34, 38–39.
476 Chemical Biological Incident Response Force. Available at: www.specialoperations.com/USMC/CBIRF, 2003.
477 World Food Programme. World Food Programme. Available at: www.wfp.org. Accessed November 8, 2002.
478 Martchenke J, Rusteen J, Pointer J E. Prehospital communications during the Loma Prieta earthquake. Prehospital Disaster Med. Oct-Dec. 1995;10(4):225-231. [pmid: 10161248].
479 Pointer J E, Michaelis J, Saunders C, et al. The 1989 Loma Prieta earthquake: impact on hospital patient care. Ann Emerg Med. Oct. 1992;21(10):1228-1233. [pmid: 1416302].
480 Leonard R B, Stringer L W, Alson R. Patient-data collection system used during medical operations after the 1994 San Fernando Valley-Northridge earthquake. Prehospital Disaster Med. Jul-Sep. 1995;10(3):178-183. [pmid: 10155427].
481 Quinn B, Baker R, Pratt J. Hurricane Andrew and a pediatric emergency department. Ann Emerg Med. Apr. 1994;23(4):737-741. [pmid: 8161041].
482 Schultz C H, Koenig K L, Noji E K. A medical disaster response to reduce immediate mortality after an earthquake. N Engl J Med. Feb 15. 1996;334(7):438-444. [pmid: 8552147].
483 Haynes B E, Freeman C, Rubin J L, Koehler G A, Enriquez S M, Smiley D R. Medical response to catastrophic events: California's planning and the Loma Prieta earthquake. Ann Emerg Med. Apr. 1992;21(4):368-374. [pmid: 1554172].
484 Klitzman S, Freudenberg N. Implications of the World Trade Center attack for the public health and health care infrastructures. Am J Public Health. Mar. 2003;93(3):400-406. [pmid: 12604481]. [pmcid: 1447752].
485 Carr S J, Leahy S M, London S, Sidhu S, Vogt J. The public health response to Los Angeles' 1994 earthquake. Am J Public Health. Apr. 1996;86(4):589-590. [pmid: 8604800].
486 Neal DM. The local Red Cross in time of disaster: characteristics and conditions of organizational effectiveness during the Loma Prieta earthquake and central Texas floods. J Volunt Adm. Winter 1992;11(2):6–16.
487 Pesola G R, Dujar A, Wilson S. Emergency preparedness: the World Trade Center and Singapore airline disasters. Acad Emerg Med. Mar. 2002;9(3):220-222. [pmid: 11874787].
488 Samii R, Van Wassenhove L, Kumar K, Becerra-Fernandez I. IFRC: Choreographer of Disaster Management: Preparing for tomorrow's disasters. Fontainebleau, France: INSEAD; 2002.
489 Samii R, Van Wassenhove L, Kumar K, Becerra-Fernandez I. IFRC: Choreographer of Disaster Management: The Gujarat Earthquake. Fontainebleau, France: INSEAD; 2002.
490 Ginzburg H M, Jevec R J, Reutershan T. The Public Health Service's response to Hurricane Andrew. Public Health Rep. Mar-Apr. 1993;108(2):241-244. [pmid: 8464982]. [pmcid: 1403368].
491 Jacoby I. Lessons for hospitals from the Midwest flood of 1993. J Emerg Med. May-Jun. 1996;14(3):379-380. [pmid: 8782038].
492 Bennett PV, Freeman RE. The Exxon Valdez Oil Spill. Charlottesville, VA: Darden Graduate School of Business Administration, University of Virginia; 1996.
493 Vanholder R, Sever M S, De Smet M, Erek E, Lameire N. Intervention of the Renal Disaster Relief Task Force in the 1999 Marmara, Turkey earthquake. Kidney Int. 2001;59(2):783-791. [pmid: 11168962].
494 de Jong K, Ford N, Kleber R. Mental health care for refugees from Kosovo: the experience of Medecins Sans Frontieres. Lancet. May 8. 1999;353(9164):1616-1617. [pmid: 10334275].
495 Dellinger A M, Waxweiler R J, Mallonee S. Injuries to rescue workers following the Oklahoma City bombing. Am J Ind Med. Jun. 1997;31(6):727-732. [pmid: 9131228].
496 Dodgen D, LaDue L R, Kaul R E. Coordinating a local response to a national tragedy: community mental health in Washington, DC after the Pentagon attack. Mil Med. Sep. 2002;167(9 Suppl):87-89. [pmid: 12363154].
497 Weiss T, Weiss L, Teeter D, Geraci J. Care provided by VA mobile clinic staff during Northridge earthquake relief. Prehospital Disaster Med. Jul-Sep. 1999;14(3):191-197. [pmid: 10724745].
498 Handling Hurricane Hugo: disaster planning that works. Hosp Secur Saf Manage. Feb 1990;10(10):5–10.
499 Personett J D. Earthquake!. Nurs Manage. Aug. 1994;25(8):58-59. [pmid: 8065678].
500 Samii R. The United Nations Joint Logistics Centre (UNJLC): The Afganistan Crisis. Fontainebleu, France: INSEAD; 2003.
501 Samii R, Van Wassenhove L. The United Nations Joint Logistics Centre (UNJLC): The Genesis of a Humanitarian Relief Coordination Platform. Fontainebleau, France: INSEAD; 2003 2003.
502 RIMS Overview. Office of Emergency Services of California. Available at: http://rimsinland.oes.ca.gov/rims.nsf/RIMS%20Overview?OpenPage. Accessed August 27, 2003.
503 Samii R, Van Wassenhove L. The United Nations Joint Logistics Centre (UNJLC): The Afghanistan Crisis. Fontainebleau, France: INSEAD; 2003.
504 What is SUMA? Pan American Health Organization. Available at: http://www.disaster.info.desastres.net/SUMA/ingles/menu1.htm. Accessed December 16, 2003.
505 Tanaka K. The Kobe earthquake: the system response. A disaster report from Japan. Eur J Emerg Med. Dec. 1996;3(4):263-269. [pmid: 9056140].
506 Okumura T, Suzuki K, Fukuda A, et al. The Tokyo subway sarin attack: disaster management, Part 3: National and international responses. Acad Emerg Med. 1998;5(6):625-628. [pmid: 9660291].
507 Emergency Alert System: Frequently Asked Questions. California Office of Emergency Services. Available at: http://www.eas.ca.gov/Pages/easfaq.htm. Accessed January 29, 2003.
508 Resources for optimal care of the injured patient: 1999. Chicago: Committee on Trauma, American College of Surgeons; 1998.
509 Sampalis JS, Denis R, Lavoie A, et al. Trauma care regionalization: a process-outcome evaluation. J Trauma. Apr 1999;46(4):565–579; discussion 579–581.
510 West J G, Trunkey D D, Lim R C. Systems of trauma care. A study of two counties. Arch Surg. Apr. 1979;114(4):455-460. [pmid: 435058].
511 Eastman A B. Blood in our streets. The status and evolution of trauma care systems. Arch Surg. Jun. 1992;127(6):677-681. [pmid: 1596168].
512 Bass R R, Gainer P S, Carlini A R. Update on trauma system development in the United States. J Trauma. Sep. 1999;47(3 Suppl):S15-21. [pmid: 10496605].
513 Ammons M A, Moore E E, Pons P T, Moore F A, McCroskey B L, Cleveland H C. The role of a regional trauma system in the management of a mass disaster: an analysis of the Keystone, Colorado, chairlift accident. J Trauma. 1988;28(10):1468-1471. [pmid: 3172307].
514 Bazzoli G J. Community-based trauma system development: key barriers and facilitating factors. J Trauma. Sep. 1999;47(3 Suppl):S22-24. [pmid: 10496606].
515 Cayten CG, Quervalu I, Agarwal N. Fatality Analysis Reporting System demonstrates association between trauma system initiatives and decreasing death rates. J Trauma. May 1999;46(5):751–755; discussion 755–756.
516 Clay Mann N, Mullins R J, Hedges J R, Rowland D, Arthur M, Zechnich A D. Mortality among seriously injured patients treated in remote rural trauma centers before and after implementation of a statewide trauma system. Med Care. 2001;39(7):643-653. [pmid: 11458129].
517 Cone J B. Tertiary trauma care in a rural state. Am J Surg. Dec. 1990;160(6):652-654. [pmid: 2252130].
518 Eastman A B, Lewis F R Jr, Champion H R, Mattox K L. Regional trauma system design: critical concepts. Am J Surg. Jul. 1987;154(1):79-87. [pmid: 3605516].
519 Guss D A, Meyer F T, Neuman T S, et al. The impact of a regionalized trauma system on trauma care in San Diego County. Ann Emerg Med. Nov. 1989;18(11):1141-1145. [pmid: 2817556].
520 Hedges J R, Mann N C, Mullins R J, Rowland D, Worrall W, Zechnich A D. Impact of a statewide trauma system on rural emergency department patient assessment documentation. OHSU Rural Trauma Research Group. Acad Emerg Med. Apr. 1997;4(4):268-276. [pmid: 9107324].
521 Jurkovich G J, Mock C. Systematic review of trauma system effectiveness based on registry comparisons. J Trauma. Sep. 1999;47(3 Suppl):S46-55. [pmid: 10496611].
522 MacKenzie E J, Steinwachs D M, Ramzy A I. Evaluating performance of statewide regionalized systems of trauma care. J Trauma. Jun. 1990;30(6):681-688. [pmid: 2352297].
523 Mann N C, Mullins R J, MacKenzie E J, Jurkovich G J, Mock C N. Systematic review of published evidence regarding trauma system effectiveness. J Trauma. Sep. 1999;47(3 Suppl):S25-33. [pmid: 10496607].
524 Mann N C, Cahn R M, Mullins R J, Brand D M, Jurkovich G J. Survival among injured geriatric patients during construction of a statewide trauma system. J Trauma. Jun. 2001;50(6):1111-1116. [pmid: 11426127].
525 Miller T R, Levy D T. The effect of regional trauma care systems on costs. Arch Surg. Feb. 1995;130(2):188-193. [pmid: 7848090].
526 Mullins R J, Mann N C. Introduction to the Academic Symposium to Evaluate Evidence Regarding the Efficacy of Trauma Systems. J Trauma. Sep. 1999;47(3 Suppl):S3-7. [pmid: 10496603].
527 Nathens A B, Jurkovich G J, Cummings P, Rivara F P, Maier R V. The effect of organized systems of trauma care on motor vehicle crash mortality. JAMA. Apr 19. 2000;283(15):1990-1994. [pmid: 10789667].
528 Nathens AB, Jurkovich GJ, Rivara FP, Maier RV. Effectiveness of state trauma systems in reducing injury-related mortality: a national evaluation. J Trauma. Jan 2000;48(1):25–30; discussion 30-21.
529 Shackford S R, Hollingworth-Fridlund P, Cooper G F, Eastman A B. The effect of regionalization upon the quality of trauma care as assessed by concurrent audit before and after institution of a trauma system: a preliminary report. J Trauma. Sep. 1986;26(9):812-820. [pmid: 3746956].
530 Sheil A G. The necessary requirements for the development of a national liver transplant programme. Transplant Proc. Oct. 1992;24(5):1949-1950. [pmid: 1412923].
531 Simms P B. A profile of regionalization. Emergency. May. 1989;21(5):30-35. [pmid: 10303438].
532 Smith RS. Regionalization of trauma care: a necessity for Kansas. Kans Med. Summer-Fall 1997;98(2):20–23.
533 Voeller G R, Mangiante E C, Fabian T C. The effect of a trauma system on the outcome of patients with pancreatic trauma. Arch Surg. May. 1991;126(5):578-580. [pmid: 2021340].
534 NIIT (National Information Infrastructure Testbed) update: Denver Health and Hospitals links rural areas. Health Manag Technol. May 1996;17(6):38.
535 American Academy of Pediatrics. Committee on Pediatric Emergency Medicine. American College of Critical Care Medicine. Society of Critical Care Medicine. Consensus report for regionalization of services for critically ill or injured children. Pediatrics. Jan. 2000;105(1 Pt 1):152-155. [pmid: 10617722].
536 Abernathy J H 3rd, McGwin G Jr, Acker J E 3rd, Rue L W 3rd. Impact of a voluntary trauma system on mortality, length of stay, and cost at a level I trauma center. Am Surg. Feb. 2002;68(2):182-192. [pmid: 11842968].
537 Ammon A A, Fath J J, Brautigan M, Mehta R, Matthews J. Transferring patients to a pediatric trauma center: the transferring hospital's perspective. Pediatr Emerg Care. Oct. 2000;16(5):332-334. [pmid: 11063361].
538 Beresky R E, Flores D J, Crosland E M, Allison D C. An organized system of trauma care in an Army community hospital. Mil Med. Oct. 1990;155(10):498-501. [pmid: 2122293].
539 Biffl W L, Moore E E, Offner P J, Franciose R J, Johnson J L, Burch J M. The Outreach Trauma Program: a model for survival of the academic trauma center. J Trauma. May. 2002;52(5):840-846. [pmid: 11988647].
540 Bray T J. Design of the Northern Nevada Orthopaedic Trauma Panel: a model, level-II community-hospital system. J Bone Joint Surg Am. Feb. 2001;83-A(2):283-289. [pmid: 11216690].
541 Burney R E, Tibbs J J, Mattice C, Buechler C M, Scholten D J. Assuring trauma system quality by outcomes reporting in two voluntary regional trauma networks. Todays OR Nurse. Jul-Aug. 1995;17(4):27-31. [pmid: 7570802].
542 Deane S A, Gaudry P L, Woods W P, Read C M, McNeil R J. Interhospital transfer in the management of acute trauma. Aust N Z J Surg. Jun. 1990;60(6):441-446. [pmid: 2346439].
543 Gray A J, Goodacre S, Johnson G, McGowan A. Regional standards in trauma care. J Accid Emerg Med. Sep. 1996;13(5):365. [pmid: 8894873].
544 Hulka F. Pediatric trauma systems: critical distinctions. J Trauma. Sep. 1999;47(3 Suppl):S85-89. [pmid: 10496619].
545 Hunt J, Hill D, Besser M, West R, Roncal S. Outcome of patients with neurotrauma: the effect of a regionalized trauma system. Aust N Z J Surg. Feb. 1995;65(2):83-86. [pmid: 7857235].
546 Kinny S J, Jones D H. Trauma services requirements in a district general hospital serving a rural area. BMJ. Feb 24. 1990;300(6723):504-508. [pmid: 2107928]. [pmcid: 1662280].
547 Kissoon N, Tepas J J 3rd, Peterson R J, Pieper P, Gayle M O. The evaluation of pediatric trauma care using audit filters. Pediatr Emerg Care. Aug. 1996;12(4):272-276. [pmid: 8858651].
548 Knuth T E, Wilson A, Oswald S G. Military training at civilian trauma centers: the first year's experience with the Regional Trauma Network. Mil Med. Sep. 1998;163(9):608-614. [pmid: 9753986].
549 Kortbeek J B. A review of trauma systems using the Calgary model. Can J Surg. Feb. 2000;43(1):23-28. [pmid: 10714253].
550 MacKenzie E J, Morris J A Jr, de Lissovoy G V, Smith G, Fahey M. Acute hospital costs of pediatric trauma in the United States: how much and who pays?. J Pediatr Surg. Sep. 1990;25(9):970-976. [pmid: 2120416].
551 MacKenzie E J. Review of evidence regarding trauma system effectiveness resulting from panel studies. J Trauma. Sep. 1999;47(3 Suppl):S34-41. [pmid: 10496608].
552 Miller J D, Jones P A. The work of a regional head injury service. Lancet. May 18. 1985;1(8438):1141-1144. [pmid: 2860345].
553 Pagliarello G, Dempster A, Wesson D. The Integrated Trauma Program: a model for cooperative trauma triage. J Trauma. Aug 1992;33(2):198–203; discussion 203-194.
554 Schwab W, Frankel HL, Rotondo MF, et al. The impact of true partnership between a university Level I trauma center and a community Level II trauma center on patient transfer practices. J Trauma. May 1998;44(5):815–819; discussion 819–820.
555 Sharar S R, Luna G K, Rice C L, Valenzuela T D, Copass M K. Air transport following surgical stabilization: an extension of regionalized trauma care. J Trauma. Jun. 1988;28(6):794-798. [pmid: 3385823].
556 Simons R, Kasic S, Kirkpatrick A, Vertesi L, Phang T, Appleton L. Relative importance of designation and accreditation of trauma centers during evolution of a regional trauma system. J Trauma. May 2002;52(5):827–833; discussion 833-824.
557 Sloan E P, Callahan E P, Duda J, Sheaff C M, Robin A P, Barrett J A. The effect of urban trauma system hospital bypass on prehospital transport times and Level 1 trauma patient survival. Ann Emerg Med. Nov. 1989;18(11):1146-1150. [pmid: 2817557].
558 Southard P. Rural trauma: the next trauma system challenge. J Emerg Nurs. Oct. 1991;17(5):346-348. [pmid: 1921079].
559 Trooskin S Z, Faucher M B, Santora T A, Talucci R C. Consolidation of trauma programs in the era of large health care delivery networks. J Trauma. Mar. 1999;46(3):488-493. [pmid: 10088857].
560 Young JS, Bassam D, Cephas GA, Brady WJ, Butler K, Pomphrey M. Interhospital versus direct scene transfer of major trauma patients in a rural trauma system. Am Surg. Jan 1998;64(1):88–91; discussion 91-82.
561 Lerner E B, Billittier A Jt, Sikora J, Moscati R M. Use of a geographic information system to determine appropriate means of trauma patient transport. Acad Emerg Med. Nov. 1999;6(11):1127-1133. [pmid: 10569385].
562 Olson C J, Arthur M, Mullins R J, Rowland D, Hedges J R, Mann N C. Influence of trauma system implementation on process of care delivered to seriously injured patients in rural trauma centers. Surgery. Aug. 2001;130(2):273-279. [pmid: 11490360].
563 Frascone R J, Gisch T. Implementation of a subregional trauma system. Minn Med. Jun. 1999;82(6):49-52. [pmid: 10389457].
564 Hammond J S, Breckenridge M B. Longitudinal analysis of the impact of a level 1 trauma center designation at a university hospital. J Am Coll Surg. Mar. 1999;188(3):217-224. [pmid: 10065808].
565 Bazzoli G J, Harmata R, Chan C. Community-based trauma systems in the United States: an examination of structural development. Soc Sci Med. May. 1998;46(9):1137-1149. [pmid: 9572604].
566 Rutledge R, Fakhry SM, Meyer A, Sheldon GF, Baker CC. An analysis of the association of trauma centers with per capita hospitalizations and death rates from injury. Ann Surg. Oct 1993;218(4):512–521; discussion 521-514.
567 Esposito T J, Nania J, Maier R V. State trauma system evaluation: a unique and comprehensive approach. Ann Emerg Med. Apr. 1992;21(4):351-357. [pmid: 1554169].
568 Thompson C T. The trauma center: what it is, what it is not, what it can accomplish. Surg Annu. 1985;17:153-161. [pmid: 3975790].
569 Cales R H. Trauma mortality in Orange County: the effect of implementation of a regional trauma system. Ann Emerg Med. Jan. 1984;13(1):1-10. [pmid: 6689851].
570 Haller J A Jr, Shorter N, Miller D, Colombani P, Hall J, Buck J. Organization and function of a regional pediatric trauma center: does a system of management improve outcome?. J Trauma. Aug. 1983;23(8):691-696. [pmid: 6887285].
571 West J G, Cales R H, Gazzaniga A B. Impact of regionalization. The Orange County experience. Arch Surg. Jun. 1983;118(6):740-744. [pmid: 6847371].
572 Mucha P Jr, Farnell M B, Czech J M, Melton L J 3rd. A rural regional trauma center. J Trauma. Apr. 1983;23(4):337-340. [pmid: 6842638].
573 Eggold R. Trauma care regionalization: a necessity. J Trauma. Mar. 1983;23(3):260-262. [pmid: 6834452].
574 Boyd D R, Cowley R A. Comprehensive regional trauma/emergency medical services (EMS) delivery systems: the United States experience. World J Surg. Jan. 1983;7(1):149-157. [pmid: 6837054].
575 Trunkey D D. Regionalization of trauma care. Top Emerg Med. Jul. 1981;3(2):91-96. [pmid: 10252086].
576 Egges J, Turnock B J. Evaluation of an EMS regional referral system using a tracer methodology. Ann Emerg Med. Oct. 1980;9(10):518-523. [pmid: 7425405].
577 Tye J, Vargish T, Jensen A. The role of a hospital-based emergency helicopter service in a rural state. Emerg Med Serv. Jul-Aug 1980;9(4):17–20, 23.
578 California's Trauma Care: System Capacity and Demand: California Health Care Foundation; September 2002.
579 Cooper A, Barlow B, DiScala C, String D, Ray K, Mottley L. Efficacy of pediatric trauma care: results of a population-based study. J Pediatr Surg. Mar 1993;28(3):299–303; discussion 304-295.
580 Smith J S Jr, Martin L F, Young W W, Macioce D P. Do trauma centers improve outcome over non-trauma centers: the evaluation of regional trauma care using discharge abstract data and patient management categories. J Trauma. Dec. 1990;30(12):1533-1538. [pmid: 2258968].
581 Preliminary Survey of US Trauma Centers and State-by-State Analysis of Trauma Systems Development. Reston, VA: Eastern Association for the Surgery of Trauma; 1991.
582 Bravata DM, McDonald K, Smith W, et al. Surveillance Systems for Bioterrorism and Emerging Infectious Diseases: A Systematic Review. Manuscript under review. 2003.
583 Public Health Information Network. Centers for Disease Control and Prevention. December 13, 2003. Available at: www.cdc.gov/phin. Accessed December 15, 2003.
584 Sosin D M. Draft framework for evaluating syndromic surveillance systems. J Urban Health. Jun. 2003;80(Suppl 1):I8-I13. [pmid: 12791773].
585 Buckeridge DL, Graham J, O'Connor MJ, Choy MK, Tu SW, Musen MA. Knowledge-based bioterrorism surveillance. Proc AMIA Symp. 2002:76–80.
586 Langmuir A A. The surveillance of communicable diseases of national importance. New Engl J Med. 1963;288:182-192. [pmid: 13928666].
587 Barthell E N, Cordell W H, Moorhead J C, et al. The Frontlines of Medicine Project: a proposal for the standardized communication of emergency department data for public health uses including syndromic surveillance for biological and chemical terrorism. Ann Emerg Med. Apr. 2002;39(4):422-429. [pmid: 11919529].
588 Irvin C B, Nouhan P P, Rice K. Syndromic analysis of computerized emergency department patients' chief complaints: An opportunity for bioterrorism and influenza surveillance. Ann Emerg Med. Apr. 2003;41(4):447-452. [pmid: 12658241].
589 Valleron AJ, Vidal JJ. Timely redistribution of information for epidemiological surveillance and alert: the experience from the French communicable diseases network. Proc AMIA Symp. 2002:830–834.
590 Lazarus R, Kleinman K, Dashevsky I, et al. Use of automated ambulatory-care encounter records for detection of acute illness clusters, including potential bioterrorism events. Emerg Infect Dis. Aug. 2002;8(8):753-760. [pmid: 12141958].
591 Krenzelok E P. The critical role of the Poison Center in the recognition, mitigation and management of biological and chemical terrorism. Przegl Lek. 2001;58(4):177-181. [pmid: 11450330].
592 Burkom H S. Biosurveillance applying scan statistics with multiple, disparate data sources. J Urban Health. Jun. 2003;80(Suppl 1):I57-I65. [pmid: 12791780].
593 Goldenberg A, Shmueli G, Caruana R A, Fienberg S E. Early statistical detection of anthrax outbreaks by tracking over-the-counter medication sales. Proc Natl Acad Sci U S A. Apr 16. 2002;99(8):5237-5240. [pmcid: 122753]. [pmid: 11959973].
594 Lewis M D, Pavlin J A, Mansfield J L, et al. Disease outbreak detection system using syndromic data in the greater Washington DC area. Am J Prev Med. Oct. 2002;23(3):180-186. [pmid: 12350450].
595 Pavlin JA, Kelley PW. ESSENCE: Electronic Surveillance System for the Early Notification of Community-based Epidemics. Silver Spring, MD: U.S. Department of Defense, Global Emerging Infections Surveillance and Response System; October 4 2001.
596 Rogerson P A. A Cumulative Sum Approach to Syndromic Surveillance in Geographic Regions. J Urban Health. June 1. 2003;80(Suppl 1):i130.
597 Kulldorf M, Huang L, Pickle L. An Elliptic Spatial Scan Statistic and Its Application to Breast Cancer Mortality Data in Northweastern United States. J Urban Health. June 1. 2003;80(Suppl 1):i130-131.
598 Osaka K, Takahashi H, Ohyama T. Testing a symptom-based surveillance system at high-profile gatherings as a preparatory measure for bioterrorism. Epidemiol Infect. Dec. 2002;129(3):429-434. [pmid: 12558324].
599 Chauvin P, Valleron A J. Attitude of French general practitioners to the public health surveillance of communicable diseases. Int J Epidemiol. 1995;24(2):435-440. [pmid: 7635607].
600 Kaufmann A F, Meltzer M I, Schmid G P. The economic impact of a bioterrorist attack: are prevention and postattack intervention programs justifiable?. Emerg Infect Dis. Apr-Jun. 1997;3(2):83-94. [pmid: 9204289].
601 Thackway S. Public health surveillance during the Sydney 2000 Olympic and Paralympic Games. N S W Public Health Bull. Dec. 2000;11(12):201-202. [pmid: 12105518].
602 Jorm L, Visotina M. Keeping the dream alive - and healthy: Public health preparations for the Sydney 2000 Olympic and Paralympic Games: guest editorial. N S W Public Health Bull. Aug. 2000;11(8):137-138. [pmid: 12105454].
603 Dougherty M. The changing face of public health reporting. J AHIMA. Apr. 2002;73(4):61-62. [pmid: 12432817].
604 Web survey. October results: are we prepared? Mod Healthc. Dec 3 2001;31(49):33.
605 Wein L M, Craft D L, Kaplan E H. Emergency response to an anthrax attack. Proc Natl Acad Sci U S A. Apr 1. 2003;100(7):4346-4351. [pmcid: 153095]. [pmid: 12651951].
606 Brookmeyer R, Blades N, Hugh-Jones M, Henderson D A. The statistical analysis of truncated data: application to the Sverdlovsk anthrax outbreak. Biostatistics. Jun. 2001;2(2):233-247. [pmid: 12933552].
607 Bell D M, Kozarsky P E, Stephens D S. Conference Summary: Clinical issues in prophylaxis, diagnosis and treatment of anthrax. Emerg Infect Dis. 2002;8(2):222-225. [pmid: 11897081].
608 Jefferds M D, Laserson K, Fry A M, et al. Adherence to antimicrobial inhalational anthrax prophylaxis among postal workers, Washington, D.C., 2001. Emerg Infect Dis. Oct. 2002;8(10):1138-1144. [pmid: 12396929].
609 Cost Containment of Medicaid HIV/AIDS Drug Expenditures. Washington, D.C.: Department of Health and Human Services, Office of Inspector General; July 2001. OEI-05-99-00611.
610 MarkeTips. Veterans Administration Supply News. January/February, 2000.
611 Clinical Pathway: Anthrax Inhalational Exposure. Center for Infectious Disease Research and Policy (CIDRAP) and Infectious Diseases Society of America (IDSA). Available at: http://www.cidrap.umn.edu/cidrap/files/17/anthrax-clinical-pathway.pdf. Accessed September 9, 2003.
612 Ala'Aldeen D. Risk of deliberately induced anthrax outbreak. Lancet. Oct 27. 2001;358(9291):1386-1388. [pmid: 11705480].
613 Cohen ML. Bioterrorism: CDC's Public Health Response. Testimony before the Committee on Governmental Affairs and Subcommittee on International Security, Proliferation and Federal Services, United States Senate. October 30. Available at: www.hhs.gov/asl/testify/t011030.html. Accessed September 3, 2003.
614 Receiving, Distributing, and Dispensing the National Pharmaceutical Stockpile: A guide for Planners. Version 9 - Draft: Centers for Disease Control and Prevention; April 2002.
615 International Information Programs. U.S. Department of State. Available at: http://usinfo.state.gov/topical/pol/terror/01102416.htm. Accessed September 5, 2003.
616 Wetter D C, Daniel W E, Treser C D. Hospital Preparedness for Victims of Chemical or Biological Terrorism. Amer J Public Health. 2001;91(5):710-716. [pmid: 11344876]. [pmcid: 1446687].
617 Data Profiles. U.S. Census Bureau. Available at: http://www.census.gov/acs/www/Products/index.htm. Accessed September 3, 2003.
618 Dartmouth Atlas of Health Care, the Pacific States. The Center for the Evaluative Clinical Sciences, Dartmouth Medical School. Available at: www.dartmouthatlas.org/. Accessed September 3, 2003.
619 SMARTpages. SMARTpages.com. Available at: www.smartpages.com/. Accessed September 3, 2003.
620 Hupert N, Cuomo J. Weill/Cornell Mass Prophylaxis/Vaccination Model. Available at: http://www.ahcpr.gov/research/biomodel/index.asp. Accessed Sepetember 3, 2003.
621 Bice SD. CDC Efforts to Assist State and Local Government Preparedness for Terrorist Attacks: Testimony before the Subcommittee on Government Efficiency, Financial Management, and Intergovernmental Relations, Committee on Government Reform Unites States House of Representatives. Washington, D.C. April 2 2002.
622 Projection of the Total Resident Population by 5-Year Age Groups and Sex with Special Age Categories: Middle Series, 1999 to 2000. US Census Bureau. July 13. Available at: http://www.census.gov/population/projections/nation/summary/np-t3-a.pdf. Accessed September 9, 2003.
623 Hetzel L, Smith A. The 65 Years and Over Population: 2000. US Census Bureau[Census 2000 Brief]. October. Available at: http://www.census.gov/prod/2001pubs/c2kbr01-10.pdf. Accessed September 9, 2003.
624 Disability Status: 2000 - Census 2000 Brief. US Census Bureau. May 14. Available at: http://www.census.gov/hhes/www/disable/disabstat2k/table1.html. Accessed September 9, 2003.
625 Births, Marriages, Divorces, and Deaths: Provisional Data for July 2001. National Center for Health Statistics. March 8. Available at: http://www.cdc.gov/nchs/data/nvsr/nvsr50/nvsr50_03.pdf. Accessed September 9, 2003.
626 Thoreau HD. Paradise (To Be) Regained (1843). The Writings of Henry David Thoreau. Vol 4: Houghton Mifflin; 1906:299.