# Acknowledgments

We are grateful to our expert advisors and peer reviewers for their thoughtful comments and guidance. During the preparation of this Report, Dr. Owens was supported by the Department of Veterans Affairs.