# Appendix B: Data Abstraction Form

Peer-reviewers
Wally Lee
Chief Technology Officer
Fritz Institute
Diane K. Mack
Assistant Director of Homeland Security
State of Indiana
Richard Nolan
Strategic National Stockpile Liaison to the Department of Homeland Security
Strategic National Stockpile, Centers for Disease Control and Prevention
Gianfranco Pezzino, M.D., M.P.H.
Medical Epidemiologist
Ray Strikas, M.D.
Director
Smallpox Preparedness and Response Activity, Centers for Disease Control and Prevention
Margaret Race, Ph.D.
Visiting Fellow
Center for International Security and Cooperation, Stanford University
Lawrence Wein, Ph.D.
Professor of Management Science
Graduate School of Business, Stanford University