# Appendix A: Expert Advisors and Peer Reviewers

Expert advisors
Michael S. Ascher, M.D., F.A.C.P.
Senior Medical Advisor, Biodefense Division, Biology and Biotechnology Research Program
Lawrence Livermore National Laboratory
Sumner Lee Bossler Jr., R.N., B.S.N., C.E.N.
Project Officer, Bioterrorism Hospital Preparedness Program
Health Resources Services Administration
Sara Cody, M.D.
Communicable Disease Control Officer and Assistant Health Officer
Santa Clara County Public Health Department
Margaret A. Hamburg, M.D.
Vice President for Biological Programs
Nuclear Threat Initiative
Nathaniel Hupert, M.D., M.P.H.
Assistant Professor of Medicine and Public Health
Weill Medical College, Cornell University
Patrick Kelley, M.D., Dr.P.H.
Director, Board on Global Health
Institute of Medicine, National Academies of Science
Hau Lee, Ph.D.
Professor of Operations, Information, and Technology
Director, Stanford Global Supply Chain Management Forum
Jerod M. Loeb, Ph.D.
Executive Vice President, Division of Research
Joint Commission on Accreditation of Healthcare Organizations
Eric K. Noji, M.D., M.P.H.
Principle Deputy to the U.S. Surgeon General for Homeland Security and Disaster Medicine
U.S. Public Health Service
Michael Osterholm, Ph.D.
Director
Center for Infectious Disease Research and Policy, School of Public Health, University of Minnesota
Richard Owens, Jr.
Vice President, JSI Logistics Services
John Snow, Inc.
Frances Edwards-Winslow, Ph.D.
Director of Emergency Preparedness
City of San Jose