# References

1 Milsten A. Hospital responses to acute-onset disasters: a review. Prehosp Disaster Med. 2000;15(1):32-45. [pmid: 11066840].
2 Public Health Threats and Emergencies Act of 2000. Available at: http://www.senate.gov/~frist/Issues/Issues-National_Defense/Fighting/Terrorism/_Public_Health_Threats_and_Eme/_public_health_threats_and_eme.html. Accessed 2003 Feb 21.
3 Breman J G, Henderson D A. Diagnosis and management of smallpox. N Engl J Med. 2002;346(17):1300-8. [pmid: 11923491].
4 Inglesby T V, Dennis D T, Henderson D A, et al. Plague as a biological weapon: medical and public health management. Working Group on Civilian Biodefense. JAMA. 2000;283(17):2281-90. [pmid: 10807389].
5 Inglesby T V, O'Toole T, Henderson D A, et al. Anthrax as a biological weapon, 2002: updated recommendations for management. JAMA. 2002;287(17):2236-52. [pmid: 11980524].
6 Joint Commission on Accreditation of Healthcare Organizations. Comprehensive Accreditation Manual for Hospitals: The Official Handbook. Oakbrook Terrace, IL: Joint Commission Resources; 2003. p EC-9.
7 Joint Commission on Accreditation of Healthcare Organizations. Comprehensive Accreditation Manual for Hospitals: The Official Handbook. Oakbrook Terrace, IL: Joint Commission Resources; 2003. p EC-21.
8 Catlett C, Perl T, Jenckes MW, et al. Training of Clinicians for Public Health Events Relevant to Bioterrorism Preparedness. Evidence Report/Technology Assessment No. 51. Rockville, MD: Agency for Healthcare Research and Quality. 2002 Jan. AHRQ Publication No. 02-E011.
9 EPC Evidence Reports Subdirectory Page. Available at: http://www.ahcpr.gov/clinic/epcindex.htm. Accessed 2003 Mar 3.
10 The HEICS plan. Available at: http://www.emsa.cahwnet.gov/dms2/download.htm. Accessed 2003 Feb 28.
11 Gebo KA, Jenckes MJ, Chander G, et al. Management of Chronic Hepatitis C. Evidence Report/Technology Assessment No. 60. Rockville, MD: Agency for Healthcare Research and Quality. 2002 Jul. AHRQ Publication No. 02-E030.
12 Kern DE, Thomas PA, Howard DM, et al. Curriculum development for medical education: a six-step approach. Baltimore: The Johns Hopkins University Press; 1998.
13 Berlin JA. Randomized trial comparing masked/unmasked meta analysis. Technical Report prepared for the Agency for Health Care Policy and Research. Rockville, MD: Agency for Health Care Policy and Research. 1997. National Technical Information Service (NTIS accession number PB98-109382).
14 Jampel HD, Lubomski LH, Friedman DS, et al. Evidence Report on Surgical Treatment of Coexisting Cataract and Glaucoma. Evidence Report/Technology Assessment No. 38. Rockville, MD: Agency for Healthcare Research and Quality. 2000 Sep. AHRQ Publication No. 00-E031.
15 Schein OD, Friedman DS, Fleisher LA, et al. Evidence Report on Anesthesia Management During Cataract Surgery. Evidence Report/Technology Assessment No. 16. Rockville, MD: Agency for Healthcare Research and Quality. 2000 Jul. AHRQ Publication No. 01-E017.
16 Chobin N, Engle L. Are you ready for an ethylene oxide spill? J Healthc Mater Manage 1989; 7(3): 56–7, 60.
17 Saxena K, Cicero J J, Hass W F. Chemical disaster drill in the State of Minnesota. Minn Med. 1986;69(3):137-9. [pmid: 3504225].
18 Baughman K S, Calvert D R. Internal disaster drill critique. J Emerg Nurs. 1990;16(4):240-1. [pmid: 2385052].
19 Halstead M A. Fire drill in the operating room. Role playing as a learning tool. AORN J. 1993;58(4):697-706. [pmid: 8215323].
20 Menczer L F. The Hartford disaster exercise. N Engl J Med. 1968;278(15):822-4. [pmid: 5642500].
21 Classic K L, Knutson A H, Smith G D. Radiation safety role in institutional disaster planning. Health Phys. 2000;78(5 Suppl):S35-9. [pmid: 10770155].
22 Cook L. Hospital disaster drill game: a strategy for teaching disaster protocols to hospital staff. J Emerg Nurs. 1990;16(4):269-73. [pmid: 2385061].
23 Eisner M E, Waxman K, Mason G R. Evaluation of possible patient survival in a mock airplane disaster. Am J Surg. 1985;150(3):321-3. [pmid: 4037190].
24 Fishel E R. Exercise “Med-Ex” 73. Md State Med J. 1974;23(9):46-8. [pmid: 4851959].
25 Maxwell C, Cherneski M. Post-disaster drill analysis. Using victim-tracking cards. J Emerg Med Serv. 1987;12(2):43-6.
26 Paris P M, Stewart R D, Pelton G H, et al. Triage success in disasters: dynamic victim-tracking cards. Am J Emerg Med. 1985;3(4):323-6. [pmid: 4005004].
27 Inglesby T V, Grossman R, O'Toole T. A plague on your city: observations from TOPOFF. Clin Infect Dis. 2001;32(3):436-45. [pmid: 11170952].
28 Tur-Kaspa I, Lev E I, Hendler I, et al. Preparing hospitals for toxicological mass casualties events. Crit Care Med. 1999;27(5):1004-8. [pmid: 10362427].
29 Gofrit O N, Leibovici D, Shemer J, et al. The efficacy of integrating “smart simulated casualties” in hospital disaster drills. Prehospital Disaster Med. 1997;12(2):97-101. [pmid: 10187010].
30 Gray D. Disaster plan education: how we made and tested a video. J Accid Emerg Med. 1996;13(1):21-2. [pmid: 8821219].
31 Levi L, Bregman D, Geva H, et al. Hospital disaster management simulation system. Prehospital Disaster Med. 1998;13(1):29-34. [pmid: 10187023].
32 Gretenkort P, Harke H, Blazejak J, et al. Interface between hospital and fire authorities—a concept for management of incidents in hospitals. Prehospital Disaster Med. 2002;17(1):42-7. [pmid: 12357565].
33 Weston C J. The operating theatre's on fire. Health Serv Manage. 1988;84(3):20-3. [pmid: 10287894].
34 Levy K, Aghababian R V, Hirsch E F, et al. An Internet-based exercise as a component of an overall training program addressing medical aspects of radiation emergency management. Prehospital Disaster Med. 2000;15(2):18-25. [pmid: 11183457].
35 Lau P F, Lau C C. A disaster drill in Hong Kong. Accid Emerg Nurs. 1997;5(1):34-8. [pmid: 9069733].
36 Burns K A. Experience in the use of gaming and simulation as an evaluation tool for nurses. J Contin Educ Nurs. 1984;15(6):213-7. [pmid: 6438196].
37 Hogan DE, Burstein JL, editors. Disaster Medicine. Baltimore, MD: Lippincott Williams & Wilkins; 2002.
38 Rutherford WH. The place of exercises in disaster management. Injury 1990; 21(1): 58–60; discussion 63–4.
39 Nigro C M. Economical citywide tabletop disaster preparedness drill. J Emerg Nurs. 1995;21(2):137-9. [pmid: 7776603].
40 Chi C H, Chao W H, Chuang C C, et al. Emergency medical technicians' disaster training by tabletop exercise. Am J Emerg Med. 2001;19(5):433-6. [pmid: 11555806].
41 Idris A H, Becker L B, Ornato J P, et al. Utstein-style guidelines for uniform reporting of laboratory CPR research. A statement for healthcare professionals from a task force of the American Heart Association, the American College of Emergency Physicians, the American College of Cardiology, the European Resuscitation Council, the Heart and Stroke Foundation of Canada, the Institute of Critical Care Medicine, the Safar Center for Resuscitation Research, and the Society for Academic Emergency Medicine. Writing Group. Circulation. 1996;94(9):2324-36. [pmid: 8901707].