# Acknowledgements

The Johns Hopkins University Evidence-based Practice Center expresses its appreciation to Neil R. Powe, M.D., M.B.A., M.P.H., for overall guidance, Christine Napolitano for her assistance with data management, and to Patricia Peer for her assistance in preparing the manuscript.