# Appendix H: Excluded Articles

Citation | Reason for exclusion
Balch DC, West VL. Telemedicine used in a simulated disaster response. Stud Health Technol Inform. 2001; 81:41–5. | Does not include hospital staff
Bragdon RL, Gousse GC, Piwarzyk P, et al. Regional disaster planning for hospital pharmacies. Am J Hosp Pharm. 1982; 39(11): 1913–5. | Does not include training or education
Chi CH, Chao WH, Chuang CC, et al. Emergency medical technicians' disaster training by tabletop exercise. Am J Emerg Med. 2001; 19(5): 433–6. | Does not include hospital staff
DeMars ML, Buss RM, Cleland LC. Victim-tracking cards in a community disaster drill. Ann Emerg Med. 1980; 9(4): pp 207–209. | No information about hospital component of drill
ED managers react to threat against hospitals: here are security strategies. ED Management. 2003; 15(1): 1–5. | Does not include training or education
Fawcett W, Oliveira CS. Casualty treatment after earthquake disasters: development of a regional simulation model. Disasters. 2000; 24(3): 271–87. | No original data
Freeman KM, Thompson SF, Allely EB, et al. A virtual reality patient simulation system for teaching emergency response skills to U.S. Navy medical providers. Prehospital and Disaster Med. 2001 Jan-2001; 16(1): 3–8. | No original data
Klein JS, Weigelt JA. Disaster management. Lessons learned. Surg Clin North Am. 1991; 71(2): 257–66. | Article does not apply to any of the research questions
Lafreniere F. A mock evacuation is an exercise in saving lives. Dimens Health Serv 1988; 65(5): 35–7. | Results of evaluation not presented
Nigro CM. Economical citywide tabletop disaster preparedness drill. J Emerg Nurs. 1995; 21(2): 137–9. | No results of evaluation provided
Ochsner MG, Harviel JD, Stafford PW, et al. Development and organization for casualty management on a 1,000-bed hospital ship in the Persian Gulf. J Trauma. 1992; 32(4): 501–12; discussion 512–3. | No evaluation
Rutherford WH. The place of exercises in disaster management. Injury. 1990; 21(1): 58–60; discussion 63–4. | Does not include hospital staff
Vardi A, Levin I, Berkenstadt H, et al. Simulation-based training of medical teams to manage chemical warfare casualties. Isr Med Assoc J. 2002; 4(7): 540–4. | No original data
Whitney J. Disaster drill--'73. JFMA 1974; 61(3): 233–5. | Specific results of evaluation not reported