# Appendix G: Bibliography

Balch D C, West V L. Telemedicine used in a simulated disaster response. Stud Health Technol Inform. 2001;81:41-5. [pmid: 11317780].
Baughman K S, Calvert D R. Internal disaster drill critique. J Emerg Nurs. 1990;16(4):240-1. [pmid: 2385052].
Berlin JA. Randomized trial comparing masked/unmasked meta analysis. Technical Report prepared for the Agency of Health Care Policy and Research. Rockville, MD: Agency for Health Care Policy and Research. 1997. National Technical Information Service (NTIS accession number PB98-109382).
Bragdon R L, Gousse G C, Piwarzyk P, et al. Regional disaster planning for hospital pharmacies. Am J Hosp Pharm. 1982;39(11):1913-5. [pmid: 7148858].
Breman J G, Henderson D A. Diagnosis and management of smallpox. N Engl J Med. 2002;346(17):1300-8. [pmid: 11923491].
Burns K A. Experience in the use of gaming and simulation as an evaluation tool for nurses. J Contin Educ Nurs. 1984;15(6):213-7. [pmid: 6438196].
Catlett C, Perl T, Jenckes MW, et al. Training of Clinicians for Public Health Events Relevant to Bioterrorism Preparedness. Evidence Report/Technology Assessment No. 51. Rockville, MD: Agency for Healthcare Research and Quality. 2002 Jan. AHRQ Publication No. 02-E011.
Chi C H, Chao W H, Chuang C C, et al. Emergency medical technicians' disaster training by tabletop exercise. Am J Emerg Med. 2001;19(5):433-6. [pmid: 11555806].
Chobin N, Engle L. Are you ready for an ethylene oxide spill? J Healthc Mater Manage 1989; 7(3): 56–7, 60.
Classic K L, Knutson A H, Smith G D. Radiation safety role in institutional disaster planning. Health Phys. 2000;78(5 Suppl):S35-9. [pmid: 10770155].
Cook L. Hospital disaster drill game: a strategy for teaching disaster protocols to hospital staff. J Emerg Nurs. 1990;16(4):269-73. [pmid: 2385061].
DeMars M L, Buss R M, Cleland L C. Victim-tracking cards in a community disaster drill. Annals of Emergency Medicine. 1980;9(4):207-209. [pmid: 7369565].
ED managers react to threat against hospitals: here are security strategies. ED Manag 2003; 15(1):1–5.
Eisner M E, Waxman K, Mason G R. Evaluation of possible patient survival in a mock airplane disaster. Am J Surg. 1985;150(3):321-3. [pmid: 4037190].
EPC Evidence Reports Subdirectory Page. Available at:http://www.ahcpr.gov/clinic/epcindex.htm. Accessed 2003 Mar 3.
Fawcett W, Oliveira C S. Casualty treatment after earthquake disasters: development of a regional simulation model. Disasters. 2000;24(3):271-87. [pmid: 11026160].
Fishel E R. Exercise “Med-Ex” 73. Md State Med J. 1974;23(9):46-8. [pmid: 4851959].
Freeman K M, Thompson S F, Allely E B, et al. A virtual reality patient simulation system for teaching emergency response skills to U.S. Navy medical providers. Prehospital Disaster Med. 2001;16(1):3-8. [pmid: 11367936].
Gebo KA, Jenckes MJ, Chander G, et al. Management of Chronic Hepatitis C. Evidence Report/Technology Assessment No. 60. Rockville, MD: Agency for Healthcare Research and Quality. 2002 Jul. AHRQ Publication No. 02-E030.
Gofrit O N, Leibovici D, Shemer J, et al. The efficacy of integrating “smart simulated casualties” in hospital disaster drills. Prehospital Disaster Med. 1997;12(2):97-101. [pmid: 10187010].
Gray D. Disaster plan education: how we made and tested a video. J Accid Emerg Med. 1996;13(1):21-2. [pmid: 8821219].
Gretenkort P, Harke H, Blazejak J, et al. Interface between hospital and fire authorities--a concept for management of incidents in hospitals. Prehospital Disaster Med. 2002;17(1):42-7. [pmid: 12357565].
Halstead M A. Fire drill in the operating room. Role playing as a learning tool. AORN J. 1993;58(4):697-706. [pmid: 8215323].
The HEICS plan. Available at: http://www.emsa.cahwnet.gov/dms2/download.htm. Accessed 2003 Feb 28.
Hogan DE, Burstein JL, editors. Disaster Medicine. Baltimore, MD: Lippincott Williams & Wilkins; 2002.
Idris A H, Becker L B, Ornato J P, et al. Utstein-style guidelines for uniform reporting of laboratory CPR research. A statement for healthcare professionals from a task force of the American Heart Association, the American College of Emergency Physicians, the American College of Cardiology, the European Resuscitation Council, the Heart and Stroke Foundation of Canada, the Institute of Critical Care Medicine, the Safar Center for Resuscitation Research, and the Society for Academic Emergency Medicine. Writing Group. Circulation. 1996;94(9):2324-36. [pmid: 8901707].
Inglesby T V, Dennis D T, Henderson D A, et al. Plague as a biological weapon: medical and public health management. Working Group on Civilian Biodefense. JAMA. 2000;283(17):2281-90. [pmid: 10807389].
Inglesby T V, Grossman R, O'Toole T. A plague on your city: observations from TOPOFF. Clin Infect Dis. 2001;32(3):436-45. [pmid: 11170952].
Inglesby T V, O'Toole T, Henderson D A, et al. Anthrax as a biological weapon, 2002: updated recommendations for management. JAMA. 2002;287(17):2236-52. [pmid: 11980524].
Jampel HD, Lubomski LH, Friedman DS, et al. Evidence Report on Surgical Treatment of Coexisting Cataract and Glaucoma. Evidence Report/Technology Assessment No. 38. Rockville, MD: Agency for Healthcare Research and Quality. 2000 Sep. AHRQ Publication No. 00-E031.
Joint Commission on Accreditation of Healthcare Organizations. Comprehensive Accreditation Manual for Hospitals: The Official Handbook. Oakbrook Terrace, IL: Joint Commission Resources; 2003.
Kern DE, Thomas PA, Howard DM, et al. Curriculum development for medical education: a six-step approach. Baltimore: The Johns Hopkins University Press; 1998.
Klein J S, Weigelt J A. Disaster management. Lessons learned. Surg Clin North Am. 1991;71(2):257-66. [pmid: 2003249].
Lafreniere F. A mock evacuation is an exercise in saving lives. Dimens Health Serv. 1988;65(5):35-7. [pmid: 3255636].
Lau P F, Lau C C. A disaster drill in Hong Kong. Accid Emerg Nurs. 1997;5(1):34-8. [pmid: 9069733].
Levi L, Bregman D, Geva H, et al. Hospital disaster management simulation system. Prehospital Disaster Med. 1998;13(1):29-34. [pmid: 10187023].
Levy K, Aghababian R V, Hirsch E F, et al. An Internet-based exercise as a component of an overall training program addressing medical aspects of radiation emergency management. Prehospital Disaster Med. 2000;15(2):18-25. [pmid: 11183457].
Maxwell C, Cherneski M. Post-disaster drill analysis. Using victim-tracking cards. J Emerg Med Serv. 1987;12(2):43-6.
Menczer L F. The Hartford disaster exercise. N Engl J Med. 1968;278(15):822-4. [pmid: 5642500].
Milsten A. Hospital responses to acute-onset disasters: a review. Prehosp Disaster Med. 2000;15(1):32-45. [pmid: 11066840].
Nigro C M. Economical citywide tabletop disaster preparedness drill. J Emerg Nurs. 1995;21(2):137-9. [pmid: 7776603].
Ochsner MG, Harviel JD, Stafford PW, et al. Development and organization for casualty management on a 1,000-bed hospital ship in the Persian Gulf. J Trauma 1992; 32(4): 501–12; discussion 512–3.
Paris P M, Stewart R D, Pelton G H, et al. Triage success in disasters: dynamic victim-tracking cards. Am J Emerg Med. 1985;3(4):323-6. [pmid: 4005004].
Public Health Threats and Emergencies Act of 2000. Available at: http://www.senate.gov/~frist/Issues/Issues-National_Defense/FightingTerrorism/_Public_Health_Threats_and_Eme/_public_health_threats_and_eme.html.
Accessed 2003 Feb 21
Rutherford WH. The place of exercises in disaster management. Injury 1990; 21(1): 58–60; discussion 63–4.
Saxena K, Cicero J J, Hass W F. Chemical disaster drill in the State of Minnesota. Minn Med. 1986;69(3):137-9. [pmid: 3504225].
Schein OD, Friedman DS, Fleisher LA, et al. Evidence Report on Anesthesia Management During Cataract Surgery. Evidence Report/Technology Assessment No. 16. Rockville, MD: Agency for Healthcare Research and Quality. 2000 Jul. AHRQ Publication No. 01-E017.
Tur-Kaspa I, Lev E I, Hendler I, et al. Preparing hospitals for toxicological mass casualties events. Crit Care Med. 1999;27(5):1004-8. [pmid: 10362427].
Vardi A, Levin I, Berkenstadt H, et al. Simulation-based training of medical teams to manage chemical warfare casualties. Isr Med Assoc J. 2002;4(7):540-4. [pmid: 12120468].
Weston C J. The operating theatre's on fire. Health Serv Manage. 1988;84(3):20-3. [pmid: 10287894].
Whitney J. Disaster drill--'73. JFMA. 1974;61(3):233-5. [pmid: 4816673].