# Appendix E: Evidence Tables

Evidence Table 1. Characteristics of studies evaluating training programs for hospital staff to respond to an MCI^a^

Author, year location | Type(s) of training intervention, type(s) of event addressed | Hospitals involved (N) | Hospital department(s) involved | Type(s) of hospital staff targeted, total staff involved (N) | Training objective(s)^b^ | Training evaluation method(s)
Hospital disaster drills
Baughman, 1990 U.S. | Disaster drill; hospital fire and explosion in the emergency department | 1 | Emergency medicine; intensive care unit; nursing; security; other departments. | Nurses; physicians. (N=NS^a^) | K: To assess what resources would be available if 1) the usual triage team was unable to perform because of injuries, 2) usual treatment area was not available because of a disaster in that location. | Not specified.
| | | | | S: To assess intensive care unit nurses' ability to triage victims.
Chobin, 1989 U.S. | Disaster drill; chemical | 1 | Administration; emergency medicine; nursing; security. | Administrator (CEO^a^); nurses; physicians; first responders; telephone operator; security office; nursing administration; admitting; maintenance. (N=NS^a^) | K: To test the preparedness of the necessary resources (hospital employees, hospital fire brigade, emergency room staff, local fire department) in the event of an ethylene oxide spill. | Not specified.
Classic, 2000 U.S. | Disaster drill; radiational | 1 | Emergency medicine; security; hospital communications; facilities; operations; radiational safety. | Nurses; physicians; radiation safety staff. (N=NS^a^) | S: To assess the function of intercom and security systems in radiation emergency. | Group interviews/debriefings.
| | | | | B: To assess the time to contact radiation safety staff and set up portable decontamination area; appropriateness of setup of triage area.
Cook, 1990 U.S. | Disaster drill; transportation accident | 1 | All hospital. | Not specified. (N=NS^a^) | K: To understand overall implementation of hospital disaster plan and how their departments interact. | Group interviews/debriefings; “smart” observers^c^; observer checklists.
| | | | | S: To move disaster victims through the hospital system as appropriately and efficiently as possible.
| | | | | C/O: To minimize patient time spent in each area waiting for disposition.
Eisner, 1985 U.S. | Disaster drill; transportation accident | >1 (but only data on 1) | Emergency medicine. | First responders; physicians; triage team. (N=NS^a^) | K: To gain knowledge of time needed to initiate care of patients from an airplane disaster at the local airport. | Mock disaster patient charts.
| | | | | S: To initiate care to patients with varying degrees of injury severity in a timely manner.
| | | | | C/O: To evaluate triage of victims and severity of injuries by arrival time at trauma center.
Fishel, 1974 U.S. | Disaster drill; transportation accident | 18 | Central supply; emergency medicine; nursing; security; | Nurses; physicians, first responders. (N=NS^a^) | K: To evaluate the effectiveness of the total exercise operation. | Group interviews/debriefings; “smart” observers^c^.
| | | | | S: To assess the transportation of 300 victims to 18 hospitals by ambulance and bus.
Gofrit, 1997 Middle East | Disaster drill; NS^a^ | 8 | Emergency medicine; nursing; radiology; surgery. | First responders; nurses; physicians. (N=NS^a^) | C/O: To assess the feasibility of integrating physicians among the simulated casualties of a hospital disaster drill. | Group interviews/debriefings; written exam or questionnaire; “smart” casualties^c^.
Gretenkort, 2002 Europe | Disaster drill; hospital fire | 1 | Nursing; central supplies; inpatient units. | Administrators; first responders; nurses; physicians. (N=500) | K: To educate the coordinating physician of the hospital in communication procedures during an MCI^a^. | Group interviews/debriefings; “smart” observers^c^; other observers; patient impersonators.
| | | | | S: To evacuate immobile patients quickly and effectively to designated collection points.
| | | | | C/O: Comparison of patient evacuation time with group using carry sheet versus single person using Jaerven Rescue Drag Sheet.
Halstead, 1993 U.S. | Disaster drill; hospital fire in operating room | 1 | Nursing; security; surgery; operating room staff. | Nurses; physicians. (N=48) | K: To list the three elements of fire; know how to initiate the procedure for notifying hospital personnel of fire; know the location of the fire extinguishers. | Group interviews/debriefings; “smart” observers^c^.
| | | | | S: To know how to use fire extinguishers.
| | | | | S: To evacuate patients safely.
Lau, 1997 Asia | Disaster drill; transportation accident | 1 | Emergency medicine; nursing; radiology; security; central supplies; emergency mobile team. | Administrators; nurses; physicians; security; transport staff. (N=60) | K: To familiarize hospital staff with the disaster plan and with their roles in disaster management. | Group interviews/debriefings.
| | | | | S: To handle patient flow in an orderly and timely manner; to appropriately triage patients.
| | | | | B: To test the efficiency of the plan and coordinate among hospital departments during disaster management.
Maxwell, 1987 U.S. | Disaster drill; transportation accident | 1 | Not specified. | Physicians; first responders. (N=NS^a^) | K: To assess the value of using victim- tracking cards in a hospital disaster drill. | Group interviews/debriefings; trained casualties; victim-tracking cards.
| | | | | C/O: To appropriately triage and transport casualties to the correct treatment areas.
Menczer, 1968 U.S. | Disaster drill; incendiary device and boiler explosion | 4 | Emergency medicine | Physicians, first responders. (N=NS^a^) | S: To assess handling and transportation of victims; to assess first aid at the scene of a disaster; to assess medical care at the hospital after a disaster. | Written exam or questionnaire, trained casualties, videotape.
Paris, 1985 U.S. | Disaster drill; transportation accident | NS^a^ | Not specified. | Not specified. (N=NS^a^) | S: To analyze the care provided to victims in a community airport disaster drill. | “Smart” casualties^c^; triage cards.
Saxena, 1986 U.S. | Disaster drill; chemical | 1 | Emergency medicine. | Physicians, first responders. (N=NS^a^) | B: To demonstrate the capability to make a coordinated response to a hazardous materials incident by dispatching appropriate local and state response vehicles and teams; to exercise chemical disaster emergency plans within political guidelines; to meet the information needs of federal, state, and local government agencies by establishing on-site communications from an incident site; to demonstrate the ability to notify and assemble emergency response personnel at the scene of a chemical disaster and at Emergency Operating Center; to demonstrate the ability to cooperatively and effectively manage hazardous material accidents; to demonstrate the capabilities of a major hospital emergency room to handle the chemical disaster. | Not specified.
Tur-Kaspa, 1999 Middle East | Disaster drill; chemical | 21 | All hospital. | Not specified. (N=NS^a^) | S: To evaluate the quality of patient care in response to a chemical disaster. | “Smart” casualties^c^; “smart” observers^c^; other observers (administrative personnel); Army physicians with experience in managing chemical casualties.
| | | | | C/O: To evaluate the ability to provide continuity of patient care in response to a chemical disaster.
Weston, 1988 Europe | Disaster drill; hospital fire in operating room | 1 | Nursing; security; surgery. | Administrators; nurses; physicians. (N=NS^a^) | S: To assess time to evacuation. | Group interviews/debriefings; “smart” observers^c^; other observers.
Computer simulations
Levi, 1998 Middle East | Computer simulation; NS^a^ | 1 | Senior management. | Administrators. (N=NS^a^) | B: To evaluate hospital disaster plan without activating whole system (to carry out a limited scale drill); to train decision makers. | Group interviews/debriefings; other observers; constructing a detailed computerized scenario.
| | | | | C/O: To assist in managing real situations by identifying bottlenecks and evaluating solutions.
Tabletop and other exercises
Burns, 1984 Not specified | Tabletop exercise (competitive simulation); incendiary device | 1 | Emergency medicine; nursing. | Nurses; emergency management team. (N=NS^a^) | K: To evaluate nursing care for persons with burn injuries. | Written exam or questionnaire; self assessment forms; other observers.
| | | | | B: To assess 5 performance objectives, each requiring 4 to 5 activities (these were not specified further).
Gray, 1996 Middle East (Saudi Arabia) | Other exercise (video simulation); transportation accident | 1 | All hospital. | First responders; nurses. (N=500+ viewed video within 2 weeks) | K: To evaluate information recall in a group of hospital employees who had seen the video versus a group who had read the disaster plan. | Written exam or questionnaire.
Inglesby, 2001 U.S. | Other exercise; biological | 3 | Emergency medicine; intensive care unit; medicine; pharmacy; security. | Not specified. (N=NS^a^) | K: To test readiness of top government and other officials to respond to terrorist attacks directed at multiple geographic locations. | Group interviews/debriefings; individual interviews/debriefings.
Levy, 2000 Eastern Europe (Russian Federation, Armenia, Estonia, Georgia, Moldova, Ukraine) | Other exercise (audio-graphic teleconferencing); radiational | NS^a^ | Emergency medicine. | Emergency department staff. (N=NS^a^) | K: To recognize accidental exposure to radiation. | Group interviews/debriefings.
| | | | | B: To perform medical assessment of exposed victims; to estimate radiation exposure; to report to national authorities; to establish communication between participating counties.
| | | | | C/O: To achieve coordination and consultation regarding victims.

a Abbreviations: CEO = chief executive officer, MCI = mass casualty incident, NS = not stated

b Key: K = Knowledge, S = Skills, B = Behavior, C/O = Clinical outcome

c “Smart” casualties and observers have medical training

Evidence Table 2. Quality of studies evaluating training programs for hospital staff to respond to an MCI^a^

Author, year | Representativeness^b^ | Bias^c^ | Description^d^ | Outcomes^e^ | Statistics^f^ | Total score^g^
Hospital disaster drills
Baughman, 1990 | 0 | N/A | 38 | 25 | N/A | 21
Chobin, 1989 | 75 | N/A | 63 | 13 | N/A | 50
Classic, 2000 | 75 | N/A | 25 | 25 | N/A | 42
Cook, 1990 | 25 | N/A | 63 | 63 | N/A | 50
Eisner, 1985 | 25 | N/A | 38 | 50 | N/A | 38
Fishel, 1974 | 75 | N/A | 38 | 13 | N/A | 42
Gofrit, 1997 | 50 | N/A | 25 | 38 | N/A | 38
Gretenkort, 2002 | 50 | N/A | 50 | 50 | 0 | 38
Halstead, 1993 | 100 | N/A | 75 | 50 | N/A | 75
Lau, 1997 | 75 | N/A | 38 | 38 | N/A | 50
Maxwell, 1987 | 50 | N/A | 63 | 63 | 100 | 69
Menczer, 1968 | 75 | N/A | 50 | 38 | N/A | 54
Paris, 1985 | 25 | N/A | 25 | 38 | N/A | 29
Saxena, 1986 | 50 | N/A | 63 | 13 | N/A | 42
Tur-Kaspa, 1999 | 50 | N/A | 38 | 25 | N/A | 38
Weston, 1988 | 25 | N/A | 25 | 25 | N/A | 25
Computer simulations
Levi, 1998 | 0 | N/A | 38 | 13 | N/A | 17
Tabletop and other exercises
Burns, 1984 | 50 | N/A | 50 | 75 | 50 | 56
Gray, 1996 | 50 | 69 | 38 | 50 | 100 | 61
Inglesby, 2001 | 50 | N/A | 38 | 25 | N/A | 38
Levy, 2000 | 50 | N/A | 38 | 25 | N/A | 38

a Abbreviations: MCI = mass casualty incident, N/A = not applicable.

b Representativeness: The total maximum for this section was 4 points. This included detailed descriptions of subjects provided (maximum 2 points) and the setting and department(s) described (maximum 2 points).

c Bias (and confounding): The total maximum for this section was 8 points. This included presence of a comparison group (maximum 2 points), assignment of study groups (maximum of 2 points), whether the education intervention groups had important differences on key factors at baseline (maximum 2 points), and intervention other than the educational intervention of interest that differed between groups (maximum 2 points).

d Description (of intervention): The total maximum score for this section was 8 points. This included the objectives of the intervention clearly stated in specific measurable terms (maximum 2 points), whether the objectives of the intervention specifically took into consideration knowledge, beliefs/attitudes, skills, behaviors, or clinical outcomes (maximum 2 points), complete description of the educational methods, content, resources and organization of the educational intervention (maximum 2 points), and the key people measuring the educational outcomes appropriately masked to intervention (maximum 2 points).

e Outcomes (of the educational intervention): The total maximum for this section was 8 points. This included outcomes of the educational intervention based on pre- and post-intervention evaluation (maximum 2 points), the evaluation methods described in sufficient detail to replicate (maximum 2 points), objective methods used to evaluate outcomes (maximum 2 points), and evaluation of long-term retention of information relating to training hospital staff in case of a MCI (maximum 2 points).

f Statistics (quality and interpretation): The total maximum for this section was 6 points. This included the magnitude of difference between groups and an index of variability for primary endpoints (maximum 2 points), the appropriate analyses and statistical tests performed (maximum 2 points), and adjustment of potential confounders with multi-variate or stratified analyses and confounders coded (maximum 2 points).

g Total score: Mean of the percent scores from the previous four categories.

Evidence Table 3. Results of studies evaluating training programs for hospital staff to respond to an MCI^a^

Author, year | Type(s) of event addressed | Results | Summary/conclusion
Hospital disaster drills
Baughman, 1990 | Hospital fire and explosion in the emergency department | Incident control: Confusion resulted because no single person was designated as incident commander. | Disaster located in the ED^a^ immobilized procedures, revealing deficiencies in the internal chain of command, distribution of disaster charts, and training of nurses in triage.
| | Triage: Usual triage area was not available causing confusion. Secondary staff was inexperienced in triage.
| | Internal communications: Considerable time delay because ED^a^ was immobilized.
| | Patient care: Treatment began in triage areas before patients were sent to treatment areas.
| | Patient flow: No triage area.
| | Security: Security informed fire department of situation.
| | Resources: Disaster charts not available because stored in ED^a^.
Chobin, 1989 | Chemical | Internal communications: Hospital operator was called using established hotline. Hospital fire brigade alerted by code. Hospital operator notified nursing administration. | Enactment of a disaster drill involving both external and internal response, and involving multiple departments with simulated patients, enables the departments, hospital and local agencies to test Occupational Safety and Health Agency-required disaster plans before an emergency arises.
| | External communications: Requested assistance from local fire department. Requested hospital Chief Executive Officer to call a disaster code.
| | Patient flow: Victims evacuated to ED^a^.
| | Resources: Fire department arrives on scene in full gear: material safety data sheet and breathing apparatus used.
| | Patient tracking: Admitting personnel present in ED^a^ making charts and identification bracelets.
Classic, 2000 | Radiational | Triage: Physical barriers to identify “hot”, “warm”, and “cold” zones for ambulatory victims not used correctly. | Drill provided education to spill team members and identified areas for improvement in response.
| | Internal communications: Intercom system inadequate, as message could not be clearly understood. Fire alarms worked well. Radiation call staff contacted successfully. | Drill was not only educational but also built responder confidence in abilities.
| | External communications: Contact of radiation safety immediate, but message incomplete (significant deficiency).
| | Patient care: Plan to use building exits as “choke points” for screening works well.
| | Patient flow: 30 victims transported to ED^a^.
| | Security: Security of building and perimeter exceeded the standards.
| | Decon ^ a ^: County Hazardous Materials Response Team required an hour to set-up the portable decon^a^ facility. Only one nurse had been released to prepare the hospital decon^a^ facility, an activity that requires at least two people. Victims found dead on the scene are not released to local funeral homes until they have first gone to the autopsy laboratory, allowing hospital control of the body in the event it is contaminated.
| | Other: Disaster response personnel needed special identification. Bioassay specimen collection needed for those with radiation exposure. Access to facilities may not be able to occur within regulatory time frames.
Cook, 1990 | Transportation accident | Incident control: Less confusion. | Use of a game approach in disaster planning produced benefits in increased understanding of disaster plans, identification of disaster plan flaws, and increased coordination regarding thoughtfully planned disaster care.
| | Internal communications: Overhead announcement not heard. Some vital personnel had not received new disaster plan.
| | Patient flow: Less congestion in triage and ED^a^ since personnel reported directly to assigned areas rather than to the ED^a^ to ask for guidance.
| | Other: At least one person in each department now has an in-depth understanding post drill. Staff stress levels more manageable with game approach.
Eisner, 1985 | Transportation accident | Triage: 53% of the group that needed immediate care arrived at care location greater than 1.5 hours post-disaster. 15% of patients triaged were discharged home compared to 85% of patients requiring hospital admission. | Simulation of an airplane crash at a local airport revealed a long delay in patient care for seriously or critically injured people.
Fishel, 1974 | Transportation accident | Triage: Teams of doctors and nurses were not experienced or knowledgeable in triage. A course to develop triage personnel is needed. The triage tags were not easily identifiable, color coded tags may address this problem. | An 18 hospital city-wide disaster drill was able to locate deficiencies in patient transport, internal and external communications, and triage even though only 175 of the expected 300 simulated casualties participated.
| | Internal Communications: The emergency call-up system was inadequate because names and telephone numbers were not correct.
| | External Communications: Radio communications developed several technical and operational problems.
| | Patient Flow: Ambulance crews became exhausted moving the victims.
Gofrit, 1997 | Not stated | Triage: 9% of patients were over-triaged. 4 % of patients were under-triaged. | Integrating physicians (“smart” casualties) among the simulated casualties in a hospital disaster drill may contribute to achieving the objectives of hospital disaster drills and add to disaster management education of the simulated casualty physicians.
| | Patient care: Simulated casualties were not examined head-to-toe. Patients with post-traumatic stress disorder were not examined fully and referred directly to psychology. | The “smart” casualty also can identify faults in the medical organization and in the medical care provided.
| | Patient flow: Delays were encountered in treatment due to lack of leadership and shortage of personnel. Patients transferred from one area to another without appropriate medical escort and without properly controlled ventilation.
| | Resources: There was a shortage of ventilators and other trauma care equipment resulting from failure to report from in-hospital storage to ED^a^.
| | Patient tracking: Medical documentation was inadequate.
Gretenkort, 2002 | Hospital fire | Incident control: The leadership concept of the Coordinating Physician of the Hospital working together with other hospital executives and the incident commander proved effective. | Reorganization of leadership for hospital disaster incidents, complemented by the use of predefined checklists and Jaerven Rescue Drag Sheets, greatly streamlined elevator-independent evacuation of immobile patients.
| | External communications: Went smoothly and provided true interface between authorities and hospital administration.
| | Patient flow: Patient flow and staff allocation greatly aided by Jaerven Rescue Drag Sheet.
| | Resources: For 120 patients, Jaerven Rescue Drag Sheet took 601 minutes for complete evacuation, compared to 799 minutes for carrying teams.
| | Other: Preparation of patient collection points did not meet the needs for the actual number of patients.
Halstead, 1993 | Hospital fire in operating room | Internal communications: Could not hear overhead announcement of fire in operating room. Needed printed protocol for fighting fire. Operating room representatives to be added to hospital committee. | Operating room specific drills and programs should be developed and tested to teach operating room staff about fire prevention and responding to fire disasters.
| | Patient care: Operating room beds too heavy to maneuver for evacuation.
| | Patient flow: Corridors, exits, and evacuation routes were blocked with equipment. More storage space needed for extra equipment.
| | Resources: Gas levers were difficult to find. Fire door in back corridor did not close. Need second water hose.
| | Other: A secondary program taught the operating room staff how to use fire extinguishers.
Lau, 1997 | Transportation accident | Incident control: Disaster plan activated successfully. | Organizing practice drills provided clinicians with the opportunity to anticipate possible operational difficulties and find remedies to track them, as well as develop effective coordination and cooperation around various departments of the hospital in disaster management.
| | Triage: 19 patients triaged and discharged. Patients' particulars were inadequately up-dated on the Accident and Emergency clinical record sheets.
| | Internal communications: Better radio training needed.
| | External communications: Telephone operator preferred native language under stressful conditions.
| | Patient care: Charting and filling out forms detracted from patient care. Staff summoned from other units were not familiar with ED^a^.
| | Patient flow: 45 minutes from first patient in to last patient out. Porters did not know role in drill.
| | Resources: Nurse wasted time to summon back staff. Not enough wheelchairs, extra chairs in waiting room, or poles and ropes to maintain order.
| | Patient tracking: Patients given bracelets and record sheet with identification. All patients accounted for.
Maxwell, 1987 | Transportation accident | Triage: 6 victims were not assigned any hospital triage category. | Victim tracking cards contribute to the process of post drill analysis.
| | Patient care: 13 of the 14 victims were judged to have received appropriate treatment.
| | Patient flow: The median time to triage was 3 minutes with a range of 0 to 10. The median time to treatment area was 10 minutes with a range from 0 to 39.
| | Patient tracking: 4 victims slipped through hospital triage without being tagged.
Menczer, 1968 | Incendiary device and boiler explosion | Incident control: No overall recognized leader to coordinate services and agencies. No medical authority at the scene. | The disaster exercise identified a number of important deficiencies in disaster management.
| | Triage: No selection of victims for removal from the scene. Immediate establishment of an area for victim safety and treatment was an unfulfilled need. One observer found no evidence of effective triage and no follow-up.
| | Patient care: Training of police and fire department personnel in first aid was deficient. Victims need more thorough and adequate first aid after being removed from the disaster site.
| | Patient flow: Transportation of victims from the disaster scene was done with little regard to the type or site of injury. A great deal of unnecessary handling of victims occurred. Several victims were laid on cold ground uncovered for as long as 20 to 30 minutes. Ambulance services generally provided proper handling and transpiration.
| | Resources: First aid equipment and supplies in quantity must be taken to site as soon as the type of disaster is ascertained.
| | Other: Out-of-town ambulance drivers did not know hospital locations as the state highway signs were inadequate.
Paris, 1985 | Not stated | Triage: 5% of victims never assigned to a triage category. 44% of victims assigned to proper triage category. | Victim-tracking cards useful in evaluating the patient management aspect of a disaster drill.
| | Patient care: All 133 patient-tracking cards collected. 3% of victims with correctable injuries “died” as a result of necessary treatment not provided in timely manner. 6% of victims had deterioration attributed to lack of timely intervention.
Saxena, 1986 | Chemical | External communications: Notification for the activation of Emergency Operating Centers among participating agencies was not effectivity accomplished. The list of chemicals involved was not correctly reported to the state Emergency Operating Center. Exercise communications between the Emergency Operating Center were inefffective and in come cases nonexistent. | The chemical disaster drill will help the state to be in a state of readiness for hazardous material accidents.
Tur-Kaspa, 1999 | Chemical | External communications: An effective communication system between different sites and the control center is essential. | Lessons learned from hospital disaster drills can be incorporated into the current hospital deployment plan.
| | Patient care: Continuous care and repeated re-evaluation of patients are essential during transfer and treatment. Clinicians must know dosages and side affects of antidotes. Training should occur in full protective equipment and include “intubation dolls”, ventilation, and decon^a^ procedures. At each treatment site, medical personnel must be ready to handle casualties with injuries other than those of the specific type and severity for which they have been prepared. | The described hospital deployment plan for management of chemical casualties and the preparation process that accompanies it can serve as a basis for hospital planning. This has implications for the handling of large-scale disasters, with maximum efficiency and minimum loss of life.
| | Decon ^ a ^: Full protective equipment must be worn in the “contaminated area.” Decon^a^ must be directed by personnel with loudspeakers.
| | Patient tracking: Clear labeling, identification, and record keeping are vital for efficient reception and treatment of casualties.
| | Other: Adequate pre-drill instruction and training are vital for the drill's success.
| | Note: The above statements were presented as the “results” of the drill.
Weston, 1988 | Hospital fire in operating room | Incident control: Absence of senior hospital nursing officer led to command confusion. Incident flow charts needed. | Simulation of a small fire in the surgical theaters revealed deficiencies in command, communication, and execution of evacuation during the disaster drill.
| | Internal communications: Poor communication because of low number of alarm bells and low level of buzzers.
| | Patient care: Patient casualty occurred due to surgical evacuation.
| | Patient flow: Patients were incorrectly moved outside instead of to opposite side of first fire door.
| | Patient tracking: All patients and staff were accounted for at the end of the 28 minute evacuation.
Computer simulation
Levi, 1998 | Not stated | Patient flow: Able to identify bottlenecks and predict ability to care for more casualties. | The described simulation techniques used in preparatory limited scale drill had advantages in evaluating and improving preparedness of hospitals for managing an MCI^a^ before a full-scale drill is done.
| | Security: Able to identify crowd control issues and other security problems.
| | Resources: Able to identify specific medical equipment/medication needs and electro-mechanical failures.
Tabletop and other exercises
Burns, 1984 | Incendiary device (competitive simulation exercise) | Patient care: Participants' burn care knowledge increased 6 to 7 points from pre-test to post exercise (total score = 200). The median outcome of self-scoring was 87% with a range from 60–96%. Leadership personnel from the ED^a^ working with members of the burn unit scored the highest. A team consisting of an ED^a^ technician and a staff nurse scored the lowest. | The competitive simulation used to test and educate nurses on the treatment of burn victims was found to have advantages in motivation of the participants, utilization of new concepts prior to actual practice, realism, relevance, and the simplification of complex nursing problems.
Gray, 1996 | Transportation accident (video simulation) | Other: In a video describing the use of a control room, a staff reporting station, field equipment, and protective clothing in a transportation accident, video viewers retained information significantly better than those who had read the disaster plan (72% versus 45%, p<0.01). | Use of video has three advantages: 1) video allows staff to see equipment and how to use it, 2) video gives staff insight into facing mass casualties, and 3) video viewing is easy to plan and supervise. Overall this was an efficient, convenient, and enjoyable way for hospital staff to learn about the disaster plan.
Inglesby, 2001 | Biological | Incident control: Unclear how to coordinate different operation centers set up by a variety of state and federal emergency management offices. Not familiar with language used in disaster control. Leadership roles and authorities in the crisis were uncertain; not clear who was in charge. | Clear, scientifically and politically sound principles for containment of highly infectious disease in large, urban communities are needed. Public health resources now in place would not be sufficient to respond to the demand created by a bioterrorism epidemic.
| | Triage: Concern over ability to distinguish between “worried well” and those harboring early signs of plague.
| | Internal communications: A significant amount of time spent exchanging phone, beeper, and FAX numbers; exchange should have been done prior to exercise.
| | External communications: Process of decision making by conference call was highly inefficient and led to indecision and significant delays in taking action. 800 MHz radios had efficient communication where regular phone lines were not answered or otherwise dysfunctional.
| | Patient care: Hospitals were beyond capacity for patients in less than 24 hours.
| | Patient flow: Inadequate plans for disposition of patients before and after triage, and for the deceased.
| | Security: Concerns about security's ability to create an effective “security lock-down”.
| | Resources: Antibiotic supplies were exhausted early in the exercise and antibiotic distribution was logistically difficult. Other resources were scarce.
| | Other: Serious disagreements about antibiotic distribution. Not clear which health care workers should be wearing protective equipment or what level of protection was appropriate.
Levy, 2000 | Radiational (audio-graphic teleconferencing) | Triage: Correlations made between clinical symptoms in ED^a^ and common source of exposure. Names of those exposed were identified and sent to the Departments of Public Health in participating countries. | Practice with the technological component of a training activity is an effective means to familiarize emergency responders with policies and procedures regarding radiation accidents.
| | External communications: Extensive live communication among sites in 5 time zones. All sites participated in 7 live conferences within 74 hours. Proper authorities notified in each country.

a Abbreviations: decon = decontamination, ED = emergency department, MCI = mass casualty incident