# Appendix D: Coding Forms_Quality Review Form

Section III: Representativeness of Targeted Hospital Staff
For each question, circle one response.
1. Were detailed descriptions of subjects provided?
| a. | Adequate | (Detailed description, e.g., number of doctors, number of nurses, etc.) | 2
| b. | Fair | (Some general description, e.g., professionals involved) | 1
| c. | Indequate | (Minimal description or none at all, e.g., disaster team) | 0
2. Were the setting and department(s) described?
| a. | Adequate | (Setting and departments described in sufficient detail to replicate) | 2
| b. | Fair | (Setting OR departments NOT reported OR poor descriptions) | 1
| c. | Inadequate | (Neither specified) | 0
Section IV: Bias and Confounding
For each question, circle one response.
3. Was there a comparison group?
| a. | Adequate | (Concurrent and similar group) | 2
| b. | Fair | (Non-concurrent OR non-similar) | 1
| c. | Inadequate | (Non-concurrent and non-similar) | 0
| d. | None | Skip to item 7
4. Was assignment of study groups randomized?
| a. | Yes | | 2
| b. | No | | 0
| c. | Unclear | | 0
5. Did the education intervention groups have any important differences on key factors at baseline?
| Key Factors:
| Profession (e.g., Nurses, Emergency Medical Technicians, Doctors)
| Specialty (e.g., Emergency Medicine, Internal Medicine, Pediatrics)
| a. | Groups equivalent in all key factors | | 2
| b. | Groups have minor difference in 1 factor | | 1.5
| c. | Groups have major difference in 1 factor or minor differences in more than 1 factor | | 1
| d. | No information about groups' characteristics or inadequate to compare | | 0
6. Was there any intervention other than the educational intervention of interest that differed between groups?
| a. | Yes | | 0
| b. | No | | 2
| c. | Unclear | | 0
Section V: Description of Intervention
For each question, circle one response.
7. Are the objectives of the intervention clearly stated in specific measurable terms?
| a. | Adequate | (Objectives clearly stated in measurable terms) | 2
| b. | Fair | (Objectives stated but not stated in specific measurable terms) | 1
| c. | Inadequate | (Objectives not stated) | 0
8. Did the objectives of the intervention specifically take into consideration knowledge, beliefs/attitudes, skills, behaviors, or clinical outcomes?
| a. | Adequate | (Considers any 3 of 5) | 2
| b. | Fair | (Considers 1 or 2 of 5) | 1
| c. | Inadequate | (Considers none of the above) | 0
9. Was there a complete description of the educational methods, content, resources, and organization of the educational intervention?
| a. | Adequate | (Intervention could be replicated given the completeness of description) | 2
| b. | Fair | (Some detail but insufficient to ensure replication) | 1
| c. | Inadequate | (No detail) | 0
10. Were the key people measuring the educational outcomes appropriately masked to intervention?
| a. | Yes | | 2
| b. | No | | 0
| c. | Unclear | | 0
Section VI: Outcomes of the Educational Intervention
For each question, circle one response.
11. Outcomes of the educational intervention were based upon:
| a. | Pre- and post-intervention evaluation | | 2
| b. | Post-intervention evaluation | | 1
| c. | Neither pre- nor post-intervention evaluation | | 0
12. Are the evaluation methods described in sufficient detail to replicate?
| a. | Adequate | (Evaluation methods could be replicated) | 2
| b. | Fair | (Evaluation methods described but could not be replicated) | 1
| c. | Inadequate | (Evaluation methods not described) | 0
13. Were objective methods used to evaluate outcomes?
| a. | Adequate | (Evaluation methods were objective) | 2
| b. | Fair | (Objectivity of evaluation is questionable) | 1
| c. | Inadequate | (Evaluation methods not objective) | 0
14. Was there any evaluation of long-term retention of information related to training hospital staff in case of an MCI event?
| a. | Yes | (At least one month after completion of the intervention) | 2
| b. | No | | 0
Section VII: Statistical Quality and Interpretation
For each question, circle one response.
15. Was there quantitative data analysis?
| a. | Yes | Continue on with questions 16 – 18 below
| b. | No | Thank you, your form is complete
16. For primary endpoints of the evaluation, does the study report the magnitude of difference between groups AND an index of variability (e.g., test statistic, p value, standard error, confidence interval)?
| a. | Adequate | (Both reported with index of variability using standard error or confidence intervals) | 2
| b. | Fair | (Both reported with index of variability using only test statistic or p value) | 1
| c. | Inadequate | (One or both not reported) | 0
| d. | No comparison group
17. Were the appropriate analyses and statistical tests performed?
| a. | Adequate | (Yes for all analyses) | 2
| b. | Fair | (Yes for only some of the analyses) | 1
| c. | Inadequate | (Not for any of the analyses or can't tell) | 0
18. If groups were not comparable at study onset, was there adjustment of potential confounders with multi-variate or stratified analyses AND were confounders coded in a way to make such control adequate?
| a. | Adequate | (Adjustment done AND confounders appropriately coded) | 2
| b. | Fair | (Adjustment done BUT confounders not coded appropriately OR coding unclear OR can't tell) | 1
| c. | Inadequate | (Adjustment not done OR comparability not previously reported) | 0
| d. | No comparison group
THANK YOU! For completing this form. Please return it to Mollie.