# Appendix C: Methodological Approach to Searching Literature Sources

Search Strategy for PubMed^®^
(disaster planning[mh] OR disaster*[tiab] OR mass-casualt*[tiab] OR mass-casualt*[tiab]) AND (drill*[tiab] OR simulation[tiab] OR exercise*[tiab]) AND eng[la] NOT (animal[mh] NOT human[mh]) NOT (review[pt] OR meta-analysis[pt])
Search Strategy for the Cochrane CENTRAL Register of Controlled Trials
(((DISASTER* or CATASTROPH*) or BIOTERRORISM) or CASUALT*)
((((EXERCISE* or TABLETOP) or SIMULAT*) or DRILL*) or TRAIN*)
(#1 and #2)
Search Strategy for the Excerpta Medica Database
#1Disaster Planning/
#2disaster$.tw
#3mass casualt$.tw
#4hospital$.tw
#5Emergency Health Service/
#6drill$.tw
#7simulation.tw
#8exercise$.tw
#91 or 2 or 3
#104 or 5
#116 or 7 or 8
#129 and 10 and 11
Search Strategy for the Specialized Register of Effective Practice and Organization of Care Cochrane Review Group
(disaster* OR catastroph* OR bioterrorism OR “biological weapon” OR casualt*) AND (exercise OR tabletop OR simulat* OR drill* OR train*)
Search Strategy for the Educational Research Information Clearinghouse
(poison, poisoning, “communicable disease”, “disease control”, bioterrorism, “biological warfare”, disaster, catastroph*) + (“health personnel”, “allied health personnel”, “health services”) + (“program evaluation”, “course evaluation”)
Search Strategy for the Research and Development Resource Base in Continuing Medical Education
‘disaster’ in indexed and non-indexed fields.