# Appendix B: Priority Journals ^a^ a All volumes of the journals listed were searched during the month of January 2003.

Academic Emergency Medicine
Annals of Emergency Medicine
Clinical Infectious Diseases
Disasters
ED Management
Emergency Medicine Clinics of North America
Emerging Infectious Diseases
Hospital Security and Emergency Management (formerly Hospital Security and Safety Management)
Journal of Emergency Nursing
Military Medicine
Morbidity and Mortality Weekly Report (MMWR)
Prehospital and Disaster Medicine
Prehospital Emergency Care