# Appendix A: Expert Reviewers

Organization | Last Name | First Name | Location and Position
Internal Reviewers-Johns Hopkins University
Johns Hopkins University | Van Rooyen | Michael | Johns Hopkins University
| | | Center for International Emergency, Disaster and Refugee Studies
| | | Baltimore, MD
Johns Hopkins University | O'Toole | Tara | JHU Center for Civilian Biodefense Strategies
| | | Baltimore, MD
Johns Hopkins University | Inglesby | Thomas | JHU Center for Civilian Biodefense Strategies
| | | Baltimore, MD
Government
Health Resources and Services Administration (HRSA) | Bossler | Sumner | Commander, United States Public Health Service
| | | Health Resources and Services Administration's Bioterrorism Preparedness Program
| | | Rockville, MD
Agency for Health Care Research and Quality (AHRQ) | Phillips | Sally | Agency for Healthcare Research and Quality's Center for Primary Care Research
| | | Rockville, MD
University
Vanderbilt School of Nursing | Conway-Welch | Colleen | Dean, Vanderbilt School of Nursing
| | | Nashville, TN
University of Alabama at Birmingham | Terndrup | Thomas | Professor and Chair, Department of Emergency Medicine
| | | Director, Center for Disaster Preparedness
| | | University of Alabama at Birmingham
| | | Birmingham, AL
Philadelphia Veterans Administration Medical Center | Henning | Kelly | Philadelphia Veterans Administration Medical Center
| | | Division of Infectious Diseases, University of Pennsylvania
| | | Philadelphia, PA
St. Louis University School of Public Health | Evans | Greg | Director, Center for Study of Bioterrorism and Emerging Infection, School of Public Health, St. Louis University
| | | St. Louis, MO
Harbor-UCLA Medical Center | Kaji | Amy | Department of Emergency Medicine
| | | Harbor-UCLA Medical Center
| | | Torrance, CA
Professional Organizations
Joint Commission for Accreditation of Health Organizations (JCAHO) | Smith | Marc | Chair, Joint Commission for Accreditation of Health Organizations roundtable on emergency preparedness
| | | Washington, DC
Society for Medical Decision Making (SMDM) | Bravata | Dena | Center for Primary Care and Outcomes Research
| | | Stanford University School of Medicine
| | | Stanford, CA