# Appendixes

Appendix A: Expert Reviewers

Appendix B: Priority Journals

Appendix C: Methodological Approach to Searching Literature Sources

Appendix D: Coding Forms_Quality Review Form

Appendix E: Evidence Tables

Appendix F: Literature Search Summary

Appendix G: Bibliography

Appendix H: Excluded Articles