# Acronyms and Abbreviations

Acronyms | Abbreviation
A (20:4 n-6) | Arachidonic acid
ABCC | Alpha-Tocopherol Beta-Carotene Cancer Prevention Trial
ADVENTIST | Adventist Health Study
AE | Adverse events
AHRQ | Agency for Healthcare Research and Quality
ALA (18:3 n-3) | Alpha linolenic acid
AMI | Acute myocardial infarction
BMI | Body mass index
CAD | Coronary artery disease
CCD | Cross check dietary history
CCTR | Cochrane Central Register of Controlled Trials
CHD | Coronary heart disease
CHS | Cardiovascular Health Study
CI | Confidence interval
CSF II | Continuing Food Survey of Intakes by Individuals 1994-1998
CVD | Cardiovascular disease
DART | Diet and Reinfarction Trial
DHA (22:6 n-3) | Decosahexaenoic acid
DM | Diabetes mellitus
DPA (22:5 n-3 or n-6) | Docosapentaenoic acid
DRI | Dietary References Intakes
EAR | Estimated Average Requirement
ECG | Electrocardiogram
EFA | Essential fatty acid
EPA (20:5 n-3) | Eicosapentaenoic acid
EPC | Evidence-based Practice Center
EPIC | European Investigation into Cancer and Nutrition Study
FA | Fatty acid
FDA | Food and Drug Administration
FFQ | Food frequency questionnaire
GEN | General population—applicability category
GI | gastrointestinal
GISSI | Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardio
GLA (18:3 n-6) | Gamma linolenic acid
HPS, HPFS | Health Professionals Follow-up Study
HR | Hazard ratio
HRT | Hormone replacement therapy
HTN | Hypertension
IHD | Ischemic heart disease
IOM | Institute of Medicine
LA (18:2 n-6) | Linoleic acid
LC PUFA | Long-chain polyunsaturated fatty acid
MARGARIN | Meditteranean Alpha-Linolenic Enriched Groningen Dietary Intervention Study
MI | Myocardial infarction
MRFIT | Multiple Risk Factor Intervention Trial
MUFA | Mono unsaturated fatty acid
n-3 FA | Omega-3 fatty acids
NA | Not applicable
NCHS | National Center for Health Statistics
ND | No data
NEMC | New England Medical Center
NHANES III | National Health and Nutrition Examination 1988-1994
NHEFS | NHANES I Epidemiological Follow-up Study
NHLBI | National Heart Lung and Blood Institute (Family Heart Study)
NHS | Nurses' Health Study
NIH | National Institutes of Health
ns | not significant
ODS | Office of Dietary Supplements
PHS | Physicians' Health Study
PUFA | Polyunsaturated fatty acid
RDA | Recommended Dietary Allowances
RBC | Red blood cells
RCT | Randomized controlled trial
RR | Relative risk
RSE | Relative standard error
SC-RAND | Southern California-RAND
SD | Standard deviation
SE | Standard error
SEM | Standard error of the mean
SREBP | Sterol regulatory element binding protein
TC | Total cholesterol
TEP | Technical Expert Panel
TNF | Tumor necrosis factor
UO | University of Ottawa
USDA | United States Department of Agriculture
WES | (Chicago) Western Electric Study