# Excluded Studies

Author, Year | Title | Reason
Bainton, 1992 | Plasma triglyceride and high density lipoprotein cholesterol as predictors of ischaemic heart disease in British men. The Caerphilly and Speedwell Collaborative Heart Disease Studies. | Inappropriate Intervention/Exposure (No omega-3 fatty acid)
British Heart Journal, 68:60–66
Bairati, 1993 | Measurement errors in standard visual analysis of coronary angiograms: consequences on clinical trials. | Inappropriate Intervention/Exposure (No omega-3 fatty acid)
Canadian Journal of Cardiology, 9:225–230
Bang, 1980 | Personal reflections on the incidence of ischaemic heart disease in Oslo during the Second World War. | No outcome of interest
American Journal of Clinical Nutrition, 33:2657–2661
Bang, 1981 | The consumption of the Eskimo food in north Western Greenland. | Review (not primary study)
Acta Medica Scandinavia, 210:245–248
Bates, 1985 | Plasma essential fatty acids in pure and mixed race American Indians on and off a diet exceptionally rich in salmon. | Measurements of serum fatty acid
Prostaglandins Leukotrienes & Medicine, 17:77–84
Baylin, 2003 | Adipose tissue alpha-linolenic acid and nonfatal acute myocardial infarction in Costa Rica. | Adipose tissue
Circulation, 17:1586–1591
Berg, 1991 | The effect of n-3 polyunsaturated fatty acids on Lp(a). | No outcome of interest
Clinica Chimica Acta, 198:271–277
Boniface, 2002 | Dietary fats and 16-year coronary heart disease mortality in a cohort of men and women in Great Britain. | Inappropriate Intervention/Exposure (No omega-3 fatty acid)
European Journal of Clinical Nutrition, 56:786–792
Brox, 2002 | Blood lipids, fatty acids, diet and lifestyle parameters in adolescents from a region in northern Norway with a high mortality from coronary heart disease. | No outcomes of interest; age less than “adult”
European Journal of Clinical Nutrition, 56:694–700
Burr, 2001 | Evidence and perspectives on n-3 polyunsaturated fatty acids in cardiovascular disease 2001; biological background, and research priorities on n-3 fatty acids. | Review (not primary study)
European Heart Journal Supplements, 3:D75–D78
Crombie, 1987 | International differences in coronary heart disease mortality and consumption of fish and other foodstuffs. | Inappropriate Intervention/Exposure (No fish intake data)
European Heart Journal, 6:560–563
Das, 1995 | Essential fatty acid metabolism in patients with essential hypertension, diabetes mellitus and coronary heart disease. | Inappropriate Intervention/Exposure (No fish or omega-3 fatty acid intake data)
Prostaglandins Leukotrienes & Essential Fatty Acids, 52:387–391
Dayton, 1968 | Controlled trial of a diet high in unsaturated fat for prevention of atherosclerotic complications. | Serum composition
Lancet, 2:1060–1062 | Dietary linolenic acid and carotid atherosclerosis: the National Heart, Lung and Blood Institute Family Heart Study. | Inappropriate Intervention/Exposure
Djousse, 2003
American Journal of Clinical Nutrition; 77:819–825
Guallar, 1995 | A prospective study of plasma fish oil levels and incidence of myocardial infarction in U.S. male physicians. | Plasma fish oil level
Journal of the American College of Cardiology, 25:387–394
Guallar, 1999 | Omega-3 fatty acids in adipose tissue and risk of myocardial infarction: the EURAMIC study. | Adipose tissue level
Arteriosclerosis Thrombosis & Vascular Biology, 19:1111–1118
Haligren, 2001 | Markers of high fish intake are associated with decreased risk of a first myocardial infarction. | No outcome of interest
British Journal of Nutrition, 86:397–404
Hardarson, 1989 | Cod liver oil does not reduce ventricular extrasystoles after myocardial infarction. | No outcome of interest
Journal of Internal Medicine, 226:33–37
Hu, 1999 | Dietary saturated fats and their food sources in relation to the risk of coronary heart disease in women. | Inappropriate Intervention/Exposure (No fish or omega-3 fatty acid data)
American Journal of Clinical Nutrition, 70:1001–1008
Hunter, 1988 | Fish consumption and cardiovascular mortality in Canada: an inter-regional comparison. | Inappropriate Intervention/Exposure (No fish intake data quantified)
American Journal of Preventive Medicine, 4:5–10
Iso, 2002 | Linoleic acid, other fatty acids, and the risk of stroke. | Serum composition
Stroke, 22:2086–2093
Joossens, 1989 | Nutrition and cardiovascular mortality in Belgium. For the B.I.R.N.H. study group. | Inappropriate Intervention/Exposure (No omega-3 fatty acid data)
Acta Cardiologica, 44:157–182
Lancet, 1968 | Controlled trial of soya-bean oil in myocardial infarction. | Inappropriate Intervention/Exposure (No omega-3 fatty acid data)
2:693–699
Laurenzi, 1989 | Is Italy losing the “Mediterranean advantage?” Report on the Gubbio population study: cardiovascular risk factors at baseline. | Inappropriate Intervention/Exposure (No omega-3 fatty acid data)
Preventive Medicine, 18:35–44
Lemaitre, 2002 | Cell membrane trans-fatty acids and the risk of primary cardiac arrest. | Inappropriate Intervention/Exposure (No omega-3 fatty acid data)
Circulation, 105:697–701
Lemaitre, 2003 | n-3 Polyunsaturated fatty acids, fatal ischemic heart disease, and nonfatal myocardial infarction in older adults: the Cardiovascular Health Study. | Serum composition
Am J Clin Nutr, 77:319–325
Leng, 1999 | Essential fatty acids and cardiovascular disease: the Edinburgh Artery Study. | Serum composition
Vascular Medicine, 4:219–226
Martinez-Gonzalez, 2002 | Mediterranean diet and reduction in the risk of a first acute myocardial infarction: an operational healthy dietary score. | Inappropriate Intervention/Exposure (No fish intake data)
European Journal of Nutrition, 41:153–160
Mehta, 1988 | Dietary supplementation with omega-3 polyunsaturated fatty acids in patients with stable coronary heart disease. Effects on indices of platelet and neutrophil function and exercise performance. | No outcome of interest
Americal Journal of Medicine, 84:45–52
Miettinen, 1982 | Fatty-acid composition of serum lipids predicts myocardial infarction. | Inappropriate Intervention/Exposure (No omega-3 fatty acid data)
British Medical Journal, 285:993–996
Nakamura, 2003 | Serum fatty acid levels, dietary style and coronary heart disease in three neighboring areas in Japan: the Kumihama study. | Serum composition
Br J Nutr, 89:267–272
Nobmann, 1998 | Dietary intakes among Siberian Yupiks of Alaska and implications for cardiovascular disease. | No outcome of interest
International Journal of Circumpolar Health, 57:4–17
Norell, 1986 | Fish consumption and mortality from coronary heart disease. | No outcome of interest (letter only)
BMJ, 293:436
Omoto, 1984 | Dietary habits and cardiovascular diseases (I). The mortality rate from cerebrovascular and cardiovascular diseases and the eicosapentaenoic acid and arachidonic acid ratio in the blood of the inland-and coast-dwellers in Japan. | No outcome of interest
Nippon Eiseigaku Zasshi - Japanese Journal of Hygiene, 38:887–898
Paganelli, 2001 | Altered erythrocyte n-3 fatty acids in Mediterranean patients with coronary artery disease. | Serum composition
International Journal of Cardiology, 78:27–32
Pedersen, 1999 | N-3 fatty acids as a risk factor for haemorrhagic stroke. | N<=5 in omega-3 treatment arm (4 cases)
Lancet, 353:812–813
Pitsavos, 2002 | The effect of Mediterranean diet on the risk of the development of acute coronary syndromes in hypercholesterolemic people: a case-control study. | Inappropriate Intervention/Exposure (Mediterranean diet, fish intake not quantified)
Coronary Artery Disease, 13:295–300
Rodriguez, 1998 | Consumption of fruit and wine and the decline in cerebrovascular disease mortality in Spain. | Review (not primary studies)
Stroke, 29:1556–1561
Schmidt, 1988 | Antithrombin III and protein C in stable angina pectoris—influence of dietary supplementation with polyunsaturated fatty acids. | No outcomes of interest
Scandinavian Journal of Clinical & Laboratory Investigation, 48:469–473
Simon, 1995 | Serum fatty acids and the risk of coronary heart disease. | Serum composition
American Journal of Epidemiology, 142:469–476
Singh, 1991 | The effect of diet and aspirin on patient outcome after myocardial infarction. | Inappropriate Intervention/Exposure (No omega-3 fatty acid)
Nutrition, 7:125–129
Singh, 1995 | Effect of antioxidant-rich goods on plasma ascorbic acid, cardiac enzymes, and lipid peroxide levels in patients hospitalized with acute myocardial infarction. | Inappropriate Intervention/Exposure (No omega-3 fatty acid)
Journal of the American Dietetic Association, 95:775–780
Stampfer, 2000 | Primary prevention of coronary heart disease in women through diet and lifestyle. | Inappropriate Intervention/Exposure (No omega-3 fatty acid)
New England Journal of Medicine, 343:16–22
Tornwall, 1996 | Effect of serum and dietary fatty acids on the short-term risk of acute myocardial infarction in male smokers. | Serum composition
Nutritional Metabolism and Cardiovascular Diseases, 6:73–80
Vacek, 1989 | Short-term effects of mega-3 fatty acids on exercise stress test parameters, angina and lipoproteins. | No outcome of interest; Dose>5 g/d
Biomedicine & Pharmacotherapy, 43:375–79
Watts, 1995 | Relationships between nutrient intake and progression/regression of coronary atherosclerosis as assessed by serial quantitative angiography. | Inappropriate Intervention/Exposure (No omega-3 fatty acid data)
Canadian Journal of Cardiology, 11:110G–114G
Woo, 2002 | Lifestyle factors and health outcomes in elderly Hong Kong chinese aged 70 years and over. | Inappropriate Intervention/Exposure (No fish intake data)
Gerontology, 48:234–240
Yamori, 1994 | Nutritional factors for stroke and major cardiovascular diseases: international epidemiological comparison of dietary prevention. | Inappropriate Intervention/Exposure (No intake data)
Health Reports, 6:22–27
Yli-Jama, 2002 | Serum free fatty acid pattern and risk of myocardial infarction: a case-control study. | Serum level
Journal of Internal Medicine, 251:19–28
Zhang, 1999 | Fish consumption and mortality from all causes, ischemic heart disease, and stroke: an ecological study. | Review (not primary study)
Preventive Medicine, 28:520–529