# Summary Tables

Table 1.1 Estimates of the mean±standard error of the mean (SEM) intake of linoleic acid (LA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), and docosahexaenoic acid (DHA) in the US population, based on analyses of a single 24-hour dietary recall of NHANES III data

Table 1.1 Estimates of the mean±standard error of the mean (SEM) intake of linoleic acid (LA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), and docosahexaenoic acid (DHA) in the US population, based on analyses of a single 24-hour dietary recall of NHANES III data

| Grams/day | | % Kcal/day
| Mean±SEM | Median (range)^a^ | Mean±SEM | Median (range) ^a^
LA (18:2 n-6) | 14.1±0.2 | 9.9 (0 – 168) | 5.79±0.05 | 5.30 (0 – 39.4)
ALA (18:3 n-3) | 1.33±0.02 | 0.90 (0 – 17) | 0.55±0.004 | 0.48 (0 – 4.98)
EPA (20:5 n-3) | 0.04±0.003 | 0.00 (0 – 4.1) | 0.02±0.001 | 0.00 (0 – 0.61)
DHA (22:6 n-3) | 0.07±0.004 | 0.00 (0 – 7.8) | 0.03±0.002 | 0.00 (0 –2.86)

a The distributions are not adjusted for the over-sampling of Mexican Americans, non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old in the NHANES III dataset.

Table 1.2 Mean, range, and median usual daily intakes of linoleic acid (LA), total omega-3 fatty acids (n-3 FA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA) and docosahexaenoic acid (DHA) in the US population, based on CSFII data (1994-1996, 1998)

Table 1.2 Mean, range, and median usual daily intakes of linoleic acid (LA), total omega-3 fatty acids (n-3 FA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA) and docosahexaenoic acid (DHA) in the US population, based on CSFII data (1994-1996, 1998)

| Grams/day
| Mean±SEM | Median±SEM
LA (18:2 n-6) | 13.0±0.1 | 12.0±0.1
Total n-3 FA | 1.40±0.01 | 1.30±0.01
ALA (18:3 n-3) | 1.30±0.01 | 1.21±0.01
EPA (20:5 n-3) | 0.028 | 0.004
DPA (22:5 n-3) | 0.013 | 0.005
DHA (22:6 n-3) | 0.057±0.018 | 0.046±0.013

Table 1.3 The omega-3 fatty acid content, in grams per 100 g food serving, of a representative sample of commonly consumed fish, shellfish, and fish oils, and nuts and seeds, and plant oils that contain at least 5 g omega-3 fatty acids per 100 g (http://www.nal.usda.gov/fnic/foodcomp).

Table 1.3 The omega-3 fatty acid content, in grams per 100 g food serving, of a representative sample of commonly consumed fish, shellfish, and fish oils, and nuts and seeds, and plant oils that contain at least 5 g omega-3 fatty acids per 100 g (http://www.nal.usda.gov/fnic/foodcomp)

Food item | EPA | DHA | ALA
[underlined: Fish (Raw ^a^)]
Anchovy, European | 0.6 | 0.9 | -
Bass, Freshwater, Mixed Sp. | 0.2 | 0.4 | 0.1
Bass, Striped | 0.2 | 0.6 | trace
Bluefish | 0.2 | 0.5 | -
Carp | 0.2 | 0.1 | 0.3
Catfish, Channel | trace | 0.2 | 0.1
Cod, Atlantic | trace | 0.1 | trace
Cod, Pacific | trace | 0.1 | trace
Eel, Mixed Sp. | trace | trace | 0.4
Flounder & Sole Sp. | trace | 0.1 | trace
Grouper, Mixed Sp. | trace | 0.2 | trace
Haddock | trace | 0.1 | trace
Halibut, Atlantic and Pacific | trace | 0.3 | trace
Halibut, Greenland | 0.5 | 0.4 | trace
Herring, Atlantic | 0.7 | 0.9 | 0.1
Herring, Pacific | 1.0 | 0.7 | trace
Mackerel, Atlantic | 0.9 | 1.4 | 0.2
Mackerel, Pacific and Jack | 0.6 | 0.9 | trace
Mullet, Striped | 0.2 | 0.1 | trace
Ocean Perch, Atlantic | trace | 0.2 | trace
Pike, Northern | trace | trace | trace
Pike, Walleye | trace | 0.2 | trace
Pollock, Atlantic | trace | 0.4 | -
Pompano, Florida | 0.2 | 0.4 | -
Roughy, Orange | trace | - | trace
Salmon, Atlantic, Farmed | 0.6 | 1.3 | trace
Salmon, Atlantic, Wild | 0.3 | 1.1 | 0.3
Salmon, Chinook | 1.0 | 0.9 | trace
Salmon, Chinook, Smoked ^b^ | 0.2 | 0.3 | -
Salmon, Chum | 0.2 | 0.4 | trace
Salmon, Coho, Farmed | 0.4 | 0.8 | trace
Salmon, Coho, Wild | 0.4 | 0.7 | 0.2
Salmon, Pink | 0.4 | 0.6 | trace
Salmon, Pink, Canned ^c^ | 0.9 | 0.8 | trace
Salmon, Sockeye | 0.6 | 0.7 | trace
Sardine, Atlantic, Canned in Oil ^d^ | 0.5 | 0.5 | 0.5
Seabass, Mixed Sp. | 0.2 | 0.4 | -
Seatrout, Mixed Sp. | 0.2 | 0.2 | trace
Shad, American | 1.1 | 1.3 | 0.2
Shark, Mixed Sp. | 0.3 | 0.5 | trace
Snapper, Mixed Sp. | trace | 0.3 | trace
Swordfish | 0.1 | 0.5 | 0.2
Trout, Mixed Sp. | 0.2 | 0.5 | 0.2
Trout, Rainbow, Farmed | 0.3 | 0.7 | trace
Trout, Rainbow, Wild | 0.2 | 0.4 | 0.1
Tuna, Fresh, Bluefin | 0.3 | 0.9 | -
Tuna, Fresh, Skipjack | trace | 0.2 | -
Tuna, Fresh, Yellowfin | trace | 0.2 | trace
Tuna, Light, Canned in Oil ^e^ | trace | 0.1 | trace
Tuna, Light, Canned in Water ^e^ | trace | 0.2 | trace
Tuna, White, Canned in Oil ^e^ | trace | 0.2 | 0.2
Tuna, White, Canned in Water ^e^ | 0.2 | 0.6 | trace
Whitefish, Mixed Sp. | 0.3 | 0.9 | 0.2
Whitefish, Mixed Sp., Smoked | trace | 0.2 | -
Wolffish, Atlantic | 0.4 | 0.3 | trace
[underlined: Shellfish (Raw)]
Abalone, Mixed Sp. | trace | - | -
Clam, Mixed Sp. | trace | trace | trace
Crab, Blue | 0.2 | 0.2 | -
Crayfish, Mixed Sp., Farmed | trace | 0.1 | trace
Lobster, Northern | - | - | -
Mussel, Blue | 0.2 | 0.3 | trace
Oyster, Eastern, Farmed | 0.2 | 0.2 | trace
Oyster, Eastern, Wild | 0.3 | 0.3 | trace
Oyster, Pacific | 0.4 | 0.3 | trace
Scallop, Mixed Sp. | trace | 0.1 | -
Shrimp, Mixed Sp. | 0.3 | 0.2 | trace
Squid, Mixed Sp. | 0.1 | 0.3 | trace
[underlined: Fish Oils]
Cod Liver Oil | 6.9 | 11.0 | 0.9
Herring Oil | 6.3 | 4.2 | 0.8
Menhaden Oil | 13.2 | 8.6 | 1.5
Salmon Oil | 13.0 | 18.2 | 1.1
Sardine Oil | 10.1 | 10.7 | 1.3
[underlined: Nuts and Seeds]
Butternuts, Dried | - | - | 8.7
Flaxseed | | | 18.1
Walnuts, English | - | - | 9.1
[underlined: Plant Oils]
Canola (Rapeseed) | - | - | 9.3
Flaxseed Oil | - | - | 53.3
Soybean Lecithin Oil | - | - | 5.1
Soybean Oil | - | - | 6.8
Walnut Oil | - | - | 10.4
Wheatgerm Oil | - | - | 6.9

trace = <0.1; - = 0 or no data; Sp. = species.

a Except as indicated.

b Lox.

c Solids with bone and liquid.

d Drained solids with bone.

e Drained solids.

Table 3.1 The Sociodemographic Characteristics of the Participants in the Third National Health and Nutrition Survey, 1988-94

Table 3.1 The Sociodemographic Characteristics of the Participants in the Third National Health and Nutrition Survey, 1988-94

Sub-populations | Number of participants | Percent
Gender
- Male | 16,295 | 48%
- Female | 17,699 | 52%
Race/ethnicity
- Non-Hispanic white | 13,085 | 38%
- Non-Hispanic black | 9,627 | 28%
- Mexican-American | 9,751 | 29%
- Other | 1,531 | 5%
Age groups*
- 2–6 months | 1,076 | 3%
- 7–12 months | 1,129 | 3%
- 1–3 years | 3,189 | 9%
- 4–8 years | 4,271 | 13%
- 9–13 years | 2,744 | 8%
- 14–18 years | 2,183 | 6%
- 19–30 years | 4,550 | 13%
- 31–50 years | 6,307 | 19%
- 51–70 years | 4,678 | 14%
- 71+years | 3,848 | 11%
Urbanization of living areas
- Metro areas | 17,183 | 51%
- Non-metro areas | 16,811 | 49%
Poverty Income Ratio ^†^
- = 1.3 | 13,335 | 39%
- > 1.3 | 18,509 | 54%

* Contain small number of missing data.

† 6% (2,150) participants refused to report their income or income category.

Table 3.2 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Table 3.2 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Age/Gender Groups | NHANES III (1988-94) | | | | CSFII (1994-1996, 1998)
| Sample Size | Population Size | Mean Intake | | Sample Size | Mean Intake (g/day)
| | | (g/day) | (%kcal/day)
Both sexes, 0–6 months¶ | 793 | 1,323,807 | 6.90 | 8.32 | 596 | 6.70
SEM | | | 0.15 | 0.14 | | 0.10
Both sexes, 7–12 months | 915 | 1,625,559 | 5.91 | 5.28 | 530 | 6.90
SEM | | | 0.14 | 0.12 | | 0.20
Both sexes, 1–3 y | 2,734 | 8,724,437 | 7.27 | 4.69 | 3,949 | 7.30
SEM | | | 0.14 | 0.07 | | 0.10
Both sexes, 4–8 y | 3,673 | 17,409,438 | 10.31 | 5.16 | 3,935 | 10.10
SEM | | | 0.28 | 0.11 | | 0.10
M, 9–13 y | 1,251 | 9,113,670 | 13.79 | 5.09 | 595 | 13.40
SEM | | | 0.48 | 0.11 | | 0.40
M, 14–18 y | 925 | 8,908,287 | 18.12 | 5.37 | 474 | 16.60
SEM | | | 0.92 | 0.17 | | 0.50
M, 19–30 y | 1,902 | 21,918,936 | 19.34 | 5.60 | 920 | 17.60
SEM | | | 0.59 | 0.13 | | 0.50
M, 31–50 y | 2,579 | 35,368,777 | 18.90 | 5.95 | 1,806 | 17.00
SEM | | | 0.50 | 0.09 | | 0.30
M, 51–70 y | 1,934 | 18,623,500 | 15.37 | 5.86 | 1,680 | 15.30
SEM | | | 0.34 | 0.09 | | 0.30
M, 71+ y | 1,296 | 6,723,233 | 12.42 | 5.69 | 722 | 12.20
SEM | | | 0.29 | 0.09 | | 0.40
F, 9–13 y | 1,261 | 8,888,987 | 12.23 | 5.56 | 606 | 11.00
SEM | | | 0.41 | 0.14 | | 0.30
F, 14–18 y | 1,062 | 8,962,331 | 13.61 | 5.98 | 449 | 11.70
SEM | | | 0.54 | 0.19 | | 0.50
F, 19–30 y | 2,181 | 22,809,351 | 13.59 | 6.13 | 808 | 11.80
SEM | | | 0.36 | 0.11 | | 0.30
F, 31–50 y | 3,097 | 37,172,408 | 13.44 | 6.24 | 1,690 | 11.70
SEM | | | 0.26 | 0.10 | | 0.20
F, 51–70 y | 2,075 | 20,961,630 | 10.62 | 5.82 | 1,605 | 11.00
SEM | | | 0.29 | 0.13 | | 0.20
F, 71+ y | 1,421 | 9,687,597 | 9.54 | 5.92 | 670 | 9.30
SEM | | | 0.21 | 0.10 | | 0.30
All individuals | 29,099 | 238,221,947 | 14.13 | 5.79 | 21,159 | 13.00
SEM | | | 0.20 | 0.05 | | 0.10

§ All NHANES III variance estimates were based on Taylor Series (WR) method.

¶ NHANES III data consisted of individuals ≥ 2 months and excluded nursing infants and children.

Table 3.3 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Table 3.3 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Age/Gender Groups | Non-Hispanic White | | | Non-Hispanic Black | | | Mexican-American | | | Other
| Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM
Both Sexes, Total | 10,634 | 14.27 | 0.24 | 8,510 | 14.23 | 0.20 | 8,626 | 14.07 | 0.20 | 1,329 | 12.77 | 0.48
Both sexes, 2–6 months | 444 | 6.45 | 0.18 | 156 | 7.50 | 0.40 | 124 | 8.03 | 0.44 | 69 | 8.03 | 0.44
Both sexes, 7–12 months | 488 | 5.36 | 0.14 | 156 | 7.53 | 0.47 | 181 | 6.58 | 0.38 | 90 | 6.58 | 0.38
Both sexes, 1–3 y | 854 | 7.08 | 0.20 | 784 | 8.78 | 0.19 | 962 | 7.78 | 0.18 | 134 | 7.78 | 0.18
Both sexes, 4–8 y | 989 | 10.19 | 0.45 | 1,179 | 11.54 | 0.25 | 1,322 | 10.38 | 0.29 | 183 | 10.38 | 0.29
Both sexes, 9–13 y | 646 | 13.14 | 0.40 | 886 | 13.23 | 0.39 | 881 | 13.21 | 0.55 | 99 | 13.21 | 0.55
Both sexes, 14–18 y | 517 | 15.58 | 0.81 | 714 | 17.07 | 0.54 | 646 | 14.87 | 0.56 | 110 | 14.87 | 0.56
Both sexes, 19–30 y | 1,065 | 16.31 | 0.47 | 1,314 | 17.68 | 0.44 | 1,533 | 16.75 | 0.34 | 171 | 16.75 | 0.34
Both sexes, 31–50 y | 1,894 | 16.45 | 0.39 | 1,869 | 15.54 | 0.32 | 1,669 | 16.07 | 0.32 | 244 | 16.07 | 0.32
Both sexes, 51–70 y | 1,836 | 13.19 | 0.29 | 1,024 | 11.05 | 0.35 | 985 | 12.18 | 0.39 | 164 | 12.18 | 0.39
Both sexes, 71+ y | 1,901 | 10.91 | 0.21 | 428 | 9.44 | 0.51 | 323 | 9.79 | 0.55 | 65 | 9.79 | 0.55
M, Total | 5,028 | 16.70 | 0.34 | 4,001 | 15.87 | 0.25 | 4,264 | 15.84 | 0.25 | 628 | 14.40 | 0.66
M, 2–6 months | 229 | 6.52 | 0.23 | 81 | 7.57 | 0.41 | 66 | 8.64 | 0.55 | 32 | 8.64 | 0.55
M, 7–12 months | 239 | 5.38 | 0.19 | 78 | 7.55 | 0.71 | 96 | 6.09 | 0.44 | 37 | 6.09 | 0.44
M, 1–3 y | 421 | 7.55 | 0.25 | 396 | 9.23 | 0.27 | 478 | 8.04 | 0.29 | 81 | 8.04 | 0.29
M, 4–8 y | 491 | 11.10 | 0.72 | 580 | 11.71 | 0.36 | 627 | 10.78 | 0.45 | 102 | 10.78 | 0.45
M, 9–13 y | 320 | 14.07 | 0.64 | 440 | 13.08 | 0.49 | 440 | 13.11 | 0.65 | 51 | 13.11 | 0.65
M, 14–18 y | 228 | 18.14 | 1.13 | 333 | 18.82 | 0.74 | 320 | 16.13 | 0.74 | 44 | 16.13 | 0.74
M, 19–30 y | 460 | 19.85 | 0.76 | 583 | 20.33 | 0.73 | 776 | 19.27 | 0.55 | 83 | 19.27 | 0.55
M, 31–50 y | 853 | 19.22 | 0.61 | 826 | 18.14 | 0.49 | 800 | 18.57 | 0.38 | 100 | 18.57 | 0.38
M, 51–70 y | 895 | 15.70 | 0.41 | 483 | 12.46 | 0.61 | 488 | 14.72 | 0.51 | 68 | 14.72 | 0.51
M, 71+ | 892 | 12.75 | 0.29 | 201 | 10.35 | 0.69 | 173 | 10.99 | 0.84 | 30 | 10.99 | 0.84
F, Total | 5,606 | 11.96 | 0.19 | 4,509 | 12.82 | 0.21 | 4,362 | 12.20 | 0.21 | 701 | 11.23 | 0.61
F, 2–6 months | 215 | 6.37 | 0.27 | 75 | 7.41 | 0.52 | 58 | 7.28 | 0.46 | 37 | 7.28 | 0.46
F, 7–12 months | 249 | 5.33 | 0.24 | 78 | 7.52 | 0.42 | 85 | 7.16 | 0.60 | 53 | 7.16 | 0.60
F, 1–3 y | 433 | 6.60 | 0.25 | 388 | 8.34 | 0.27 | 484 | 7.50 | 0.23 | 53 | 7.50 | 0.23
F, 4–8 y | 498 | 9.15 | 0.32 | 599 | 11.36 | 0.35 | 695 | 10.01 | 0.37 | 81 | 10.01 | 0.37
F, 9–13 y | 326 | 12.17 | 0.55 | 446 | 13.39 | 0.55 | 441 | 13.32 | 0.72 | 48 | 13.32 | 0.72
F, 14–18 y | 289 | 12.88 | 0.70 | 381 | 15.32 | 0.67 | 326 | 13.58 | 0.74 | 66 | 13.58 | 0.74
F, 19–30 y | 605 | 13.03 | 0.43 | 731 | 15.48 | 0.51 | 757 | 13.63 | 0.35 | 88 | 13.63 | 0.35
F, 31–50 y | 1,041 | 13.71 | 0.30 | 1,043 | 13.38 | 0.35 | 869 | 13.50 | 0.38 | 144 | 13.50 | 0.38
F, 51–70 y | 941 | 10.93 | 0.37 | 541 | 10.00 | 0.38 | 497 | 9.99 | 0.51 | 96 | 9.99 | 0.51
F, 71+ | 1,009 | 9.65 | 0.22 | 227 | 8.84 | 0.66 | 150 | 8.61 | 0.75 | 35 | 8.61 | 0.75

Table 3.4 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Alpha Linolenic Acid (ALA, 18:3 n-3), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Table 3.4 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Alpha Linolenic Acid (ALA, 18:3 n-3), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Age/Gender Groups | NHANES III (1988-94) | | | | CSFII (1994-1996, 1998)
| Sample Size | Population Size | Mean Intake | | Sample Size | Mean Intake
| | | (g/day) | (%kcal/day) | | (g/day)
Both sexes, 0–6 months^¶^ | 793 | 1,323,807 | 0.62 | 0.74 | 596 | 0.72
SEM | | | 0.02 | 0.021 | | 0.02
Both sexes, 7–12 months | 915 | 1,625,559 | 0.60 | 0.54 | 530 | 0.77
SEM | | | 0.02 | 0.013 | | 0.02
Both sexes, 1–3 y | 2,734 | 8,724,437 | 0.73 | 0.48 | 3,949 | 0.77
SEM | | | 0.01 | 0.005 | | 0.01
Both sexes, 4–8 y | 3,673 | 17,409,438 | 0.98 | 0.49 | 3,935 | 0.97
SEM | | | 0.03 | 0.010 | | 0.01
M, 9–13 y | 1,251 | 9,113,670 | 1.29 | 0.49 | 595 | 1.26
SEM | | | 0.05 | 0.009 | | 0.04
M, 14–18 y | 925 | 8,908,287 | 1.73 | 0.52 | 474 | 1.65
SEM | | | 0.08 | 0.018 | | 0.05
M, 19–30 y | 1,902 | 21,918,936 | 1.80 | 0.52 | 920 | 1.66
SEM | | | 0.05 | 0.011 | | 0.05
M, 31–50 y | 2,579 | 35,368,777 | 1.76 | 0.57 | 1,806 | 1.73
SEM | | | 0.04 | 0.009 | | 0.04
M, 51–70 y | 1,934 | 18,623,500 | 1.46 | 0.57 | 1,680 | 1.55
SEM | | | 0.03 | 0.010 | | 0.03
M, 71+ y | 1,296 | 6,723,233 | 1.18 | 0.55 | 722 | 1.26
SEM | | | 0.03 | 0.011 | | 0.04
F, 9–13 y | 1,261 | 8,888,987 | 1.18 | 0.54 | 606 | 1.03
SEM | | | 0.04 | 0.014 | | 0.02
F, 14–18 y | 1,062 | 8,962,331 | 1.21 | 0.53 | 449 | 1.13
SEM | | | 0.05 | 0.016 | | 0.05
F, 19–30 y | 2,181 | 22,809,351 | 1.25 | 0.56 | 808 | 1.18
SEM | | | 0.04 | 0.012 | | 0.03
F, 31–50 y | 3,097 | 37,172,408 | 1.25 | 0.58 | 1,690 | 1.19
SEM | | | 0.03 | 0.009 | | 0.02
F, 51–70 y | 2,075 | 20,961,630 | 1.04 | 0.57 | 1,605 | 1.13
SEM | | | 0.03 | 0.013 | | 0.02
F, 71+ y | 1,421 | 9,687,597 | 0.92 | 0.58 | 670 | 0.97
SEM | | | 0.02 | 0.011 | | 0.03
All individuals | 29,099 | 238,221,947 | 1.33 | 0.55 | 21,159 | 1.30
SEM | | | 0.02 | 0.004 | | 0.01

§ All NHANES III variance estimates were based on Taylor Series (WR) method.

¶ NHANES III data consisted of individuals = 2 months and excluded nursing infants and children.

Table 3.5 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Alpha Linolenic Acid (ALA, 18:3 n-3) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Table 3.5 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Alpha Linolenic Acid (ALA, 18:3 n-3) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Age/Gender Groups | Non-Hispanic White | | | Non-Hispanic Black | | | Mexican-American | | | Other
| Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM
Both Sexes, Total | 10,634 | 1.37 | 0.02 | 8,510 | 1.27 | 0.02 | 8,626 | 1.20 | 0.02 | 1,329 | 1.12 | 0.04
Both sexes, 2–6 months | 444 | 0.55 | 0.02 | 156 | 0.71 | 0.06 | 124 | 0.81 | 0.07 | 69 | 0.76 | 0.08
Both sexes, 7–12 months | 488 | 0.54 | 0.02 | 156 | 0.76 | 0.04 | 181 | 0.65 | 0.05 | 90 | 0.60 | 0.04
Both sexes, 1–3 y | 854 | 0.73 | 0.02 | 784 | 0.82 | 0.02 | 962 | 0.73 | 0.01 | 134 | 0.64 | 0.03
Both sexes, 4–8 y | 989 | 0.98 | 0.04 | 1,179 | 1.04 | 0.02 | 1,322 | 0.97 | 0.03 | 183 | 0.87 | 0.04
Both sexes, 9–13 y | 646 | 1.28 | 0.05 | 886 | 1.18 | 0.03 | 881 | 1.19 | 0.04 | 99 | 1.06 | 0.08
Both sexes, 14–18 y | 517 | 1.48 | 0.07 | 714 | 1.53 | 0.06 | 646 | 1.30 | 0.06 | 110 | 1.42 | 0.19
Both sexes, 19–30 y | 1,065 | 1.56 | 0.04 | 1,314 | 1.56 | 0.04 | 1,533 | 1.41 | 0.03 | 171 | 1.27 | 0.08
Both sexes, 31–50 y | 1,894 | 1.57 | 0.04 | 1,869 | 1.38 | 0.03 | 1,669 | 1.30 | 0.03 | 244 | 1.17 | 0.08
Both sexes, 51–70 y | 1,836 | 1.28 | 0.03 | 1,024 | 1.02 | 0.03 | 985 | 1.06 | 0.04 | 164 | 1.06 | 0.08
Both sexes, 71+ y | 1,901 | 1.05 | 0.02 | 428 | 0.87 | 0.05 | 323 | 0.83 | 0.04 | 65 | 0.88 | 0.15
M, Total | 5,028 | 1.60 | 0.03 | 4,001 | 1.43 | 0.02 | 4,264 | 1.36 | 0.02 | 628 | 1.29 | 0.06
M, 2–6 months | 229 | 0.56 | 0.03 | 81 | 0.73 | 0.02 | 66 | 0.91 | 0.08 | 32 | 0.77 | 0.09
M, 7–12 months | 239 | 0.55 | 0.02 | 78 | 0.79 | 0.06 | 96 | 0.63 | 0.06 | 37 | 0.66 | 0.06
M, 1–3 y | 421 | 0.75 | 0.02 | 396 | 0.85 | 0.07 | 478 | 0.74 | 0.02 | 81 | 0.69 | 0.03
M, 4–8 y | 491 | 1.08 | 0.07 | 580 | 1.08 | 0.02 | 627 | 0.98 | 0.03 | 102 | 0.87 | 0.06
M, 9–13 y | 320 | 1.35 | 0.07 | 440 | 1.21 | 0.03 | 440 | 1.21 | 0.07 | 51 | 1.12 | 0.08
M, 14–18 y | 228 | 1.73 | 0.09 | 333 | 1.70 | 0.04 | 320 | 1.50 | 0.07 | 44 | 2.00 | 0.46
M, 19–30 y | 460 | 1.89 | 0.07 | 583 | 1.80 | 0.07 | 776 | 1.62 | 0.06 | 83 | 1.35 | 0.09
M, 31–50 y | 853 | 1.84 | 0.05 | 826 | 1.63 | 0.06 | 800 | 1.49 | 0.04 | 100 | 1.38 | 0.15
M, 51–70 y | 895 | 1.51 | 0.04 | 483 | 1.11 | 0.05 | 488 | 1.26 | 0.04 | 68 | 1.34 | 0.11
M, 71+ | 892 | 1.22 | 0.04 | 201 | 0.97 | 0.07 | 173 | 0.92 | 0.07 | 30 | 0.94 | 0.23
F, Total | 5,606 | 1.15 | 0.02 | 4,509 | 1.14 | 0.02 | 4,326 | 1.05 | 0.02 | 701 | 0.97 | 0.04
F, 2–6 months | 215 | 0.54 | 0.03 | 75 | 0.69 | 0.08 | 58 | 0.68 | 0.07 | 37 | 0.75 | 0.10
F, 7–12 months | 249 | 0.54 | 0.03 | 78 | 0.72 | 0.05 | 85 | 0.68 | 0.05 | 53 | 0.56 | 0.05
F, 1–3 y | 433 | 0.71 | 0.02 | 388 | 0.78 | 0.03 | 484 | 0.72 | 0.02 | 53 | 0.58 | 0.05
F, 4–8 y | 498 | 0.86 | 0.02 | 599 | 1.00 | 0.02 | 695 | 0.96 | 0.04 | 81 | 0.87 | 0.07
F, 9–13 y | 326 | 1.22 | 0.06 | 446 | 1.15 | 0.04 | 441 | 1.16 | 0.05 | 48 | 0.99 | 0.17
F, 14–18 y | 289 | 1.22 | 0.07 | 381 | 1.36 | 0.08 | 326 | 1.10 | 0.05 | 66 | 1.03 | 0.09
F, 19–30 y | 605 | 1.25 | 0.04 | 731 | 1.35 | 0.05 | 757 | 1.15 | 0.03 | 88 | 1.16 | 0.16
F, 31–50 y | 1,041 | 1.30 | 0.03 | 1,043 | 1.18 | 0.03 | 869 | 1.10 | 0.03 | 144 | 1.01 | 0.08
F, 51–70 y | 941 | 1.07 | 0.04 | 541 | 0.95 | 0.03 | 497 | 0.90 | 0.04 | 96 | 0.79 | 0.08
F, 71+ | 1,009 | 0.94 | 0.02 | 227 | 0.80 | 0.05 | 150 | 0.75 | 0.06 | 35 | 0.81 | 0.12

Table 3.6 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Eicosapentaenoic Acid (EPA, 20:5 n-3), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Table 3.6 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Eicosapentaenoic Acid (EPA, 20:5 n-3), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Age/Gender Groups | NHANES III (1988-94) | | | | CSFII (1994-1996, 1998) ‡
| Sample Size | Population Size | Mean Intake | | Sample Size | Mean Intake
| | | (g/day) | (%kcal/day) | | (g/day)
Both sexes, 0–6 months ^¶^ | 793 | 1,323,807 | - | - | 578 | <0.0005
SEM
Both sexes, 7–12 months | 915 | 1,625,559 | † | † | 487 | 0.002
SEM
Both sexes, 1–3 y | 2,734 | 8,724,437 | † | † | 3,777 | 0.008
SEM
Both sexes, 4–8 y | 3,673 | 17,409,438 | 0.010 | 0.010 | 3,769 | 0.012
SEM | | | 0.002 | 0.002
M, 9–13 y | 1,251 | 9,113,670 | † | † | 569 | 0.016
SEM
M, 14–18 y | 925 | 8,908,287 | † | † | 446 | 0.018
SEM
M, 19–30 y | 1,902 | 21,918,936 | 0.040 | † | 854 | 0.030
SEM | | | 0.005
M, 31–50 y | 2,579 | 35,368,777 | 0.060 | 0.02 | 1,684 | 0.038
SEM | | | 0.007 | 0.003
M, 51–70 y | 1,934 | 18,623,500 | 0.050 | 0.02 | 1,606 | 0.046
SEM | | | 0.005 | 0.002
M, 71+ y | 1,296 | 6,723,233 | 0.050 | 0.02 | 674 | 0.049
SEM | | | 0.006 | 0.003
F, 9–13 y | 1,261 | 8,888,987 | † | † | 580 | 0.012
SEM
F, 14–18 y | 1,062 | 8,962,331 | 0.020 | † | 436 | 0.016
SEM | | | 0.003
F, 19–30 y | 2,181 | 22,809,351 | 0.030 | 0.01 | 760 | 0.024
SEM | | | 0.005 | 0.002
F, 31–50 y | 3,097 | 37,172,408 | 0.040 | 0.01 | 1,614 | 0.027
SEM | | | 0.005 | 0.002
F, 51–70 y | 2,075 | 20,961,630 | 0.040 | 0.03 | 1,539 | 0.035
SEM | | | 0.005 | 0.003
F, 71+ y | 1,421 | 9,687,597 | 0.030 | † | 623 | 0.029
SEM | | | 0.006
All individuals | 29,099 | 238,221,947 | 0.040 | 0.02 | 20,108 | 0.03
SEM | | | 0.003 | 0.001

§All NHANES III variance estimates were based on Taylor Series (WR) method.

‡EPA estimates of CSFII (1994-96, 98) in the IOM report were calculated using SAS PROC UNIVERIATE, not via JACKKNIFE replication method. SEM data was not available in IOM report.

¶NHANES III data consisted of individuals = 2 months and excluded nursing infants and children. Distribution of EPA is very skewed; means and standard errors of the means should be used and interpreted with caution.

- estimate = 0;

†Indicates a statistic that is potentially unreliable because the ratio of the SEM to the estimate times 100 > 20%.

Table 3.7 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Eicosapentaenoic Acid (EPA, 20:5 n-3) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Table 3.7 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Eicosapentaenoic Acid (EPA, 20:5 n-3) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Age/Gender Groups | Non-Hispanic White | | | Non-Hispanic Black | | | Mexican-American | | | Other
| Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM
Both Sexes, Total | 10,634 | 0.03 | 0.003 | 8,510 | 0.05 | 0.002 | 8,626 | 0.02 | 0.003 | 1,329 | 0.06 | 0.012
Both sexes, 2–6 months | 444 | - | | 156 | - | | 124 | - | | 69 | †
Both sexes, 7–12 months | 488 | † | | 156 | † | 0.001 | 181 | † | | 90 | †
Both sexes, 1–3 y | 854 | 0.01 | 0.001 | 784 | 0.01 | 0.001 | 962 | † | | 134 | †
Both sexes, 4–8 y | 989 | † | | 1,179 | 0.01 | 0.002 | 1,322 | 0.01 | 0.002 | 183 | †
Both sexes, 9–13 y | 646 | † | | 886 | 0.02 | 0.004 | 881 | † | | 99 | †
Both sexes, 14–18 years | 517 | † | | 714 | † | | 646 | † | | 110 | †
Both sexes, 19–30 y | 1,065 | 0.03 | 0.005 | 1,314 | 0.05 | 0.004 | 1,533 | 0.03 | 0.004 | 171 | †
Both sexes, 31–50 y | 1,894 | 0.04 | 0.005 | 1,869 | 0.07 | 0.008 | 1,669 | 0.04 | 0.007 | 244 | †
Both sexes, 51–70 y | 1,836 | 0.04 | 0.004 | 1,024 | 0.06 | 0.006 | 985 | 0.03 | 0.004 | 164 | †
Both sexes, 71+ y | 1,901 | 0.03 | 0.003 | 428 | † | | 323 | † | | 65 | †
M, Total | 5,028 | 0.04 | 0.004 | 4,001 | 0.05 | 0.005 | 4,264 | 0.03 | 0.004 | 628 | 0.06 | 0.010
M, 2–6 months | 229 | - | | 81 | - | | 66 | - | | 32 | †
M, 7–12 months | 239 | † | | 78 | † | | 96 | † | | 37 | †
M, 1–3 y | 421 | 0.01 | 0.002 | 396 | 0.01 | 0.001 | 478 | † | 0.001 | 81 | †
M, 4–8 y | 491 | † | | 580 | 0.02 | 0.003 | 627 | 0.01 | 0.002 | 102 | †
M, 9–13 y | 320 | † | | 440 | 0.02 | 0.004 | 440 | † | | 51 | †
M, 14–18 y | 228 | † | | 333 | † | | 320 | † | | 44 | †
M, 19–30 y | 460 | 0.04 | 0.008 | 583 | 0.05 | 0.008 | 776 | 0.03 | 0.006 | 83 | 0.06 | 0.011
M, 31–50 y | 853 | 0.06 | 0.009 | 826 | 0.09 | 0.015 | 800 | † | | 100 | †
M, 51–70 y | 895 | 0.05 | 0.006 | 483 | 0.07 | 0.013 | 488 | † | | 68 | †
M, 71+ | 892 | 0.05 | 0.006 | 201 | † | | 173 | † | | 30 | †
F, Total | 5,606 | 0.03 | 0.003 | 4,509 | 0.04 | 0.002 | 4,362 | 0.02 | 0.003 | 701 | †
F, 2–6 months | 215 | - | | 75 | - | | 58 | - | | 37 | -
F, 7–12 months | 249 | † | | 78 | - | | 85 | - | | 53 | †
F, 1–3 y | 433 | † | | 388 | † | | 484 | † | | 53 | †
F, 4–8 y | 498 | † | | 599 | † | | 695 | † | | 81 | †
F, 9–13 y | 326 | † | | 446 | † | | 441 | † | | 48 | †
F, 14–18 y | 289 | † | | 381 | † | | 326 | † | | 66 | †
F, 19–30 y | 605 | 0.03 | 0.005 | 731 | 0.04 | 0.005 | 757 | † | | 88 | †
F, 31–50 y | 1,041 | 0.03 | 0.004 | 1,043 | 0.06 | 0.006 | 869 | † | | 144 | †
F, 51–70 y | 941 | 0.04 | 0.005 | 541 | 0.05 | 0.007 | 497 | † | | 96 | †
F, 71+ | 1,009 | 0.02 | 0.003 | 227 | † | | 150 | † | | 35 | †

- estimate = 0; † Indicates a statistic that is potentially unreliable because the ratio of the SEM to the estimate times 100 > 20%.

Table 3.8 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Docosahexaenoic Acid (DHA, 22:6 n-3), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Table 3.8 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Docosahexaenoic Acid (DHA, 22:6 n-3), United States, NHANES III (1988-94) and CSFII (1994-1996, 1998) Data ^§^

Age/Gender Groups | NHANES III (1988-94) | | | | CSFII (1994-1996, 1998)
| Sample Size | Population Size | Mean Intake | | Sample Size | Mean Intake
| | | (g/day) | (%kcal/day) | | (g/day)
Both sexes, 0–6 months ^¶^ | 793 | 1,323,807 | - | † | 596 | <0.0005
SEM | | | | | | 0.001
Both sexes, 7–12 months | 915 | 1,625,559 | † | † | 530 | 0.030
SEM | | | | | | 0.008
Both sexes, 1–3 y | 2,734 | 8,724,437 | 0.020 | 0.01 | 3,949 | 0.032
SEM | | | 0.002 | 0.001 | | 0.001
Both sexes, 4–8 y | 3,673 | 17,409,438 | 0.030 | 0.01 | 3,935 | 0.050
SEM | | | 0.003 | 0.002 | | 0.005
M, 9–13 y | 1,251 | 9,113,670 | 0.030 | 0.01 | 595 | 0.063
SEM | | | 0.005 | 0.002 | | 0.010
M, 14–18 y | 925 | 8,908,287 | † | † | 474 | 0.072
SEM | | | | | | 0.012
M, 19–30 y | 1,902 | 21,918,936 | 0.090 | 0.03 | 920 | 0.079
SEM | | | 0.008 | 0.004 | | 0.006
M, 31–50 y | 2,579 | 35,368,777 | 0.120 | 0.04 | 1,806 | 0.094
SEM | | | 0.012 | 0.005 | | 0.006
M, 51–70 y | 1,934 | 18,623,500 | 0.100 | 0.04 | 1,680 | 0.111
SEM | | | 0.008 | 0.003 | | 0.007
M, 71+ y | 1,296 | 6,723,233 | 0.080 | 0.04 | 722 | 0.128
SEM | | | 0.008 | 0.004 | | 0.019
F, 9–13 y | 1,261 | 8,888,987 | 0.030 | 0.02 | 606 | 0.055
SEM | | | 0.006 | 0.003 | | 0.009
F, 14–18 y | 1,062 | 8,962,331 | 0.030 | 0.02 | 449 | 0.062
SEM | | | 0.004 | 0.002 | | 0.009
F, 19–30 y | 2,181 | 22,809,351 | 0.060 | 0.03 | 808 | 0.067
SEM | | | 0.010 | 0.003 | | 0.006
F, 31–50 y | 3,097 | 37,172,408 | 0.080 | 0.03 | 1,690 | 0.071
SEM | | | 0.009 | 0.004 | | 0.009
F, 51–70 y | 2,075 | 20,961,630 | 0.080 | 0.04 | 1,605 | 0.089
SEM | | | 0.007 | 0.004 | | 0.006
F, 71+ y | 1,421 | 9,687,597 | 0.050 | 0.03 | 670 | 0.077
SEM | | | 0.008 | 0.005 | | 0.010
All individuals | 29,099 | 238,221,947 | 0.070 | 0.03 | 21,159 | 0.057
SEM | | | 0.004 | 0.002 | | 0.018

§All NHANES III variance estimates were based on Taylor Series (WR) method.

¶NHANES III data consisted of individuals = 2 months and excluded nursing infants and children. Distribution of EPA is very skewed; means and standard errors of the means should be used and interpreted with caution.

- estimate = 0

†Indicates a statistic that is potentially unreliable because the ratio of the SEM to the estimate times 100 > 20%.

‡EPA estimates of CSFII (1994-96, 98) in the IOM report were calculated using SAS PROC UNIVERIATE, not via JACKKNIFE replication method. SEM data was not available in IOM report.

Table 3.9 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Docosahexaenoic Acid (DHA, 22:6n-3) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Table 3.9 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Docosahexaenoic Acid (DHA, 22:6n-3) (g/d), United States, NHANES III (1988-94) by Race/Ethnicity Groups

Age/Gender Groups | Non-Hispanic White | | | Non-Hispanic Black | | | Mexican-American | | | Other
| Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM | Sample Size | Mean | SEM
Both Sexes, Total | 10,634 | 0.07 | 0.005 | 8,510 | 0.09 | 0.004 | 8,626 | 0.05 | 0.003 | 1,329 | 0.10 | 0.015
Both sexes, 2–6 months | 444 | † | | 156 | - | | 124 | - | | 69 | -
Both sexes, 7–12 months | 488 | † | | 156 | * | 0.002 | 181 | * | 0.002 | 90 | †
Both sexes, 1–3 y | 854 | † | | 784 | 0.02 | 0.004 | 962 | 0.01 | 0.002 | 134 | †
Both sexes, 4–8 y | 989 | 0.02 | 0.004 | 1,179 | 0.03 | 0.003 | 1,322 | 0.03 | 0.004 | 183 | †
Both sexes, 9–13 y | 646 | 0.03 | 0.004 | 886 | 0.04 | 0.005 | 881 | 0.03 | 0.003 | 99 | †
Both sexes, 14–18 years | 517 | † | | 714 | 0.07 | 0.012 | 646 | 0.03 | 0.004 | 110 | †
Both sexes, 19–30 y | 1,065 | 0.07 | 0.010 | 1,314 | 0.10 | 0.007 | 1,533 | 0.06 | 0.006 | 171 | †
Both sexes, 31–50 y | 1,894 | 0.09 | 0.009 | 1,869 | 0.13 | 0.013 | 1,669 | 0.07 | 0.010 | 244 | †
Both sexes, 51–70 y | 1,836 | 0.08 | 0.006 | 1,024 | 0.10 | 0.008 | 985 | 0.06 | 0.007 | 164 | 0.13 | 0.024
Both sexes, 71+ y | 1,901 | 0.06 | 0.004 | 428 | † | | 323 | 0.04 | 0.008 | 65 | †
M, Total | 5,028 | 0.08 | 0.006 | 4,001 | 0.11 | 0.008 | 4,264 | 0.06 | 0.004 | 628 | 0.10 | 0.012
M, 2–6 months | 229 | † | | 81 | - | | 66 | - | | 32 | -
M, 7–12 months | 239 | † | | 78 | † | | 96 | * | 0.003 | 37 | †
M, 1–3 y | 421 | 0.02 | 0.004 | 396 | 0.02 | 0.003 | 478 | 0.01 | 0.002 | 81 | †
M, 4–8 y | 491 | 0.02 | 0.004 | 580 | 0.03 | 0.004 | 627 | 0.03 | 0.002 | 102 | †
M, 9–13 y | 320 | 0.03 | 0.006 | 440 | 0.05 | 0.006 | 440 | 0.03 | 0.005 | 51 | †
M, 14–18 y | 228 | † | | 333 | 0.08 | 0.017 | 320 | 0.03 | 0.004 | 44 | †
M, 19–30 y | 460 | 0.08 | 0.012 | 583 | 0.13 | 0.014 | 776 | 0.07 | 0.007 | 83 | 0.10 | 0.011
M, 31–50 y | 853 | 0.11 | 0.013 | 826 | 0.18 | 0.025 | 800 | 0.08 | 0.015 | 100 | 0.14 | 0.028
M, 51–70 y | 895 | 0.09 | 0.010 | 483 | 0.12 | 0.015 | 488 | 0.08 | 0.013 | 68 | †
M, 71+ | 892 | 0.08 | 0.009 | 201 | † | | 173 | 0.06 | 0.016 | 30 | †
F, Total | 5,606 | 0.05 | 0.005 | 4,509 | 0.07 | 0.003 | 4,326 | 0.04 | 0.004 | 701 | †
F, 2–6 months | 215 | - | | 75 | - | | 58 | - | | 37 | -
F, 7–12 months | 249 | † | | 78 | * | 0.001 | 85 | * | 0.002 | 53 | †
F, 1–3 y | 433 | † | | 388 | † | | 484 | † | | 53 | †
F, 4–8 y | 498 | 0.03 | 0.006 | 599 | 0.03 | 0.005 | 695 | † | | 81 | †
F, 9–13 y | 326 | 0.03 | 0.006 | 446 | 0.04 | 0.007 | 441 | † | | 48 | †
F, 14–18 y | 289 | 0.03 | 0.005 | 381 | 0.06 | 0.011 | 326 | 0.03 | 0.005 | 66 | †
F, 19–30 y | 605 | 0.06 | 0.012 | 731 | 0.08 | 0.007 | 757 | 0.04 | 0.006 | 88 | †
F, 31–50 y | 1,041 | 0.07 | 0.009 | 1,043 | 0.09 | 0.008 | 869 | 0.06 | 0.009 | 144 | †
F, 51–70 y | 941 | 0.07 | 0.008 | 541 | 0.08 | 0.011 | 497 | 0.04 | 0.006 | 96 | †
F, 71+ | 1,009 | 0.04 | 0.006 | 227 | † | | 150 | † | 0.010 | 35 | †

- estimate = 0;

* Value < 0.001 but greater than 0.

†Indicates a statistic that is potentially unreliable because the ratio of the SEM to the estimate times 100 > 20%.

Table 3.10 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) and Omega-3 PUFAs, United States, NHANES III (1988-94), Adults vs. Youths (Age < 18 y)

Table 3.10 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) and Omega-3 PUFAs, United States, NHANES III (1988-94), Adults vs. Youths (Age < 18 y)

PUFAs | Sample Size | Population Size | Mean | SEM | Design Effect
LA (18:2 n-6) (g/d) †
Total | 29,099 | 238,221,947 | 14.13 | 0.1962 | 9.48
Adults | 16,683 | 175,098,828 | 14.94 | 0.2298 | 7.02
Youths | 12,416 | 63,123,119 | 11.88 | 0.2215 | 6.65
ALA (18:3 n-3) (g/d) †
Total | 29,099 | 238,221,947 | 1.33 | 0.0154 | 6.81
Adults | 16,683 | 175,098,828 | 1.40 | 0.0191 | 5.59
Youths | 12,416 | 63,123,119 | 1.13 | 0.0191 | 5.97
¶ EPA (20:5 n-3) (g/d)
Total | 29,099 | 238,221,947 | 0.04 | 0.0026 | 8.57
Adults | 16,683 | 175,098,828 | 0.04 | 0.0035 | 6.99
Youths | 12,416 | 63,123,119 | 0.01 | 0.0014 | 3.90
¶ DHA (22:6 n-3) (g/d)
Total | 29,099 | 238,221,947 | 0.07 | 0.0044 | 8.69
Adults | 16,683 | 175,098,828 | 0.08 | 0.0058 | 7.40
Youths | 12,416 | 63,123,119 | 0.03 | 0.0031 | 4.18
LA (18:2 n-6) (%kcal/d) †
Total | 29,097 | 238,218,723 | 5.79 | 0.0458 | 7.29
Adults | 16,683 | 175,098,828 | 5.95 | 0.0512 | 5.06
Youths | 12,414 | 63,119,895 | 5.36 | 0.0603 | 6.19
ALA (18:3 n-3) (%kcal/d) †
Total | 29,097 | 238,218,723 | 0.55 | 0.0041 | 5.78
Adults | 16,683 | 175,098,828 | 0.56 | 0.0049 | 4.33
Youths | 12,414 | 63,119,895 | 0.51 | 0.0047 | 4.12
¶ EPA (20:5 n-3) (%kcal/d)
Total | 29,097 | 238,218,723 | 0.02 | 0.0011 | 8.47
Adults | 16,683 | 175,098,828 | 0.02 | 0.0014 | 6.89
Youths | 12,414 | 63,119,895 | 0.01 | 0.0006 | 3.56
¶ DHA (22:6 n-3) (%kcal/d)
Total | 29,097 | 238,218,723 | 0.03 | 0.0019 | 10.67
Adults | 16,683 | 175,098,828 | 0.04 | 0.0025 | 8.52
Youths | 12,414 | 63,119,895 | 0.01 | 0.0010 | 3.97

† P< .001 between groups

¶Distribution of EPA and DHA were very skewed; means and standard errors of the means should be used and interpreted with caution. No test of differences in the mean intakes of EPA, DPA, and DHA between groups was performed.

Table 3.11 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) & Omega-3 PUFAs, United States, NHANES III (1988-94), Males vs. Females

Table 3.11 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) & Omega-3 PUFAs, United States, NHANES III (1988-94), Males vs. Females

PUFAs | Sample Size | Population Size | Mean | SEM | Design Effect
LA (18:2 n-6) (g/d) †
Total | 29,105 | 238,245,897 | 14.13 | 0.1962 | 9.48
Male | 13,923 | 115,778,180 | 16.36 | 0.2841 | 7.48
Female | 15,182 | 122,467,717 | 12.02 | 0.1618 | 5.04
ALA (18:3 n-3) (g/d) †
Total | 29,105 | 238,245,897 | 1.33 | 0.0154 | 6.81
Male | 13,923 | 115,778,180 | 1.54 | 0.0233 | 6.05
Female | 15,182 | 122,467,717 | 1.13 | 0.0134 | 3.84
¶ EPA (20:5 n-3) (g/d)
Total | 29,105 | 238,245,897 | 0.04 | 0.0026 | 8.57
Male | 13,923 | 115,778,180 | 0.04 | 0.0032 | 4.89
Female | 15,182 | 122,467,717 | 0.03 | 0.0031 | 8.34
¶ DHA (22:6 n-3) (g/d)
Total | 29,105 | 238,245,897 | 0.07 | 0.0044 | 8.69
Male | 13,923 | 115,778,180 | 0.08 | 0.0050 | 4.36
Female | 15,182 | 122,467,717 | 0.06 | 0.0051 | 8.11
LA (18:2 n-6) (%kcal/d) †
Total | 29,103 | 238,242,673 | 5.79 | 0.0458 | 7.29
Male | 13,922 | 115,776,672 | 5.65 | 0.0526 | 5.02
Female | 15,181 | 122,466,001 | 5.93 | 0.0606 | 6.22
ALA (18:3 n-3) (%kcal/d) †
Total | 29,103 | 238,242,673 | 0.55 | 0.0041 | 5.78
Male | 13,922 | 115,776,672 | 0.54 | 0.0047 | 4.05
Female | 15,181 | 122,466,001 | 0.56 | 0.0054 | 4.81
¶ EPA (20:5 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.02 | 0.0011 | 8.47
Male | 13,922 | 115,776,672 | 0.02 | 0.0011 | 4.67
Female | 15,181 | 122,466,001 | 0.02 | 0.0014 | 7.40
¶ DHA (22:6 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.03 | 0.0019 | 10.67
Male | 13,922 | 115,776,672 | 0.03 | 0.0020 | 5.19
Female | 15,181 | 122,466,001 | 0.03 | 0.0023 | 9.00

† P< .001 between groups

¶Distribution of EPA and DHA were very skewed; means and standard errors of the means should be used and interpreted with caution. No test of differences in the mean intakes of EPA, DPA, and DHA between groups was performed.

Table 3.12 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2n-6) & Omega-3 PUFAs, United States, NHANES III (1988-94), by Race/Ethnicity groups

Table 3.12 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2n-6) & Omega-3 PUFAs, United States, NHANES III (1988-94), by Race/Ethnicity groups

PUFAs | Sample Size | Population Size | Mean | SEM | Design Effect
LA (18:2 n-6) (g/d)
Total | 29,105 | 238,245,897 | 14.13 | 0.1962 | 9.48
* Non-Hispanic white | 10,634 | 174,119,805 | 14.27 | 0.2354 | 5.05
* Non-Hispanic black | 8,513 | 29,355,656 | 14.23 | 0.1956 | 2.55
* Mexican- American | 8,627 | 14,878,866 | 14.07 | 0.2025 | 2.82
Other | 1,331 | 19,891,569 | 12.77 | 0.4797 | 2.78
ALA (18:3 n-3) (g/d)
Total | 29,105 | 238,245,897 | 1.33 | 0.0154 | 6.81
† Non-Hispanic white | 10,634 | 174,119,805 | 1.37 | 0.0192 | 3.78
* Non-Hispanic black | 8,513 | 29,355,656 | 1.27 | 0.0166 | 2.16
* Mexican- American | 8,627 | 14,878,866 | 1.20 | 0.0168 | 3.04
Other | 1,331 | 19,891,569 | 1.12 | 0.0379 | 2.32
^¶^EPA (20:5 n-3) (g/d)
Total | 29,105 | 238,245,897 | 0.04 | 0.0026 | 8.56
Non-Hispanic white | 10,634 | 174,119,805 | 0.03 | 0.0026 | 3.79
Non-Hispanic black | 8,513 | 29,355,656 | 0.05 | 0.0024 | 1.37
Mexican- American | 8,627 | 14,878,866 | 0.02 | 0.0026 | 4.35
Other | 1,331 | 19,891,569 | 0.06 | 0.0120 | 4.60
^¶^DHA (22:6 n-3) (%kcal/d)
Total | 29,105 | 238,245,897 | 0.07 | 0.0044 | 8.69
Non-Hispanic white | 10,634 | 174,119,805 | 0.07 | 0.0048 | 3.93
Non-Hispanic black | 8,513 | 29,355,656 | 0.09 | 0.0040 | 1.58
Mexican- American | 8,627 | 14,878,866 | 0.05 | 0.0033 | 4.27
Other | 1,331 | 19,891,569 | 0.10 | 0.0153 | 4.21
LA (18:2 n-6) (%kcal/d)
Total | 29,103 | 238,242,673 | 5.79 | 0.0458 | 7.29
* Non-Hispanic white | 10,634 | 174,119,805 | 5.79 | 0.0579 | 4.38
† Non-Hispanic black | 8,512 | 29,353,940 | 5.98 | 0.0592 | 3.42
† Mexican- American | 8,626 | 14,877,359 | 5.93 | 0.0476 | 2.11
Other | 1,331 | 19,891,569 | 5.37 | 0.1279 | 2.48
ALA (18:3 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.55 | 0.0041 | 5.78
† Non-Hispanic white | 10,634 | 174,119,805 | 0.56 | 0.0054 | 3.55
† Non-Hispanic black | 8,512 | 29,353,940 | 0.54 | 0.0051 | 2.77
† Mexican- American | 8,626 | 14,877,359 | 0.52 | 0.0063 | 5.20
Other | 1,331 | 19,891,569 | 0.48 | 0.0106 | 2.23
^¶^EPA (20:5 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.02 | 0.0011 | 8.47
Non-Hispanic white | 10,634 | 174,119,805 | 0.01 | 0.0010 | 3.26
Non-Hispanic black | 8,512 | 29,353,940 | 0.02 | 0.0009 | 1.18
Mexican- American | 8,626 | 14,877,359 | 0.01 | 0.0009 | 3.39
Other | 1,331 | 19,891,569 | 0.03 | 0.0057 | 4.72
^¶^DHA (22:6 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.03 | 0.0019 | 10.67
Non-Hispanic white | 10,634 | 174,119,805 | 0.03 | 0.0019 | 4.20
Non-Hispanic black | 8,512 | 29,353,940 | 0.04 | 0.0016 | 1.63
Mexican- American | 8,626 | 14,877,359 | 0.02 | 0.0013 | 3.60
Other | 1,331 | 19,891,569 | 0.05 | 0.0079 | 4.67

Other race/ethnicity group was the reference group.

* P < .05 compared to the reference group.

† P < .001 compared to the reference group.

¶Distribution of EPA and DHA were very skewed; means and standard errors of the means should be used and interpreted with caution. No test of differences in the mean intakes of EPA, DPA, and DHA between groups was performed.

Table 3.13 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) and Omega-3 PUFAs, United States, NHANES III (1988-94), Metro vs. Non-metro Areas

Table 3.13 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) and Omega-3 PUFAs, United States, NHANES III (1988-94), Metro vs. Non-metro Areas

PUFAs | Sample Size | Population Size | Mean | SEM | Design Effect
LA (18:2 n-6) (g/d)
Total | 29,105 | 238,245,897 | 14.13 | 0.1962 | 9.48
Metro | 14,374 | 114,581,912 | 14.28 | 0.2701 | 8.23
Non-metro | 14,731 | 123,663,985 | 13.99 | 0.2479 | 8.25
ALA (18:3 n-3) (g/d)
Total | 29,105 | 238,245,897 | 1.33 | 0.0154 | 6.81
Metro | 14,374 | 114,581,912 | 1.34 | 0.0250 | 8.28
Non-metro | 14,731 | 123,663,985 | 1.32 | 0.0203 | 6.39
EPA (20:5 n-3) (g/d)
Total | 29,105 | 238,245,897 | 0.04 | 0.0026 | 8.56
Metro | 14,374 | 114,581,912 | 0.04 | 0.0032 | 6.45
Non-metro | 14,731 | 123,663,985 | 0.03 | 0.0040 | 10.49
DHA (22:6 n-3) (g/d)
Total | 29,105 | 238,245,897 | 0.07 | 0.0044 | 8.69
Metro | 14,374 | 114,581,912 | 0.08 | 0.0056 | 5.81
Non-metro | 14,731 | 123,663,985 | 0.06 | 0.0069 | 13.43
LA (18:2 n-6) (%kcal/d)
Total | 29,103 | 238,242,673 | 5.79 | 0.0458 | 7.29
Metro | 14,373 | 114,580,196 | 5.79 | 0.0554 | 5.06
Non-metro | 14,730 | 123,662,477 | 5.79 | 0.0629 | 7.28
ALA (18:3 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.55 | 0.0041 | 5.78
Metro | 14,373 | 114,580,196 | 0.55 | 0.0066 | 6.97
Non-metro | 14,730 | 123,662,477 | 0.55 | 0.0059 | 6.29
^¶^EPA (20:5 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.02 | 0.0011 | 8.47
Metro | 14,373 | 114,580,196 | 0.02 | 0.0014 | 6.39
Non-metro | 14,730 | 123,662,477 | 0.01 | 0.0017 | 10.44
^¶^DHA (22:6 n-3) (%kcal/d)
Total | 29,103 | 238,242,673 | 0.03 | 0.0019 | 10.67
Metro | 14,373 | 114,580,196 | 0.03 | 0.0021 | 5.95
Non-metro | 14,730 | 123,662,477 | 0.03 | 0.0032 | 16.57

¶Distribution of EPA and DHA were very skewed; means and standard errors of the means should be used and interpreted with caution. No test of differences in the mean intakes of EPA, DPA, and DHA between groups was performed.

Table 3.14 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) & Omega-3 PUFAs, United States, NHANES III (1988-94)*, PIR = 1.3 vs. PIR > 1.3

Table 3.14 Means and the Standard Error of the Mean (SEMs) for Usual Daily Intake of Linoleic Acid (LA, 18:2 n-6) & Omega-3 PUFAs, United States, NHANES III (1988-94)*, PIR = 1.3 vs. PIR > 1.3

Poverty Index Ratio (PIR) | Sample Size | Population Size | Mean | SEM | Design Effect
LA (18:2 n-6) (g/d)
Total | 27,482 | 226,488,050 | 14.15 | 0.2015 | 9.48
PIR <= 1.3 | 11,711 | 53,365,381 | 12.85 | 0.2258 | 5.50
PIR > 1.3 | 15,771 | 173,122,669 | 14.55 | 0.2289 | 6.89
ALA (18:3 n-3) (g/d)
Total | 27,482 | 226,488,050 | 1.33 | 0.0160 | 6.88
PIR <= 1.3 | 11,711 | 53,365,381 | 1.19 | 0.0191 | 4.67
PIR > 1.3 | 15,771 | 173,122,669 | 1.38 | 0.0186 | 5.22
^¶^EPA (20:5 n-3) (g/d)
Total | 27,482 | 226,488,050 | 0.04 | 0.0026 | 8.03
PIR <= 1.3 | 11,711 | 53,365,381 | 0.03 | 0.0027 | 4.67
PIR > 1.3 | 15,771 | 173,122,669 | 0.04 | 0.0031 | 6.45
^¶^DHA (22:6 n-3) (g/d)
Total | 27,482 | 226,488,050 | 0.07 | 0.0042 | 7.77
PIR <= 1.3 | 11,711 | 53,365,381 | 0.06 | 0.0056 | 5.65
PIR > 1.3 | 15,771 | 173,122,669 | 0.07 | 0.0050 | 6.15
LA (18:2 n-6) (%kcal/d)
Total | 27,480 | 226,484,827 | 5.79 | 0.0470 | 7.27
PIR <= 1.3 | 11,710 | 53,363,665 | 5.58 | 0.0562 | 4.35
PIR > 1.3 | 15,770 | 173,121,162 | 5.86 | 0.0527 | 5.27
ALA (18:3 n-3) (%kcal/d)
Total | 27,480 | 226,484,827 | 0.55 | 0.0042 | 5.83
PIR <= 1.3 | 11,710 | 53,363,665 | 0.52 | 0.0056 | 4.83
PIR > 1.3 | 15,770 | 173,121,162 | 0.56 | 0.0047 | 4.00
^¶^EPA (20:5 n-3) (%kcal/d)
Total | 27,480 | 226,484,827 | 0.01 | 0.0011 | 7.98
PIR <= 1.3 | 11,710 | 53,363,665 | 0.01 | 0.0009 | 3.09
PIR > 1.3 | 15,770 | 173,121,162 | 0.02 | 0.0013 | 6.68
^¶^DHA (22:6 n-3) (%kcal/d)
Total | 27,480 | 226,484,827 | 0.03 | 0.0019 | 9.97
PIR <= 1.3 | 11,710 | 53,363,665 | 0.02 | 0.0015 | 3.41
PIR > 1.3 | 15,770 | 173,121,162 | 0.03 | 0.0023 | 7.97

* 6% participants refused to report their income or income category.

¶Distribution of EPA and DHA were very skewed; means and standard errors of the means should be used and interpreted with caution. No test of differences in the mean intakes of EPA, DPA, and DHA between groups was performed.

Table 3.15 The Demographic Characteristics of Adult Participants With and Without a History of Cardiovascular Diseases, United States, NHANES III (1988-94) ^§^

Table 3.15 The Demographic Characteristics of Adult Participants With and Without a History of Cardiovascular Diseases, United States, NHANES III (1988-94) ^§^

Gender and Race/Ethnicity Groups | People With a History of CVD | | People Without a History of CVD
| Sample Size | Population Size | Sample Size | Population Size
Total | 2,121 | 14,964,332 | 14,562 | 160,134,496
Male | 1,136 | 8,036,546 | 6,664 | 75,438,001
Female | 985 | 6,927,787 | 7,898 | 84,696,495
Non-Hispanic White
Total | 973 | 10,966,582 | 5,771 | 121,941,462
Male | 554 | 6,165,912 | 2,567 | 57,378,183
Female | 419 | 4,800,670 | 3,204 | 64,563,276
Non-Hispanic Black
Total | 686 | 2,445,381 | 4,033 | 17,057,068
Male | 353 | 1,175,699 | 1,777 | 7,493,735
Female | 333 | 1,269,682 | 2,256 | 9,563,333
Mexican-American
Total | 391 | 502,292 | 4,176 | 8,673,940
Male | 205 | 261,129 | 2,060 | 4,507,199
Female | 186 | 241,163 | 2,116 | 4,166,741
Other
Total | 71 | 1,050,078 | 582 | 12,462,026
Male | 24 | 433,807 | 260 | 6,058,884
Female | 47 | 616,271 | 322 | 6,403,141

§All NHANES III variance estimates were based on Taylor Series (WR) method.

Table 3.16 The Mean Intakes ± SEMs of Linoleic Acid (LA, 18:2n-6), Respondents With a History of CVD Compared to Those Without CVD, NHANES III (1988-94)

Table 3.16 The Mean Intakes ± SEMs of Linoleic Acid (LA, 18:2n-6), Respondents With a History of CVD Compared to Those Without CVD, NHANES III (1988-94)

| Linoleic acid (LA, 18:2n-6)
| CVD | | Non-CVD | | CVD | | Non-CVD
| Mean (g/d) | SEM | Mean (g/d) | SEM | Mean (%kcal/d) | SEM | Mean (%kcal/d) | SEM
Total | 12.58 | 0.4753 | 15.16 | 0.2355 | 5.80 | 0.0954 | 5.96 | 0.0536
Male | 15.12 | 0.8243 | 17.96 | 0.3390 | 5.87 | 0.1263 | 5.80 | 0.0598
Female | 9.64 | 0.2815 | 12.67 | 0.1980 | 5.73 | 0.1343 | 6.10 | 0.0729
Non-Hispanic White
Total | 13.06 | 0.6196 | 15.20 | 0.2798 | 5.98 | 0.1178 | 5.96 | 0.0663
Male | 15.62 | 1.0596 | 18.17 | 0.4158 | 6.06 | 0.1699 | 5.82 | 0.0739
Female | 9.76 | 0.3733 | 12.57 | 0.2245 | 5.88 | 0.1803 | 6.08 | 0.0844
Non-Hispanic Black
Total | 11.71 | 0.5201 | 15.42 | 0.2521 | 5.60 | 0.1378 | 6.09 | 0.0687
Male | 13.96 | 0.7583 | 17.85 | 0.3712 | 5.62 | 0.1692 | 5.79 | 0.0613
Female | 9.62 | 0.4955 | 13.52 | 0.2714 | 5.57 | 0.1811 | 6.33 | 0.0999
Mexican-American
Total | 11.36 | 0.4970 | 15.92 | 0.2814 | 5.79 | 0.1469 | 6.16 | 0.0706
Male | 11.28 | 0.6263 | 18.57 | 0.3443 | 5.17 | 0.2655 | 6.06 | 0.0874
Female | 11.44 | 0.7056 | 13.05 | 0.3075 | 6.46 | 0.2943 | 6.26 | 0.0819
Other
Total | 10.27 | 1.3049 | 13.88 | 0.5446 | 4.43 | 0.4121 | 5.67 | 0.1486
Male | 13.47 | 2.9402 | 15.65 | 0.6688 | 4.16 | 0.7905 | 5.44 | 0.2131
Female | 8.02 | 0.7190 | 12.21 | 0.7737 | 4.62 | 0.4265 | 5.88 | 0.2396

Table 3.17 The Mean Intakes ± SEMs of Alpha Linolenic Acid (ALA, 18:3 n-3), Respondents With a History of CVD Compared to Those Without CVD, NHANES III (1988-94)

Table 3.17 The Mean Intakes ± SEMs of Alpha Linolenic Acid (ALA, 18:3 n-3), Respondents With a History of CVD Compared to Those Without CVD, NHANES III (1988-94)

| Alpha Linolenic Acid (ALA, 18:3 n-3)
| CVD | | Non-CVD | | CVD | | Non-CVD
| Mean (g/d) | SEM | Mean (g/d) | SEM | Mean (%kcal/d) | SEM | Mean (%kcal/d) | SEM
Total | 1.16 | 0.0349 | 1.42 | 0.0201 | 0.55 *† | 0.0093 | 0.57 *† | 0.0051
Male | 1.38 | 0.0600 | 1.69 | 0.0298 | 0.55 | 0.0132 | 0.55 | 0.0059
Female | 0.90 | 0.0238 | 1.19 | 0.0181 | 0.54 | 0.0108 | 0.58 | 0.0066
Non-Hispanic White
Total | 1.20 | 0.0399 | 1.46 | 0.0253 | 0.56 | 0.0105 | 0.58 | 0.0069
Male | 1.40 | 0.0651 | 1.75 | 0.0368 | 0.57 | 0.0148 | 0.57 | 0.0075
Female | 0.93 | 0.0305 | 1.21 | 0.0224 | 0.56 | 0.0132 | 0.59 | 0.0089
Non-Hispanic Black
Total | 1.08 | 0.0456 | 1.37 | 0.0222 | 0.52 | 0.0115 | 0.54 | 0.0057
Male | 1.25 | 0.0684 | 1.60 | 0.0389 | 0.51 | 0.0141 | 0.52 | 0.0067
Female | 0.92 | 0.0552 | 1.19 | 0.0224 | 0.54 | 0.0192 | 0.56 | 0.0079
Mexican-American
Total | 0.96 | 0.0453 | 1.32 | 0.0221 | 0.49 | 0.0161 | 0.52 | 0.0078
Male | 1.04 | 0.0600 | 1.53 | 0.0332 | 0.47 | 0.0252 | 0.50 | 0.0099
Female | 0.87 | 0.0627 | 1.09 | 0.0248 | 0.52 | 0.0234 | 0.53 | 0.0095
Other
Total | 1.07 | 0.1754 | 1.18 | 0.0453 | 0.44 | 0.0370 | 0.48 | 0.0167
Male | 1.57 | 0.3688 | 1.13 | 0.0701 | 0.46 | 0.0820 | 0.46 | 0.0244
Female | 0.72 | 0.0584 | 1.03 | 0.0724 | 0.42 | 0.0314 | 0.50 | 0.0233

* Univariate analysis showed significant differences between the CVD groups (P=.04)

†Multivariate analysis (adjusted for sex, age, and race/ethnicity) showed significant differences between the CVD groups. The results are shown in Appendix C in detail.

Table 3.18 The Mean Intakes ± SEMs of Eicosapentaenoic Acid (EPA, 20:5 n-3), Respondents with a History of CVD Compared to Those Without CVD, NHANES III (1988-94) ^§^

Table 3.18 The Mean Intakes ± SEMs of Eicosapentaenoic Acid (EPA, 20:5 n-3), Respondents with a History of CVD Compared to Those Without CVD, NHANES III (1988-94) ^§^

| Elcosapentaenoic acid (EPA,20:5 n-3)
| CVD | | Non-CVD | | CVD | | Non-CVD
| Mean (g/d) | SEM | Mean (g/d) | SEM | Mean (%kcal/d) | SEM | Mean (%kcal/d) | SEM
Total | 0.04 | 0.0042 | 0.04 | 0.0037 | 0.02 | 0.0023 | 0.02 | 0.0015
Male | 0.05 | 0.0071 | 0.05 | 0.0045 | 0.02 | 0.0034 | 0.02 | 0.0017
Female | 0.04 | 0.0061 | 0.04 | 0.0041 | 0.03 | 0.0043 | 0.02 | 0.0019
Non-Hispanic White
Total | 0.04 | 0.0044 | 0.04 | 0.0036 | 0.02 | 0.0028 | 0.02 | 0.0013
Male | 0.04 | 0.0067 | 0.05 | 0.0056 | 0.02 | 0.0033 | 0.02 | 0.0018
Female | 0.04 | 0.0082 | 0.03 | 0.0034 | 0.03 | 0.0061 | 0.02 | 0.0014
Non-Hispanic Black
Total | 0.07 | 0.0131 | 0.06 | 0.0039 | 0.03 | 0.0057 | 0.02 | 0.0013
Male | 0.09 | 0.0261 | 0.07 | 0.0082 | 0.04 | 0.0103 | 0.02 | 0.0025
Female | 0.05 | 0.0113 | 0.05 | 0.0027 | 0.03 | 0.0061 | 0.02 | 0.0013
Mexican-American
Total | 0.02 | 0.0064 | 0.03 | 0.0039 | 0.01 | 0.0030 | 0.01 | 0.0014
Male | 0.04 | 0.0117 | 0.04 | 0.0058 | 0.02 | 0.0053 | 0.01 | 0.0019
Female | 0.01 | 0.0040 | 0.02 | 0.0039 | 0.00 | 0.0014 | 0.01 | 0.0017
Other
Total | 0.07 | 0.0240 | 0.08 | 0.0188 | 0.03 | 0.0110 | 0.04 | 0.0088
Male | 0.11 | 0.0530 | 0.07 | 0.0138 | 0.05 | 0.0224 | 0.03 | 0.0066
Male | 0.04 | 0.0184 | 0.09 | 0.0290 | 0.02 | 0.0097 | 0.04 | 0.0137

§Distribution of this nutrient is very skewed; means and standard errors of the means should be used and interpreted with caution.

Table 3.19 The Mean Intakes ± SEMs of Docosahexaenoic Acid (DHA, 22:6 n-3), Respondents With a History of CVD Compared to Those Without CVD, NHANES III (1988-94) ^§^

Table 3.19 The Mean Intakes ± SEMs of Docosahexaenoic Acid (DHA, 22:6 n-3), Respondents With a History of CVD Compared to Those Without CVD, NHANES III (1988-94) ^§^

| Docosahexaenoic acid (DHA, 22:6 n-3)
| CVD | | Non-CVD | | CVD | | Non-CVD
| Mean (g/d) | SEM | Mean (g/d) | SEM | Mean (%kcal/d) | SEM | Mean (%kcal/d) | SEM
Total | 0.08 | 0.0050 | 0.09 | 0.0062 | 0.04 | 0.0032 | 0.04 | 0.0026
Male | 0.08 | 0.0085 | 0.10 | 0.0074 | 0.04 | 0.0042 | 0.04 | 0.0031
Female | 0.07 | 0.0103 | 0.07 | 0.0067 | 0.04 | 0.0066 | 0.03 | 0.0029
Non-Hispanic White
Total | 0.07 | 0.0060 | 0.08 | 0.0066 | 0.04 | 0.0040 | 0.03 | 0.0025
Male | 0.07 | 0.0096 | 0.10 | 0.0088 | 0.03 | 0.0045 | 0.03 | 0.0033
Female | 0.06 | 0.0132 | 0.06 | 0.0065 | 0.04 | 0.0091 | 0.03 | 0.0024
Non-Hispanic Black
Total | 0.12 | 0.0167 | 0.12 | 0.0063 | 0.06 | 0.0078 | 0.05 | 0.0023
Male | 0.14 | 0.0280 | 0.15 | 0.0129 | 0.06 | 0.0104 | 0.05 | 0.0040
Female | 0.09 | 0.0205 | 0.09 | 0.0041 | 0.06 | 0.0104 | 0.04 | 0.0020
Mexican-American
Total | 0.05 | 0.0093 | 0.06 | 0.0049 | 0.03 | 0.0047 | 0.03 | 0.0018
Male | 0.08 | 0.0158 | 0.08 | 0.0069 | 0.04 | 0.0082 | 0.03 | 0.0023
Female | 0.03 | 0.0053 | 0.05 | 0.0051 | 0.02 | 0.0025 | 0.03 | 0.0023
Other
Total | 0.11 | 0.0300 | 0.13 | 0.0234 | 0.05 | 0.0138 | 0.06 | 0.0119
Male | 0.14 | 0.0580 | 0.13 | 0.0142 | 0.06 | 0.0249 | 0.05 | 0.0086
Female | 0.08 | 0.0358 | 0.14 | 0.0385 | 0.04 | 0.0151 | 0.07 | 0.0194

§Distribution of this nutrient is very skewed; means and standard errors of the means should be used and interpreted with caution.

Table 3.20 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: all cause mortality, CVD death, cardiac death, sudden death (secondary prevention)

Table 3.20 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: all cause mortality, CVD death, cardiac death, sudden death (secondary prevention)

Author Year Country | Omega - 3 fatty acid | | Control | | Duration (year) | All cause mortality | | CVD death | | Cardiac death | | Sudden death | | Quality | | | Applicability
| N | Type Dose | N | Type Dose | | Control Group Event Rate (%) | RR 95% Cl | Control Group Event Rate (%) | RR 95% Cl | Control Group Event Rate | RR 95% Cl | Control Group Event Rate (%) | RR 95% Cl | Summary | Jadad score | Alloc. conceal.
EPA + DHA
Marchioli 2002 Italy | 5665 | EPA + DHA (1:2) | 5658 | Control ±Vit E | 3.5 | 9.8 | 0.79^1^ | 6.5 | 0.70^1^ | 5.4 | 0.65^1^ | 2.7 | 0.55^1^ | B | 3 | A | CVD I
| | 0.85 g/d±Vit E | | | | | 0.66–0.93 | | 0.56–0.86 | | 0.51–0.82 | | 0.39–0.77
Nilsen 2001 Norway | 150 | EPA + DHA | 150 | Corn oil 1.7 g/d | 1.5 | 7.3 | 1.0 | - | nd | 5.3 | 1.0 | - | nd. | B | 4 | U | CVD II
| | (1:2) 1.7 g/d | | | | | 0.45–2.2 | | | | 0.39–2.6
Singh 1997 India | 122 | EPA + DHA | 118 | Non-oil placebo | 1 | - | nd | - | nd | 22 | 0.52 | 6.6 | 0.24 | C | 4 | I | CVD II
| | (1:1) 1.8 g/d | | | | | | | | | 0.29–0.95 | | 0.05–1.1
Leng 1998 Scotland | 60 | EPA 0.27g/d | 60 | Sun flower seed oil 3 g/d | 2 | 5.0 | 1.0 | 3.3 | 1.0 | - | nd | - | nd. | A | 5 | A | CVD II
| | | | | | | 0.21–4.8 | | 0.15–6.9
Sacks 1995 US | 31 | EPA + DHA | 28 | Olive Oil | 2.4 | 3.6 | 0.3 | 3.6 | 0.3 | 3.6 | 0.3 | 0 | nd | B | 3 | U | CVD II
| | (3:2) 4.8 g/d | | | | | 0.01–7.1 | | 0.01–7.1 | | 0.01–7.1
ALA
Singh 1997 India | 120 | Mustard Oil | 118 | Non-oil placebo | 1 | - | nd | - | nd | 22 | 0.61 | 6.6 | 0.25 | C | 4 | I | CVD II
| | ALA 2.9 g/d | | | | | | | | | 0.34–1.1 | | 0.05–1.1

1 RR adjusted for main confounders as reported in article.

Alloc. conceal. - allocation concealment; g/d - grams per day; nd - no data

Applicability is derived from a combination of the target population (GEN or CVD) and the three-level grades (I, II, III). CVD-II represents a relevant subgroup of US subjects with history or risk of CVD. Most studies in this table are graded CVD-II because they are foreign mixed-gender populations with different background diets at risk for CVD.

Table 3.21 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: myocardial infarction, stroke, all CVD events (secondary prevention)

Table 3.21 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: myocardial infarction, stroke, all CVD events (secondary prevention)

Author Year Country | Omega -3 Fatty acid | | Control | | Duration (year) | Fatal MI | | Non-fatal MI | | All strokes | | All CVD events | | Quality | | | Applicability
| N | Type Dose | N | Type Dose | | Control group event rate (%) | RR 95% Cl | Control group event rate (%) | RR 95% Cl | Control group event rate (%) | RR 95% Cl | Control group event rate (%) | RR 95% Cl | Summary | Jadad score | Alloc. conceal.
EPA + DHA
Marchioli 2002 Italy | 5665 | EPA + DHA (1:2) 0.85 g/d±Vit E | 5658 | Control Or Vit E | 3.5 | 4.6 | 0.68^1^ | 4.1 | 0.91^1^ | 1.4 | 1.2^1^ | 11 | 0.80^1^ | B | 3 | A | CVD I
| | | | | | | 0.53–0.88 | | 0.70–1.2 | | 0.81–1.9 | | 0.68–0.94
Nilsen 2001 Norway | 150 | EPA + DHA (1:2) 1.7 g/d | 150 | Corn oil 1.7 g/d | 1.5 | - | nd | 10 | 1.4 | - | nd | 47 | 1.1 | B | 4 | U | CVD II
| | | | | | | | | 0.75–2.6 | | | | 0.84–1.3
Singh 1997 India | 122 | EPA + DHA (1:1) 1.8 g/d | 118 | Non-oil palcebo | 1 | - | nd | 25 | 0.52 | - | nd | 35 | .0.71 | C | 4 | I | CVD II
| | | | | | | | | 0.3–.0..9 | | | | 0.48–1.1
Leng 1998 Scotland | 60 | EPA 0.27g/d | 60 | Sunflower seed oil 3 g/d | 2 | - | nd | 6.7 | 0.75 | 1.7 | Non-fatal stroke | 23 | 0.86^2^ | A | 5 | A | CVD II
| | | | | | | | | 0.18–3.2 | | 3.0 | | 0.43–1.7
| | | | | | | | | | | 0.32–28
Sacks 1995 US | 31 | EPA + DHA (3:2) 4.8 g/d | 28 | Olive oil | 2.4 | 3.6 | 0.3 | 7.1 | 0.45 | 0 | 2.7 | - | nd | B | 3 | U | CVD II
| | | | | | | 0.01–7.1 | | 0.04–4.7 | | 0.12–64
ALA
Singh 1997 India | 120 | Mustard Oil ALA 2.9 g/d | 118 | Non-oil placebo | 1 | - | nd | 25 | 0.59 | - | nd | 35 | 0.82 | C | 4 | I | CVD II
| | | | | | | | | 0.35–1.0 | | | | 0.56–1.2

1 RR adjusted for main confounders as reported in article.

2 Includes critical ischemia/amputation, angioplasty and bypass surgery.

Alloc. conceal. - allocation concealment; g/d - grams per day; nd - no data

Applicability is derived from a combination of the target population (GEN or CVD) and the three-level grades (I, II, III). CVD-II represents a relevant subgroup of US subjects with history or risk of CVD. Most studies in this table are graded CVD-II because they are foreign mixed-gender populations with different background diets at risk for CVD

Table 3.22 Randomized controlled trials of omega-3 fatty acid diet or dietary advice on cardiovascular disease outcomes: all cause mortality, CVD death, cardiac death, sudden death (secondary prevention)

Table 3.22 Randomized controlled trials of omega-3 fatty acid diet or dietary advice on cardiovascular disease outcomes: all cause mortality, CVD death, cardiac death, sudden death (secondary prevention)

Author Year Country | Diet / Fish advice | | No Diet / No fish advice | | Duration (year) | All cause mortality | | CVD death | | Cardiac death | | Sudden death | | Quality | | | Applicability
| N | Estimated omega-3 fatty acid intake | N | Estimated omega-3 fatty acid intake | | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Summary | Jadad score | Alloc. conceal.
EPA estimate
Burr 2003 UK | 1571 | EPA 2.11–2.65 g/wk | 1543 | EPA 0.12–0.17 g/wk | 5 | 16 | HR 1.15 0.86–1.36 | - | - | 9 | HR 1.26 (1.00–1.58) | 3 | HR 1.54 (1.06–2.23) | C | 2 | A | CVD II
Burr 1989 UK | 1015 | EPA 2.4 g/wk (SD 1.4) | 1018 | EPA 0.6g/wk (SD 0.7) | 2 | 13 | 0.73 | - | nd | 11 | 0.67 | - | nd | C | 1 | U | CVD II
| | | | | | | 0.56–0.93 | | | | 0.51–0.89
ALA estimate
Singh 2002 India | 499 | Indo Mediterranean diet ALA 1.8 g/d | 501 | ALA 0.8 g/d | 2 | 8 | 0.63 | - | nd | - | nd | 3.2 | 0.38 | C | 3 | U | CVD II
| | | | | | | 0.38–1.04 | | | | | | 0.15–0.95
Leren 1966 Norway | 406 | Cholestrol-lowering diet^1^ ALA 1–1.9 g/d (soybean oil) | 406 | Usual diet | 5 | 27 | 0.75 | 25 | 0.73 | - | nd | 13 | 1.00 0.61–1.64 | C | 2 | I | CVD II
| | | | | | | 0.52–1.06 | | 0.50–1.06
DeLorgeril 1999 France | 302 | Cretan Mediterranean diet^1^ ALA 1.9 g/d | 303 | Prudent diet^2^ ALA 0.67 g/d | 2.3 | 7.9 | 0.44^3^ 0.21–0.94 | - | nd | 6.3 | 0.35^3^ | 2.6 | 0.06 0.003–1.02 | C | 4 | A | CVD II
| | | | | | | | | | | 0.15–0.83
Bemelmans 2002 Netherlands | 109 | ALA 6.3 g/d | 157 | ALA 1.0 g/d | 2 | 0.6 | 4.3 | 0.6 | 1.44 | - | nd | - | nd | B | 3 | A | CVD I
| | | | | | | 0.46–41 | | 0.09–23

1 ALA = 0.84% energy = calculated from daily nutrient recorded on the final visit in 144 unselected consecutive experimental patients

2 ALA = 0.29% energy = calculated from daily nutrient recorded on the final visit in 83 unselected consecutive control patients

3 RR adjusted for main confounders as reported in article.

Alloc. Conceal. - allocation concealment; g/d - grams per day; nd - no data

Table 3.23 Randomized controlled trials of omega-3 fatty acid diet or dietary advice on cardiovascular disease outcomes: myocardial infarction, stroke, all CVD events (secondary prevention)

Table 3.23 Randomized controlled trials of omega-3 fatty acid diet or dietary advice on cardiovascular disease outcomes: myocardial infarction, stroke, all CVD events (secondary prevention)

Author Year Country | Diet / Fish advice | | No Diet / No fish advice | | Duration (year) | Fatal MI | | Non-fatal MI | | All strokes | | All CVD events | | Quality | | | Applicability
| N | Estimated omega-3 fatty acid intake | N | Estimated omega-3 fatty acid intake | | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Summary | Jadad score | Alloc. conceal.
EPA estimate
Burr 2003 UK | 1571 | EPA 2.11–2.65 g/wk | 1543 | EPA 0.12–0.17 g/wk | 5 | - | nd | - | nd | - | nd | - | nd | C | 1 | U | CVD II
Burr 1989 UK | 1015 | EPA 2.4 g/wk | 1018 | EPA 0.6g/wk (SD 0.7) | 2 | - | 0.7 | 3.2 | 1.5 | - | nd | - | nd | C | 1 | U | CVD II
| | | | | | | 0.5–0.9 | | 0.97–2.3
ALA estimate
Singh 2002 India | 499 | Indo Mediterranean diet ALA 1.8 g/d | 501 | ALA 0.8 g/d | 2 | 3.4 | 0.71 | 8.6 | 0.49 | 2.6 | 0.54 | - | nd | C | 3 | U | CVD II
| | | | | | | 0.34–1.5 | | 0.30–0.81 | | 0.22–1.3
Leren 1966 Norway | 406 | Cholestrol-lowering diet ALA 1–1.9 g/d (soybean oil) | 406 | Usual diet | 5 | 11 | 0.43 | 15 | 0.77 | - | nd | - | nd | C | 2 | I | CVD II
| | | | | | | 0.21–0.89 | | 0.47–1.27
DeLorgeril 1999 France | 302 | Cretan Mediterranean diet^1^ ALA 1.9 g/d | 303 | Prudent diet^2^ ALA 0.67 g/d | 2.3 | - | nd | 8.3 | 0.32 | 13 | 0.11 | 59 | 0.53^3^ | C | 4 | A | CVD II
| | | | | | | | | 0.15–0.70 | | 0.01–2.1 | | 0.38–0.74
Bemelmans 2002 Netherlands | 109 | ALA 6.3 g/d | 157 | ALA 1.0 g/d | 2 | - | nd | 2.5 | 0.16 | 1.3 | 0.29 | 5.7 | 0.16 | B | 3 | A | CVD I
| | | | | | | | | 0.01–2.9 | | 0.01–5.9 | | 0.02–1.3

1 ALA = 0.84% daily energy = calculated from daily nutrient recorded on the final visit in 144 unselected consecutive experimental patients

2 ALA = 0.29% daily energy = calculated from daily nutrient recorded on the final visit in 83 unselected consecutive control patients

3 Total major and minor endpoints.

Alloc. conceal. - allocation concealment; g/d - grams per day; nd - no data

Table 3.24 Association of estimates of fish consumption with all cause mortality, cardiovascular death, and myocardial infarction in prospective cohort studies (secondary prevention)

Table 3.24 Association of estimates of fish consumption with all cause mortality, cardiovascular death, and myocardial infarction in prospective cohort studies (secondary prevention)

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Fish consumption (amount or frequency)
| | | | Relative risk (unless stated otherwise)
Erkkila 2003 Finland | 415 | 5 | 4-day food record | | 0 | 1–57 | >57 g/d
| | | | All cause mortality | 1.0 | 0.50 | 0.37* | 0.06 | + | B | CVD II
| | | | CV Death | 1.0 | 0.64 | 0.45 | NS | +
| | | | CAD death or MI | 1.0 | 1.0 | 0.49 | NS | 0

Table 3.25 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: all cause mortality, CVD death, cardiac death, sudden death (Primary intervention)

Table 3.25 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: all cause mortality, CVD death, cardiac death, sudden death (Primary intervention)

Author Year Country | Omega-3 Fatty acid | | Control | | Duration (year) | All cuase mortality | | CVD death | | Cardiac death | | Sudden death | | Quality | | | Applicability
| N | Type Dose | N | Type Dose | | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Summary | Jadad score | Alloc. conceal.
ALA
Natvig 1968 Norway | 6716 | Linseed oil ALA 5.5 g/d | 6690 | Sunflower seed oil ALA 0.14 g/d | 1 | 0.6 | 1.1 | - | nd | 0.4 | 1.0 | - | nd | C | 4 | A | GEN II
| | | | | | | 0.7–1.6 | | | | 0.58–1.7

Table 3.26 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: myocardial infarction, stroke, all CVD events (Primary intervention)

Table 3.26 Randomized controlled trials of omega-3 fatty acid supplements on cardiovascular disease outcomes: myocardial infarction, stroke, all CVD events (Primary intervention)

Author Year Country | Omega-3 Fatty acid | | Control | | Duration (year) | Fatal MI | | Non-fatal MI | | All strokes | | All CVD events | | Quality | | | Applicability
| N | Type Dose | N | Type Dose | | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Control group event rate (%) | RR 95% CI | Summary | Jadad score | Alloc. conceal.
ALA
Natvig 1968 Norway | 6716 | Linseed oil ALA 5.5 g/d | 6690 | Sunflower seed oil ALA 0.14 g/d | 1 | All MI 0.8 | All MI | | | 0.13 | 1.4 | - | nd | C | 4 | A | GEN II
| | | | | | | 1.2 (0.84–1.7) | | | | 0.62–3.4

Table 3.27 Association of estimates of omega-3 fatty acid consumption with all cause mortality in prospective cohort studies

Table 3.27 Association of estimates of omega-3 fatty acid consumption with all cause mortality in prospective cohort studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results^1^ | | | | | | Trend P-value^2^ | Overall effect | Quality | Applicability
| | | | Estimated omega-3 fatty acid consumption
| | | | Relative risk (unless stated otherwise)
Nagata 2002 Japan | 29079 | 7 | FFQ | EPA+DHA | | | | | | NS | + + | A | GEN II
| | | | Men | 0.41 | 0.6 | 0.79 | 1.1 | 1.6 g/d | 0.01
| | | | Hazard ratio | 1.0 | 0.82* | 0.87 | 0.88 | 0.87
| | | | Women | 0.33 | 0.49 | 0.64 | 0.83 | 1.3 g/d
| | | | Hazard ratio | 1.0 | 0.92 | 0.84 | 0.90 | 0.77*
Yuan 2001 China | 18244 | 12 | FFQ | EPA+DHA | 0.15 | 0.38 | 0.65 | 0.91 | 1.7 g/wk | 0.01 | + + | A | GEN II
| | | | | 1.0 | 0.79* | 0.76* | 0.86* | 0.79*
Dolecek 1992 US | 6250 | 10.5 | Multiple 24-hr recall | ALA | 0.87 | 1.3 | 1.6 | 1.9 | 2.8 g/d | 0.014 | + + | A | GEN II
MRFIT | | | | EPA+DHA | 1.0 | 0.96 | 0.69 | 0.89 | 0.69 | 0.01
| | | | | 0.0 | 0.009 | 0.046 | 0.15 | 0.66 g/d
| | | | | 1.0 | 1.1 | 1.0 | 0.85 | 0.76

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.28 Association of estimates of fish consumption with all cause mortality in prospective cohort studies

Table 3.28 Association of estimates of fish consumption with all cause mortality in prospective cohort studies

AuthorYear Location | N | Duration (year) | Dietary Assessment | Results | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Fish consumption (amount or frequency)
| | | | Relative risk (unless stated otherwise)
Nagata 2002 Japan | 29079 | 7 | FFQ | Men | 46 | 68 | 87 | 112 | 158 g/d | NS | 0 | A | GEN II
| | | | Hazard ratio | 1.0 | 0.92 | 0.91 | 0.90 | 0.94
| | | | Women | 37 | 54 | 69 | 88 | 122 g/d
| | | | Hazard ratio | 1.0 | 0.93 | 0.96 | 0.93 | 0.86
Albert 1998 US | 20551 | 12 | FFQ | <1/mo | 1–3/mo | 1-<2/wk | 2-<5/wk | ≥5/wk | | 0.045 | + + | A | GEN II
PHS | | | | 1.0 | 0.79 | 0.71* | 0.70* | 0.73*
Yuan 2001 China | 18244 | 12 | FFQ | <50 | 50–100 | 100–150 | 150–200 | ≥200 g/wk | | 0.01 | + + | A | GEN II
| | | | 1.0 | 0.79* | 0.76* | 0.86* | 0.79*
Mann 1997 | 10802 | 13.3 | FFQ | | 0 | <1 | ≥1 /wk | | | NS | 0 | B | GEN II
UK | | | | Death rate ratio | 100 | 97 | 96
Gillum 2000 US | 8825 | 18.8 | FFQ + 24-hr recall | | Never | <1 | 1 | >1 /wk | | | + | B | GEN I
NHANES | | | | White Men | 1.0 | 0.88 | 0.76* | 0.85 | | 0.01
| | | | Black Men | 1.0 | 1.0 | 1.0 | 1.1 | | NS
| | | | White Women | 1.0 | 1.0 | 1.0 | 0.90 | | nd
| | | | Black Women | 1.0 | 0.77 | 0.79 | 0.82 | | nd
Osler 2003 Denmark | 8497 | 18 | FFQ | | ≤1/mo | 2/mo | 1/wk | >2/wk | | 0.02↑ | - | B | GEN I
| | | | Hazard ratio | 0.88 | 0.84* | 1.0 (ref) | 1.1
Daviglus 1997 US | 1822 | 30 | FFQ | 0 | 1–17 | 18–34 | =35 g/d | | | NS | 0 | A | GEN II
WES | | | | 1.0 | 1.02 | 0.98 | 0.85
Fraser 1997 US | 603 | 12 | FFQ | >84 years old subset of Adventist Health Study | | | | | | NS | 0 | B | GEN III
Adventist | | | | | | <1/wk | >1/wk
| | | | Hazard ratio | | 1.0 | 0.98
Kromhout 1995 Holland | 272 | 17 | CCD | Non-fish eaters | | Fish Eaters (24 g/d) | | | | NS | 0 | C | GEN II
| | | | 1.0 | | 0.96

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.29 Association of estimates of omeg-3 fatty acid consumption with cardiovascular death in prospective cohort studies

Table 3.29 Association of estimates of omeg-3 fatty acid consumption with cardiovascular death in prospective cohort studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Fish consumption (amount or frequency)
| | | | Relative risk (unless stated otherwise)
Nagata 2002 Japan | 29079 | 7 | FFQ | | Quintiles (amount not reported) | | | | | Hazard ratio | NS | + | A | GEN II
| | | | Men | 1.0 | 0.74 | 0.71 | 0.82 | 0.76 | | NS
| | | | Women | 1.0 | 0.82 | 0.79 | 0.86 | 0.77* | | NS
Dolecek 1992 US | 6250 | 10.5 | Multiple 24-hr recall | ALA | 0.87 | 1.3 | 1.6 | 1.9 | 2.8 g/d | | 0.067 | + + | A | GEN II
MRFIT | | | | | 1.0 | 0.89 | 0.64 | 0.83 | 0.6 | | 0.004
| | | | EPA+DHA | 0.0 | 0.009 | 0.046 | 0.15 | 0.66 g/d
| | | | | 1.0 | 1.06 | 0.92 | 0.92 | 0.59

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.30 Association of estimates of fish consumption with cardiovascular death in prospective cohort studies

Table 3.30 Association of estimates of fish consumption with cardiovascular death in prospective cohort studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | Trend P-value | Overall affect | Quality | Applicability
| | | | Fish consumption (amount or frequency)
| | | | Relative risk (unless stated otherwise)
Albert 1998 US | 20551 | 11 | FFQ | <1/mo | 1–3/mo | 1-<2/wk | 2-<5/wk | =5/wk | NS | + | A | GEN II
PHS | | | | 1.0 | 0.96 | 0.79 | 0.84 | 0.81
Gillum 2000 US | 8825 | 18.8 | FFQ + 24-hr recall | | Never | <1 | 1 | >1 /wk
NHANES | | | | White men | 1.0 | 0.98 | 0.87 | 0.95 | NS | 0 | B | GEN II
| | | | Black men | 1.0 | 0.96 | 0.99 | 1.1 | NS
| | | | White women | 1.0 | 1.1 | 1.1 | 1.1 | nd
| | | | Black women | 1.0 | 0.85 | 0.94 | 0.99 | nd
Daviglus 1997 US | 1822 | 30 | FFQ | 0 | 1–17 | 18–34 | =35 g/d | | 0.01 | + + | A | GEN II
WES | | | | 1.0 | 0.94 | 0.89 | 0.74

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.31 Association of estimates of omega-3 fatty acids with cardiac death in prospective cohort studies

Table 3.31 Association of estimates of omega-3 fatty acids with cardiac death in prospective cohort studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Estimated omega-3 fatty acid consumption
| | | | Relative risk (unless stated otherwise)
Pietinen 1997 Finland | 21930 | 6.1 | FFQ | ALA | 0.9 | 1.2 | 1.5 | 1.9 | 2.5 | g/d | NS | 0 | A | GEN II
ABCC | | | | | 1.0 | 0.94 | 0.98 | 1.03 | 0.99
| | | | EPA+DHA | 0.2 | 0.3 | 0.4 | 0.5 | 0.8 | g/d
| | | | | 1.0 | 0.94 | 1.0 | 1.1 | 1.3
Dolecek1992 US | 6250 | 10.5 | Multiple 24-hr recall | ALA | 0.87 | 1.3 | 1.6 | 1.9 | 2.8 | g/d | NS 0.01 | + + | A | GEN II
MRFIT | | | | | 1.0 | 0.98 | 0.57 | 0.98 | 0.68
| | | | EPA+DHA | 0 | 0.009 | 0.046 | 0.15 | 0.66 | g/d
| | | | | 1.0 | 1.1 | 0.91 | 0.88 | 0.60

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.32 Association of estimates of fish consumption with cardiac death in prospective cohort studies

Table 3.32 Association of estimates of fish consumption with cardiac death in prospective cohort studies

Author Year Location | N | Duration ( year) | Dietary Assessment | Results | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Fish consumption (amount or frequency)
| | | | Relative risk (unless stated otherwise)
Hu 2002, US NHS | 84688 | 16 | FFQ | <1/mo | 1–3/mo | 1/wk | 2–4/wk | >5/wk | | 0.01 | + + | A | GEN II
| | | | 1.0 | 0.80 | 0.65* | 0.72 | 0.55*
Ascherio 1995, US HPS | 44895 | 6 | FFQ | 1–3/mo | 1/wk | 2–3/wk | 4–5/wk | >6/wk | | NS | + | A | GEN II
| | | | 0.74 | 0.86 | 0.71 | 0.54* | 0.77
Egeland 2001 Norway | 42612 | 7 | Dietary quest-ionnaire | | | | None | Cod liver oil | | NS | + | C | GEN II
| | | | Never smoker | | Hazard ratio | 1.0 | 0.7
| | | | Current smoker | | | 1.0 | 0.8
Fraser 1997, US Adventist | 26743 | 6 | FFQ | | | 0 | <1/wk | >1/wk | | nd | 0 | B | GEN II
| | | | Hazard ratio | | 1.0 | 1.1 | 0.74
Albert 1998, US PHS | 20551 | 11 | FFQ | <1/mo | 1–3/mo | 1-<2/wk | 2-<5/wk | ≥5/wk | | NS | + | A | GEN II
| | | | 1.0 | 1.18 | 0.82 | 0.91 | 0.81
Mann 1997 UK | 10802 | 13.3 | FFQ | | | 0 | <1 | ≥1/wk | | NS | - | B | GEN II
| | | | Death Rate Ratio | | 100 | 121 | 123
Rodriguez 1996 US Honolulu | 8006 | 23 | Dietary quest-ionnaire | Cigarettes/d | | < 2/wk | ≥2/wk | Fish consumption | | NS | + | C | GEN II
| | | | <20 | | 0.30 | 0.42 | | | NS
| | | | 20–30 | | 0.38 | 0.45 | | | nd
| | | | >30 | | 1.0 | 0.50*
Osler 2003 Denmark | 8497 | 18 | FFQ | | | ≤1/mo | 2/mo | 1/wk | >2/wk | NS | 0 | B | GEN I
| | | | Hazard ratio | | 1.1 | 0.98 | 1.0 (ref) | 0.98
Mozaffarian 2003 US CHS | 3910 | 9.3 | FFQ | Tuna/other fish | <1/mo | 1–3/mo | 1/wk | 2/wk | >3/wk | 0.002 | + + | A | GEN II
| | | | Total IHD death | 1.0 | 0.78 | 0.77 | 0.53* | 0.47 | NS | -
| | | | Fried fish/sand | <1/mo | 1–3/mo | 1/wk | 2/wk | >3/wk
| | | | Total IHD death | 1.0 | 1.2 | 1.6 | 1.1 | 1.4
| | | | | Hazard ratios
Oomen 2000 Finland Italy Holland | 2738 | 20 | CCD | | | 1–19 | 20–39 | >40 g/d | | NS | + | A | GEN II
| | | | Total fish | | 0.93 | 0.95 | 1.1
| | | | Fatty fish | | 0.57* | 0.87(=20 g/d)
Daviglus 1997, US WES | 1822 | 30 | FFQ | 0 | 1–17 | 18–34 | ≥35 g/d | | | 0.04 | + + | A | GEN II
| | | | 1.0 | 0.88 | 0.84 | 0.62*
Kromhout 1985 Holland | 852 | 20 | CCD | 0 | 1–14 | 5–29 | 30–44 | 45 g/d | | nd | + | B | GEN II
| | | | 1.0 | 0.64 | 0.56 | 0.36* | 0.39
Kromhout 1995 Holland | 272 | 17 | CCD | No fish | Fish eater | | | | | nd | + | C | GEN I
| | | | 1.0 | 0.51*

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.33 Association of estimates of omega-3 fatty acids with sudden death in prospective cohort and case-control studies

Table 3.33 Association of estimates of omega-3 fatty acids with sudden death in prospective cohort and case-control studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Estimated omega-3 fatty acid consumption
| | | | Relative risk (unless stated otherwise)
Prospective cohort
Albert 1998 US | 20551 | 12 | FFQ | EPA+DHA | <0.3 | 0.3–2.7 | 2.7–4.9 | 4.9–7.4 | >7.4 g/mo | NS | + + | A | GEN II
PHS | | | | | 1.0 | 0.58 | 0.34* | 0.60 | 0.43*
Case control
Siscovick 1995 US | 827 | na | FFQ | EPA+DHA | 0 | 0.96 | 2.9 | 5.5 | 13.7 g/mo | ND | + + | A | GEN I
| | | | Odds ratio | 1.0 | 0.9* | 0.7* | 0.5* | 0.4*

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.34 Association of estimates of fish consumption with sudden death in prospective cohort studies

Table 3.34 Association of estimates of fish consumption with sudden death in prospective cohort studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Fish consumption (amount or frequency)
| | | | Relative risk
Albert 1998 US | 20551 | 12 | FFQ | <1/mo | 1–3/mo | 1–2/wk | 2–5/wk | =5/wk | NS | + + | A | GEN II
PHS | | | | 1.0 | 0.64 | 0.47* | 0.51 | 0.39*
Daviglus 1997 US | 1822 | 30 | FFQ | 0 | 1–17 | 18–34 | =35 | g/d | NS | + | A | GEN II
WES | | | | 1.0 | 0.78 | 0.80 | 0.68

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.35 Association of estimates of omega-3 fatty acids consumption with myocardial infarction in prospective cohort and case-control studies

Table 3.35 Association of estimates of omega-3 fatty acids consumption with myocardial infarction in prospective cohort and case-control studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Estimated omega-3 fatty acid consumption
| | | | Relative risk (unless stated otherwise)
Prospective cohort
Hu 2002 | 84688 | 16 | FFQ | EPA+DHA | | | | | | <0.001 | + + | A | GEN II
Hu 1999 US | | | | Median intake (% energy) | 0.03 | 0.05 | 0.08 | 0.14 | 0.24
NHS | | | | Nonfatal MI | 1.0 | 0.92 | 0.83 | 0.75* | 0.69*
| | 10 | | ALA | | | | | | 0.001 | + +
| | | | Median intake g/d | 0.71 | 0.86 | 0.98 | 1.12 | 1.36 | 0.05
| | | | Fatal IHD | 1.0 | 0.99 | 0.90 | 0.67 | 0.55*
| | | | Non-fatal MI | 1.0 | 0.92 | 0.94 | 1.02 | 0.85
Ascherio 1995 US | 44895 | 6 | FFQ | EPA+DHA | <0.11 | 0.12–0.19 | 0.20–0.28 | 0.29–0.41 | >0.42 g/d | NS | + | A | GEN II
HPS | | | | Total MI | 1.0 | 1.0 | 0.92 | 0.86 | 1.1 | NS
| | | | Nonfatal MI | 1.0 | 0.93 | 0.89 | 0.78 | 1.1
Morris 1995 US | 21185 | 4 | FFQ | EPA+DHA | <0.05 | 0.5-<1.0 | 1.0-<1.7 | 1.7-<2.3 | >2.3 g/wk | NS | - | A | GEN II
PHS | | | | Total MI | 1.0 | 1.6 | 1.4 | 1.2 | 1.2
| | | | Nonfatal MI | 1.0 | 1.5 | 1.3 | 1.2 | 1.1
Yuan 2001 China | 18244 | 12 | FFQ | EPA+DHA | <0.27 | 0.27-0.43 | 0.44-0.72 | 0.73-1.1 | >1.1 g/wk | 0.02 | + + | A | GEN II
| | | | Fatal MI | 1.0 | 0.39* | 0.67 | 0.53* | 0.43*
Oomen 2001 Holland | 667 | 0 | CD | ALA (% energy) | <0.45 | 0.45- 0.58 | >0.58 | | | NS | - | B | GEN III
| | | | Fatal and nonfatal CAD | 1.0 | 1.5 | 1.7 | | | NS
| | | | Fatal CAD | 1.0 | 0.99 | 1.6
Case control
Tavani 2001 Italy | 975 | na | FFQ | EPA+DHA | <0.81 | 0.81–1.28 | >1.28 g/wk | | | 0.03 | + + | B | GEN II
| | | | Nonfatal MI odds ratio | 1.0 | 0.71* | 0.67*

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.36 Association of estimates of fish consumption with myocardial infarction in prospective cohort and case control studies

Table 3.36 Association of estimates of fish consumption with myocardial infarction in prospective cohort and case control studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Fish consumption (amount or frequency)
| | | | Relative risk (unless stated otherwise)
Prospective cohort
Hu 2002 | 84688 | 16 | FFQ | | 1–3/mo | 1/wk | 2–4/wk | >5/wk | | | 0.03 | ++ | A | GEN II
NHS | | | | Nonfatal MI | 0.78* | 0.74* | 0.68* | 0.73
Ascherio 1995 US | 44895 | 6 | FFQ | | <1/mo | 1–3/mo | 1/wk | 2–3/wk | 4–5/wk | >6/wk | NS | ++ | A | GEN II
HPS | | | | | 0 | 7 | 18 | 37 | 69 | 119 g/d | NS
| | | | MI | 1.0 | 0.66* | 0.82 | 0.69* | 0.65* | 0.90
| | | | Nonfatal MI | 1.0 | 0.62* | 0.80 | 0.67* | 0.69 | 0.96
Fraser 1992a US | 26743 | 6 | FFQ | | 0 | <1 | | >1/wk | | | NS | 0 | B | GEN II
Adventist | | | | Nonfatal MI | 1.0 | 1.0 | | 1.04
Albert 1998 US | 20551 | 11 | FFQ | | <1/mo | 1–3/mo | 1–2/wk | 2–5/wk | >5/wk | | NS | 0 | A | GEN II
PHS | | | | All MI | 1.0 | 0.91 | 0.99 | 1.0 | 1.0
Yuan 2001 China | 18244 | 12 | FFQ | | <50 | 50–100 | 100–150 | 150–200 | ≥200 g/wk | | 0.03 | + + | A | GEN II
| | | | Fatal MI | 1.0 | 0.55* | 0.65 | 0.66 | 0.41*
Mozaffarian 2003 US | 3910 | 9.3 | FFQ | Tuna/other fish | | 1–3/m | 1/wk | 2/wk | >3/wk
CHS | | | | Nonfatal MI | | 0.81 | 0.71 | 0.75 | 0.67 | | 0.10 | + | A | GEN II
| | | | Fried fish/sandwich | | 1–3/m | 1/wk | 2/wk | >3/wk
| | | | Nonfatal MI | | 1.3 | 1.6 | 1.2 | 1.9 | | NS | -
| | | | | | | Hazard ratio
Daviglus 1997 US | 1822 | 30 | FFQ | | | 0 | 1–17 | 18–34 | ≥35 g/d | | 0.017 | + + | A | GEN II
WES | | | | All MI | | 1.0 | 0.88 | 0.76 | 0.56*
Case control
Tavani, 2001 Italy | 975 | na | FFQ | | | | <1 | 1-<2 | ≥2/wk | | 0.02 | + + | B | GEN II
| | | | Nonfatal MI odds ratio | | | 1.0 | 0.79 | 0.67*
Sasazuki 2001 Japan | 1846 | na | FFQ | | | | | <2 | 2–3 | >4/wk
| | | | Nonfatal MI odds ratio | | | Men | 1.0 | 0.6* | 0.7* | NS | + | B | GEN II
| | | | | | | Women | 1.0 | 0.8 | 1.3 | 0.09

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.37 Association of estimates of omega-3 fatty acid consumption with stroke in prospective cohort and case-control studies

Table 3.37 Association of estimates of omega-3 fatty acid consumption with stroke in prospective cohort and case-control studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Estimated omega-3 fatty acid consumption
| | | | Relative risk (unless stated otherwise)
Prospective cohort
Iso 2001 US | 79839 | 14 | FQ | EPA+DHA | 0.077 | 0.12 | 0.17 | 0.22 | 0.48 g/d
NHS | | | | Ischemic | 1.0 | 0.83 | 0.67* | 0.82 | 0.71 | NS | + | A | GEN II
| | | | Hemorrhagic | 1.0 | 0.94 | 0.66 | 0.93 | 0.76 | NS
He 2002 US | 43671 | 12 | FQ | EPA+DHA | <0.05 | <0.05-<0.2 | 0.2–0.4 | 0.4-<0.6 | >0.6 g/d
HPS | | | | Ischemic | 1.0 | 0.56* | 0.63* | 0.54* | 0.73 | NS | + + | A | GEN II
| | | | Hemorrhagic | 1.0 | 1.3 | 1.0 | 0.89 | 1.1 | NS
Morris 1995 US | 21185 | 4 | FQ | EPA+DHA | <0.5 | 0.5-<1.0 | 1.0-<1.7 | 1.7-<2.3 | >2.3 g/wk
PHS | | | | All stokes | 1.0 | 0.9 | 1.1 | 0.7 | 1.0 | NS | 0 | A | GEN II
Yuan 2001 China | 18244 | 9 | FFQ | EPA+DHA | <0.26 | 0.27–0.43 | 0.44–0.72 | 0.73–1.1 | ≥1.1 g/wk
| | | | Fatal strokes | 1.0 | 0.76 | 0.76* | 0.93 | 1.0 | NS | + | A | GEN II
Seino 1997 Japan | 2283 | 15.5 | FFQ | n-3 fatty acid | 1.8 | 2.3 | 2.7 | 3.2 g/d
| | | | Ischemic stroke | 1.0 | 0.99 | 1.6 | 1.4 | | NS | - | B | GEN II
Case control
Caicoya 2002 Spain | 913 | na | FQ | EPA+DHA | <0.12 | 0.12–0.32 | 0.32–0.66 | >0.66 g/d
| | | | All Strokes odds ratio | 1.0 | 1.1 | 1.4 | 1.8 | | 0.01↑ | - | A | GEN II

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.38 Association of estimates of fish consumption with stroke in prospective cohort and case-control studies

Table 3.38 Association of estimates of fish consumption with stroke in prospective cohort and case-control studies

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Fish consumption (amount of frequency)
| | | | Relative risk (unless stated otherwise)
Prospective cohort
Kinjo 1999 Japan | 223170 | 15 | 1-page questionnarie | | >1 | 1–3 | ≥4 /wk
| | | | Ischemic deaths | 1.0 | 1.05 | 0.99 | | | nd | 0 | C | GEN II
| | | | Hemorrhagic deaths | 1.0 | 1.02 | 0.87* | | | nd
Iso 2001 US | 79839 | 14 | FQ | | <1/m | 1–3/m | 1/wk | 2–4/wk | >5/wk
NHS | | | | Ischemic | 1.0 | 0.83 | 0.69 | 0.63 | 0.38 | 0.09 | + | A | GEN II
| | | | Hemorrhagic | 1.0 | 1.4 | 1.1 | 0.93 | 1.0 | NS
He 2002 US | 43671 | 12 | FQ | | <1/mo | 1–3/mo | 1/wk | 2–4/wk | >5/wk
HPS | | | | Ischemic | 1.0 | 0.57* | 0.56* | 0.55* | 0.54* | NS | + + | A | GEN II
| | | | Hemorrhagic | 1.0 | 1.8 | 1.4 | 0.96 | 1.6 | NS
Morris 1995 US | 21185 | 4 | FFQ | | <1 | 1 | 2–4 | >5 /wk
PHS | | | | Non-fatal strokes | 1.0 | 1.3* | 1.1 | 0.9 | | NS | - | A | GEN II
Yuan 2001 China | 18244 | 9 | FQ | | <50 | 50–100 | 100–150 | 150–200 | ≥200 g/wk
| | | | Fatal strokes | 1.0 | 0.93 | 0.79 | 1.01 | 1.11 | NS | 0 | A | GEN II
Gillum 1996 US | 5192 | 12 | FFQ | Ischemic stroke | | 0 | <1 | 1 | >1 /wk
NHANES | | | | Women | aged 45–74 | 1.0 | 0.78 | 0.77 | 0.55* | nd | + | B | GEN I
| | | | Men | aged 45–74 | 1.0 | 1.3 | 1.2 | 0.85
| | | | Black men+women | Never fish | some fish
| | | | Stroke incidence | 1.0 | 0.51* | | | | na
| | | | Stroke death | 1.0 | 0.26*
Orencia 1996 USA | 1847 | 30 | FFQ / 24-hr recall | | 0 | 1–17 | 18–34 | >35 | g/d
WES | | | | All strokes | 1.0 | 0.94 | 0.89 | 1.3 | Hazard ratio | NS | 0 | A | GEN II
Keli 1994 Holland | 872 | 15 | CCD | | 6.3 (<20) | 35.4 (≥20) | g/d
| | | | All strokes | 1.0 | 0.49 | Hazard ratio | | | 0.06 | + | B | GEN II
Case control
Caicoya 2002 Spain | 913 | na | FFQ | Total | 0 | 1–22.5 | 23–45 | 46–90 | >91 g/d
| | | | Odds ratio | 1.0 | 0.30* | 0.44 | 0.59 | 0.76 | nd | + | A | GEN II
| | | | Ischemic | 0–11.2 | 11.3–28.7 | 28.8–46.5 | >46.5 g/d
| | | | Odds ratio | 1.0 | 1.1 | 0.90 | 2.0 | | 0.08↑ | -

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.39 Association of estimates of omega-3 fatty acid consumption with all CVD events in cross-sectional study

Table 3.39 Association of estimates of omega-3 fatty acid consumption with all CVD events in cross-sectional study

Author Year Location | N | Duration (year) | Dietary Assessment | Results | | | | | | Trend P-value | Overall effect | Quality | Applicability
| | | | Estimated omega-3 fatty acid consumption
| | | | Prevalence odds ratio for all CVD events
Djousse 2001 US | 406 | n.a | FQ | ALA | 0.53 | 0.67 | 0.78 | 0.90 | 1.1 g/d
| | | | men | 1.0 | 0.77 | 0.61* | 0.58* | 0.60* | 0.012 | + + | B | GEN I
| | | | ALA | 0.46 | 0.58 | 0.65 | 0.76 | 0.96 g/d
| | | | women | 1.0 | 0.57 | 0.52 | 0.30* | 0.42* | 0.014

1 Adjusted results are presented here when reported in original study. See evidence tables for details.

2 Trend for inverse association. Up arrow indicates a statistically significant positive association (worse outcome).

* Statistically significant p<0.05; numerical p-value reported for p<0.1.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist Health Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.40 Association of estimates of omega-3 fatty acid consumption with all cause mortality in prospective cohort studies of general population (based on data in Table 3.27)

Table 3.40 Association of estimates of omega-3 fatty acid consumption with all cause mortality in prospective cohort studies of general population (based on data in Table 3.27)

| Methodological Quality
| | A | | | | B | C
Applicability | I
| II | Study | Year | N | Effect
| | Nagata | 2002 | 29079 | ++
| | Yuan | 2001 | 18244 | ++
| | MRFIT | 1992 | 6250 | ++
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.41 Association of estimates of fish consumption with all cause mortality in prospective cohort studies of general population (based on data in Table 3.28)

Table 3.41 Association of estimates of fish consumption with all cause mortality in prospective cohort studies of general population (based on data in Table 3.28)

| Methodological Quality
| | A | | | | B | | | | C
Applicability | I | | | | | Study | Year | N | Effect
| | | | | | NHANES | 2000 | 8825 | +
| | | | | | Osler | 2003 | 8487 | -
| II | Study | Year | N | Effect | Study | Year | N | Effect | Study | Year | N | Effect
| | Nagata | 2002 | 29079 | 0 | Mann | 1997 | 10802 | 0 | Kromhout | 1995 | 272 | 0
| | PHS | 1998 | 20551 | ++
| | Yuan | 2001 | 18244 | ++
| | WES | 1997 | 1822 | 0
| III | | | | | Study | Year | N | Effect
| | | | | | Adventist | 1997 | 603 | 0

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.42 Association of estimates of omega-3 fatty acid consumption with cardiovascular death in prospective cohort studies of general population (based on data in Table 3.29)

Table 3.42 Association of estimates of omega-3 fatty acid consumption with cardiovascular death in prospective cohort studies of general population (based on data in Table 3.29)

| Methodological Quality
| | A | | | | B | C
Applicability | I
| II | Study | Year | N | Effect
| | Nagata | 2002 | 29079 | +
| | MRFIT | 1992 | 6250 | ++
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.43 Association of estimates of fish consumption with cardiovascular death in prospective cohort studies of general population (based on data in Table 3.30)

Table 3.43 Association of estimates of fish consumption with cardiovascular death in prospective cohort studies of general population (based on data in Table 3.30)

| Methodological Quality
| | A | | | | B | | | | C
Applicability | I
| II | Study | Year | N | Effect | Study | Year | N | Effect
| | PHS | 1998 | 20551 | + | NHANES | 2000 | 8825 | 0
| | WES | 1997 | 1822 | ++
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.44 Association of estimates of omega-3 fatty acid consumption with cardiac death in prospective cohort studies of general population (based on data in Table 3.31)

Table 3.44 Association of estimates of omega-3 fatty acid consumption with cardiac death in prospective cohort studies of general population (based on data in Table 3.31)

| Methodological Quality
| | A | | | | B | C
Applicability | I
| II | Study | Year | N | Effect
| | ABCC | 1997 | 21930 | 0
| | MRFIT | 1992 | 6250 | ++
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.45 Association of estimates of fish consumption with cardiac death in prospective cohort studies of general population (based on data in Table 3.32)

Table 3.45 Association of estimates of fish consumption with cardiac death in prospective cohort studies of general population (based on data in Table 3.32)

| Methodological Quality
| | A | | | | B | | | | C
Applicability | I | | | | | Study | Year | N | Effect | Study | Year | N | Effect
| | | | | | Osler | 2003 | 8497 | 0 | Kromhout | 1985 | 272 | +
| II | Study | Year | N | Effect | Study | Year | N | Effect | Study | Year | N | Effect
| | NHS | 2002 | 84688 | ++ | Adventist | 1997 | 26743 | 0 | Egeland | 2001 | 42612 | +
| | HPS | 1995 | 44895 | + | Mann | 1997 | 10802 | - | Honolulu | 1996 | 8006 | +
| | PHS | 1998 | 20551 | + | Kromhout | 1985 | 852 | +
| | CHS | 2003 | 3910 | ++
| | Oomen | 2000 | 2738 | +
| | WES | 1997 | 1822 | ++
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.46 Association of estimates of omega-3 fatty acid consumption with sudden death in prospective cohort studies of general population (based on data in Table 3.33)

Table 3.46 Association of estimates of omega-3 fatty acid consumption with sudden death in prospective cohort studies of general population (based on data in Table 3.33)

| Methodological Quality
| | A | | | | B | C
Applicability | I
| II | Study | Year | N | Effect
| | PHS | 1998 | 20551 | ++
| | CHS | 2003 | 3910 | +
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.47 Association of estimates of fish consumption with sudden death in prospective cohort studies of general population (based on data in Table 3.34)

Table 3.47 Association of estimates of fish consumption with sudden death in prospective cohort studies of general population (based on data in Table 3.34)

| Methodological Quality
| | A | | | | B | C
Applicability | I
| II | Study | Year | N | Effect
| | PHS | 1998 | 20551 | ++
| | CHS | 2003 | 3910 | +
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.48 Association of estimates of omega-3 fatty acid consumption with myocardial infarction in prospective cohort studies of general population (based on data in Table 3.35)

Table 3.48 Association of estimates of omega-3 fatty acid consumption with myocardial infarction in prospective cohort studies of general population (based on data in Table 3.35)

| Methodological Quality
| | A | | | | B | | | | C
Applicability | I
| II | Study | Year | N | Effect
| | NHS^1^ | 2002 | 84688 | ++
| | HPS | 1995 | 44895 | +
| | PHS | 1995 | 21185 | -
| | Yuan | 2001 | 18244 | ++
III | | | | | | Study | Year | N | Effect
| | | | | | Oomen | 2001 | 667 | -

1 Nurses' Health Study analysis using fish oil (EPA+DHA) published in 2002 and analysis using ALA published in 1999 both reported significant beneficial effect on myocardial infarction.

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.49 Association of estimates of fish consumption with myocardial infarction in prospective cohort studies of general population (based on data in Table 3.36)

Table 3.49 Association of estimates of fish consumption with myocardial infarction in prospective cohort studies of general population (based on data in Table 3.36)

| Methodological Quality
| | A | | | | B | | | | C
Applicability | I
| | Study | Year | N | Effect | Study | Year | N | Effect
| II | NHS | 2002 | 84688 | ++ | Adventist | 1992 | 26743 | 0
| | HPS | 1995 | 44895 | ++
| | PHS | 1998 | 20551 | 0
| | Yuan | 2001 | 18244 | ++
| | CHS | 2003 | 3910 | +
| | WES | 1997 | 1822 | ++
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.50 Association of estimates of omega-3 fatty acid consumption with stroke in prospective cohort studies of general population (based on data in Table 3.37)

Table 3.50 Association of estimates of omega-3 fatty acid consumption with stroke in prospective cohort studies of general population (based on data in Table 3.37)

| Methodological Quality
Applicability | | A | | | | B | | | | C
| I
| II | Study | Year | N | Effect | Study | Year | N | Effect
| | NHS | 2001 | 79839 | + | Seino | 1997 | 2283 | -
| | HPS | 2002 | 43671 | ++
| | PHS | 1995 | 21185 | 0
| | Yuan | 2001 | 18244 | +
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.51 Association of estimates of fish consumption with stroke in prospective cohort studies of general population (based on data in Table 3.38)

Table 3.51 Association of estimates of fish consumption with stroke in prospective cohort studies of general population (based on data in Table 3.38)

| Methodological Quality
| | A | | | | B | | | | C
Applicability | I
| II | Study | Year | N | Effect | Study | Year | N | Effect | Study | Year | N | Effect
| | NHS | 2001 | 79839 | + | NHANES | 1996 | 5192 | + | Kinjo | 1999 | 223710 | 0
| | HPS | 2002 | 43671 | ++ | Keli | 1994 | 872 | +
| | PHS | 1995 | 21185 | -
| | Yuan | 2001 | 18244 | +
| | WES | 1996 | 1847 | 0
| III

Study acronyms:

ABCC = Alpha-Tocopherol Beta-Carotene Cancer Prevention

ADVENTIST = Adventist HeSalth Study

CHS = Cardiovascular Health Study

HPS = Health Professionals Study

MRFIT = Multiple Risk Factor Intervention Study

NHANES = National Health and Nutrition Examination Study

NHS = Nurses' Health Study

PHS = Physicians' Health Study

WES = Western Electric Company Study

Table 3.52 Randomized Controlled Trials That Reported Adverse Events with Consumption of Omega-3 Fatty Acid Supplements

Table 3.52 Randomized Controlled Trials That Reported Adverse Events with Consumption of Omega-3 Fatty Acid Supplements

Author Year | Omega-3 Fatty Acids | | Control | | Duration (weeks) | Clinical Bleeding | | GI Complaints | | Withdraw Due to AE | | Comments
| n | Type Dose (g/d) | n | Type Dose (g/d) | | N-3 | C | N-3 | C | N-3 | C
General population
Wander 1996 | 24 | EPA+DHA 4.3 | 24 | Soybean oil 4 capsules | 36 | | | 1 | 0 | | | Post-menopausal women
Hamazaki 1996 | 13 | DHA 1.5–1.8 | 11 | Soybean oil ND | 13 | | | 2 | 3 | | | 1 weight gain in each group
Kaminski 1993 | 7 | EPA+DHA 5.8 | 7 | ND | 6 | | | “some”
Allard 1997 | 35 | EPA+DHA 5.4 | 37 | Olive oil 6.3 | 6 | | | 3 | 0 | 3 | 0
Hawkes 2002 | 40 | EPA+DHA 0.74 | 40 | Placebo oil 2.0 | 4 | | | 4 | | | | 1 skin rash in n-3 FA
| 40 | EPA+DHA 0.37
Stark 2000 | 18 | EPA+DHA 4.0 | 17 | Primrose oil 8 capsules | 4 | | | 2 | | | | Post-menopausal women
Harris 1993 | 4 | EPA+DHA 0.64 | 4 | Olive oil ND | 4 | | | 1 | | | | 1 headache in n-3 FA
Mueller 1991 | 6 | n-3 FA 8.0 + EPA 3.5 | 6 | Olive oil 8 capsules | 3 | | | 3 | 3 | | | 1 constipation, 1 weight gain, 1 headache in n-3 FA
| | | | | | | | | | | | 1 diarrhea in olive oil
Total | 187 | | 146 | | | | | 16 | 6 | 3 | 0
Cardiovascular disease population
GISSI-P 2001 | 5665 | EPA+DHA 0.85±VitE | 5658 | Vit E or Control | 182 | | | 179 | 93 | 215 | 119
Sacks 1995 | 31 | EPA+DHA 4.8 | 28 | Olive oil ND | 112 | | | 3 | | 3 | 0 | ≥93% in both groups took antiplatelet agents
Von Schacky 1999 | 111 | EPA+DHA 3.5 to1.7 | 112 | Blend of fish oil | 104 | | | 4 | 3 | 4 | 3 | 1 rash in n-3 FA
Leng 1998 | 60 | GLA 1.7 + EPA 0.27 | 60 | Sunflower seed oil 3.0 | 104 | | | 30 | 19 | | | 47 vs 40% on aspirin
Kaul 1992 | 58 | EPA+DHA 3.0 | 49 | Calcium blocker | 48 | 0 | 0 | 2 | 0 | | | All on aspirin
Borchgrevink 1966 | 100 | Linseed oil 10 ml | 100 | Corn oil 10 ml | 40 | | | 7 | 7 | 3 | 0 | All taking anticoagulants
Eritsland 1995 | 119 | EPA+DHA ^2^ and Aspirin | 106 | Aspirin | 36 | 10 | 8 | 34 | | | 5 | 4 | See footnote 2
General population
| 132 | EPA+DHA ^2^ and Warfarin | 154 | Warfarin | | 17 | 14
Maresta 2002 | 125 | EPA+DHA 5.1 | 132 | Olive oil | 26 | 0 | 0 | 2 | 2 | | | All on aspirin
Leaf 1994 | 226 | EPA+DHA 6.9 | 221 | Corn oil | 24 | 8 | 8 | 19 | 22 | 3 | 8 | All on aspirin, 4% (11) infections in each group
Johansen 1999 | 196 | EPA+DHA 5.1 | 192 | Corn oil 5.1 | 24 | | | 3 | 2 | | | 71 vs 67 % on Aspirin
| | | | | | | | | | | | 18% vs 16 on Warfarin
Reis 1989 | 124 | n-3 FA 6.0 + aspirin | 62 | Olive oil | 24 | 4^3^ | 0 | 59 | 11 | 46 | | n-3 vs olive Weight gain: 6 vs 3 (5% in each group)
| | | | | | | | | | | | Diarrhea: 15 vs 4
Milner 1989 | 95 | EPA+DHA 4.5 | 99 | Olive oil | 24 | 1^4^ | 0 | 24 | | | | 1 insomnia, 1 headache in n-3 FA
Bairati 1992 | 59 | EPA+DHA 4.5 | 60 | Olive oil 15 | 24 | | | 29 | 30 | | | All on aspirin
Bellamy 1992 | 60 | EPA+DHA 3.0 | 53 | ND | 24 | | | 4 | 0 | | | 1 diarrhea with n-3 FA, 96% of all on aspirin
Dehmer 1988 | 43 | EPA+DHA 5.4 | 39 | ND | 24 | 0 | 0 | 7 | 3 | | | All on aspirin + dipyridamole
Cairns 1996 | 325 | EPA+DHA 5.4 | 328 | Corn oil | 18 | 17 | 38 | 122 | 101 | 3 | 3 | All on aspirin See footnote 5
Franzen 1993 | 92 | n-3 FA 3.2 | 83 | Olive oil 9 capsules | 16 | 0 | 0 | 13 | 5 | 13 | | All on aspirin
Berrettini 1996 | 20 | EPA+DHA 2.6 | 19 | Corn oil 3.0 | 16 | | | | 1 | 0 | 1 | > 2/3 on aspirin
Berg 1965 | 42 | Linseed oil 10 – 30 ml | 37 | Corn oil 10 – 30 ml | 12 | | | 5 | | 0 | 0 | Diarrhea: 5 in n-3 FA, all on anticoagulants
Berg 1988 | 14 | EPA+DHA 4.5 | 16 | Vegetable oil 15 capsules | 12 | | | 0 | 1 | 0 | 1
Davidson 1989 | 15 | EPA+DHA 3.6 | 15 | Olive oil 20 capsules | 4 | | | | | | | 1 diarrhea in olive oil
| | EPA+DHA 2.4
Total | 7712 | | 7623 | | | 57 | 68 | 512 | 300 | 236 | 139
Hyperlipdemia population
General population
Sirtori 1997 | 470 | EPA+DHA 2.5 to 1.7 | 465 | Olive oil ND | 24 | | | 18 | 21
Harris 1997 | 22 | EPA+DHA 3.4 | 20 | Corn oil ND | 16 | | | 4 | 3 | 0 | 0
Boberg 1986 | 7 | EPA+DHA 3.0 | 7 | Olive oil ND | 16 | | | “some” | | | | 1 skin rash in n-3 FA
Grundt 1995 | 28 | EPA+DHA 3.4 | 29 | Corn oil 4.0 | 12 | | | “some”
Alaswad 1999 | 11 | EPA+DHA 3.4 | 42 | Placebo | 12 | 1 nose | 0
Bonaa 1992 | 72 | EPA+DHA 5.1 | 74 | Corn oil 6.0 | 10 | | | 10 | 7
Wilt 1989 | 19 | EPA+DHA 6.0 | 19 | Placebo | 12 | | | 8 | 8
Silva, 1996 | 20 | EPA+DHA 3.6 | 15 | Soya oil 12 capsules | 8 | | | 4 | | 4
Mori 1999a | 36 | EPA+DHA 4.0 | 20 | Olive oil 4.0 | 6 | | | 1 | | 1
Mori 2000a | 26 | EPA+DHA 4.0 | 14 | Olive oil 4.0 | 6 | | | 1 | | 1
Davidson 1997 | 18 | DHA 1.25 or 2.5 | 8 | Corn and soybean oil 12 capsules | 6 | | | “some”
Contacos 1993 | 10 | EPA+DHA 3.0 | 11 | Placebo | 6 | | | 1
Brox 1983 | 7 | Cod liver oil 30 ml | 11 | ND | 6 | | | 2 | 0
Demke 1988 | 13 | EPA+DHA 1.7 | 18 | Safflower oil 5.0 | 4 | | | “some” | | | | Some diarrhea and headache
Subtotal | 759 | | 753 | | | 1 | 0 | 34 | 31
Diabetes population
Myrup 2001 | 14 | EPA+DHA 4.6 | 15 | Olive oil 21 ml | 52 | | | 3 | 1 | 3 | 0
Rossing 1996 | 14 | EPA+DHA 4.6 | 15 | Olive oil 21 ml | 52 | | | 2 | 0 | 2 | 0
Schectman 1988 | 13 | EPA+DHA 4.0 | 13 | Safflower oil 12 | 24 | | | 1 | 0 | 1 | 0
Vessby 1990 | 5 | EPA+DHA 3.0 | 9 | Olive oil 10 | 8 | | | “some” | | 0 | 1
Hendra 1990 | 40 | EPA+DHA 3.0 | 40 | Olive oil 5 capsules | 6 | | | 1 | 0 | 1 | 0
Mori 1991 | 9 | EPA+DHA 5.2 | 9 | Olive oil ND | 3 | | | “some”
General population
Fasching 1996 | 5 | EPA+DHA 4.7 | 5 | Gemfibrozil (0.9) | 2 | | | 2 | 0
Subtotal | 100 | | 106 | | | | | 9 | 1 | 7 | 1
Hypertension population
Margolin 1991 | 22 | n-3 FA 4.7 | 24 | Corn oil 9.0 | 8 | 1 | | 4 | | | | 1.8% dizziness 5.1% diarrhea, 1 skin rash in n-3 FA
Gray 1996 | 9 | EPA+DHA 3.4 | 10 | Corn oil 1 capsule | 8 | | | 0 | 3 | 0 | 0 | 4 headaches in n-3 FA
Levinson 1990 | 8 | EPA+DHA 15 | 8 | Vegetable oil 50 | 6 | | | 2 | 1 | 1 | 0
Landmark 1993 | 8 | EPA+DHA 4.6 | 10 | Olive oil 5 capsules | 4 | | | 2 | 1 | 0 | 0 | No diarrhea
Subtotal | 47 | | 52 | | | | | 4 | 5 | 1 | 0
All Studies
Total | 8805 | | 8680 | | | 58 | 68 | 575 | 373 | 247 | 140

AE= Adverse Events; C=Control; ND= No data

[] Serious adverse events defined by Scotia Pharmaceuticals based on a WHO scale, including death, life-threatening illness, significant disability on handicap and in –patient hospitalization for any reason.

[] Only bleeding episodes detected clinically were recorded. One bleeding episode required transfusion and operation, the other episodes were minor. In addition, a bleeding complication was the reason for withdrawal in 9 out of the 66 patients.

[] Important bleeding occurred in 4 patients on fish oil and none on placebo. Two patients had severe bleeding at the site of femoral puncture.

[] one patient with chronic lower GI bleeding + and a known diagnosis of diverticulosis required partial colectomy.

[] Most bleeding was mild, leading to permanent discontinuation of study medication in 6 patients.

Table 3.53 Adverse Events Reported in Non-randomized Studies of Omega-3 Fatty Acid Supplements

Table 3.53 Adverse Events Reported in Non-randomized Studies of Omega-3 Fatty Acid Supplements

Author Year | n | Omega-3 fatty acids (g/d) | Duration (weeks) | Clinical bleeding | GI complaints | Withdrawal due to AE | Comments
General population
Schmidt 1992a | 24 | EPA+DHA 3.2 | 36 | | “some”
Berg 1990 | 10 | n-3 FA 1.3 – 9 | 18 | | “some”
Brown 1991 | 12 | n-3 FA 5.0 | 6 | | | 5 | 1 weight gain after 2 wk
Mortensen 1983 | 20 | n-3 FA 4.0 | 4 | | 1
Wojenski 1991 | 9 | EPA+DHA 3.0 | 4 | | 4
Subtotal | 75 | | | | 4 | 5
Cardiovascular disease population
Bowles 1991 | 85 | EPA 2.8 | 24 | | 28 | | “Considerable symptoms” and some diarrhea
Verheugt 1986 | 5 | n-3 FA 3.0 | 24 | | 1
Smith 1989 | 22 | EPA+DHA 3.4 | 4 | 1 nose | 3
Kahl 1987 | 16 | n-3 FA 8.1 | 2 | | 10 | | 4 increased appetite
Subtotal | 128 | | | 1 | 42
Hyperlipdemia population
Dallongeville 1991 | 18 | EPA+DHA 4.8 | 12 | | 6 | 0
Schectman 1989 | 16 | EPA+DHA 6.0 | 12 | | 18 | 1 | 3 diarrhea
Pichter 1992 | 12 | EPA+DHA 3.6 | 12 | | | | Inverse in blood glucose from 97–249 mg/dl, HbA from 5.5 to 7.1%, after removal of n-3 fatty acids, blood glucose normalized.
Otto 1996 | 23 | EPA+DHA 1.5 to 3.0 | 8 | | 1
Schmidt 1989a | 17 | EPA+DHA 5.1 | 6 | | “some”
Subtotal | 86 | | | | 25 | 1
Diabetes population
Tamura 1987 | 62 | EPA 1.8 to 2.7 | 16 | | 1 or 2
Mori 1989 | 10 | EPA+DHA 4.3 | 3 | | 2
Fasching 1991 | 8 | EPA+DHA 6.3 | 2 | | 2
Subtotal | 80 | | | | 5 – 6

GI = Gastrointestinal (not including liver inflammation). AE= Adverse Events

Table 3.54 Randomized Trials of Omega-3 Fatty Acid Supplements that Reported No Adverse Events

Table 3.54 Randomized Trials of Omega-3 Fatty Acid Supplements that Reported No Adverse Events

Author, Year | N | Omega-3 Fatty Acids (g/d) | Duration (Weeks)
Nilsen, 2001 | 150 | EPA+DHA 1.7 | 104
Brox, 2001 | 36 | EPA+DHA 2.6 | 56
Eritsland,1994 | 260 | EPA+DHA 3.4 | 36
Satterfield, 1991 | 175 | n-3 FA 3.0 | 24
Hamazaki 1996 | 16 | EPA 1.8 | 24
Radack, 1990 | 17 | n-3 FA 1.1 – 2.2 | 20
Toft, 1997 | 38 | EPA+DHA 3.4 | 16
Gans, 1990 | 16 | EPA+DHA 3.0 | 16
Goodfellow, 2000 | 15 | EPA+DHA 3.4 | 16
Prisco, 1994 | 10 | EPA+DHA 3.4 | 16
Prisco, 1995 | 10 | EPA+DHA 3.4 | 16
Prisco, 1998 | 8 | EPA+DHA 3.4 | 16
Schmidt, 1988 | 18 | n-3 FA 4.5 | 12
Radack, 1991 | 16 | n-3 FA 2.0 | 12
Vandongen, 1993 | 17 | EPA 1.3 – 2.6 | 12
Nenseter, 2000 | 34 | Fish powder 10 | 12
Yam, 2002 | 34 | n-3 FA 7.0 | 12
Adler, 1997 | 10 | n-3 FA 3.6 | 12
Morris, 1993 | 12 | n-3 FA 3.0 – 6.0 | 12
Salanchas, 1994 | 20 | EPA+DHA 4.0 | 12
Warner, 1989 | 7 | Max EPA 50ml | 12
Solomon, 1990 | 5 | EPA+DHA 4.6 | 12
Mehta, 1988 | 8 | EPA+DHA 5.4 | 12
Calabresi, 2000 | 14 | EPA+DHA 3.4 | 8
Schmidt, 1992 | 11 | n-3 FA 2.0 – 9.0 | 8
Steiner, 1989 | 3 | EPA+DHA 1.6 | 8
Wing, 1990 | 20 | EPA+DHA 4.5 | 8
Luo , 1998 | 6 | EPA+DHA 1.8 | 8
Grimsgaard, 1998 | 147 | EPA+DHA 4.0 | 7
Hansen, 1993 | 11 | EPA+DHA 3.4 to 3.6 | 7
Grimsgaard 1997 | 147 | EPA 4, DHA 4 | 7
Honstra, 1990 | 40 | n-3 FA 1.7 | 6
Van Houwelingen, 1988 | 40 | EPA+DHA 4.7 | 6
Howe, 1994 | 28 | n-3 FA 5.0 | 6
Chan, 2003a | 25 | EPA+DHA 3.4 | 6
Pirich, 1999 | 13 | EPA+DHA 0.4 | 6
Chan, 2002 | 12 | EPA+DHA 3.4 | 6
Conquer, 1999 | 10 | EPA+DHA 3.0 | 6
Vericel, 1999 | 10 | EPA+DHA 0.2 | 6
Axelrod, 1994 | 9 | EPA+DHA 2.6 | 6
Brox, 1981 | 6 | Cod liver oil 25 ml | 6
Chan 2002b | 25 | EPA+DHA 3.4 | 6
Balestieri, 1996 | 8 | n-3 FA 5.1 | 4
Baumann, 1999 | 7 | EPA+DHA 4.6 | 4
Freese, 1997 | 24 | EPA+DHA 5.2 | 4
Mori, 1992 | 15 | EPA+DHA 4.6 | 4
Nozaki, 1991 | 12 | EPA+DHA 8.0 | 4
Davi, 1990 | 10 | EPA 1.8 | 4
Harris, 1991 | 16 | EPA+DHA 2.2 | 4
illa, 2002 | 10 | n-3 FA 3.0 – 6.0 | 4
Swails, 1993 | 7 | EPA+DHA 1.6 | 1
Total | 1,618

Table 3.55 Non-Randomized Studies of Omega-3 Fatty Acid Supplements that Reported No Adverse Events

Table 3.55 Non-Randomized Studies of Omega-3 Fatty Acid Supplements that Reported No Adverse Events

Author, Year | N | Omega-3 Fatty Acid (g/d) | Duration (week)
Saynor, 1992 | 365 | EPA+DHA 1.1–1.8 | 4–364
Shinozaki, 1996 | 16 | EPA 1.8 | 96
Blok, 1997 | 44 | EPA+DHA 1.0–2.9 | 52
Rhodes, 1994 | 15 | EPA+DHA 3.0 | 24
Von Schacky, 1985 | 6 | Cod liver oil 10–40 ml | 20
Nelson, 1997 | 10 | DHA 6.0 | 17
Russo, 1995 | 24 | EPA+DHA 2.6 | 16
Meydani, 1991 | 25 | EPA+DHA 2.4 | 12
Bagdade, 1990 | 8 | EPA+DHA 6.0 | 12
Nau, 1991 | 14 | EPA+DHA 1.0 | 8
Toth, 1995 | 10 | n-3 FA 0.2 | 8
Bonanome, 1996 | 12 | n-3 FA 2.5 | 8
Bagdade, 1996 | 9 | EPA+DHA 4.6 | 8
Berg, 1989 | 10 | EPA+DHA 0.7 | 6
Schmidt, 1991 | 10 | EPA+DHA 0.7 | 6
Schmidt, 1990 | 10 | EPA+DHA 2.1 | 6
Schmidt, 1989 | 10 | n-3 FA 4.0 | 6
Berg, 1989 | 17 | EPA+DHA 5.1 | 6
Haglund, 1990 | 13 | EPA 2.7–5.4 | 4
Glauber, 1988 | 6 | EPA+DHA 5.5 | 4
Suehiro, 1994 | 27 | EPA 1.8 | 4
Harris , 1983 | 12 | n-3 FA 20–29 | 4
Owens, 1990 | 6 | EPA+DHA 4.5 | 4
Kasim-Karakas, 1995 | 14 | EPA+DHA 3.3 | 4
Terano, 1983 | 8 | EPA+DHA 0.3 | 4
Nordoy, 1994 | 6 | EPA+DHA 4.8 | 3
Total | 707