# References and Bibliography

### References

1 USDA. Individual Fatty Acid Intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). Available online at <http://www.barc.usda.gov/bhnrc/foodsurvey/home.htm>.
2 Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). 2002. The National Academy Press.
3 Simopoulos A P, Leaf A. Essentiality of and recommended dietary intakes for omega-6 and omega-3 fatty acids. Ann Nutr Metab. 1999;43(2):127-130. [pmid: 10436312].
4 Fallon S, Enig MG. Tripping Lightly Down the Prostaglandin Pathways.The Price-Pottenger Nutrition Foundation. Avaliable online at <http://www.price-pottenger.org/Articles/Prostaglandin.htm>. 2001.
5 Nair S S, Leitch J W, Falconer J, Garg M L. Prevention of cardiac arrhythmia by dietary (n-3) polyunsaturated fatty acids and their mechanism of action. [Review] [93 refs]. Journal of Nutrition. 1997;127(3):383-393. [pmid: 9082021].
6 James M J, Gibson R A, Cleland L G. Dietary polyunsaturated fatty acids and inflammatory mediator production. Am J Clin Nutr. 2000;71(1 SUPPL.):343S-348S. [pmid: 10617994].
7 Krummel D. Nutrition in Cardiovascular Disease. In: Mahan LK, Escot-Stump S, editors. Krause's Food, Nutrition, and Diet Therapy. W.B. Saunder Company, 1996.
8 Hornstra G. Omega-3 long-chain polyunsaturated fatty acids and health benefits. Amended and updated version of the English translation of <<Oméga-3 et bénéfice santé>>, initially published by Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience). Available online: <http://www.vita-web.com/whatsnew/Omega 3.pdf>. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience).
9 Wright JD, Ervin B, Briefel RR. Consensus workshop on dietary assessment: nutrition monitoring and tracking the year 2000 objectives. Available on line at http://www.cdc.gov/nchs/data/misc/nutri94acc.pdf. 1994. Hyattsville, MD, National Center for Health Statistics.
10 U.S.Department of Agriculture Agricultural Research Service. USDA National Nutrient Database for Standard Reference, Release 16. Nutrient Data Laboratory Home Page. . 2003.
11 Bang H O, Dyerberg J, Sinclair H M. The composition of the Eskimo food in north western Greenland. Am J Clin Nutr. 1980;33(12):2657-2661. [pmid: 7435433].
12 Dyerberg J, Bang H O, Stoffersen E, Moncada S, Vane J R. Eicosapentaenoic acid and prevention of thrombosis and atherosclerosis?. Lancet. 1978;2(8081):117-119. [pmid: 78322].
13 Kromann N, Green A. Epidemiological studies in the Upernavik district, Greenland. Incidence of some chronic diseases 1950-1974. Acta Medica Scandinavica. 1980;208(5):401-406. [pmid: 7457208].
14 Kinjo Y, Beral V, Akiba S, et al. Possible protective effect of milk, meat and fish for cerebrovascular disease mortality in Japan. Journal of Epidemiology. 1999;9(4):268-274. [pmid: 10510585].
15 Crombie I K, McLoone P, Smith W C, Thomson M, Pedoe H T. International differences in coronary heart disease mortality and consumption of fish and other foodstuffs. European Heart Journal. 1987;8(6):560-563. [pmid: 3622538].
16 Kromhout D, Bloemberg B P, Feskens E J, et al. Alcohol, fish, fibre and antioxidant vitamins intake do not explain population differences in coronary heart disease mortality. International Journal of Epidemiology. 1996;25(4):753-759. [pmid: 8921452].
17 Curb J D, Reed D M. Fish consumption and mortality from coronary heart disease (Letter). New Engl J Med. 1985;313:821.
18 Vollset S E, Heuch I, Bjelke E. Fish consumption and mortality from coronary heart disease. New Engl J Med. 1985;313:820-827. [pmid: 4033711].
19 Guallar E, Sanz-Gallardo M I, Van'T V P, et al. Mercury, fish oils, and the risk of myocardial infarction. New England Journal of Medicine. 2002;347(22):1747-1754. [pmid: 12456850].
20 Yoshizawa K, Rimm E B, Morris J S, et al. Mercury and the risk of coronary heart disease in men. New England Journal of Medicine. 2002;347(22):1755-1760. [pmid: 12456851].
21 Harris RP, Helfand M, Woolf SH et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine 2001; 20(3:Suppl):Suppl-35.
22 Tippett K, Enns C, Moshfegh A. Food Consumption Survey in the U.S. Department of Agriculture. National Today. 1999;34(1):33-46.
23 Institute of Medicine Food and Nutrition Board. Dietary Reference Intakes: Applications in Dietary Assessment. Washington DC: National Academy Press, 2000.
24 Damico K, Stoll A, Marangell L, Cohen B. How blind is double-blind? A study of fish oil versus placebo. Prostaglandins Leukotrienes & Essential Fatty Acids. 2003;66(393):395.
25 Balk E M, Bonis P A, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-2982. [pmid: 12052127].
26 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clinical Trials. 1996;17(1):1-12. [pmid: 8721797].
27 Schulz K F, Chalmers I, Hayes R J, Altman D G. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials.[comment]. JAMA. 1995;273(5):408-412. [pmid: 7823387].
28 Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis.[comment]. JAMA. 1999;282(11):1054-1060. [pmid: 10493204].
29 Levey A S, Coresh J, Balk E, et al. National Kidney Foundation practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Annals of Internal Medicine. 2003;139(2):137-147. [pmid: 12859163].
30 Slimani N, Ferrari P, Ocke M, et al. Standardization of the 24-hour diet recall calibration method used in the european prospective investigation into cancer and nutrition (EPIC): general concepts and preliminary results. European Journal of Clinical Nutrition. 2000;54(12):900-917. [pmid: 11114689].
31 Welch A A, Lund E, Amiano P, et al. Variability of fish consumption within the 10 European countries participating in the European Investigation into Cancer and Nutrition (EPIC) study. Public Health Nutrition. 2002;5(6B):1273-1285. [pmid: 12639232].
32 Kromhout D, Keys A, Aravanis C, et al. Food consumption patterns in the 1960s in seven countries. Am J Clin Nutr. 1989;49(5):889-894. [pmid: 2718924].
33 Moreno L A, Sarria A, Popkin B M. The nutrition transition in Spain: A European Mediterranean country. Eur J Clin Nutr. 2002;56(10):992-1003. [pmid: 12373620].
34 Leng G C, Lee A J, Fowkes F G, et al. Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. Clinical Nutrition. 1998;17(6):265-271. [pmid: 10205349].
35 Marchioli R, Barzi F, Bomba E, et al. Early protection against sudden death by n-3 polyunsaturated fatty acids after myocardial infarction: time-course analysis of the results of the Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico (GISSI)-Prevenzione. [see comments.]. Circulation. 2002;105(16):1897-1903. [pmid: 11997274].
36 Nilsen D W, Albrektsen G, Landmark K, et al. Effects of a high-dose concentrate of n-3 fatty acids or corn oil introduced early after an acute myocardial infarction on serum triacylglycerol and HDL cholesterol. Am J Clin Nutr. 2001;74(1):50-56. [pmid: 11451717].
37 Sacks F M, Stone P H, Gibson C M, et al. Controlled trial of fish oil for regression of human coronary atherosclerosis. HARP Research Group. Journal of the American College of Cardiology. 1995;25(7):1492-1498. [pmid: 7759696].
38 Singh R B, Niaz M A, Sharma J P, et al. Randomized, double-blind, placebo-controlled trial of fish oil and mustard oil in patients with suspected acute myocardial infarction: the Indian experiment of infarct survival--4. Cardiovascular Drugs & Therapy. 1997;11(3):485-491. [pmid: 9310278].
39 GISSI-Prevenzione Investigators. Dietary supplementation with n-3 polyunsaturated fatty acids and vitamin E after myocardial infarction: results of the GISSI-Prevenzione trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto miocardico. Lancet. 1999;354(9177):447-455. [pmid: 10465168].
40 Burr M L, Fehily A M, Rogers S, et al. Diet and reinfarction trial (DART): design, recruitment, and compliance. European Heart Journal. 1989;10(6):558-567. [pmid: 2547617].
41 Burr M L, Ashfield-Watt P A L, Dunstan F D J, et al. Lack of benefit of dietary advice to men with angina: Results of a controlled trial. Eur J Clin Nutr. 2003;57(2):193-200. [pmid: 12571649].
42 Leren P. The effect of plasma cholesterol lowering diet in male survivors of myocardial infarction. A controlled clinical trial. Acta Medica Scandinavica - Supplementum. 1966;466:1-92. [pmid: 5228820].
43 de Lorgeril M, Salen P, Martin J L, et al. Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: final report of the Lyon Diet Heart Study. [see comments.]. Circulation. 1999;99(6):779-785. [pmid: 9989963].
44 Singh R B, Dubnov G, Niaz M A, et al. Effect of an Indo-Mediterranean diet on progression of coronary artery disease in high risk patients (Indo-Mediterranean Diet Heart Study): A randomised single-blind trial. Lancet. 2002;360(9344):1455-1461. [pmid: 12433513].
45 Bemelmans W J, Broer J, Feskens E J, et al. Effect of an increased intake of alpha-linolenic acid and group nutritional education on cardiovascular risk factors: the Mediterranean Alpha-linolenic Enriched Groningen Dietary Intervention (MARGARIN) study. Am J Clin Nutr. 2002;75(2):221-227. [pmid: 11815311].
46 Erkkila A T, Lehto S, Pyorala K, Uusitupa M I. n-3 Fatty acids and 5-y risks of death and cardiovascular disease events in patients with coronary artery disease.[comment]. American Journal of Clinical Nutrition. 2003;78(1):65-71. [pmid: 12816772].
47 Burr M L, Fehily A M, Gilbert J F, et al. Effects of changes in fat, fish, and fibre intakes on death and myocardial reinfarction: diet and reinfarction trial (DART). [see comments.]. Lancet. 1989;2(8666):757-761. [pmid: 2571009].
48 Ness A R, Hughes J, Elwood P C, et al. The long-term effect of dietary advice in men with coronary disease: follow-up of the Diet and Reinfarction trial (DART). European Journal of Clinical Nutrition. 2002;56(6):512-518. [pmid: 12032650].
49 Natvig H, Borchgrevink C F, Dedichen J, et al. A controlled trial of the effect of linolenic acid on incidence of coronary heart disease. The Norwegian vegetable oil experiment of 1965-66. Scandinavian Journal of Clinical & Laboratory Investigation - Supplement. 1968;105:1-20. [pmid: 5756076].
50 Nagata C, Takatsuka N, Shimizu H. Soy and fish oil intake and mortality in a Japanese community. Am J Epidemiol. 2002;156(9):824-831. [pmid: 12397000].
51 Yuan J M, Ross R K, Gao Y T, Yu M C. Fish and shellfish consumption in relation to death from myocardial infarction among men in Shanghai, China. American Journal of Epidemiology. 2001;154(9):809-816. [pmid: 11682363].
52 Dolecek T A. Epidemiological evidence of relationships between dietary polyunsaturated fatty acids and mortality in the multiple risk factor intervention trial. Proceedings of the Society for Experimental Biology & Medicine. 1992;200(2):177-182. [pmid: 1579579].
53 Osler M, Andreasen A H, Hoidrup S. No inverse association between fish consumption and risk of death from all-causes, and incidence of coronary heart disease in middle-aged, Danish adults. Journal of Clinical Epidemiology. 2003;56(3):274-279. [pmid: 12725883].
54 Kromhout D, Feskens E J, Bowles C H. The protective effect of a small amount of fish on coronary heart disease mortality in an elderly population. International Journal of Epidemiology. 1995;24(2):340-345. [pmid: 7635594].
55 Mann N, Sinclair A, Pille M, et al. The effect of short-term diets rich in fish, red meat, or white meat on thromboxane and prostacyclin synthesis in humans. Lipids. 1997;32(6):635-644. [pmid: 9208393].
56 Daviglus M L, Stamler J, Orencia A J, et al. Fish consumption and the 30-year risk of fatal myocardial infarction. New England Journal of Medicine. 1997;336(15):1046-1053. [pmid: 9091800].
57 Fraser G E, Shavlik D J. Risk factors for all-cause and coronary heart disease mortality in the oldest-old. The Adventist Health Study. Archives of Internal Medicine. 1997;157(19):2249-2258. [pmid: 9343002].
58 Albert C M, Hennekens C H, O'Donnell C J, et al. Fish consumption and risk of sudden cardiac death. JAMA. 1998;279(1):23-28. [pmid: 9424039].
59 Gillum R F, Mussolino M, Madans J H. The relation between fish consumption, death from all causes, and incidence of coronary heart disease. the NHANES I Epidemiologic Follow-up Study. Journal of Clinical Epidemiology. 2000;53(3):237-244. [pmid: 10760632].
60 Mozaffarian D L R. Cardiac benefits of fish consumption may depend on the type of fish meal consumed: The Cardiovascular Health Study. Circulation. 2003;107(10):1372-1377. [pmid: 12782612].
61 Siscovick D S, Raghunathan T E, King I, et al. Dietary intake and cell membrane levels of long-chain n-3 polyunsaturated fatty acids and the risk of primary cardiac arrest. JAMA. 1995;274(17):1363-1367. [pmid: 7563561].
62 Iso H, Rexrode K M, Stampfer M J, et al. Intake of fish and omega-3 fatty acids and risk of stroke in women. JAMA. 2001;285(3):304-312. [pmid: 11176840].
63 He K, Rimm E B, Merchant A, et al. Fish consumption and risk of stroke in men. JAMA. 2002;288(24):3130-3136. [pmid: 12495393].
64 Morris M C, Manson J E, Rosner B, et al. Fish consumption and cardiovascular disease in the physicians' health study: a prospective study. American Journal of Epidemiology. 1995;142(2):166-175. [pmid: 7598116].
65 Institute of Medicine. Methods of Technology Assessment. Washington DC: National Academy Press, 1985.
66 Gillum R F, Mussolino M E, Madans J H. The relationship between fish consumption and stroke incidence. The NHANES I Epidemiologic Follow-up Study (National Health and Nutrition Examination Survey). Archives of Internal Medicine. 1996;156(5):537-542. [pmid: 8604960].
67 Fraser G E, Strahan T M, Sabate J, Beeson W L, Kissinger D. Effects of traditional coronary risk factors on rates of incident coronary events in a low-risk population. The Adventist Health Study. Circulation. 1992;86(2):406-413. [pmid: 1638709].
68 Djousse L, Pankow J S, Eckfeldt J H, et al. Relation between dietary linolenic acid and coronary artery disease in the National Heart, Lung, and Blood Institute Family Heart Study. American Journal of Clinical Nutrition. 2001;74(5):612-619. [pmid: 11684529].
69 Hu F B, Bronner L, Willett W C, et al. Fish and omega-3 fatty acid intake and risk of coronary heart disease in women. JAMA. 2002;287(14):1815-1821. [pmid: 11939867].
70 Hu F B, Stampfer M J, Manson J E, et al. Dietary intake of alpha-linolenic acid and risk of fatal ischemic heart disease among women. Am J Clin Nutr. 1999;69(5):890-897. [pmid: 10232627].
71 Eritsland J, Arnesen H, Seljeflot I, Hostmark A T. Long-term metabolic effects of n-3 polyunsaturated fatty acids in patients with coronary artery disease. Am J Clin Nutr. 1995;61(4):831-836. [pmid: 7702027].
72 Eritsland J, Arnesen H, Berg K, Seljeflot I, Abdelnoor M. Serum Lp(a) lipoprotein levels in patients with coronary artery disease and the influence of long-term n-3 fatty acid supplementation. Scandinavian Journal of Clinical & Laboratory Investigation. 1995;55(4):295-300. [pmid: 7569731].
73 Eritsland J, Seljeflot I, Arnesen H, Westvik A-B, Kierulf P. Effect of long-term, moderate-dose supplementation with omega-3 fatty acids on monocyte procoagulant activity and release of interleukin-6 in patients with coronary artery disease. Thromb Res. 1995;77(4):337-346. [pmid: 7740525].
74 Reis G J, Boucher T M, Sipperly M E, et al. Randomised trial of fish oil for prevention of restenosis after coronary angioplasty. Lancet. 1989;2(8656):177-181. [pmid: 2568519].
75 Schectman G, Kaul S, Kissebah A H. Effect of fish oil concentrate on lipoprotein composition in NIDDM. Diabetes. 1988;37(11):1567-1573. [pmid: 3181646].
76 Vessby B, Boberg M. Dietary supplementation with n-3 fatty acids may impair glucose homeostasis in patients with non-insulin-dependent diabetes mellitus. J Intern Med. 1990;228(2):165-171. [pmid: 2394967].
77 Hendra T J, Britton M E, Roper D R, et al. Effects of fish oil supplements in NIDDM subjects. Controlled study. Diabetes Care. 1990;13(8):821-829. [pmid: 2209315].
78 Mori T A, Vandongen R, Mahanian F, Douglas A. The effect of fish oil on plasma lipids, platelet and neutrophil function in patients with vascular disease. Advances in Prostaglandin, Thromboxane, & Leukotriene Research. 1991;21A:229-232.
79 Rossing P, Hansen B V, Nielsen F S, et al. Fish oil in diabetic nephropathy. Diabetes Care. 1996;19(11):1214-1219. [pmid: 8908382].
80 Fasching P, Rohac M, Liener K, et al. Fish oil supplementation versus gemfibrozil treatment in hyperlipidemic NIDDM. A randomized crossover study. Hormone & Metabolic Research. 1996;28(5):230-236. [pmid: 8738112].
81 Myrup B, Rossing P, Jensen T, et al. Lack of effect of fish oil supplementation on coagulation and transcapillary escape rate of albumin in insulin-dependent diabetic patients with diabetic nephropathy. Scandinavian Journal of Clinical & Laboratory Investigation. 2001;61(5):349-356. [pmid: 11569481].
82 Eritsland J, Arnesen H, Seljeflot I, Kierulf P. Long-term effects of n-3 polyunsaturated fatty acids on haemostatic variables and bleeding episodes in patients with coronary artery disease. Blood Coagulation & Fibrinolysis. 1995;6(1):17-22. [pmid: 7795149].
83 Leaf A, Jorgensen M B, Jacobs A K, et al. Do fish oils prevent restenosis after coronary angioplasty?. Circulation. 1994;90(5):2248-2257. [pmid: 7955181].
84 Cairns J A, Gill J, Morton B, et al. Fish oils and low-molecular-weight heparin for the reduction of restenosis after percutaneous transluminal coronary angioplasty. The EMPAR Study. Circulation. 1996;94(7):1553-1560. [pmid: 8840843].
85 Milner M R, Gallino R A, Leffingwell A, et al. Usefulness of fish oil supplements in preventing clinical evidence of restenosis after percutaneous transluminal coronary angioplasty. American Journal of Cardiology. 1989;64(5):294-299. [pmid: 2526993].
86 Food and Drug Administration. Safety Reporting Requirements for Human Drug and Biiological Products. 21 CFR Part 310, 312, 314, 320, 600, and 606. Proposed Rules. Available on line at: http://www.fda.gov/ohrms/dockets. Food and Drug Administration, HHS , 12405–12497. 2003. 8-1-0003.

### Bibliography

Clinical Practice Guidelines for Chronic Kidney Disease: Evaluation, classification, and stratification. Am J Kid Dis [39(Suppl 1)], S223–S231. 2002.
Comparative Dietary Risks: Balancing the risk and benefits of fish consumption. The U.S. Environmental Protection Agency and Toxicology Excellence for Risk Assessment (TERA), 1999. Accessed August 3, 2003. Available online at http://www.tera.org/pubs/cdrpage.htm. U.S.Environmental Protection Agency 2003.
Estimated Per Capita Fish Consumption in the United States. Available online at http://www.epa.gov/waterscience/fish/consumption_report.pdf. Accessed August 9, 2003. Environmental Protection Agency . 2002. United States Environmental Protection Agency.
NHANES III Series 11, No.2A, April 1998. Electrocardiogram, Dietary Recall, Laboratory, Dietary Supplement and Prescription Drug. Available online at http://www.cdc.gov/nchs/about/major/nhanes/nh3data.htm. Accessed August 2003. National Center for Health Statistics. 1998.
NHANES III Series 11, No 3A, July 1999. Second Exam files for Dietary Recall, Examination, Laboratory, Additional Laboratory Analyses. Available online at http://www.cdc.gov.nchs/about/major/nhanes/nh3data.htm. Accessed August 2003. National Center for Health Statistics . 1999.
Adler A J, Holub B J. Effect of garlic and fish-oil supplementation on serum lipid and lipoprotein concentrations in hypercholesterolemic men.[comment]. American Journal of Clinical Nutrition. Feb. 1997;65(2):445-50. [pmid: 9022529].
Alaswad K, Pogson G W, Harris W S, et al. Effects of phenytoin, niacin, gemfibrozil, and omega-3 fatty acids on high density lipoproteins in patients with hypoalphalipoproteinemia. Preventive Cardiology. 1999;2(4):144-50.
Albert C M, Hennekens C H, O'Donnell C J, et al. Fish consumption and risk of sudden cardiac death. JAMA. Jan 7. 1998;279(1):23-8. [pmid: 9424039].
Albert C M, Campos H, Stampfer M J, et al. Blood levels of long-chain n-3 fatty acids and the risk of sudden death. New England Journal of Medicine. Apr 11. 2002;346(15):1113-8. [pmid: 11948270].
Allard J P, Kurian R, Aghdassi E, et al. Lipid peroxidation during n-3 fatty acid and vitamin E supplementation in humans. Lipids. May. 1997;32(5):535-41. [pmid: 9168460].
Ascherio A, Rimm E B, Stampfer M J, et al. Dietary intake of marine n-3 fatty acids, fish intake, and the risk of coronary disease among men. New England Journal of Medicine. Apr 13. 1995;332(15):977-82. [pmid: 7885425].
Axelrod L, Camuso J, Williams E, et al. Effects of a small quantity of omega-3 fatty acids on cardiovascular risk factors in NIDDM. A randomized, prospective, double-blind, controlled study. Diabetes Care. Jan. 1994;17(1):37-44. [pmid: 8112187].
Bagdade J D, Buchanan W E, Levy R A, et al. Effects of omega-3 fish oils on plasma lipids, lipoprotein composition, and postheparin lipoprotein lipase in women with IDDM. Diabetes. Apr. 1990;39(4):426-31. [pmid: 2318345].
Bagdade J D, Ritter M, Subbaiah P V. Marine lipids normalize cholesteryl ester transfer in IDDM. Diabetologia. Apr. 1996;39(4):487-91. [pmid: 8778000].
Bairati I, Roy L, Meyer F. Double-blind, randomized, controlled trial of fish oil supplements in prevention of recurrence of stenosis after coronary angioplasty. Circulation. Mar. 1992;85(3):950-6. [pmid: 1537131].
Bairati I, Roy L, Meyer F. Effects of a fish oil supplement on blood pressure and serum lipids in patients treated for coronary artery disease. Canadian Journal of Cardiology. Jan. 1992;8(1):41-6. [pmid: 1617510].
Balestrieri G P, Maffi V, Sleiman I, et al. Fish oil supplementation in patients with heterozygous familial hypercholesterolemia. Recenti Progressi in Medicina. Mar. 1996;87(3):102-5. [pmid: 8650428].
Balk E M, Bonis P A, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. Jun 12. 2002;287(22):2973-82. [pmid: 12052127].
Bang H O, Dyerberg J, Sinclair H M. The composition of the Eskimo food in north western Greenland. Am J Clin Nutr. Dec. 1980;33(12):2657-61. [pmid: 7435433].
Baumann K H, Hessel F, Larass I, et al. Dietary omega-3, omega-6, and omega-9 unsaturated fatty acids and growth factor and cytokine gene expression in unstimulated and stimulated monocytes. A ran-domized volunteer study. Arteriosclerosis Thromb Vasc Biol. Jan. 1999;19(1):59-66.
Bellamy C M, Schofield P M, Faragher E B, et al. Can supplementation of diet with omega-3 polyunsaturated fatty acids reduce coronary angioplasty restenosis rate?. European Heart Journal. Dec. 1992;13(12):1626-31. [pmid: 1289091].
Bemelmans W J, Muskiet F A, Feskens E J, et al. Associations of alpha-linolenic acid and linoleic acid with risk factors for coronary heart disease. European Journal of Clinical Nutrition. Dec. 2000;54(12):865-71. [pmid: 11114683].
Berg K J, Skaga E, Skjaeggestad O, et al. Effect of linseed oil on platelet adhesiveness and bleeding-time in patients with coronary heart-disease. Lancet. Nov 13. 1965;2(7420):980-2. [pmid: 4159214].
Berg S E, Kristensen S D, Dyerberg J. The effect of fish oil on lipids, coagulation and fibrinolysis in patients with angina pectoris. Artery. 1988;15(6):316-29. [pmid: 3178506].
Berg S E, Ernst E, Varming K, et al. The effect of n-3 fatty acids on lipids and haemostasis in patients with type IIa and type IV hyperlipidaemia. Thrombosis & Haemostasis. 1989;62(2):797-801. [pmid: 2814927].
Berrettini M, Parise P, Ricotta S, et al. Increased plasma levels of tissue factor pathway inhibitor (TFPI) after n-3 polyunsaturated fatty acids supplementation in patients with chronic atherosclerotic disease. Thrombosis & Haemostasis. Mar. 1996;75(3):395-400. [pmid: 8701396].
Bialostosky, K. Dietary intake of macronutrients, micronutrients and other dietary constituents: United States, 1988-1994. National Center for Health Statistics. Vital Health Stat 11(245). 2002.
Blok W L, Deslypere J P, Demacker P N, et al. Pro- and anti-inflammatory cytokines in healthy volunteers fed various doses of fish oil for 1 year. European Journal of Clinical Investigation. Dec. 1997;27(12):1003-8. [pmid: 9466128].
Boberg M, Vessby B, Selinus I. Effects of dietary supplementation with n-6 and n-3 long-chain polyunsaturated fatty acids on serum lipoproteins and platelet function in hypertriglyceridaemic patients. Acta Medica Scandinavica. 1986;220(2):153-60. [pmid: 3535392].
Boberg M, Pollare T, Siegbahn A, et al. Supplementation with n-3 fatty acids reduces triglycerides but increases PAI-1 in non-insulin-dependent diabetes mellitus. European Journal of Clinical Investigation. Oct. 1992;22(10):645-50. [pmid: 1459169].
Bonaa K H, Bjerve K S, Nordoy A. Docosahexaenoic and eicosapentaenoic acids in plasma phospholipids are divergently associated with high density lipoprotein in humans. Arteriosclerosis & Thrombosis. Jun. 1992;12(6):675-81. [pmid: 1534256].
Bonanome A, Biasia F, De Luca M, et al. n-3 fatty acids do not enhance LDL susceptibility to oxidation in hypertriacylglycerolemic hemodialyzed subjects. Am J Clin Nutr. Feb. 1996;63(2):261-6. [pmid: 8561069].
Borchgrevink C F, Skaga E, Berg K J, et al. Absence of prophylactic effect of linolenic acid in patients with coronary heart-disease. Lancet. Jul 23. 1966;2(7456):187-9. [pmid: 4161161].
Bowles M H, Klonis D, Plavac T G, et al. EPA in the prevention of restenosis post PTCA. Angiology. Mar. 1991;42(3):187-94. [pmid: 2018239].
Brown A J, Roberts D C. Fish and fish oil intake: effect on haematological variables related to cardiovascular disease. Thrombosis Research. Oct 15. 1991;64(2):169-78. [pmid: 1811337].
Brox J, Olaussen K, Osterud B, et al. A long-term seal- and cod-liver-oil supplementation in hypercholesterolemic subjects. Lipids. Jan. 2001;36(1):7-13. [pmid: 11214732].
Brox J H, Killie J E, Gunnes S, et al. The effect of cod liver oil and corn oil on platelets and vessel wall in man. Thrombosis & Haemostasis. Oct. 1981;46(3):604-11. [pmid: 7031981].
Brox J H, Killie J E, Osterud B, et al. Effects of cod liver oil on platelets and coagulation in familial hypercholesterolemia (type IIa). Acta Medica Scandinavica. 1983;213(2):137-44. [pmid: 6340424].
Burr M L, Ashfield-Watt P A, Dunstan F D, et al. Lack of benefit of dietary advice to men with angina: results of a controlled trial. Eur J Clin Nutr. 2003;57:193-200. [pmid: 12571649].
Burr M L, Fehily A M, Gilbert J F, et al. Effects of changes in fat, fish, and fibre intakes on death and myocardial reinfarction: diet and reinfarction trial (DART). [see comments.]. Lancet. Sep 30. 1989;2(8666):757-61. [pmid: 2571009].
Burr M L, Fehily A M. Fatty fish and heart disease: a randomized controlled trial. World Review of Nutrition & Dietetics. 1991;66:306-12. [pmid: 1647084].
Caicoya M. Fish consumption and stroke: a community case-control study in Asturias, Spain. [see comments.]. Neuroepidemiology. May. 2002;21(3):107-14. [pmid: 12006773].
Cairns J A, Gill J, Morton B, et al. Fish oils and low-molecular-weight heparin for the reduction of restenosis after percutaneous transluminal coronary angioplasty. The EMPAR Study. Circulation. Oct 1. 1996;94(7):1553-60. [pmid: 8840843].
Calabresi L, Donati D, Pazzucconi F, et al. Omacor in familial combined hyperlipidemia: effects on lipids and low density lipoprotein subclasses. Atherosclerosis. Feb. 2000;148(2):387-96. [pmid: 10657575].
Chan D C, Watts G F, Barrett P H, et al. Effect of atorvastatin and fish oil on plasma high-sensitivity C-reactive protein concentrations in individuals with visceral obesity. Clinical Chemistry. Jun. 2002;48(6:Pt 1):t-83. [pmid: 12029003].
Chan D C, Watts G F, Mori T A, et al. Factorial study of the effects of atorvastatin and fish oil on dyslipidaemia in visceral obesity. Eur J Clin Invest. Jun. 2002;32(6):429-36. [pmid: 12059988].
Chan D C, Watts G F, Barrett P H, et al. Regulatory effects of HMG CoA reductase inhibitor and fish oils on apolipoprotein B-100 kinetics in insulin-resistant obese male subjects with dyslipidemia. Diabetes. Aug. 2002;51(8):2377-86. [pmid: 12145148].
Chan D C, Watts G F, Mori T A, et al. Randomized controlled trial of the effect of n-3 fatty acid supplementation on the metabolism of apolipoprotein B-100 and chylomicron remnants in men with visceral obesity. Am J Clin Nutr. Feb. 2003;77(2):300-7. [pmid: 12540386].
Conquer J A, Cheryk L A, Chan E, et al. Effect of supplementation with dietary seal oil on selected cardiovascular risk factors and hemostatic variables in healthy male subjects. Thromb Res. 1999;96(3):239-50. [pmid: 10588467].
Contacos C, Barter P J, Sullivan D R. Effect of pravastatin and omega-3 fatty acids on plasma lipids and lipoproteins in patients with combined hyperlipidemia. Arteriosclerosis & Thrombosis. Dec. 1993;13(12):1755-62. [pmid: 8241095].
Crombie I K, McLoone P, Smith W C, et al. International differences in coronary heart disease mortality and consumption of fish and other foodstuffs. European Heart Journal. Jun. 1987;8(6):560-3. [pmid: 3622538].
Curb J D, Reed D M. Fish consumption and mortality from coronary heart disease (Letter). New Engl J Med. 1985;313:821.
Dallongeville J, Boulet L, Davignon J, et al. Fish oil supplementation reduces beta-very low density lipoprotein in type III dysbetalipoproteinemia. Arteriosclerosis & Thrombosis. Jul. 1991;11(4):864-71. [pmid: 2065040].
Damico, K, Stoll, A, Marangell, LB, and Cohen, BM. How blind is double-blind? A study of fish oil versus placebo. Prostaglandins Leukotrienes & Essential Fatty Acids 66[393], 395. 2003.
Davi G, Belvedere M, Catalano I, et al. Platelet function during ticlopidine and eicosapentaenoic acid administration n patients with coronary heart disease. Platelets. 1990;1(2):81-4. [pmid: 21043936].
Davidson M H, Bagdade J D, Liebson P R, et al. Comparative effects of marine and olive oil dietary supplementation on coronary risk factors. Journal of Applied Cardiology. 1989;4(3):145-51.
Davidson M H, Maki K C, Kalkowski J, et al. Effects of docosahexaenoic acid on serum lipoproteins in patients with combined hyperlipidemia: a randomized, double-blind, placebo-controlled trial. Journal of the American College of Nutrition. Jun. 1997;16(3):236-43. [pmid: 9176830].
Daviglus M L, Stamler J, Orencia A J, et al. Fish consumption and the 30-year risk of fatal myocardial infarction. New England Journal of Medicine. Apr 10. 1997;336(15):1046-53. [pmid: 9091800].
de Lorgeril M, Renaud S, Mamelle N, et al. Mediterranean alpha-linolenic acid-rich diet in secondary prevention of coronary heart disease. Lancet. Jun 11. 1994;343(8911):1454-9. [pmid: 7911176].
de Lorgeril M, Salen P, Martin J L, et al. Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: final report of the Lyon Diet Heart Study. [see comments.]. Circulation. Feb 16. 1999;99(6):779-85. [pmid: 9989963].
Dehmer G J, Popma J J, van den Berg E K, et al. Reduction in the rate of early restenosis after coronary angioplasty by a diet supplemented with n-3 fatty acids. New England Journal of Medicine. Sep 22. 1988;319(12):733-40. [pmid: 2842680].
Demke D M, Peters G R, Linet O I, et al. Effects of a fish oil concentrate in patients with hypercholesterolemia. Atherosclerosis. Mar. 1988;70(12):73-80. [pmid: 3355619].
Djousse L, Pankow J S, Eckfeldt J H, et al. Relation between dietary linolenic acid and coronary artery disease in the National Heart, Lung, and Blood Institute Family Heart Study. American Journal of Clinical Nutrition. Nov. 2001;74(5):612-9. [pmid: 11684529].
Dolecek T A. Epidemiological evidence of relationships between dietary polyunsaturated fatty acids and mortality in the multiple risk factor intervention trial. Proceedings of the Society for Experimental Biology & Medicine. Jun. 1992;200(2):177-82. [pmid: 1579579].
Dyerberg J, Bang H O, Stoffersen E, et al. Eicosapentaenoic acid and prevention of thrombosis and atherosclerosis?. Lancet. Jul 15. 1978;2(8081):117-9. [pmid: 78322].
Egeland G M, Meyer H E, Selmer R, et al. Cod liver oil consumption, smoking, and coronary heart disease mortality: three counties, Norway. International Journal of Circumpolar Health. Apr. 2001;60(2):143-9. [pmid: 11507963].
Emken E A, Adlof R O, Gulley R M. Dietary linoleic acid influences desaturation and acylation of deuterium-labeled linoleic and linolenic acids in young adult males. Biochimica et Biophysica Acta. Aug 4. 1994;1213(3):277-88. [pmid: 7914092].
Eritsland J, Arnesen H, Seljeflot I, et al. Influence of serum lipoprotein(a) and homocyst(e)ine levels on graft patency after coronary artery bypass grafting. Am J Cardiol. Dec 1. 1994;74(11):1099-102. [pmid: 7977066].
Eritsland J, Arnesen H, Seljeflot I, et al. Long-term metabolic effects of n-3 polyunsaturated fatty acids in patients with coronary artery disease. Am J Clin Nutr. Apr. 1995;61(4):831-6. [pmid: 7702027].
Eritsland J, Arnesen H, Seljeflot I, et al. Long-term effects of n-3 polyunsaturated fatty acids on haemostatic variables and bleeding episodes in patients with coronary artery disease. Blood Coag Fibrinol. Feb. 1995;6(1):17-22.
Eritsland J, Arnesen H, Berg K, et al. Serum lp(a) lipoprotein levels in patients with coronary artery disease and the influence of long-term n-3 fatty acid supplementation. Scand J Clin Lab Invest. 1995;55(4):295-300. [pmid: 7569731].
Eritsland J, Seljeflot I, Arnesen H, et al. Effect of long-term moderate-dose supplementation with omega-3 fatty acids on monocyte proagulant activity and release of interleukin-6 in patients with coronary artery disease. Thromb Res. 1995;77(4):337-46. [pmid: 7740525].
Erkkila A T, Sarkkinen E S, Lehto S, et al. Dietary associates of serum total, LDL, and HDL cholesterol and triglycerides in patients with coronary heart disease. Preventive Medicine. Jun. 1999;28(6):558-65. [pmid: 10404553].
Fallon, S and Enig MG. Tripping Lightly Down the Prostaglandin Pathways.The Price-Pottenger Nutrition Foundation. Avaliable online at <http://www.price-pottenger.org/Articles/Prostaglandin.htm>. 2001.
Fasching P, Ratheiser K, Waldhausl W, et al. Metabolic effects of fish-oil supplementation in patients with impaired glucose tolerance. Diabetes. 1991;40(5):583-9. [pmid: 2022303].
Fasching P, Rohac M, Liener K, et al. Fish oil supplementation versus gemfibrozil treatment in hyperlipidemic NIDDM. A randomized crossover study. Hormone & Metabolic Research. May. 1996;28(5):230-6. [pmid: 8738112].
FDA. Safety Reporting Requirements for Human Drug and Biiological Products. 21 CFR Part 310, 312, 314, 320, 600, and 606. Food and Drug Administration, Health and Human Services . 2003. 8-1-0003.
Franzen D, Schannwell M, Oette K, et al. A prospective, randomized, and double-blind trial on the effect of fish oil on the incidence of restenosis following PTCA. Catheterization & Cardiovascular Diagnosis. Apr. 1993;28(4):301-10. [pmid: 8462079].
Fraser G E, Strahan T M, Sabate J, et al. Effects of traditional coronary risk factors on rates of incident coronary events in a low-risk population. The Adventist Health Study. Circulation. 1992;86(2):406-13. [pmid: 1638709].
Fraser G E, Shavlik D J. Risk factors for all-cause and coronary heart disease mortality in the oldest-old. The Adventist Health Study. Arch Intern Med. 1997;157(19):2249-58. [pmid: 9343002].
Fraser G E, Sabate J, Beeson W L, Strahan T M. A possible protective effect of nut consumption on risk of coronary heart disease. The Adventist Health Study. Arch Intern Med. 1992;152(7):1416-24. [pmid: 1627021].
Freese R, Mutanen M. Alpha-linolenic acid and marine long-chain n-3 fatty acids differ only slightly in their effects on hemostatic factors in healthy subjects. Am J Clin Nutr. Sep. 1997;66(3):591-8. [pmid: 9280178].
Gans R O, Bilo H J, Weersink E G, et al. Fish oil supplementation in patients with stable claudication. American Journal of Surgery. Nov. 1990;160(5):490-5. [pmid: 2240382].
Gartside P S, Wang P, Glueck C J. Prospective assessment of coronary heart disease risk factors: the NHANES I epidemiologic follow-up study (NHEFS) 16-year follow-up. Journal of the American College of Nutrition. Jun. 1998;17(3):263-9. [pmid: 9627913].
Gillum R F, Mussolino M E, Madans J H. The relationship between fish consumption and stroke incidence. The NHANES I Epidemiologic Follow-up Study (National Health and Nutrition Examination Survey). Archives of Internal Medicine. Mar 11. 1996;156(5):537-42. [pmid: 8604960].
Gillum R F, Mussolino M, Madans J H. The relation between fish consumption, death from all causes, and incidence of coronary heart disease. the NHANES I Epidemiologic Follow-up Study. Journal of Clinical Epidemiology. Mar 1. 2000;53(3):237-44. [pmid: 10760632].
Glauber H, Wallace P, Griver K, et al. Adverse metabolic effect of omega-3 fatty acids in non-insulin-dependent diabetes mellitus. Ann Intern Med. May. 1988;108(5):663-8. [pmid: 3282462].
Goodfellow J, Bellamy M F, Ramsey M W, et al. Dietary supplementation with marine omega-3 fatty acids improve systemic large artery endothelial function in subjects with hypercholesterolemia. Journal of the American College of Cardiology. Feb. 2000;35(2):265-70. [pmid: 10676668].
Grimsgaard S, Bonaa K H, Hansen J B, et al. Effects of highly purified eicosapentaenoic acid and docosahexaenoic acid on hemodynamics in humans. Am J Clin Nutr. Jul. 1998;68(1):52-9. [pmid: 9665096].
Grundt H, Nilsen D W, Hetland O, et al. Improvement of serum lipids and blood pressure during intervention with n-3 fatty acids was not associated with changes in insulin levels in subjects with combined hyperlipidaemia. Journal of Internal Medicine. Mar. 1995;237(3):249-59. [pmid: 7891046].
Grynberg A, Fournier A, Sergiel J P, et al. Membrane docosahexaenoic acid vs. eicosapentaenoic acid and the beating function of the cardiomyocyte and its regulation through the adrenergic receptors. Lipids. Mar. 1996;31(Suppl):S205-S210. [pmid: 8729120].
Guallar E, Sanz-Gallardo M I, Van'T V P, et al. Mercury, fish oils, and the risk of myocardial infarction. New England Journal of Medicine. 2002;347(22):1747-54. [pmid: 12456850].
Haglund O, Wallin R, Luostarinen R, et al. Effects of a new fluid fish oil concentrate, ESKIMO-3, on triglycerides, cholesterol, fibrinogen and blood pressure. Journal of Internal Medicine. May. 1990;227(5):347-53. [pmid: 2341828].
Hamazaki T, Sawazaki S, Asaoka E, et al. Docosahexaenoic acid-rich fish oil does not affect serum lipid concentrations of normolipidemic young adults. Journal of Nutrition. Nov. 1996;126(11):2784-9. [pmid: 8914949].
Hansen J B, Olsen J O, Wilsgard L, et al. Comparative effects of prolonged intake of highly purified fish oils as ethyl ester or triglyceride on lipids, haemostasis and platelet function in normolipaemic men. European Journal of Clinical Nutrition. Jul. 1993;47(7):497-507. [pmid: 8404785].
Harris W S, Connor W E, McMurry M P. The comparative reductions of the plasma lipids and lipoproteins by dietary polyunsaturated fats: salmon oil versus vegetable oils. Metabolism: Clinical & Experimental. Feb. 1983;32(2):179-84. [pmid: 6827988].
Harris W S, Silveira S, Dujovne C A. The combined effects of N-3 fatty acids and aspirin on hemostatic parameters in man. Thrombosis Research. Feb 15. 1990;57(4):517-26. [pmid: 2109371].
Harris W S, Windsor S L. N-3 fatty acid supplements reduce chylomicron levels in healthy volunteers. Journal of Applied Nutrition. 1991;43(1):5-15.
Harris W S, Muzio F. Fish oil reduces postprandial triglyceride concentrations without accelerating lipid-emulsion removal rates. Am J Clin Nutr. Jul. 1993;58(1):68-74. [pmid: 8317392].
Harris W S, Ginsberg H N, Arunakul N, et al. Safety and efficacy of Omacor in severe hypertriglyceridemia. Journal of Cardiovascular Risk. Oct. 1997;4(56):385-91. [pmid: 9865671].
Harris W S, Isley W L. Clinical trial evidence for the cardioprotective effects of omegaa-3 fatty acids. Curr Atherosclerosis Rep. 2001;3(2):174-9.
Hawkes J S, Bryan D L, Makrides M, et al. A randomized trial of supplementation with docosahexaenoic acid-rich tuna oil and its effects on the human milk cytokines interleukin 1 beta, interleukin 6, and tumor necrosis factor alpha. Am J Clin Nutr. Apr. 2002;75(4):754-60. [pmid: 11916764].
He K, Rimm E B, Merchant A, et al. Fish consumption and risk of stroke in men. JAMA. Dec 25. 2002;288(24):3130-6. [pmid: 12495393].
Hendra T J, Britton M E, Roper D R, et al. Effects of fish oil supplements in NIDDM subjects. Controlled study. Diabetes Care. Aug. 1990;13(8):821-9. [pmid: 2209315].
Hjermann I. Dietary trials for the prevention of coronary heart disease. Eur Heart J. 1987;8(Suppl E):39-44. [pmid: 3315676].
Honstra G, van Houwelingen A C, Kivits G A, et al. Influence of dietary fish on eicosanoid metabolism in man. Prostaglandins. Sep. 1990;40(3):311-29. [pmid: 2123355].
Hornstra, G. Omega-3 long-chain polyunsaturated fatty acids and health benefits. Amended and updated version of the English translation of <<Oméga-3 et bénéfice santé>>, initially published by Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience). Available online: <http://www.vita-web.com/whatsnew/Omega 3.pdf>. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience).
Howe P R, Lungershausen Y K, Cobiac L, et al. Effect of sodium restriction and fish oil supplementation on BP and thrombotic risk factors in patients treated with ACE inhibitors. Journal of Human Hypertension. Jan. 1994;8(1):43-9. [pmid: 8151606].
Hu F B, Stampfer M J, Manson J E, et al. Dietary intake of alpha-linolenic acid and risk of fatal ischemic heart disease among women. Am J Clin Nutr. May. 1999;69(5):890-7. [pmid: 10232627].
Hu F B, Stampfer M J, Rimm E, et al. Dietary fat and coronary heart disease: a comparison of approaches for adjusting for total energy intake and modeling repeated dietary measurements. [see comments.]. American Journal of Epidemiology. Mar 15. 1999;149(6):531-40. [pmid: 10084242].
Hu F B, Bronner L, Willett W C, et al. Fish and omega-3 fatty acid intake and risk of coronary heart disease in women. JAMA. Apr 10. 2002;287(14):1815-21. [pmid: 11939867].
Institute of Medicine. . Methods of Technology Assessment in [underlined: Assessing Medical Technologies]. Washington DC, National Academy Press , 1985. Chapter 3
Institute of Medicine, Food and Nutrition Board. Dietary Reference Intakes: Applications in Dietary Assessment. 2000. Washington DC, National Academy Press.
Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). National Academy Press, 2002
Iso H, Stampfer M J, Manson J E, et al. Prospective study of fat and protein intake and risk of intraparenchymal hemorrhage in women. Circulation. Feb 13. 2001;103(6):856-63. [pmid: 11171795].
Iso H, Rexrode K M, Stampfer M J, et al. Intake of fish and omega-3 fatty acids and risk of stroke in women. JAMA. Jan 17. 2001;285(3):304-12. [pmid: 11176840].
Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clinical Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
James M J, Gibson R A, Cleland L G. Dietary polyunsaturated fatty acids and inflammatory mediator production. Am J Clin Nutr. 2000;71(1 SUPPL.):343S-8S. [pmid: 10617994].
Johansen O, Brekke M, Seljeflot I, et al. N-3 fatty acids do not prevent restenosis after coronary angioplasty: results from the CART study. Coronary Angioplasty Restenosis Trial. Journal of the American College of Cardiology. May. 1999;33(6):1619-26. [pmid: 10334433].
Kahl P E, Schimke E, Hildebrandt R, et al. The influence of cod-liver oil diet on various lipid metabolism parameters, the thromboxane formation capacity, platelet function and the serum MDA level in patients suffering from myocardial infarction. Cor et Vasa. 1987;29(3):199-208. [pmid: 3621950].
Kaminski W E, Jendraschak E, Kiefl R, et al. Dietary omega-3 fatty acids lower levels of platelet-derived growth factor mRNA in human mononuclear cells. Blood. 1993;81(7):1871-9. [pmid: 8461472].
Kaul U, Sanghvi S, Bahl V K, et al. Fish oil supplements for prevention of restenosis after coronary angioplasty. International Journal of Cardiology. Apr. 1992;35(1):87-93. [pmid: 1563884].
Keli S O, Feskens E J, Kromhout D. Fish consumption and risk of stroke. The Zutphen Study. Stroke. Feb. 1994;25(2):328-32. [pmid: 8303739].
Kinjo Y, Beral V, Akiba S, et al. Possible protective effect of milk, meat and fish for cerebrovascular disease mortality in Japan. Journal of Epidemiology. Aug. 1999;9(4):268-74. [pmid: 10510585].
Kristensen S D, Iversen A M, Schmidt E B. N-3 polyunsaturated fatty acids and coronary thrombosis. [Review] [39 refs]. Lipids. 2001;36:S79-S82. [pmid: 11837997].
Kromhout D, Bosschieter E B, de Lezenne C C. The inverse relation between fish consumption and 20-year mortality from coronary heart disease. New England Journal of Medicine. May 9. 1985;312(19):1205-9. [pmid: 3990713].
Kromhout D. N-3 fatty acids and coronary heart disease: epidemiology from Eskimos to Western populations. Journal of Internal Medicine Supplement. 1989;225(731):47-51. [pmid: 2650698].
Kromhout D, Feskens E J, Bowles C H. The protective effect of a small amount of fish on coronary heart disease mortality in an elderly population. International Journal of Epidemiology. Apr. 1995;24(2):340-5. [pmid: 7635594].
Krummel, D. “Chapter 23: Nutrition in Cardiovascular Disease”. In Krause's food, nutrition, and diet therapy. L. Kathleen Mahan, Sylvia Escot-Stump.-9th ed. 1996. W.B. Saunder Company.
Landmark K, Thaulow E, Hysing J, et al. Effects of fish oil, nifedipine and their combination on blood pressure and lipids in primary hypertension. Journal of Human Hypertension. Feb. 1993;7(1):25-32. [pmid: 8450517].
Leaf A, Weber P C. Cardiovascular effects of n-3 fatty acids. [Review] [86 refs]. New England Journal of Medicine. Mar 3. 1988;318(9):549-57. [pmid: 3277056].
Leaf A, Jorgensen M B, Jacobs A K, et al. Do fish oils prevent restenosis after coronary angioplasty?. Circulation. Nov. 1994;90(5):2248-57. [pmid: 7955181].
Leng G C, Lee A J, Fowkes F G, et al. Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. Clinical Nutrition. Dec. 1998;17(6):265-71. [pmid: 10205349].
Leren P. The effect of plasma cholesterol lowering diet in male survivors of myocardial infarction. Acta Med Scand 1966; Suppl 466:1–92.
Levey A S, Coresh J, Balk E, et al. National Kidney Foundation practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Annals of Internal Medicine. Jul 15. 2003;139(2):137-47. [pmid: 12859163].
Levinson P D, Iosiphidis A H, Saritelli A L, et al. Effects of n-3 fatty acids in essential hypertension. American Journal of Hypertension. Oct. 1990;3(10):754-60. [pmid: 2222942].
Luo J, Rizkalla S W, Vidal H, et al. Moderate intake of n-3 fatty acids for 2 months has no detrimental effect on glucose metabolism and could ameliorate the lipid profile in type 2 diabetic men. Results of a controlled study. Diabetes Care. May. 1998;21(5):717-24. [pmid: 9589230].
Marchioli R, Schweiger C, Tavazzi L, et al. Efficacy of n-3 polyunsaturated fatty acids after myocardial infarction: results of GISSI-Prevenzione trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico. Lipids 2001;36:Suppl-26.
Marchioli R, Barzi F, Bomba E, et al. Early protection against sudden death by n-3 polyunsaturated fatty acids after myocardial infarction: time-course analysis of the results of the Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico (GISSI)-Prevenzione. [see comments.]. Circulation. Apr 23. 2002;105(16):1897-903. [pmid: 11997274].
Maresta A, Balduccelli M, Varani E, et al. Prevention of postcoronary angioplasty restenosis by omega-3 fatty acids: main results of the Esapent for Prevention of Restenosis ITalian Study (ESPRIT). American Heart Journal. Jun. 2002;143(6):E5. [pmid: 12075272].
Margolin G, Huster G, Glueck C J, et al. Blood pressure lowering in elderly subjects: a double-blind crossover study of omega-3 and omega-6 fatty acids. Am J Clin Nutr. Feb. 1991;53(2):562-72. [pmid: 1989427].
Mehta J, Lawson D, Saldeen T J. Reduction in plasminogen activator inhibitor-1 (PAI-1) with omega-3 polyunsaturated fatty acid (PUFA) intake. American Heart Journal. Nov. 1988;116(5:Pt 1):t-6. [pmid: 3142242].
Mehta J L, Lopez L M, Lawson D, et al. Dietary supplementation with omega-3 polyunsaturated fatty acids in patients with stable coronary heart disease. Effects on indices of platelet and neutrophil function and exercise performance. Am J Med. Jan. 1988;84(1):45-52. [pmid: 3276185].
Meydani M, Natiello F, Goldin B, et al. Effect of long-term fish oil supplementation on vitamin E status and lipid peroxidation in women. Journal of Nutrition. Apr. 1991;121(4):484-91. [pmid: 1826131].
Meydani S N, Endres S, Woods M M, et al. Oral (n-3) fatty acid supplementation suppresses cytokine production and lymphocyte proliferation: comparison between young and older women. Journal of Nutrition. Apr. 1991;121(4):547-55. [pmid: 2007907].
Milner M R, Gallino R A, Leffingwell A, et al. Usefulness of fish oil supplements in preventing clinical evidence of restenosis after percutaneous transluminal coronary angioplasty. American Journal of Cardiology. Aug 1. 1989;64(5):294-9. [pmid: 2526993].
Moreno L A, Sarria A, Popkin B M. The nutrition transition in Spain: A European Mediterranean country. Eur J Clin Nutr. 2002;56(10):992-1003. [pmid: 12373620].
Mori T A, Vandongen R, Masarei J R, et al. Dietary fish oils increase serum lipids in insulin-dependent diabetics compared with healthy controls. Metabolism: Clinical & Experimental. May. 1989;38(5):404-9. [pmid: 2542722].
Mori T A, Vandongen R, Masarei J R L, et al. Comparison of diets supplemented with fish oil or olive oil on plasma lipoproteins in insulin-dependent diabetics. Metabolism: Clinical & Experimental. 1991;40(3):241-6. [pmid: 2000036].
Mori T A, Vandongen R, Mahanian F, et al. The effect of fish oil on plasma lipids, platelet and neutrophil function in patients with vascular disease. Advances in Prostaglandin, Thromboxane, & Leukotriene Research. 1991;21A:229-32.
Mori T A, Vandongen R, Mahanian F, et al. Plasma lipid levels and platelet and neutrophil function in patients with vascular disease following fish oil and olive oil supplementation. Metabolism: Clinical & Experimental. Oct. 1992;41(10):1059-67. [pmid: 1328817].
Mori T A, Bao D Q, Burke V, et al. Docosahexaenoic acid but not eicosapentaenoic acid lowers ambulatory blood pressure and heart rate in humans. Hypertension. Aug. 1999;34(2):253-60. [pmid: 10454450].
Mori T A, Bao D Q, Burke V, et al. Dietary fish as a major component of a weight-loss diet: effect on serum lipids, glucose, and insulin metabolism in overweight hypertensive subjects. Am J Clin Nutr. Nov. 1999;70(5):817-25. [pmid: 10539741].
Mori T A, Dunstan D W, Burke V, et al. Effect of dietary fish and exercise training on urinary F2-isoprostane excretion in non-insulin-dependent diabetic patients. Metabolism: Clinical & Experimental. Nov. 1999;48(11):1402-8. [pmid: 10582548].
Mori T A, Burke V, Puddey I B, et al. Purified eicosapentaenoic and docosahexaenoic acids have differential effects on serum lipids and lipoproteins, LDL particle size, glucose, and insulin in mildly hyperlipidemic men. Am J Clin Nutr. May. 2000;71(5):1085-94. [pmid: 10799369].
Mori T A, Puddey I B, Burke V, et al. Effect of omega 3 fatty acids on oxidative stress in humans: GC-MS measurement of urinary F2-isoprostane excretion. Redox Report. 2000;5(1):45-6. [pmid: 10905544].
Mori T A, Watts G F, Burke V, et al. Differential effects of eicosapentaenoic acid and docosahexaenoic acid on vascular reactivity of the forearm microcirculation in hyperlipidemic, overweight men. Circulation. Sep 12. 2000;102(11):1264-9. [pmid: 10982541].
Morris M C, Taylor J O, Stampfer M J, et al. The effect of fish oil on blood pressure in mild hypertensive subjects: a randomized crossover trial. Am J Clin Nutr. Jan. 1993;57(1):59-64. [pmid: 8416666].
Morris M C, Manson J E, Rosner B, et al. Fish consumption and cardiovascular disease in the physicians' health study: a prospective study. American Journal of Epidemiology. Jul 15. 1995;142(2):166-75. [pmid: 7598116].
Mozaffarian D L R. Cardiac benefits of fish consumption may depend on the type of fish meal consumed: the Cardiovascular Health Study. Circulation. Mar 18. 2003;107(10):1372-7. [pmid: 12782612].
Mueller B A, Talbert R L, Tegeler C H, et al. The bleeding time effects of a single dose of aspirin in subjects receiving omega-3 fatty acid dietary supplementation. Journal of Clinical Pharmacology. Feb. 1991;31(2):185-90. [pmid: 2010565].
Myrup B, Rossing P, Jensen T, et al. Lack of effect of fish oil supplementation on coagulation and transcapillary escape rate of albumin in insulin-dependent diabetic patients with diabetic nephropathy. Scandinavian Journal of Clinical & Laboratory Investigation. 2001;61(5):349-56. [pmid: 11569481].
Nagata C, Takatsuka N, Shimizu H. Soy and fish oil intake and mortality in a Japanese community. Am J Epidemiol. 2002;156(9):824-31. [pmid: 12397000].
Nair S S, Leitch J W, Falconer J, et al. Prevention of cardiac arrhythmia by dietary (n-3) polyunsaturated fatty acids and their mechanism of action. [Review] [93 refs]. Journal of Nutrition. Mar. 1997;127(3):383-93. [pmid: 9082021].
Natvig H, Borchgrevink C F, Dedichen J, et al. A controlled trial of the effect of linolenic acid on incidence of coronary heart disease. The Norwegian vegetable oil experiment of 1965-66. Scandinavian Journal of Clinical & Laboratory Investigation - Supplement. 1968;105:1-20. [pmid: 5756076].
Nau K L, Katch V L, Tsai A C. Omega-3 polyunsaturated fatty acid supplementation alters selective plasma lipid values in adults with heart disease. Journal of Cardiopulmonary Rehabilitation. 1991;11(6):386-91.
Nelson G J, Kelley D S, Emken E A, et al. A human dietary arachidonic acid supplementation study conducted in a metabolic research unit: rationale and design. Lipids. Apr. 1997;32(4):415-20. [pmid: 9113630].
Nelson G J, Schmidt P S, Bartolini G L, et al. The effect of dietary docosahexaenoic acid on platelet function, platelet fatty acid composition, and blood coagulation in humans. Lipids. Nov. 1997;32(11):1129-36. [pmid: 9397397].
Nenseter M S, Osterud B, Larsen T, et al. Effect of Norwegian fish powder on risk factors for coronary heart disease among hypercholesterolemic individuals. Nutrition Metabolism & Cardiovascular Diseases. Dec. 2000;10(6):323-30.
Ness A R, Hughes J, Elwood P C, et al. The long-term,effect of dietary advice in men with coronary disease: follow-up of the Diet Reinfarction Trial (DART). Eur J Clin Nutr. 2002;56:512-8. [pmid: 12032650].
Nielsen N S, Pedersen A, Sandstrom B, et al. Different effects of diets rich in olive oil, rapeseed oil and sunflower-seed oil on postprandial lipid and lipoprotein concentrations and on lipoprotein oxidation susceptibility. Br J Nutr. May. 2002;87(5):489-99. [pmid: 12010587].
Nilsen D W, Dalaker K, Nordoy A, et al. Influence of a concentrated ethylester compound of n-3 fatty acids on lipids, platelets and coagulation in patients undergoing coronary bypass surgery. Thrombosis & Haemostasis. Aug 1. 1991;66(2):195-201. [pmid: 1771612].
Nilsen D W, Albrektsen G, Landmark K, et al. Effects of a high-dose concentrate of n-3 fatty acids or corn oil introduced early after an acute myocardial infarction on serum triacylglycerol and HDL cholesterol. Am J Clin Nutr. Jul. 2001;74(1):50-6. [pmid: 11451717].
Nordoy A, Hatcher L, Goodnight S, et al. Effects of dietary fat content, saturated fatty acids, and fish oil on eicosanoid production and hemostatic parameters in normal men. Journal of Laboratory & Clinical Medicine. Jun. 1994;123(6):914-20. [pmid: 8201271].
Nozaki S, Garg A, Vega G L, et al. Postheparin lipolytic activity and plasma lipoprotein response to omega-3 polyunsaturated fatty acids in patients with primary hypertriglyceridemia. American Journal of Clinical Nutrition. Mar. 1991;53(3):638-42. [pmid: 2000816].
Oomen C M, Feskens E J, Rasanen L, et al. Fish consumption and coronary heart disease mortality in Finland, Italy, and The Netherlands. American Journal of Epidemiology. May 15. 2000;151(10):999-1006. [pmid: 10853639].
Oomen C M, Ocke M C, Feskens E J, et al. alpha-Linolenic acid intake is not beneficially associated with 10-y risk of coronary artery disease incidence: the Zutphen Elderly Study. [see comments.]. Am J Clin Nutr. Oct. 2001;74(4):457-63. [pmid: 11566643].
Orencia A J, Daviglus M L, Dyer A R, et al. Fish consumption and stroke in men. 30-year findings of the Chicago Western Electric Study. Stroke. Feb. 1996;27(2):204-9. [pmid: 8571410].
Osler M, Andreasen A H, Hoidrup S. No inverse association between fish consumption and risk of death from all-causes, and incidence of coronary heart disease in middle-aged Danish adults. J Clin Epidemiol. 2003;56:274-9. [pmid: 12725883].
Otto C, Ritter M M, Soennichsen A C, et al. Effects of n-3 fatty acids and fenofibrate on lipid and hemorheological parameters in familial dysbetalipoproteinemia and familial hypertriglyceridemia. Metabolism, Clinical and Experimental. Apr. 1996;45(10):1305-11. [pmid: 8843189].
Owens M R, Cave W T Jr. Dietary fish lipids do not diminish platelet adhesion to subendothelium. British Journal of Haematology. May. 1990;75(1):82-5. [pmid: 2375927].
Phillipson B E, Rothrock D R, Connor W E, et al. Reduction of plasma lipids, lipoproteins and apoproteins by dietary fish oils in patients with hypertriglyceridemia. N Engl J Med. 1985;312:1210-6. [pmid: 3990714].
Pietinen P, Ascherio A, Korhonen P, et al. Intake of fatty acids and risk of coronary heart disease in a cohort of Finnish men. The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. American Journal of Epidemiology. May 15. 1997;145(10):876-87. [pmid: 9149659].
Pirich C, Gaszo A, Granegger S, et al. Effects of fish oil supplementation on platelet survival and ex vivo platelet function in hypercholesterolemic patients. Thrombosis Research. Nov 1. 1999;96(3):219-27. [pmid: 10588465].
Prisco D, Paniccia R, Filippini M, et al. No changes in PAI-1 levels after four-month n-3 PUFA ethyl ester supplementation in healthy subjects. Thrombosis Research. Nov 1. 1994;76(3):237-44. [pmid: 7863474].
Prisco D, Filippini M, Francalanci I, et al. Effect of n-3 fatty acid ethyl ester supplementation on fatty acid composition of the single platelet phospholipids and on platelet functions. Metabolism: Clinical & Experimental. May. 1995;44(5):562-9. [pmid: 7752902].
Prisco D, Paniccia R, Bandinelli B, et al. Effect of medium-term supplementation with a moderate dose of n-3 polyunsaturated fatty acids on blood pressure in mild hypertensive patients. Thrombosis Research. Aug 1. 1998;91(3):105-12. [pmid: 9733153].
Radack K, Deck C, Huster G. The effects of low doses of n-3 fatty acid supplementation on blood pressure in hypertensive subjects. A randomized controlled trial. Archives of Internal Medicine. Jun. 1991;151(6):1173-80. [pmid: 1828336].
Radack K L, Deck C C, Huster G A. N-3 fatty acid effects on lipids, lipoproteins, and apolipoproteins at very low doses: results of a randomized controlled trial in hypertriglyceridemic subjects. Am J Clin Nutr. Apr. 1990;51(4):599-605. [pmid: 2181859].
Reis G J, Kuntz R E, Silverman D I, et al. Effects of serum lipid levels on restenosis after coronary angioplasty. American Journal of Cardiology. Dec 1. 1991;68(15):1431-5. [pmid: 1746423].
Reis G J, Silverman D I, Boucher D M, et al. Effects of two types of fish oil supplements on serum lipids and plasma phospholipid fatty acids in coronary artery disease. Am J Cardiol. 1990;66(17):1171-5. [pmid: 2239719].
Renaud S, de Lorgeril M, Delaye J, et al. Cretan Mediterranean diet for prevention of coronary heart disease. Am J Clin Nutr 1995 Jun;61(6:Suppl):Suppl-1376S.
Rhodes L E, O'Farrell S, Jackson M J, et al. Dietary fish-oil supplementation in humans reduces UVB-erythemal sensitivity but increases epidermal lipid peroxidation. Journal of Investigative Dermatology. Aug. 1994;103(2):151-4. [pmid: 8040603].
Rodriguez A F, Guallar-Castillon P, Banegas B Jr, et al. Consumption of fruit and wine and the decline in cerebrovascular disease mortality in Spain (1975-1993). [see comments.]. Stroke. Aug. 1998;29(8):1556-61. [pmid: 9707192].
Rodriguez B L, Sharp D S, Abbott R D, et al. Fish intake may limit the increase in risk of coronary heart disease morbidity and mortality among heavy smokers. The Honolulu Heart Program. Circulation. Sep 1. 1996;94(5):952-6. [pmid: 8790031].
Rossing P, Hansen B V, Nielsen F S, et al. Fish oil in diabetic nephropathy. Diabetes Care. Nov. 1996;19(11):1214-9. [pmid: 8908382].
Russo C, Olivieri O, Girelli D, et al. Omega-3 polyunsaturated fatty acid supplements and ambulatory blood pressure monitoring parameters in patients with mild essential hypertension. Journal of Hypertension. Dec. 1995;13(12:Pt 2):t-6. [pmid: 8903660].
Sacks F M, Stone P H, Gibson C M, et al. Controlled trial of fish oil for regression of human coronary atherosclerosis. HARP Research Group. Journal of the American College of Cardiology. Jun. 1995;25(7):1492-8. [pmid: 7759696].
Salachas A, Papadopoulos C, Sakadamis G, et al. Effects of a low-dose fish oil concentrate on angina, exercise tolerance time, serum triglycerides, and platelet function. Angiology. Dec. 1994;45(12):1023-31. [pmid: 7985829].
Sasazuki S. Fukuoka Heart Study Group. Case-control study of nonfatal myocardial infarction in relation to selected foods in Japanese men and women. Japanese Circulation Journal. Mar. 2001;65(3):200-6. [pmid: 11266195].
Satterfield S, Cutler J A, Langford H G, et al. Trials of hypertension prevention. Phase I design. Annals of Epidemiology. Aug. 1991;1(5):455-71. [pmid: 1669525].
Saynor R, Gillott T. Changes in blood lipids and fibrinogen with a note on safety in a long term study on the effects of n-3 fatty acids in subjects receiving fish oil supplements and followed for seven years. Lipids. 1992;27(7):533-8. [pmid: 1453884].
Schectman G, Kaul S, Kissebah A H. Effect of fish oil concentrate on lipoprotein composition in NIDDM. Diabetes. Nov. 1988;37(11):1567-73. [pmid: 3181646].
Schectman G, Kaul S, Cherayil G D, et al. Can the hypotriglyceridemic effect of fish oil concentrate be sustained?. Annals of Internal Medicine. Mar 1. 1989;110(5):346-52. [pmid: 2492785].
Schmidt E B, Kristensen S D, Sorensen P J, et al. Antithrombin III and protein C in stable angina pectoris--influence of dietary supplementation with polyunsaturated fatty acids. Scandinavian Journal of Clinical & Laboratory Investigation. Sep. 1988;48(5):469-73. [pmid: 3060987].
Schmidt E B, Ernst E, Varming K, et al. The effect of n-3 fatty acids on lipids and haemostasis in patients with type IIa and type IV hyperlipidaemia. Thrombosis & Haemostasis. Sep 29. 1989;62(2):797-801. [pmid: 2814927].
Schmidt E B, Sorensen P J, Pedersen J O, et al. The effect of n-3 polyunsaturated fatty acids on lipids, haemostasis, neutrophil and monocyte chemotaxis in insulin-dependent diabetes mellitus. Journal of Internal Medicine Supplement. 1989;225(731):201-6. [pmid: 2706043].
Schmidt E B, Nielsen L K, Pedersen J O, et al. The effect of n-3 polyunsaturated fatty acids on lipids, platelet function, coagulation, fibrinolysis and monocyte chemotaxis in patients with hypertension. Clinica Chimica Acta. Jul. 1990;189(1):25-32.
Schmidt E B, Pedersen J O, Varming K, et al. n-3 fatty acids and leukocyte chemotaxis. Effects in hyperlipidemia and dose-response studies in healthy men. Arteriosclerosis & Thrombosis. Mar. 1991;11(2):429-35. [pmid: 1998659].
Schmidt E B, Lervang H-H, Varming K, et al. Long-term supplementation with n-3 fatty acids, I: Effect on blood lipids, haemostasis and blood pressure. Scandinavian Journal of Clinical & Laboratory Investigation. 1992;52(3):221-8. [pmid: 1411254].
Schmidt E B, Varming K, Svaneborg N, et al. n-3 polyunsaturated fatty acid supplementation (Pikasol) in men with moderate and severe hypertriglyceridaemia: a dose-response study. Annals of Nutrition & Metabolism. 1992;36(56):283-7. [pmid: 1492755].
Schulz K F, Chalmers I, Hayes R J, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials.[comment]. JAMA. Feb 1. 1995;273(5):408-12. [pmid: 7823387].
Seino F, Date C, Nakayama T, et al. Dietary lipids and incidence of cerebral infarction in a Japanese rural community. Journal of Nutritional Science & Vitaminology. Feb. 1997;43(1):83-99. [pmid: 9151243].
Shah, BV, Barnwell, BG, and Bieler, GS. SUDAAN User's Manual, Release 7.5. Research Triangle Institute. 1997. Research Triangle Park, NC.
Shinozaki K, Kambayashi J, Kawasaki T, et al. The long-term effect of eicosapentaenoic acid on serum levels of lipoprotein (a) and lipids in patients with vascular disease. Journal of Atherosclerosis & Thrombosis. 1996;2(2):107-9. [pmid: 9225217].
Silva J M, Souza I, Silva R, et al. The triglyceride lowering effect of fish oils is affected by fish consumption. International Journal of Cardiology. May. 1996;57(1):75-80. [pmid: 8960947].
Singh R B, Niaz M A, Sharma J P, et al. Randomized, double-blind, placebo-controlled trial of fish oil and mustard oil in patients with suspected acute myocardial infarction: the Indian experiment of infarct survival--4. Cardiovascular Drugs & Therapy. Jul. 1997;11(3):485-91. [pmid: 9310278].
Singh R B, Dubnov G, Niaz M A, et al. Effect of an Indo-Mediterranean diet on progression of coronary artery disease in high risk patients (Indo-Mediterranean Diet Heart Study): A randomised single-blind trial. Lancet. 2002;360(9344):1455-61. [pmid: 12433513].
Sirtori C R, Paoletti R, Mancini M, et al. N-3 fatty acids do not lead to an increased diabetic risk in patients with hyperlipidemia and abnormal glucose tolerance. Italian Fish Oil Multicenter Study. American Journal of Clinical Nutrition. Jun. 1997;65(6):1874-81. [pmid: 9174486].
Siscovick D S, Raghunathan T E, King I, et al. Dietary intake and cell membrane levels of long-chain n-3 polyunsaturated fatty acids and the risk of primary cardiac arrest. JAMA. Nov 1. 1995;274(17):1363-7. [pmid: 7563561].
Slimani N, Ferrari P, Ocke M, et al. Standardization of the 24-hour diet recall calibration method used in the european prospective investigation into cancer and nutrition (EPIC): general concepts and preliminary results. European Journal of Clinical Nutrition. Dec. 2000;54(12):900-17. [pmid: 11114689].
Smith P, Arnesen H, Opstad T, et al. Influence of highly concentrated n-3 fatty acids on serum lipids and hemostatic variables in survivors of myocardial infarction receiving either oral anticoagulants or matching placebo. Thrombosis Research. Mar 1. 1989;53(5):467-74. [pmid: 2660319].
Solomon S A, Cartwright I, Pockley G, et al. A placebo-controlled, double-blind study of eicosapentaenoic acid-rich fish oil in patients with stable angina pectoris. Current Medical Research & Opinion. 1990;12(1):1-11. [pmid: 2188794].
Stark K D, Park E J, Maines V A, et al. Effect of a fish-oil concentrate on serum lipids in postmenopausal women receiving and not receiving hormone replacement therapy in a placebo-controlled, double-blind trial. Am J Clin Nutr. Aug. 2000;72(2):389-94. [pmid: 10919932].
Steiner A, Oertel R, Battig B, et al. Effect of fish oil on blood pressure and serum lipids in hypertension and hyperlipidaemia. J Hypertens. 1989;7(SUPPL. 3):S73-S76.
Suehiro A, Higasa S, Ueda M, et al. Combination effect of eicosapentaenoic acid and platelet suppressive agents on platelets. Current Therapeutic Research, Clinical & Experimental. 1994;55(6):653-9.
Swails W S, Bell S J, Bistrian B R, et al. Fish-oil-containing diet and platelet aggregation. Nutrition. May. 1993;9(3):211-7. [pmid: 8353361].
Tamura Y, Hirai A, Terano T, et al. Anti-thrombotic and anti-atherogenic action of eicosapentaenoic acid. Japanese Circulation Journal. Apr. 1987;51(4):471-7. [pmid: 3039190].
Tavani A, Pelucchi C, Negri E, et al. n-3 Polyunsaturated fatty acids, fish, and nonfatal acute myocardial infarction. Circulation. Nov 6. 2001;104(19):2269-72. [pmid: 11696463].
Terano T, Hirai A, Hamazaki T, et al. Effect of oral administration of highly purified eicosapentaenoic acid on platelet function, blood viscosity and red cell deformability in healthy human subjects. Atherosclerosis. Mar. 1983;46(3):321-31. [pmid: 6303363].
Tippett, KS, Enns, CW, and Moshfegh, AJ. Food Consumption Survey in the U.S. Department of Agriculture. National Today 34[1], 33–46. 1999.
Toft I, Bonaa K H, Ingebretsen O C, et al. Fibrinolytic function after dietary supplementation with omega3 polyunsaturated fatty acids. Arteriosclerosis Thrombosis & Vascular Biology. May. 1997;17(5):814-9.
Toth K, Ernst E, Habon T, et al. Hemorheological and hemodynamical effects of fish oil (Ameu) in patients with ischemic heart disease and hyperlipoproteinemia. Clinical Hemorheology. 1995;15(6):867-75.
USDA. Individual Fatty Acid Intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). Available online at <http://www.barc.usda.gov/bhnrc/foodsurvey/home.htm>.
van Houwelingen A C, Hennissen A A, Verbeek-Schippers F, et al. Effect of a moderate fish intake on platelet aggregation in human platelet-rich plasma. Thrombosis & Haemostasis. Jun 16. 1988;59(3):507-13. [pmid: 3187936].
Vane JR, Flower RJ, Botting RM. History of aspirin and its mechanism of action. Stroke 1990 Dec;21(12:Suppl):Suppl-23.
Verheugt F W A, Schouten J A, Eeltink J C, et al. Omega-3 polyunsaturated fatty acids in the treatment of angina pectoris: Effect on objective signs of exercise-induced myocardial ischemia. Current Therapeutic Research, Clinical & Experimental. 1986;39(2):208-13.
Vericel E, Calzada C, Chapuy P, et al. The influence of low intake of n-3 fatty acids on platelets in elderly people. Atherosclerosis. Nov 1. 1999;147(1):187-92. [pmid: 10525140].
Vessby B, Boberg M. Dietary supplementation with n-3 fatty acids may impair glucose homeostasis in patients with non-insulin-dependent diabetes mellitus. J Intern Med. Aug. 1990;228(2):165-71. [pmid: 2394967].
Villa B, Calabresi L, Chiesa G, et al. Omega-3 fatty acid ethyl esters increase heart rate variability in patients with coronary disease. Pharmacol Res. Jun. 2002;45(6):475. [pmid: 12162948].
Vollset S E, Heuch I, Bjelke E. Fish consumption and mortality from coronary heart disease. New Engl J Med. 1985;313:820-7. [pmid: 4033711].
von Schacky C, Fischer S, Weber P C. Long-term effects of dietary marine omega-3 fatty acids upon plasma and cellular lipids, platelet function, and eicosanoid formation in humans. Journal of Clinical Investigation. Oct. 1985;76(4):1626-31. [pmcid: 424148]. [pmid: 2997286].
von Schacky C, Weber P C. Metabolism and effects on platelet function of the purified eicosapentaenoic and docosahexaenoic acids in humans. Journal of Clinical Investigation. Dec. 1985;76(6):2446-50. [pmcid: 424407]. [pmid: 3001149].
von Schacky C, Angerer P, Kothny W, et al. The effect of dietary omega-3 fatty acids on coronary atherosclerosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. Apr 6. 1999;130(7):554-62. [pmid: 10189324].
Wander R C, Du S-H, Ketchum S O, et al. Effects of interaction of RRR-alpha-tocopheryl acetate and fish oil on low- density-lipoprotein oxidation in postmenopausal women with and without hormone-replacement therapy. Am J Clin Nutr. 1996;63(2):184-93. [pmid: 8561059].
Warner J G, Ullrich I H, Albrink M J, et al. Combined effects of aerobic exercise and omega-3 fatty acids in hyperlipidemic persons. Medicine & Science in Sports & Exercise. 1989;21(5):498-505. [pmid: 2691812].
Welch A A, Lund E, Amiano P, et al. Variability in fish consumption in 10 European countries. IARC Scientific Publications. 2002;156:221-2. [pmid: 12484172].
Welch A A, Lund E, Amiano P, et al. Variability of fish consumption within the 10 European countries participating in the European Investigation into Cancer and Nutrition (EPIC) study. Public Health Nutrition. Dec. 2002;5(6B):1273-85. [pmid: 12639232].
Wing L M, Nestel P J, Chalmers J P, et al. Lack of effect of fish oil supplementation on blood pressure in treated hypertensives. Journal of Hypertension. Apr. 1990;8(4):339-43. [pmid: 2160490].
Wojenski C M, Silver M J, Walker J. Eicosapentaenoic acid ethyl ester as an antithrombotic agent: comparison to an extract of fish oil. Biochimica et Biophysica Acta. Jan 4. 1991;1081(1):33-8. [pmid: 1991153].
Wright, JD, Ervin, B, and Briefel, RR. Consensus workshop on dietary assessment: nutrition monitoring and tracking the year 2000 objectives. Available on line at http://www.cdc.gov/nchs/data/misc/nutri94acc.pdf. 1994. Hyattsville, MD, National Center for Health Statistics.
Yam D, Friedman J, Bott-Kanner G, et al. Omega-3 fatty acids reduce hyperlipidaemia, hyperinsulinaemia and hypertension in cardiovascular patients. Journal of Clinical & Basic Cardiology. 2002;5(3):229-31.
Yoshizawa K, Rimm E B, Morris J S, et al. Mercury and the risk of coronary heart disease in men. New England Journal of Medicine. 2002;347(22):1755-60. [pmid: 12456851].
Yuan J M, Ross R K, Gao Y T, et al. Fish and shellfish consumption in relation to death from myocardial infarction among men in Shanghai, China. American Journal of Epidemiology. Nov 1. 2001;154(9):809-16. [pmid: 11682363].