# Introduction

This evidence report is 1 of 3 reports prepared by the Tufts-New England Medical Center (Tufts-NEMC) Evidence-based Practice Center (EPC) concerning the health benefits of omega-3 fatty acids on cardiovascular diseases. These reports are among several that address topics related to omega-3 fatty acids, and that were requested by the Office of Dietary Supplements, National Institutes of Health, through the EPC Program at the Agency for Healthcare Research and Quality (AHRQ). Three EPCs—the Tufts-NEMC EPC, the Southern California-RAND EPC, and the University of Ottawa EPC—each produced evidence reports. To ensure consistency of approach, the 3 EPCs collaborated on selected methodological elements, including literature search strategies, rating of evidence, and data table design.

The aim of the reports is to summarize the current evidence on the health effects of omega-3 fatty acids on the following: CVD, cancer, child and maternal health, eye health, gastrointestinal/renal diseases, asthma, autoimmune diseases, immune-mediated diseases, transplantation, mental health, and neurological diseases and conditions. In addition to informing the research community and the public on the effects of omega-3 fatty acids on various health conditions, it is anticipated that the findings of the reports will also be used to help define the agenda for future research.

The focus of this report is on CVD outcomes in humans. The other 2 reports by the Tufts-NEMC EPC focus on risk factors of cardiovascular disease and on arrhythmic electrophysiology in animal and in-vitro studies. In this chapter, the metabolism, physiological functions, and the sources of omega-3 fatty acids are briefly discussed. Subsequent chapters describe the methods used to identify and review studies related to omega-3 fatty acids and CVD—including the analytic framework for this report, findings related to the effects of omega-3 fatty acids on cardiovascular conditions, and recommendations for future research in this area.

## Background

### Metabolism and Biological Effects of Essential Fatty Acids

Dietary fat is an important source of energy for biological activities in human beings. Dietary fat encompasses saturated fatty acids, which are usually solid at room temperature, and unsaturated fatty acids, which are liquid at room temperature. Unsaturated fatty acids can be further divided into monounsaturated and polyunsaturated fatty acids. Polyunsaturated fatty acids (PUFAs) can be classified on the basis of their chemical structure into two groups: omega-3 (n-3) fatty acids and omega-6 (n-6) fatty acids. The omega-3 or n-3 notation means that the first double bond from the methyl end of the molecule is in the third. The same principle applies to the omega-6 or n-6 notation. Despite their differences in structure, all fats contain the same amount of energy (9 kcal/g or 37 kJ/g).

Of all fats found in food, 2—alpha-linolenic acid (chemical abbreviation: ALA, 18:3 n-3) and linoleic acid (LA, 18:2 n-6)—cannot be synthesized in the human body, yet are necessary for proper physiological functioning. These 2 fats are called essential fatty acids. The essential fatty acids can be converted in the liver to long-chain polyunsaturated fatty acids (LC PUFAs), which have a higher number of carbon atoms and double bonds. These LC PUFAs retain the omega type (n-3 or n-6) of the parent essential fatty acids.

ALA and LA comprise the bulk of the total PUFAs consumed in a typical North American diet. Typically, LA comprises 89% of the total PUFAs consumed, while ALA comprises 9%. Smaller amounts of other PUFAs make up the remainder ^1^. Both ALA and LA are present in a variety of foods. For example, LA is present in high concentrations in many commonly used oils, including safflower, sunflower, soy, and corn oil. ALA, which is consumed in smaller quantities, is present in leafy green vegetables and in some commonly used oils, including canola and soybean oil. Some novelty oils, such as flaxseed oil, contain relatively high concentrations of ALA, but these oils are not commonly found in the food supply.

The Institute of Medicine suggests that, for adults 19 and older, an adequate intake (AI) of ALA is 1.1–1.6 g/day, while an adequate daily intake of LA is 11–17 g/day ^2^. Recommendations regarding AI differ by age and gender groups, and for special conditions such as pregnancy and lactation.

As shown in Figure 1.1, EPA and DHA can act as competitors for the same metabolic pathways as AA. In human studies, the analyses of fatty-acid compositions in both blood phospholipids and adipose tissue showed similar competitive relationship between omega-3 LC PUFAs and AA. General scientific agreement supports an increased consumption of omega-3 fatty acids and reduced intake of omega-6 fatty acids to promote good health. However, for omega-3 fatty acid intakes, the specific quantitative recommendations vary widely among countries not only in terms of different units - ratio, gram, total energy intake - but also in quantity ^3^. Furthermore, there remain numerous questions relating to the inherent complexities about omega-3 and omega-6 fatty acid metabolism, in particular regarding the inter-relationships between the 2 fatty acids. For example, it remains unclear to what extend ALA is converted to EPA and DHA in humans, and to what extend high intake of omega-6 fatty acids compromises any benefits of omega-3 fatty acid consumption. Without resolution of these 2 foundational questions, it remains difficult to study the importance of omega-6 to omega-3 fatty acid ratio.

Figure 1.1 Classical omega-3 and omega-6 fatty acid synthesis pathways and the role of omega-3 fatty acid in regulating health/disease markers

### Metabolic Pathways of Omega-3 and Omega-6 Fatty Acids

Omega-3 and omega-6 fatty acids share the same pools of enzymes and go through the same oxidation pathways while being metabolized (Figure 1.1). Once ingested, ALA and LA can be elongated and desaturated into LC PUFAs. LA is converted into gamma-linolenic acid (GLA, 18:3 n-6), an omega-6 fatty acid that is a positional isomer of ALA. GLA, in turn, can be converted to the long-chain omega-6 fatty acid, arachidonic acid (AA, 20:4 n-6). ALA can be converted, to a lesser extent, to the long-chain omega-3 fatty acids, eicosapentaenoic acid (EPA; 20:5 n-3) and docosahexaenoic acid (DHA; 22:6 n-3). However, the conversion from parent fatty acids into LC PUFAs occurs slowly in humans, and conversion rates are not well understood. Because of the slow rate of conversion and the importance of LC PUFAs to many physiological processes, humans must augment their level of LC PUFAs by consuming foods that are rich in these important compounds. Meat is the primary food source of AA, while fish is the primary food source of EPA.

The specific biological functions of fatty acids depend on the number and position of double bonds and the length of the acyl chain. Both EPA and AA are 20-carbon fatty acids and are precursors for the formation of prostaglandins, thromboxane, and leukotrienes—hormone-like agents that are members of a larger family of substances called eicosanoids. Eicosanoids are localized tissue hormones that seem to be 1 of the fundamental regulatory classes of molecules in most higher forms of life. They do not travel in the blood, but are created in the cells to regulate a large number of processes, including the movement of calcium and other substances into and out of cells, dilation and contraction of muscles, inhibition and promotion of clotting, regulation of secretions including digestive juices and hormones, and control of fertility, cell division, and growth ^4^.

As shown in Figure 1.1, the long-chain omega-6 fatty acid, AA, is the precursor of a group of eicosanoids including series-2 prostaglandins and series-4 leukotrienes. The omega-3 fatty acid, EPA, is the precursor to a group of eicosanoids including series-3 prostaglandins and series-5 leukotrienes. The series-2 prostaglandins and series-4 leukotrienes derived from AA are involved in intense actions (such as accelerating platelet aggregation and enhancing vasoconstriction and the synthesis of inflammatory mediators) in response to physiological stressors. The series-3 prostaglandins and series-5 leukotrienes that are derived from EPA are less physiologically potent than those derived from AA. More specifically, the series-3 prostaglandins are formed at a slower rate and work to attenuate excessive series-2 prostaglandins. Thus, adequate production of the series-3 prostaglandins, which are derived from the omega-3 fatty acid, EPA, may protect against heart attack and stroke as well as certain inflammatory diseases like arthritis, lupus, and asthma ^4^. In addition, animal studies, have demonstrated that omega-3 LC PUFAs, such as EPA and DHA, engage in multiple cytoprotective activities that may contribute to antiarrhythmic mechanisms^5^. Arrhythmias are thought to be the cause of “sudden death” in heart disease.

In addition to affecting eicosanoid production as described above, EPA also affects lipoprotein metabolism and decreases the production of other compounds—including cytokines, interleukin 1ß (IL-1ß), and tumor necrosis factor a (TNF-a)—that have pro-inflammatory effects. These compounds exert pro-inflammatory cellular actions that include stimulating the production of collagenases and increasing the expression of adhesion molecules necessary for leukocyte extravasation ^6^. The mechanism responsible for the suppression of cytokine production by omega-3 LC PUFAs remains unknown, although suppression of eicosanoid production by omega-3 fatty acids may be involved. EPA can also be converted into the longer chain omega-3 form of docosapentaenoic acid (DPA, 22:5 n-3), and then further elongated and oxygenated into DHA. EPA and DHA are frequently referred to as very long chain omega-3 fatty acids. DHA, which is thought to be important for brain development and functioning, is present in significant amounts in a variety of food products, including fish, fish liver oils, fish eggs, and organ meats. Similarly, AA can convert into an omega-6 form of DPA. Studies have reported that omega-3 fatty acids decrease triglycerides (Tg) and very low density lipoprotein (VLDL) in hypertriglyceridemic subjects, with a concomitant increase in high density lipoprotein (HDL). However, they appear to increase or have no effect on low density lipoprotein (LDL). Omega-3 fatty acids apparently lower Tg by inhibiting VLDL and apolipoprotein B-100 synthesis and decreasing post-prandial lipemia ^7^. Omega-3 fatty acids, in conjunction with transcription factors (small proteins that bind to the regulatory domains of genes), target the genes governing cellular Tg production and those activating oxidation of excess fatty acids in the liver. Inhibition of fatty acid synthesis and increased fatty acid catabolism reduce the amount of substrate available for Tg production ^8^.

As noted earlier, omega-6 fatty acids are consumed in larger quantities (>10 times) than omega-3 fatty acids. Maintaining a sufficient intake of omega-3 fatty acids is particularly important since many of the body's physiologic properties depend upon their availability and metabolism.

### Population Intake of Omega-3 Fatty Acids in the United States

The major source of omega-3 fatty acids is dietary intake of fish, fish oil, vegetable oils (principally canola and soybean), some nuts including walnuts, and dietary supplements. Two population-based surveys, the Continuing Food Survey of Intakes by Individuals 1994-98 (CSFII) and the third National Health and Nutrition Examination (NHANES III) 1988-94 surveys, are the main source of dietary intake data for the U.S. population. NHANES III collected information on the U.S. population aged =2 months. Mexican Americans and non-Hispanic African-Americans, children =5 years old, and adults = 60 years old were over-sampled to produce more precise estimates for these population groups. There were no imputations for missing 24-hour dietary recall data. A total of 29,105 participants had complete and reliable dietary recall. Complete descriptions of the methods used and fuller analyses are later described in this report, under “Methods: Method to Assess the Dietary Intake of Omega-3 Fatty Acids in the US population” and “Results: Population Intake of Omega-3 Fatty Acids in the United States”. CSFII 1994-96, popularly known as the What We Eat in America survey, addressed the requirements of the National Nutrition Monitoring and Related Research Act of 1990 (Public Law 101–445) for continuous monitoring of the dietary status of the American population. In CSFII 1994-96, an improved data-collection method known as the multiple-pass approach for the 24-hour recall was used. Given the large variation in intake from day-to-day, multiple 24-hours recalls are considered to be the best suited for most nutrition monitoring and will produce stable estimates of mean nutrient intakes from groups of individuals ^9^. In 1998, the Supplemental Children's Survey, a survey of food and nutrient intake by children under age of 10, was conducted as the supplement to the CSFII 1994-96. The CSFII 1994-96, 1998 surveyed 20,607 people of all ages with over-sampling of low-income population (<130% of the poverty threshold). Dietary intake data by individuals of all ages were collected over 2 nonconsecutive days by use of two 1-day dietary recalls.

Table 1.1 reports the NHANES III survey mean intake ± the standard error of the mean (SEM), as well as, the median and range for each omega-3 fatty acid. Distributions of EPA, DPA, and DHA were very skewed; therefore, the means and standard errors of the means should be used and interpreted with caution. Table 1.2 reports the CSFII survey mean and median intakes for each omega-3 fatty acid, along with SEMs, as reported in Dietary Reference Intakes by the Institute of Medicine ^2^.

### Dietary Sources of Omega-3 Fatty Acids

Omega-3 fatty acids can be found in many different sources of food, including fish, shellfish, some nuts, and various plant oils. Table 1.3 lists the amount of omega-3 fatty acids in some commonly consumed fish, shellfish, nuts, and edible oils, selected from the USDA website (accessed November 3, 2003) http://www.nal.usda.gov/fnic/foodcomp (Finfish and Shellfish Products, sr16fg15.pdf; Fats and Oils, sr16fg04.pdf; and Nut and Seed Products, sr16fg12.pdf) ^10^.

## Overview of Effect of Omega-3 Fatty Acids on Cardiovascular Diseases

Since the first cross-cultural epidemiological studies in the 1970s ^11,^ ^12^, the body of evidence supporting a role for omega-3 fatty acids in the prevention of CVD risk has continued to increase. Dyerberg reported that disease patterns for the Greenland Inuit, when compared with those for the population of Denmark, exhibited a significantly lower rate of death from acute myocardial infarction (MI) despite only moderate differences in blood cholesterol levels ^12^. Similar results were found among inhabitants of Greenland and Denmark who were followed for over 25 years ^13^.

Additional evidence was found in the Japanese population where it was demonstrated that higher fish intake was associated with considerably lower rates of MI, other ischemic heart diseases, and atherosclerosis ^14^. In addition, studies among the Inuit of Nunavik, Quebec showed that progressive increases in levels of the omega-3 fatty acids EPA and DHA in plasma phospholipids reflected dietary intakes of these fatty acids and were beneficially associated with key risk factors for CVD ^13^. However, the beneficial effects of omega-3 fatty acids are not consistently observed in all epidemiological studies. Data from 21 other countries showed no relation between fish consumption and mortality from coronary heart diseases ^15^. Among countries participating in the Seven Countries Study, 15-year mortality from coronary heart disease was highest in Finland despite an average fish intake of about 60 grams per day ^16^. Two other cohort studies carried out in Hawaii and Norway also found no relationship between fish consumption and CVD ^17,^ ^18^.

It should be noted, however, that some factors might confound the outcomes of all of these studies. Such factors include type of study design, the type of fish consumed, estimate of fish intake, study population, concomitant drugs, demographic features (e.g., sex, age), baseline diet, subject characteristics (e.g., lipid levels, weight, blood pressure), measurement errors, and environmental contaminants.

The effect of omega-3 fatty acids on risk factors, intermediate markers of CVD and how this effect relates to clinical outcomes, is addressed in another report Effects of Omega-3 Fatty Acids on Cardiovascular Disease Risk Factors. The report on risk factors also examines how the effects of omega-3 fatty acids on risk factors and intermediate markers can be modified by various factors, including concomitant drugs, demographic features (e.g., sex, age), baseline diet, subject characteristics (e.g., lipid levels, weight, blood pressure) and omega-3 fatty acids relates to different measures of tissue and plasma fatty acid levels.

This report reviews information from experimental and observational studies that investigate the effect of dietary or supplemental omega-3 fatty acids on CVD outcomes.

Ultimately, the most important questions relating to omega-3 fatty acids pertain to their effect on clinical outcomes such as mortality, myocardial infarction, and stroke. These questions are addressed in this report, which primarily summarizes evidence of human clinical outcomes. More specifically, this report answers the question of how dietary or supplemental omega-3 fatty acids affect each type of CVD outcomes, including mortality (all cause mortality, CVD death, cardiac death, sudden death), nonfatal MI, angina incidence, stroke, and others. The report also draws on the NHANES III database to determine the mean intake of omega-3 fatty acids in the US population and various sub-populations, and to determine whether there is a difference in the mean intake of omega-3 fatty acids between adults with and without cardiovascular disease. Finally, it investigates adverse events and drug interactions associated with omega-3 fatty acids and whether omega-3 fatty acids can play a role in primary and secondary prevention of CVD events.

Fish accounts for a large part of omega-3 fatty acid consumption in the US and around the world. Due to the effect of environmental pollution, various types of contaminants such as methylmercury, PCBs (Polychlorinated Biphenyls), dioxins, chlordane and DDT (Dichloro-diphenyl-trichloroethane) have been reported in fish caught in lakes, rivers, estuaries, and oceans. Although methylmercury occurs naturally in nature and trace amounts are found in all fish and this amount is believed to have no harmful effects on human consumption, very high levels of methylmercury that may have serious health implications have been reported in certain types of fish. The Food and Drug Administration (FDA), Environmental Protection Agency (EPA), and state government agencies have issued consumer advisories cautioning women who are pregnant and women of childbearing age who may become pregnant about the risks of mercury in fish. The FDA cautions young children and women of childbearing age to avoid four types of fish—tilefish, swordfish, shark, and king mackerel—and to limit consumption of all other fish to 12 ounces per week. Although the major toxic effect of concern for methylmercury is neurotoxicity in the unborn or young child, concerns have also been raised about its association with coronary heart disease in adults ^19,^ ^20^.

Although issues with methylmercury and other contaminants, and potential risks from carcinogens as a result of food preparation methods, are important to decision making about the benefits and risks of fish consumption, they are beyond the scope of this report. Readers are advised to learn more about these issues at the FDA and EPA websites (http://vm.cfsan.fda.gov/~dms/admehg.html, http://www.fda.gov/fdac/reprints/mercury.html, http://www.epa.gov/ost/fish/, http://www.epa.gov/mercury/fish.htm), and to read an EPA funded report on balancing the risk and benefits of fish consumption (http://www.tera.org/pubs/cdrpage.htm).