# Appendix F

## Linear Regression Results

D.1. Linear Regression Results for the Estimation of Adjusted Mean ± Standard Error of the Mean (SEM) of Linoleic Acid (LA, 18:2 n-6) (%kcal/day) Intake for Sex, Age, and Race/ethnicity; Respondents with a History of CVD Compared to those without CVD, NHANES III (1988-94)

Variance Estimation Method: Taylor Series (WR)

SE Method: Robust (Binder, 1983)

Working Correlations: Independent

Link Function: Identity

Response variable Linoleic acid (18:2n-6) %kcal/day

For Subpopulation: Adults, age>17

Independent Variables and Effects | | | | Design
| | Beta | S.E. | Effect | T:Beta=0 | P-value
Intercept | | 5.66 | 0.15 | 2.78 | 36.86 | 0.000
CVDS
| Yes | -0.10 | 0.11 | 1.57 | -0.96 | 0.3440
| No | 0.00 | 0.00 | - | - | -
SEX
| Male | -0.27 | 0.07 | 2.44 | -3.74 | 0.0005
| Female | 0.00 | 0.00 | - | - | -
Age Groups
| Adults < 45 y | 0.08 | 0.09 | 3.22 | 0.86 | 0.3946
| Adults >= 45 y | 0.00 | 0.00 | - | - | -
Race
| Non-Hispanic white | 0.40 | 0.15 | 3.10 | 2.61 | 0.0120
| Non-Hispanic black | 0.45 | 0.16 | 2.34 | 2.78 | 0.0077
| Mexican-American | 0.56 | 0.16 | 1.46 | 3.62 | 0.0007
| Other | 0.00 | 0.00 | - | - | -

Contrast | Degrees of Freedom | Wald ChiSq | P-value Wald ChiSq
OVERALL MODEL | 7 | 33568.93 | 0.0000
MODEL MINUS INTERCEPT | 6 | 35.13 | 0.0000
INTERCEPT | - | - | -
CVDS | 1 | 0.91 | 0.3393
SEX | 1 | 13.96 | 0.0002
Age groups | 1 | 0.74 | 0.3904
RACE | 3 | 13.39 | 0.0039

Marginal | | LS Mean | SE | T:Marg=0 | P-value
CVDS
| Yes | 5.85 | 0.11 | 54.76 | 0.0000
| No | 5.96 | 0.05 | 113.95 | 0.0000

D.2. Linear Regression Results for the Estimation of Adjusted Mean ± Standard Error of the Mean (SEM) of Alpha Linolenic Acid (ALA, 18:3 n-3) (%kcal/day) Intake for Sex, Age, and Race/Ethnicity; Respondents with (a History of) CVD Compared to those without CVD, NHANES III (1988-94)

Variance Estimation Method: Taylor Series (WR)

SE Method: Robust (Binder, 1983)

Working Correlations: Independent

Link Function: Identity

Response variable alpha linolenic acid (18:3 n-3) %kcal/day

For Subpopulation: Adults, age>17

Independent Variables and Effects | | Beta | SED | Design Effect | T:Beta=0 | P-value
Intercept | | 0.50 | 0.02 | 2.75 | 31.92 | 0.0000
CVDS
| Yes | -0.02 | 0.01 | 1.26 | -2.30 | 0.0259
| No | 0.00 | 0.00 | - | - | -
SEX
| Male | -0.02 | 0.01 | 2.08 | -3.27 | 0.0020
| Female | 0.00 | 0.00 | - | - | -
Age groups
| Adults < 45 y | -0.01 | 0.01 | 2.63 | -0.86 | 0.3944
| Adults >=45 y | 0.00 | 0.00 | - | - | -
RACE
| Non-Hispanic white | 0.10 | 0.02 | 4.13 | 5.47 | 0.0000
| Non-Hispanic black | 0.06 | 0.02 | 2.78 | 3.36 | 0.0015
| Mexican-American | 0.03 | 0.02 | 1.71 | 1.97 | 0.0550
| Other | 0.00 | 0.00 | - | - | -

Contrast | Degrees of Freedom | Wald ChiSq | P-value Wald ChiSq
OVERALL MODEL | 7 | 35291.10 | 0.0000
MODEL MINUS INTERCEPT | 6 | 58.79 | 0.0000
INTERCEPT | - | - | -
CVDS | 1 | 5.28 | 0.0216
SEX | 1 | 10.69 | 0.0011
Age groups | 1 | 0.74 | 0.3902
RACE | 3 | 49.59 | 0.0000

Marginal | | LS Mean | SEM | T:Marg=0 | P=value
CVDS
| Yes | 0.54 | 0.01 | 58.34 | 0.0000
| No | 0.57 | 0.01 | 111.78 | 0.0000