# Appendix E

## Minnesota Code

Minnesota Code Comments

Major Q, QA waves | 1.1 or 1.2 except 1.2.8 | Highest code in and leadgroup
ST depression | 4.1 or 4.2
Negative T waves | 5.1 or 5.2
Complete AV block | 6.1 | Coded visually, not coded in NHANES I
WPW pattern | 6.4
Artificial pacemaker | 6.8 | Coded visually, not coded in NHANES I
Ventricular conduction defect | 7.1 or 7.2 or 7.4
Atrial fibrillation/flutter | 8.3 | Coded visually
ST elevation | 9.2

## Minor ECG abnormalities

Minnesota Code Comments

Minor Q waves | 1.2.8 or 1.3
High R waves | 3.1 or 3.3 | Any 3.1 or 3.3 code
Minor ST codes | 4.3 or 4.4
Minor T wave codes | 5.3 or 5.4
Prolonged PR interval | 6.3
RR' in V1 or V2 | 7.3 or 7.5
Left anterior fascicular block | 7.7

## Probable myocardial infarction by the Minnesota Code

Major Q/QS waves (Code 1.1.1 through 1.1.7), or Moderate Q/QS waves with ST depression or T wave inversion (Code 1.2.1 through 1.2.7 and code 4.1, 4.2, 5.1 or 5.2)

## Possible myocardial infarction by the Minnesota Code

Moderate Q/QS waves without ST depression or T wave inversion (Code 1.2.1 through 1.2.7 without Code 4.1, 4.2, 5.1 and 5.2),or minor Q/QS waves with ST depression or T wave inversion (Code 1.2.8 or 1.3.1 through 1.3.6 and Code 4.1, 4.2, 5.1 or 5.2)

## Probable LVH by the Minnesota Code

Code 3.1 with code 5.1 or 5.2 or 5.3

## Possible LVH by the Minnesota Code

Code 3.1 without code 5.1 and 5.2 and 5.3, OR Any code 3.3