# Appendix D. Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

## American College of Physicians

- Katherine D. Sherif, MD
- Director, Center for Women's Health
- Medical College of Pennsylvania Hospital
- 3300 Henry Avenue
- Drexel University College of Medicine
- Philadelphia, PA 19129-1191

## American Heart Association

- Penny Kris-Etherton, PhD, RD
- Distinguished Professor of Nutrition
- Nutrition Department
- The Pennsylvania State University
- S-126 Henderson Building
- University Park, PA 16802

## Other Reviewers

- Michael Miller, MD, FACC, FAHA
- Associate Professor of Medicine and Epidemiology
- Director, Center for Preventive Cardiology
- Division of Cardiology
- University of Maryland Medical Center
- 22 South Greene Street, Room S3B06
- Baltimore, Maryland 21201

## National Heart, Lung, Blood Institute

- Eva Obarzanek, PhD, MPH, RD
- Research Nutritionist
- Prevention Scientific Research Group
- Division of Epidemiology and Clinical Applications
- National Heart, Lung, and Blood Institute
- 6701 Rockledge Drive, Room 8136
- Bethesda, MD 20892-7936

## Office of Dietary Supplements, National Institutes of Health

- Anne Thurn, PhD
- Director
- Evidence-Based Review Program
- Office of Dietary Supplements
- National Institutes of Health
- Bldg. 31, Room 1B29
- Bethesda, MD 20892-2086