# Appendix C. Evidence Tables

## Evidence Table 1 - Part A

Evidence Table 1. Randomized Controlled Trials of Effects of Omega-3 Fatty Acids on Mortality and CVD Outcomes: Part A

Author Year | Study characteristics | Duration | Eligibility Criteria | Concurrent Disease/ Conditions/Medication | | | | | *Intervention (N, Source, Dosage, Duration) | | | Comparator (N, Source)
Bemelmans 2002 | Age: 55 y | RCT | Subjects with cholesterol from 6–8 mmol/L & 2 other CV risk factors: DBP >95 mm Hg or SBP >160 mm Hg, BMI >27 kg/m2, anti-hypertensive meds, smoking, history of CVD or family hx of early onset CVD | NEC= nutritional educational control | | | | | Self-adminstered semiquantitative FFQ | | | [underlined: Average intake LA diet]
MARGARIN | % Male: 45.5 | 2 y | Exclusion: diabetes, hyperthyroidism, use of aspirin, anticoagulants, lipid lowering drugs | NEI= nutritional educational intervention | | | | | | | | | [underlined: Average intake ALA diet] | | | % LA: 58%
| Race: 100% w | | | | NEC+LA | NEC+ALA | NEI+LA | NEI+ALA | % LA: 46% | | | % ALA: 0.3%
| Enrolled/Evaluated 266 | | | %fam Hx CVD: | 44 | 40 | 47 | 37 | % ALA: 15% | | | 1.0 g/d n=157
| Location: Holland | | | %smokers: | 51 | 51 | 46 | 47 | 6.3 g/d n=109
| Sites: multiple | | | %use of Antihypertensives: | 42 | 44 | 52 | 63
Burr 2003 | Age: 61 y | RCT | Male patients <70 treated for angina | | Fish | fruit | fish+fruit | sensible diet | Fish advice (n=299) at least two weekly portions fish + fruit advice (n=307) or fish oil up to 3 g/wk | | | Sensible eating (n=297)
| % Male: 100 | 3–9 y | Exclusion: men who never had exertional chest pain or discomfort; men awaiting CABG; men who already ate oily fish 2/wk; intolerance toward fish or fish oil | %Smokers | 24 | 22 | 25 | 24 | [underlined: EPA, g/wk] | | | [underlined: EPA g/wk]
| Race: 100% w | | | %heart attack | 50 | 48 | 50 | 52 | | Fish | Fish + fruit | Baseline | 0.66
| Enrolled/Evaluated 3114/1571 | | | %HTN | 49 | 46 | 48 | 49 | Baseline | 0.67 | 0.54 | 6 mo | 0.78
| Location: UK | | | %DM | 11 | 11 | 14 | 13 | 6 mo | 3.32 | 2.65
| Sites: multiple | | | %beta blockers | 43 | 42 | 42 | 40
Burr 1989 | Age: 56.7 y | RCT | Non-diabetic men under 70 years recovering from MI. | (1989 data) | Fish adv | No Fish adv | | | Fish advice: (n=1015) at least two weekly portions (200–400 g) of fatty fish (mackerel, herring, kipper, pilchard, sardine, salmon, trout) | | | No fish advice (n=1018)
Burr 1991 | % Male: 100 | 2 y | Exclusions: diabetics, men awaiting cardiac surgery, men intending to eat an intervention diet | % Smokers: | 61.7 | 62.2 | | | EPA, g/wk | | | | 6 mo | 2 yr
DART | Race: ND | 10 y | At the end of 2000, 972 former participants still survived | %Prev MI: | 19. 0 | 22.7 | | | [underlined: At 6 months (n=947).] | | | n | 932 | 862
Ness 2002 (10 y follow up of DART) | Enrolled/Evaluated 4371/2033 | | | %Angina: | 20.8 | 23.9 | | | 2.3±1.3
| Location: UK | | | %Hypertension: | 22.7 | 24.6 | | | [underlined: At 2 years (n=883)]
| Sites: multiple | | | [underlined: Drug treatment] | | | | | Subjects: n= 883
| | | | %B-Blocker: | 26.2 | 32.6 | | | 2.4±1.4
| | | | %Other antihypertensives: | 34.9 | 32.4
| | | | %Antiangina: | 46.5 | 47.2
| | | | %Anticoagulant: | 4.8 | 6.9
| | | | %Aspirin/antiplatelet: | 10.1 | 10.3
| | | | %Digoxin/antiarrhythmic: | 9.2 | 9.8
De Lorgeril 1999 | Age: 53.5 y | RCT | Consecutive patients who survived a first MI, randomized between March 1988-March 1992. <70 yrs, clinically stable, no medical or social condition to limit ability to participate in dietary trial. | | Mediterr diet | Prudent diet | | | Diet, n=302. More bread, root & green vegetables, more fish, less meat, more fruit, butter & cream replaced by margarine. | | | Prudent diet: n=303
Renaud 1995 | % Male: 81 | 5 y | | % Curr. Smokers: | 4.9 | 7.6 | | | Since subjects would not accept olive oil as the only fat, canola oil-based margarine was supplied to experimental group.
De Lorgeril 1994 | Race: 100% W | | | % Primary ventricular fibrillation: | 4.3 | 4.0
The Lyon Heart Trial | Enrolled/Evaluated 605/605 | | | %Thrombolytics tx: | 45.9 | 49.7
| Location: France | | | %Coronary angiography: | 38.7 | 44.7
| Sites: multiple | | | %Coronary angioplasty: | 15.6 | 14.7
| | | | Anticoagulants: | 26.4 | 29.4
| | | | Antiplatelets: | 64.8 | 62.6
| | | | B-blockers: | 63.4 | 60.2
| | | | CCB: | 21.7 | 20.4
| | | | ACE inhibitors: | 6.1 | 9.3
Leng 1998 | Mean age: 65.7 y | RCT | Patients with intermittent claudication and ABPI <0.9 in 1 limb; Patients with stable claudication >6 mo recruited from Peripheral Vascular Clinic. | | Treatment | Placebo | | | 1.68 g/d GLA + 0.27 g/d EPA | | | 0.5 g/d sunflower oil
| % Male: 68.3 | 2 y | Exclusions: critical ischemia, arterial surgery or angioplasty within 30 mo, unstable angina or MI within 3 mo, severe liver disorders, malignancy or epilepsy; current anticoagulants, lithium, or phenothiazines, or pregnancy | % smokers | 40 | 38.8 | | | n=60 | | | n=60
| Race: white | | | BMI/kg | 26.5 | 26.8
| Enrolled/evaluated 120 | | | SBP | 158.7 | 161.7
| Location: Scotland | | | % Prev MI | 23.3 | 11.9
| Sites: multiple | | | % angina | 33.9 | 25
| | | | % diabetes | 6.7 | 11.7
| | | | claudication, mean yrs | 5.11 | 4.25
| | | | % aspirin use | 46.7 | 40
Leren 1966 | Mean age: 56.2 y | RCT | All Oslo male residents aged 30–64 with diagnosis of MI | | Diet | Placebo | | | Cholesterol lowering diet (more fish) | | | Usual diet
| % Male: 100 | 5 y | | % smokers | 42 | 39 | | | + 15–30 ml soybean oil/d | | | N=206
| Race: white | | | mean wt | 172 | 174 | | | (ALA ~1–1.9 g/d)
| Enrolled/evaluated 458/412 | | | HBP | 38 | 25 | | | n=206
| Location: Norway | | | % claudication | 2 | 4
| Sites: multiple
Marchioli, 2002, 1999 | Age: 59.3 y | RCT | Patients with MI w/in 3 mo | All participants=11323 | | | | | EPA+DHA, 0.85–0.88 (g/d) (n=2835) | | | Vitamin E (3 g/d): n=2830
GISSI- Prevenzione Trial (GISSI -P) | % Male: 85.3 | 3.5 y | No age limits, no contraindication to n-3 PUFA, a-tocopherol, known congenital defects of coagulation. | Disease condition, | N | (%) | | | n-3 PUFA + vit E (n=2830) | | | Control: n=2828
| Race: 100% W | | | Arterial HTN: | 4026 | (35.6)
| Enrolled/Evaluated 11323 | | | DM: | 1683 | (14.9)
| Location: Italy | | | Prev. MI: | 1357 | (12.1)
| Sites: multiple | | | Claudication: | 501 | (4.6)
| | | | Angina grade (CCVS)
| | | | Slight limit (II): | 509 | (1.9)
| | | | Severe limit (III)/at rest (IV): | 209 | (1.9)
| | | | Dyspnea on normal/mild exertion (II–III): | 1136 | (10.1)
| | | | Ventric.Arrhythmia: | 1876 | (23.5)
| | | | [underlined: Medications] | N | (%)
| | | | Antiplatelet drugs: | 10309 | (91.0)
| | | | ACE inhibitors | 5280 | (46.9)
| | | | B-blockers: | 4986 | (44.3)
| | | | Cholesterol-lowering drugs: | 534 | (4.7)
| | | | (CABG or PTCA): | 560 | (5.0)
Natvig 1968 | Age: 30–70 y | RCT | Healthy Norwegians | ND | | | | | linseed oil 10 mL/d (55% ALA) | | | Sunflower seed oil (1.4% ALA)
| % Male: 100 | 1 y | | | | | | | n=6716 | | | n=6690
| Race: 100% W
| Enrolled/Evaluated 16,600/13,406
| Location: Norway
| Sites: multiple
Nilsen 2001 | Age: 64 y | RCT | Patients w/ acute MI verified by WHO; age >18y; discontinuation of fish oil products | | n-3 | corn oil | | | Omacor: 2 capsules/d | | | Corn oil 2x/d
| % Male: 77 | 1.5 y | Exclusion: Expected survival <2 y because of severe heart failure (NY Heart Association class IV), malignancy, ongoing GI | [underlined: Smoking]: | 59 | 57 | | | 0.85–8.82 g/d EPA+DHA | | | N=150
| Race: 100% W | | bleeding or verified stomach | [underlined: SBP:] | 124.5 | 122.1 | | | n=150
| Enrolled/Evaluated 551/474 | | ulcer; thrombo-cytopenia or platelets < 100 × 109/L; liver insufficiency | %Fish oil pre-trial:
| Location: Norway | | | -No: | 104 | 113
| Sites: 1 | | | -Yes: | 45 | 37
| | | | Clinical Background (%)
| | | | Angina pectoris: | 49 | 57
| | | | Heart failure: | 15 | 11
| | | | Prev MI: | 32 | 38
| | | | Revascularizations: | 12 | 15
| | | | Hypertension: | 40 | 33
| | | | Hypertension treatment: | 29 | 26
| | | | Fam. Hist. CAD: | 98 | 97
| | | | Diabetes: | 18 | 13
| | | | β-Blocker: | 32 | 29
| | | | ACE inhibitors: | 14 | 19
| | | | Diuretics: | 18 | 19
| | | | Aspirin: | 34 | 28
| | | | Warfarin: | 4 | 10
| | | | Statins: | 9 | 12
Sacks 1995 | Age: 62 y | RCT | Patients at B&W or Beth Israel Hospitals aged 30–75 with >30% lumen diameter of major coronary artery, <250 mg/dl chol, <350 TG. | | Fish oil | olive oil | | | n-3 dose/d=6g (2.8 EPA + 1.92 DHA + 1.2 other) | | | Corn oil
| % Male: 93 | 2.3 y | Exclusions: CHF, liver, renal or serious GI disease, DM, current smoking, alcohol >14 drinks/w. | %HTN | 48 | 36 | | | n=31 | | | n=28
| Race: 100% W | | | %diabetes | 16 | 11
| Enrolled/Evaluated 59 | | | %family hx CVD | 68 | 46
| Location: US | | | %CABG | 52 | 43
| Sites: 1 | | | %MI | 55 | 57
| | | | [underlined: Medications]
| | | | BB | 55 | 54
| | | | CCBs | 52 | 43
| | | | Antiplatelets | 97 | 93
| | | | ACE | 10 | 11
Singh 1997 | Age: 48.6 y | RCT | Patients admitted with a diagnosis of suspected AMI. | | Fish | Mustard | Placebo | | 6 MaxEPA capsules/day (1.08 g EPA + 0.72 g DHA) | | | 20 g/day mustard oil (ALA 2.9 g); n=120 or Placebo: n=118
| % Male: ND | 1 y | | %PrevMI: | 24.6 | 16.6 | 15.2 | | n=122
| Race: 100% Indian | | | %Prev angina: | 14.7 | 26.6 | 25.4
| Enrolled/Evaluated 404/ 360 | | | %smokers: | 26.2 | 24.9 | 15.2
| Location: India | | | %aspirin: | 32.8 | 39.9 | 35.4
| Sites: 1 | | | % Q-Wave MI: | 77 | 76.6 | 72.8
| | | | % non Q-Wave: | 13.1 | 13.3 | 11.8
| | | | % angina: | 8.2 | 6.6 | 10.1
Singh 2002 | Age: 48.5 y | RCT | Patients >25 y with major risk factors of CAD (HBP, hyper-cholesterolemia, or DM), angina, or previous MI in absence or presence of other factors. | | Intervention diet | control | | | Indo-Mediterranean diet group: at least 400–500 g/d of fruits, vegetables, nuts. Also encouraged to eat 400–500 g/d of whole grains daily, as well as 3–4 servings of mustard or soybean oil per day. | | | NCEP diet, 30% energy from total fat,. <10% from saturated fat, <300 mg cholesterol/d
| % Male: 89.7 | 2 y | Exclusions: absence of major risk factors, cancer, chronic diarrhea or dysentery, blood urea of >6.6 mmol/L, arthritis. | % hypercholesterolemia: | 72 | 74 | | | N=499 | | | N=501
| Race: 100% Indian | | | % HBP: | 39 | 35
| Enrolled/Evaluated 1,000 | | | % DM: | 19 | 23
| Location: India | | | %Smokers (<15cig/day): | 20 | 16
| Sites: Multiple | | | %Smokers (>15cig/d): | 31 | 28

## Evidence Table 1 - Part B

Evidence Table 1. Randomized Controlled Trials of Effects of Omega-3 Fatty Acids on Mortality and CVD Outcomes: Part B

Author, Year, | Outcome, Definition | Results | | | | | | | Comments
| | | | | | | | | Funding sources
Bemelmans 2002 | Standardized questionnaire was used to inventory the mortality and morbidity outcomes. | | NEC+LA | NEC+ALA | NEI+LA | NEI+ALA | | | Limitations: baseline values between groups measuring fish intake highly significant; possible double counting
MARGAR IN | | CV death | 1 | 1 | 1 | - | | | Funding: Prevent Fund; Unilever Research.
| | Nonfatal MI | 1 | - | 3 | -
| | Stroke | 1 | - | 1 | -
| | PTCA or revascularization | 2 | - | - | 1
Burr 2003 | Details of cardiac deaths obtained from hospital records, other sources. Sudden death defined as in PHS: death within 1 hr of symptom onset | | Fish | Fruit | Fish + Fruit | Sensible diet | | | Funding: British Heart Fdn; Seven Seas, Novex Pharma; The Fish Fdn
| | N | 764 | 779 | 807 | 764
| | Deaths (%) | 141 (18.5) | 133 (17.1) | 142 (17.6) | 109 (14.3)
| | Cardiac deaths (%) | 94 (12.3) | 72 (9.2) | 86 (10.7) | 67 (8.8)
| | Sudden deaths (%) | 42 (5.5) | 30 (3.9) | 31 (3.8) | 17 (2.2)
| | | All fish | No fish | p for trend
| | N | 1571 | 1543
| | Deaths (%) | 283 (18.0) | 242 (15.7) | 0.008
| | Cardiac Deaths (%) | 180 (11.5) | 139 (9.0) | 0.02
| | Sudden Deaths (%) | 73 (4.6) | 47 (3.) | 0.02
| | [underlined: HR : mortality of subjects with fish advice] | | [underlined: p value]
| | All Deaths | 1.15 (0.96–1.36) | 0.13
| | Cardiac deaths | 1.26 (1.00–1.58) | 0.047
| | Sudden deaths | 1.54 (1.06–2.23) | 0.025
Burr 1989, Burr 1991 | Total mortality and IHD events (IHD deaths and nonfatal MI) confined to deaths and events occurring within 2 y of entry into trial | [underlined: Deaths and reinfarctions in relation to dietary advice] | | | | | | | Funding: Welsh Scheme for Development of Health + Social Research; Welsh Heart Research Fdn; Flora Project; Seven Seas Health Care, Novex Pharma.
DART | | | Fish Advice (N=1015) (%) | No fish advice (N= 1018) (%) | | | | | Additional Funding: Wales Office of Research & Development for Health & Social Care; British Heart Fdn
| | All deaths: | 94(9.3%) | 130 (12.8%)
| | IHD deaths: | 78 (7.7%) | 116 (11.4%)
| | Nonfatal MI: | 49(4.8%) | 33(3.2%)
| | IHD events: | 127 (12.5%) | 149 (14.6%)
| | Effects of Dietary Intervention on deaths and IHD events (multivariate)
| | | Effects on all deaths | Effects on IHD deaths
| | Fish Advice, RR (95% CI): | 0.71 (0.54–0.93) | 0.84 (0.66–1.07)
Ness 2002 (10y follow up of DART) | | 10 yr follow-up data | | | | | | | Additional Funding: Wales Office of Research & Development for Health & Social Care; British Heart Fdn
| | [underlined: Mortality from all-causes, coronary disease, stroke]
| | | Fish Advice | No fish advice | HR (adjusted)*
| | All-cause mortality
| | | 10 y | 143 | 166 | 0.85 (0.68–1.07)
| | | Overall | 530 | 553 | 0.95 (0.85–1.07)
| | Coronary heart Disease
| | | 10 y | 86 | 88 | 0.98 (0.72–1.32)
| | | Overall | 354 | 384 | 0.92 (0.80–1.07)
| | Stroke
| | | 10 y | 10 | 14 | 0.71 (0.32–1.61)
| | | Overall | 29 | 33 | 1.23 (0.71–2.14)
| | No stroke data for yrs 1–5
| | (Adjusted for history of MI, angina, HTN at baseline, Xray cardiomegaly, pulmonary congestion or edema at baseline, tx with beta-blockers or aantihypertensives, digoxin, anticoagulants)
De Lorgeril 1999 | Primary endpoint is all-cause mortality—each surviving subject was contacted every 2 years. Incidence of IHD events was defined as deaths attributed to IHD + reinfarctions. | [underlined: End Points in the 2 Groups and Risk Ratios for the 3 Composite Outcomes] | | | | | | | Astra-Galve Co.
De Lorgeril 1994 | | | Control n(rate) | Experimental n(rate) | Risk Ratio | P for trend
Renaud 1995 | | | Person yrs:1383 | Person yrs: 1467
The Lyon Heart Trial | | Cardiac deaths | 19 (1.37) | 6(0.41) | 0.35 (0.15–0.83) | 0.01
| | Nonfatal AMI | 25(2.70) | 8(0.54)
| | Total primary end points: | 44 (4.07) | 14(0.95) | 0.28 (0.15–0.53) | 0.0001
| | (composite outcome 1)
| | Noncardiac deaths | 5(0.36) | 8(0.54)
| | All-cause deaths | 24(1.74) | 14(0.95) | 0.44(0.21–0.94) | 0.03
| | Major 2^nd^end points:
| | Perioprocedural infarction: | 2 | 0
| | Unstable angina: | 24 | 6
| | Heart failure | 11 | 6
| | Stroke: | 4 | 0
| | Pulmonary embolism: | 3 | 0
| | Peripheral embolism: | 2 | 1
| | Total secondary endpoints: | 46(4.96) | 13(1.35)
| | Total primary+secondary endpts.
| | (composite outcome 2): | 90(9.03) | 27(2.59) | 0.33 (0.21–0.52) | 0.0001
| | Minor secondary endpts | person yrs: 927 | person yrs: 966
| | Stable angina | 29 | 21
| | Elective myocardial revascularization | 45 | 37
| | Post-PTCA restenosis: | 15 | 9
| | Thromophlebitis | 1 | 2
| | Total Minor end points: | 90(9.71) | 68 (7.04)
| | Total major minor endpoints: | 180(18.74) | 95 (9.63) | 0.53 (0.38–74) | 0.0002
| | In the Mediterranean diet group, cardiac death and nonfatal MI was reduced (14 events versus 44 in the prudent Western-type diet group, P=0.0002). Adjusted risk ratios ranged from 0.28 to 0.53.
Leng 1998 | CV Disease: divided into 4 groups: MI (evidence of ECG changes, WHO questionnaire, or recall of MI; or criteria fullfilled for MI 5 years prior to examination); stroke (recall or stroke criteria fulfilled); intermittent claudication (WHO questionnaire evidence, or major asymptomatic disease of ABPI <0.7); no disease (none of the above criteria or evidence of angina). | | Fatty Acids | Placebo | | | | | Medication and placebos supplied by Scotia Pharmaceuticals
| | % deaths, all cause | 5 | 5
| | % CV deaths | 3.3 | 3.3
| | [underlined: Nonfatal CV events]
| | % MI | 5 | 6.7
| | % coronary events | 10 | 15
| | % stroke, TIA | 5 | 1.7
| | [underlined: Lower limb disease]
| | Critical ischemia/amputation | 0 | 1.7
| | Angioplasty/bypass | 5 | 1.7
Leren 1966 | MI: development of Q wave plus typical chest pains, rise in body temp, leucocytes >10,000/mm, sedimentation rate >50% 1^st^value (Westergren method), SGOT >50 units or 100% 1^st^value, pulmonary edema, pericardial friction murmur | [underlined: Data from Hjermann 1987] | | | | | | | ND
| Sudden death: fatal episodes with chest pains preceding death | | Diet n=206 | Control n=206 | p value
| | Fatal MI | 10 | 23
| | Sudden death | 27 | 27
| | Nonfatal MI | 24 | 31
| | Major CHD relapses | 61 | 81 | 0.05
| | Total CV Mortality | 38 | 52 | 0.09
| | All-cause Mortality | 41 | 55 | 0.13
Marchioli, 2002 | The causes of death were classified according to codes (ICD-9). Sudden death was defined as natural death, instantaneous or within 1 hour of the onset of acute symptoms, and unexpected as to the time and mode of death | [underlined: Overall Efficacy Profie of n-3 PUFAs During GISSI-Prevenzione Follow-Up (42 months) (38,418 person years)] | | | | | | | Bristol-Myers Squibb, Pharmacia-Upjohn, Societa Prodotti Antibiotici, Pfizer, Bracco.
GISSI- Prevenzione Trial | | | T (%) | C (%) | RR (95% CI) | P-value
GISSI, 1999 | | Death, nonfatal MI+stroke: | 718 (12.7%) | 795 (14.1%) | 0.85 (0.74–0.98) | <0.05
| | CVD death, nonfatal MI+stroke: | 556 (9.8%) | 621 (11.0%) | 0.80 (0.68–0.94) | <0.01
| | All fatal events: | 477 (8.4%) | 554 (9.8%) | 0.79 (0.66–0.93) | <0.01
| | CVD death: | 310(5.5%) | 370 (6.5%) | 0.70 (0.56–0.86) | <0.001
| | Cardiac Death: | 247 (4.4%) | 306 (6.5%) | 0.65 (0.51–0.82) | <0.001
| | Coronary Death: | 209 (3.7%) | 258 (4.6%) | 0.68 (0.53–0.88) | <0.01
| | Sudden death: | 111(2.0%) | 154 (2.7%) | 0.55 (0.39–0.77) | <0.001
| | Nonfatal MI: | 223 (3.9%) | 233(4.1%) | 0.91(0.70–1.18) | NS
| | Nonfatal Stroke: | 62 (1.1%) | 57(1.0%) | 1.22 (0.75–1.97) | NS
| | CHD death and nonfatal MI: | 418 (7.4%) | 475 (8.4%) | 0.78 (0.65–0.94) | <0.01
| | Fatal and nonfatal stroke: | 92 (1.6%) | 77 (1.4%) | 1.22 (0.81–1.85) | NS
Natvig 1968 | Definition from ICD codes 420, 795.2 | | Deaths: All causes | | | CHD +Sudden Death | | | Funding source: Norwegian Industrial Health Services
| | | Expected | | | Expected | | | Unreliable results based on expectation of mortality
| | | Observed | Oslo | Norway | Observed | Oslo | Norway | Unclear verification of mortality
| | A) Linseed: | 43 | 79.7 | 65.5 | 27 | 31.2 | 24.9
| | B) Sunflower Seed: | 40 | 79.3 | 65.3 | 27 | 31.2 | 25.0
| | MI in observation year
| | | Observed | Expected
| | Sunflower Seed | 53 | 54.6
| | Linseed | 66 | 55.1
| | The mortality from all cause as well as from coronary heart disease was the same in the sunflower seed and linseed oil groups. Morbidity was similar, but with the following differences: a. In previous angina pectoris patients 1^st^MI were more numerous in the linseed group (12 cases) than in the sunflower seed group (2 cases). B. In the first three quarters of the observation year, particularly in the first quarter, 1^st^MI were more numerous in the linseed group. In the last quarter the situation reversed. (P=0.003)
Nilsen 2001 | Cardiac events were defined as cardiac deaths, resuscitation, recurrent MI, unstable angina, revascularization and death from other causes were also recorded. | No. of any cardiac events | n-3 | Corn oil N% | | | | | No data on funding
| | 0 | 108 | 114
| | 1 | 27 | 20
| | 2 | 8 | 9
| | ≥3 | 7 | 7
| | Type of first cardiac event
| | Cardiac death | 4 | 5
| | Resuscitation | 0 | 1
| | Recurrent MI | 15 | 11
| | Unstable angina | 21 | 18
| | Type of Most Serious Cardiac Events
| | Cardiac Death | 8 | 8
| | Resuscitation | 1 | 1
| | Recurrent MI | 15 | 11
| | Unstable angina | 18 | 16
| | Hazard Ratio (HR) of experiencing event by treatment group HR (CI)
| | No. of events: | n-3 | corn oil | n-3 vs. oil
| | Fatal cardiac events and resuscitations
| | Cardiac deaths | 8 | 8 | 1.02 (0.38, 2.71)
| | Resuscitation | 1 | 2 | --
| | Cardiac death or resuscitation | 9 | 9 | 1.01(0.40, 2.55)
| | Nonfatal cardiac events
| | Recurrent MI | 21 | 15 | 1.43(0.74, 2.78)
| | UAP | 26 | 23 | 1.16 (0.66, 2.02)
| | Recurrent MI or UAP | 39 | 31 | 1.30 (0.81, 2.08)
| | Revascularization
| | CABG or PTCA(revascularization): | 43 | 49 | 0.92 (0.61, 1.38)
| | Total Mortality
| | Cardiac or noncardiac death | 11 | 11 | 1.02 (0.46, 2.27)
| | Death or resuscitation | 12 | 12 | 1.02 (0.46, 2.27)
| | First Events
| | 1^st^cardiac event, fatal or not | 42 | 36 | 1.19 (0.76, 1.86)
| | Men | 31 | 30 | 1.10 (0.66, 1.81)
| | Women | 11 | 6 | 1.62 (0.60, 4.38)
| | Cardiac event or revascularization: | 75 | 71 | 1.10 (0.79, 1.53)
Sacks 1995 | Primary endpoints were lipids and stenosis. No definitions for CV events. | For fish oil, there were 8 events in 7 patients including 1 nonfatal MI, 1 stroke, 3 CABG, 3 UA. In control group, there were 11 events in 7 patients including 1 coronary death, 2 nonfatal MI, 1 CHF, 3 CABG, 4 UA. | | | | | | | No data on funding
Singh 1997 | AMI was diagnosed in the presence of a symmetrical ST segment elevation of >1 mm from baseline in limb leads or of >2mm in chest leads. Suspected AMI or possible AMI was diagnosed as the presence of a convincing history of cardiac chest pain accompanied by less than twice the increase in cardiac enzymes at the upper limit of normal values. Unstable angina was considered in the presence of a cardiac chest pain for >30 minutes without a significant increase in enzymes. | [underlined: Complications in different groups of patients after 1y follow up] | | | | | | | No data on funding;
| | | Fish | Mustard | Placebo% | Fish oil vs. | Mustard Oil | | Many calculating errors in RR & confidence intervals
| | | Oil%(n=122) | Oil(n=120) | (n=118) | Placebo | vs. placebo
| | Sudden Death: | 2(1.6) | 2 (1.6) | 8 (6.6) | 0.24 (0.03,2.0) | 0.24(0.03,2.0)
| | Total Deaths: | 14(11.4) | 16(3.3) | 26(22.0) | 0.52(0.22,1.21) | 0.52(0.22,1.21)
| | Nonfatal MI | 16(13.0) | 18(15.0) | 30(25.4) | 0.51(0.23,1.21) | 0.51(0.23,1.28)
| | Total Events: | 30(24.5) | 34(28.2) | 41(34.7) | 0.70(0.29,0.90) | 0.70(0.29,0.90)

## Evidence Table 2 - Part A

Evidence Table 2. Observational studies of effects of Omega-3 Fatty Acids and Fish Consumption on Mortality and CVD Outcomes: Part A

Author Year | Study characteristics | Study design and duration | Eligibility criteria | Concurrent disease/ Conditions/Medication | | | | | | Dietary assessment *Intervention/Exposure (N, Omega-3 fatty acid source/ serving size/ dosage/ time/ measurement) | | | | Comparator: N / Control or background diet, source, dose etc.
Albert 1998 (Physicians Health Study) | Age: 53.2 | Prosp. | US male physicians | Fish consumption quintiles | | | | | | FFQ | | | | [underlined: Frequency of Fish Intake n]
| % male: 100% | Cohort | 40–84 in 1982 with no history of MI, stroke, or cancer (except non-melanoma skin cancer). | | <1/m | 1–3/m | 1≤2/w | 2≤5/w | ≥5/w | [underlined: Frequency of Fish Intake n] | | | | <1 time/m: 637
| Race: ND | 11 y | | Current Smoking Status | | | | | | 1–3 times/m: 1262
| Enrolled/Evaluate | | | ≥20 cig/day: | 6.9 | 9.1 | 8.5 | 6.3 | 5.5 | 1≤2 times/m: 6443
| 20551 | | | <20 cig/day: | 4.3 | 4.7 | 4.0 | 3.9 | 2.5 | 2≤5 times/m: 9997
| Location: US | | | %Alcohol Use/d | | | | | | >5 times/m: 2212
| Sites: multiple | | | | 17.3 | 20.7 | 24.1 | 26.2 | 24.9
| | | | %Diabetes: | 3.9 | 2.9 | 2.3 | 2.2 | 2.4
| | | | %High cholesterol:
| | | | | 3.3 | 3.8 | 5.4 | 6.3 | 6.9
| | | | %HTN: | 12.4 | 13.7 | 13.1 | 13.7 | 15.9
Albert 2002 (Physicians Health Study) | Ave Age: 58.3 | Nested case-control | US male physicians | | Group w/ sudden death | control | | | | FFQ | | | | Control = 184
| % Male: 100 | | 40–84 in 1982 with no history of MI, stroke, or cancer (except nonmelanoma skin cancer). | N | 84 | 184 | | | | Group w/ sudden death: n=94
| Race: ND | | | % current smoker | 13.8 | 13.6
| Cases sudden death =94 | | | %Diabetes | 5.3 | 3.3
| Controls =184
| Location: US
| Sites: multiple
Ascherio 1995 (Health Profession-als Follow up Study) | Age range:40–75 | Prosp. | Male healthcare professionals | [underlined: n-3 fatty acid intake by quintiles] | | | | | | FFQ | | | | [underlined: Range of n-3 intake g/d (person-yrs):]
| % Male: 100 | cohort | Exclusions: prior stroke, MI, coronary artery surgery, angina, peripheral artery disease, diabetes, TIA, CVD | | 1 | 2 | 3 | 4 | 5 | [underlined: Range of n-3 intake g/d (person-yrs):] | | | | 0.01–0.11: 50,449
| Race: 100% W | 6 y | | BMI | 24.9 | 24.9 | 24.9 | 24.8 | 24.8 | 0.12–0.19: 49,902 | | | | [underlined: Servings of fish (person-yrs):]
| Enrolled/Evaluate | | | %Smokers: | 11.4 | 10.9 | 10.1 | 8.5 | 7.8 | 0.20–0.28: 48,613 | | | | <1/m: 10,975
| 44895 | | | Alcohol g/d | 11.4 | 12.1 | 13.1 | 11.6 | 10.8 | 0.29–0.41: 47,722
| Location: US | | | %HTN: | 18.1 | 19.5 | 20.6 | 20.7 | 21.8 | 0.42–6.52: 45,343
| Sites: multiple | | | %High chol | 7.5 | 8.9 | 9.9 | 11.9 | 14.4 | [underlined: Servings of fish (person-yrs):]
| | | | % Diabetes | 2.5 | 2.3 | 2.6 | 2.5 | 3.0 | 1–3/m: 17,886
| | | | %family CHD | 10.0 | 11.5 | 11.0 | 11.6 | 13.8 | 1/w: 66,367
| | | | %Vitamin E use: | 14 | 16 | 18 | 20 | 24 | 2–3/w: 91,370
| | | | | | | | | | 4–5/w: 33,779
| | | | | | | | | | >6/w: 21,652
Caicoya 2002 | Age range: 69.3 | Case-Control | Acute stroke patients meeting WHO criteria who registered at Stroke Data Bank between 10/1990-6/1991 | | Cases | controls | | | | FFQ | | | | Controls who did not have stroke: 473
| % Male: 53.9 | 1.5 y | Cases: patients suffering from acute stroke | %Smokers: | 42.5 | 40.5 | | | | Incident strokes: 440 | | | | [underlined: Fish consumption controls]
| Race: white | | Controls: subjects living in the same area as cases, of similar age, who were not suffering from stroke | %HTN: | 56.3 | 29.7 | | | | [underlined: Fish consumption cases] | | | | 0 10
| Cases: 440 | | | %Hypercholesterolemia: | | | | | | 0 18 | | | | 1–22.5 g/d: 145
| Controls: 473 | | | | 17.7 | 19 | | | | 1–22.5 g/d: 99 | | | | 23–45 g/d: 145
| Location: Spain | | | %Diabetes: | 20.5 | 12.2 | | | | 23–45 g/d: 128 | | | | 46–90 g/d: 144
| Sites: multiple | | | %CAD: | 16.6 | 7.8 | | | | 46–90 g/d: 155 | | | | 91–250 g/d: 29
| | | | % AF: | 30.7 | 3.9 | | | | 91–250 g/d: 42 | | | | [underlined: Omega-3 intake mg/d controls]
| | | | %PAD: | 8.1 | 2.5 | | | | [underlined: Omega-3 intake mg/d cases (calculated by EPIC tables)] | | | | 0–115: 80
| | | | alcohol g/d: | 21.8 | 17.1 | | | | 0–115 : 56 | | | | 116–319: 155
| | | | | | | | | | 116–319: 155 | | | | 320–659: 134
| | | | | | | | | | 320–659: 134 | | | | >659: 88
| | | | | | | | | | >659: 95
Daviglus 1997 (Western Electric Study) | Age: 47 | Prosp. | Employees of the Chicago Western Electric Study, 40 to 55 years old in 1957 | | 0 g/d | 1–17g/d | 18–34 g/d | >35g/d | | Standard dietary questionnaires | | | | [underlined: Fish Consumption]
| % Male: 100 | Cohort | | % Diabetes: | 1.6 | 1.4 | 1.5 | 1.6 | | [underlined: Fish Consumption] | | [underlined: Person/yrs] | | [underlined: Person/yrs]
| Race: ND | 30 y | | % current | | | | | | 1–17 g/day | N=646 | 16684 | | 0 g: N=189
| Enrolled/Evaluate | | | smokers: | 56.2 | 60.7 | 56.2 | 56.0 | | 18–34 g/day | N=745 | 19350 | | person/yrs 4754
| 1822 | | | % drinkers: | 80.4 | 83.4 | 86.0 | 91.2 | | ≥35 g/day | N=242 | 6368
| Location: US | | | | | | | | | Total | N=1882
| Sites: multiple
Djousse 2001 (NHLBI Family Heart Study) | Mean age: 52.1 | Cross-Section study | Families chosen either at random or on basis of high risk for CAD from other cohorts, such as Framingham, ARIC, Utah Health Family Tree Study | Age and energy-adjusted quintiles of total linolenic acid intake (2024M) | | | | | | FFQ | | | | [underlined: ALA intake by quintile (n):]
| % Male: 46 | | Exclusions: African-Americans because of limited number of participants to provide reliable estimates, or energy intakes outside acceptable ranges | Mean g/d: | 0.53 | 0.67 | 0.78 | 0.90 | 1.14 | [underlined: ALA intake by quintile (n):] | | | | 0.19–0.97 g/d:
| Race: 100% W | | | %high risk | 57.9 | 50.0 | 47.6 | 52.3 | 52.4 | 0.35–1.8 g/d: 408M 484 F | | | | 392M, 455F
| Enrolled/Evaluate | | | %diabetes | 4.1 | 5.6 | 5.6 | 8.5 | 9.0 | 0.41–1.35 g/d: 414M 486 F | | | | [underlined: Fish consumption (n)]
| 4406 | | | %aspirin use | 43.4 | 39.7 | 41.8 | 37.5 | 35.1 | 0.45–1.73 g/d: 411M 484 F | | | | 0/w: 1207
| Location: USA | | | %smokers | 13.5 | 13.0 | 15.5 | 15.1 | 17.0 | 0.55–3.48 g/d: 399M, 473 F
| Sites: multiple | | | %alcohol | 53.1 | 44.6 | 43.9 | 34.5 | 33.6 | [underlined: Fish consumption (n)]
| | | | %vitamins | 21.4 | 20.1 | 19.1 | 19.7 | 19.8 | 1 serving/w: 1976
| | | | Age and energy-adjusted quintiles of total linolenic acid intake(2382F) | | | | | | >2 servings/w: 1223
| | | | mean g/d: | 0.46 | 0.58 | 0.65 | 0.76 | 0.96
| | | | %high risk | 51.2 | 54.6 | 57.2 | 48.6 | 53.9
| | | | %diabetes | 4.2 | 6.2 | 8.0 | 3.3 | 6.8
| | | | %aspirin use | 32.2 | 30.2 | 32.1 | 30.6 | 32.1
| | | | %smokers | 13.6 | 10.0 | 11.1 | 13.0 | 16.5
| | | | %alcohol | 34.5 | 32.4 | 25.9 | 20.7 | 21.1
| | | | %vitamins | 30.8 | 28.7 | 25.7 | 26.0 | 22.8
Dolecek 1992 | Age: 46 | Follow up of usual-care arm of MRFIT, n= 6250 | Men aged 35–57 at high risk of developing CHD due to smoking status and DBP. | [underlined: Data from MRFIT Trial 1982 (usual care group)] | | | | | | 24 hr dietary recall interviews | | | | Mean ALA n
(MRFIT) | % Male: 100 | 10.5 y | | % Smoking: 63.5% | | | | | | Mean ALA g/d | | | | 7g/d=1251
| Race: 92.8 W | | | % Major ECG Abnormalities: 4.6 | | | | | | 10.6 g/d=1252
| Enrolled/Evaluate | | | % HTN: 62.0 | | | | | | 13.4 g/d=1252
| 12866 / 6250 | | | | | | | | | 16.8 g.d=1252
| Location: US | | | | | | | | | 25.1 g/d=1252
| Sites: multiple
Egeland 2001 | Average Age: 44.5 | Prosp. | Residents of 3 Norwegian counties attending CV screening 1977-1983 | [underlined: Men] | | | | | | Detailed dietary study | | | | [underlined: No Cod Liver Oil Consumption]
| % Male: 50 | Cohort | | Cod Liver Oil | Yes(2569) | No(18849) | | | | [underlined: Usual Weekly Cod Liver Oil Consumption] | | | | Men=18849(88%)
| Race: 100% W | 9 y | | %Current smokers: | 36.7 | 47.5 | | | | Men=2569 (12%) | | | | Women=18420 (87%)
| Enrolled/Evaluate | | | %Body Mass Index: | 20.3 | 28.3 | | | | Women=2774(13%)
| 42612 | | | %Hx CHD^+^: | 2.0 | 2.8 | | | | Cod liver oil users more likely to report fish consumption <2 times/w
| Location: Norway | | | | Yes(2774) | No(18420)
| Sites: multiple | | | %Current smoker: | 28.3 | 34.9
| | | | %Body Mass Index: | 17.8 | 26.0
| | | | % Hx CHD^+^: | 0.8 | 1.1
Erkkila 2003 | Average Age: 61 | Prosp. | Patients<71 yrs, with established CAD, 1991-1994. | | Patients who died | patients who lived | | | | Structured questionnaire | | | | [underlined: No fish]
| % Male: 69 | cohort | | | (n=36) | (n=379) | | | | [underlined: Consumption of fish] | | | | 0 g/d = 103
| Race: 100% W | 5 y | | SBP: | 145±27 | 140±22 | | | | < 57 g/d = 147
| Enrolled/Evaluate | | | DBP: | 85±16 | 82±12 | | | | > 57 g/d = 150
| 415 | | | %Diabetes: | 22 | 16
| Location:Finland | | | %Lipid-lowerers: | 28 | 40
| Sites: 1 | | | %Smoking: | 14 | 13
Fraser 1992 | Average Age: 52 | Prosp. cohort | Cohort of California 7^th^ -day Adventists aged >25 who responded to detailed questionnaire to identify CHD risk | | Men | Women | | | | FFQ | | | | [underlined: Fish consumption]
Adventist Health Study | % Male: 37.5 | 6 y | | %Diabetes | 3.6 | 4.7 | | | | [underlined: Fish consumption] | | | | None 39%
| Race: 100% non-Hispanic Whites | | | %HTN | 15.8 | 22.6 | | | | <1/wk 47%
| Enrolled/Evaluate | | | Curr smokers | 2.2 | 1.4 | | | | >1/wk 10%
| 27658 / 26743 | | | Quetelet index | 24.9 | 24.3
| Location: US
| Sites: multiple
Fraser 1997 | Age: >84 | Prosp. cohort | Adventist Health Study subset, all responders >84 y | ND | | | | | | FFQ | | | | [underlined: Fish consumption]
Adventist Health Study | % Male: 29.5 | 12 y | | | | | | | | [underlined: Fish consumption] | | | | None
subset | Race: 100% non-Hispanic Whites | | | | | | | | | <1/wk 93%
| Enrolled/Evaluate | | | | | | | | | >1/wk 7%
| 603
| Location: US
| Sites: multiple
Gartside 1998 | Age: 58 | Follow-up of longitu- | The population of NHANES I since 1971 which had complete data sets. | Cholesterol | <209 | 209–249 | >249 | | | Questionnaire | | | | [underlined: Frequency of fish intake]
NHEFS | % Male: 100 | dinal | Exclusion: subjects with special diets to reduce CHD risk | Fish None | 39% | 40% | 45% | | | [underlined: Frequency of fish intake] | | | | None
| %Race: 100% w | cohort | | <1w | 33% | 32% | 41% | | | <1/wk
| Enrolled/Evaluate | study | | >1/w | 26% | 30% | 38% | | | >1/d
| 5811 | 16 y
| Location: USA
| Sites: multiple
Gillum 2000 | Age: 49.5 | Prosp. cohort | White and black persons 25–74 y. | [underlined: Levels of stroke risk factors and concurrent diseases stratified by various subgroups:] | | | | | | 3 month FFQ administered by registered dieticians | | | | [underlined: Frequency of fish consumption]
NHEFS | % Male: 50 | 18.8 y | Exclusions: | %Smokers: range 11.9–30.9 | | | | | | [underlined: Frequency of fish consumption] | | | | Men 45–64
| Race: 84% W | | 1068 patients w/ positive history of heart disease at baseline, and 382 persons with unknown baseline fish consumption, | %Drinkers: range 29.7–85.5 | | | | | | age 45–64 | Men | Women | | Never 87
| Enrolled/Evaluate | | SBP, chol, DM, cigarette smoking status, alcohol intake, BMI, heart disease | %Diabetics: range 1.1–12.0 | | | | | | <1 time/w | 367 | 386 | | [underlined: Women 45–64]
| 8825 | | | | | | | | | 1/w | 386 | 447 | | Never 74
| Location: US | | | | | | | | | >1/w | 141 | 187 | | [underlined: Men 65–74]
| Sites: multiple | | | | | | | | | age 65–74 | Men | Women | | Never 149
| | | | | | | | | | <1 time/w | 426 | 528 | | [underlined: Women 65–74]
| | | | | | | | | | 1/w | 359 | 400 | | Never 175
| | | | | | | | | | >1/w | 144 | 154
Gillum 1996 | Age: 45–74 | Prosp. | Civilian non-institutionalized population | [underlined: Levels of stroke risk factors and concurrent diseases stratified by various subgroups:] | | | | | | 3-month FFQ administered by registered dieticians | | | | [underlined: Fish consumption (n)]
NHEFS | % Male: ~47 | cohort | Exclusion: history of stroke | %Smokers: range 11.9–30.9 | | | | | | [underlined: Fish consumption (n)] | | | | F 45–64 never: 74
| %Race: 84.9 W | 12y | | %Drinkers: range 29.7–85.5 | | | | | | F 45–64 <1/wk: 386 | | | | M-45–64 never: 87
| Enrolled/Evaluate | | | %Diabetics: range 1.1–12.0 | | | | | | F 45–64 1/wk: 447 | | | | F 65–74 never:175
| 5192 | | | | | | | | | F 45–64 >1wk: 187 | | | | M65–74 never: 154
| Location: USA | | | | | | | | | M 45–64 <1/wk: 367
| Sites: multiple | | | | | | | | | M 45–64 1/wk: 386
| | | | | | | | | | M 45–64 >1wk: 141
| | | | | | | | | | F 65–74 <1/wk: 528
| | | | | | | | | | F 65–74 1/wk: 400
| | | | | | | | | | F 65–74 >1wk: 154
| | | | | | | | | | M 65–74 <1/wk: 426
| | | | | | | | | | M 65–74 1/wk: 359
| | | | | | | | | | M 65–74 >1wk: 144
He 2002 (Health Professionals Follow up Study) | Age range: 54 | Prosp. | Male healthcare professionals who had no CVD in 1986 | [underlined: For all 43,671 participants:] | | | | | | FFQ | | | | [underlined: Fish consumption]
| % Male: 100 | cohort | Exclusions: prior stroke, MI, coronary artery surgery, angina, peripheral artery disease, diabetes, TIA, CVD | %Overweight: 51.6 | | | | | | [underlined: Fish consumption] | | | | [underlined: (person-years)]
| Race: ND | 12 y | | %Smokers: 10 | | | | | | [underlined: (person-years)] | | | | <1 serving/mo: 22,883
| Enrolled/Evaluate | | | %HTN: 19.5 | | | | | | 1–3 servings/mo: 44,629 | | | | [underlined: Cumulative long-chain omega-3 intake g/d (p-yrs)]
| 43671 | | | %Hypercholesterolemia: 10.3 | | | | | | 1/wk: 214,851 | | | | <0.05: 19,741
| Location: US | | | %Aspirin use: 26.4 | | | | | | 2–4/wk: 143,507
| Sites: multiple | | | %Vitamin E use: 18.9 | | | | | | >5/wk: 36,154
| | | | | | | | | | [underlined: Cumulative long- chain omega-3 intake g/d (p-yrs)]
| | | | | | | | | | 0.05-<0.2: 155,579
| | | | | | | | | | 0.2-<0.4: 175,161
| | | | | | | | | | 0.4-<0.6: 68,003
| | | | | | | | | | >0.6: 43,539
Hu 2002 (Nurses' Health Study) | Age range:30–55 | Prosp. cohort | Registered female nurses | [underlined: Data from Iso 2001 (data from 14 yr follow up):] | | | | | | FFQ | | | | [underlined: Fish consumption (person yrs)]
| % Male: 0 | 16 y | Exclusions: cancer, prior stroke, MI, coronary revas-cularization, angina, CVD, diabetes, high cholesterol | Frequency of fish intake | | | | | | [underlined: Fish consumption] | | | | <1 serving/m: 67, 537
| Race: 98% W | | | | 1/mo | 1–3/m | 1/wk | 2–4/wk | 5/wk | [underlined: (person yrs):] | | | | [underlined: Median intake omega-3 fatty acids, % of energy (person yrs):]
| Enrolled/Evaluate | | | %Smoking: | 28.6 | 25.3 | 21.5 | 18.6 | 19.2 | 1–3 servings/m: 337,393 | | | | 0.03: 255,434
| 84,688 | | | %HBP: | 20.8 | 20.8 | 22.5 | 25.1 | 27.2 | 1/w: 690,479
| Location: USA | | | Aspirin >1/w: | 46.3 | 54.7 | 60.8 | 56.7 | 54.6 | 2–4/w: 157,711
| Sites: multiple | | | %Vitamin use: | 36.4 | 36.4 | 39.9 | 44.3 | 47.1 | >5/w: 54,525
| | | | %Alcohol >25g/d: | 6.4 | 6.7 | 6.9 | 6.6 | 5.7 | [underlined: Median intake omega-3 fatty acids, g/d % of energy (person yrs):]
| | | | %HRT: | 18.1 | 20.9 | 23.6 | 22.2 | 20.8 | 0.05: 270,898
| | | | Average energy-adjusted ALA intake g/d: | | | | | | 0.08: 263,131
| | | | | 0.71 | 0.86 | 0.98 | 1.12 | 1.36 | 0.14: 259,454
| | | | %Smoking: | 25 | 23.4 | 22.4 | 21.5 | 19 | 0.24: 258,583
| | | | %HBP: | 21 | 21.2 | 22.2 | 23.1 | 25.1
| | | | Aspirin >1/w: | 57.5 | 58.3 | 58.6 | 58.5 | 56.5
| | | | %Vitamin use: | 36.2 | 37.7 | 39.7 | 41.1 | 44.3
| | | | %Alcohol >25g/d: | 7 | 6.7 | 7.5 | 6.5 | 6.2
| | | | %HRT: | 22.6 | 22.7 | 22.2 | 23.3 | 21.6
Hu 1999 (Nurses' Health Study) | Age range:30–55 | Prosp. cohort | Registered female nurses | Data from Hu 1999: | | | | | | [underlined: FFQ] | | | | [underlined: ALA consumption]
| % Male: 0 | 10 y | Exclusions: cancer, prior stroke, MI, coronary revas-cularization, angina, CVD, diabetes, high cholesterol | Average energy-adjusted ALA intake g/d: | | | | | | ALA consumption | | | | [underlined: (person yrs):]
| Race: 98% W | | | | 0.71 | 0.86 | 0.98 | 1.12 | 1.36 | [underlined: (person yrs):] | | | | 0.71 g/d: 138,468
| Enrolled/Evaluate | | | %Smoking: | 24 | 23.7 | 23.5 | 23.5 | 25.6 | 0.86 g/d: 139,658
| 84,688 | | | %HBP: | 22.1 | 21.6 | 20.8 | 22 | 21.5 | 0.98: 140,606
| Location: USA | | | Aspirin >1/w: | 44 | 45.8 | 45.4 | 45.1 | 42.7 | 1.12: 139,711
| Sites: multiple | | | %Vitamin use: | 40 | 37.4 | 37 | 35.7 | 35.2 | 1.36: 140,306
| | | | %Alcohol >25g/d: | 8.3 | 6.9 | 6.8 | 6.8 | 6.5
| | | | %HRT: | 19.5 | 18.4 | 19.6 | 19.4 | 19.6
Iso 2001 | Age range:30–55 | Prosp. cohort | Registered female nurses | [underlined: Risk factors according to fish intake:] | | | | | | FFQ | | | | [underlined: Average frequency of fish intake](person-yrs)
Nurse Health Study | % Male: 0 | 14 y | Exclusions: cancer, prior stroke, MI, coronary revascularization, angina, CVD, diabetes, high cholesterol | | <1/mo | 1–3/m | 1/wk | 2–4/wk | 5/wk | [underlined: Average frequency of fish intake (person-yrs)] | | | | <1 serving/mo: 53,008
| Race: 98% W | | | %Smoking: | 28.6 | 25.3 | 21.5 | 18.6 | 19.2 | 1–3 servings/mo: 285,973
| Enrolled/Evaluate 79,839 | | | %HBP: | 20.8 | 20.8 | 22.5 | 25.1 | 27.2 | 1 /wk: 576,099
| Location: USA | | | Aspirin >1/w: | 46.3 | 54.7 | 60.8 | 56.7 | 54.6 | 2–4/wk: 147,026
| Sites: multiple | | | %Vitamin use | 36.4 | 36.4 | : 39.9 | 44.3 | 47.1 | >5/wk: 24,155
| | | | %Alcohol >25g/d: | 6.4 | 6.7 | 6.9 | 6.6 | 5.7 | [underlined: Average omega-3 fatty acids (EPA+DHA)]
| | | | %HRT: | 18.1 | 20.9 | 23.6 | 22.2 | 20.8 | Quintile 1 (ND on n)
| | | | [underlined: Risk factors according to average EPA+DHA] | | | | | | Quintile 2
| | | | [underlined: Quintile] | 1 | 2 | 3 | 4 | 5 | Quintile 3
| | | | Median intake g/d | | | | | | Quintile 4
| | | | | 0.077 | 0.118 | 0.171 | 0.221 | 0.481 | Quintile 5
| | | | %Smoking: | 25 | 23.4 | 22.4 | 21.5 | 19
| | | | %HBP: | 21 | 21.2 | 22.2 | 23.1 | 25.1
| | | | Aspirin >1/w: | 57.5 | 58.3 | 58.6 | 58.5 | 56.5
| | | | %Vitamin use: | 36.2 | 37.7 | 39.7 | 41.1 | 44.3
| | | | %Alcohol >25g/d: | 7 | 6.7 | 7.5 | 6.5 | 6.2
| | | | %HRT: | 22.6 | 22.7 | 22.2 | 23.3 | 21.6
Keli 1994 | Age: 60 | Prosp. | Middle aged Dutch men surveyed in 1970 | | No stroke (510) | Stroke (42) | | | | Cross-check dietary history method describing food patterns over 6 mo—6 interviews each yr every 5^th^ yr by trained dietitians | | | | [underlined: Fish consumption]
Zutphen Study | % Male: 100 | cohort | | Cigarettes/d × yrs | | | | | | [underlined: Fish consumption] | | | | <20 g/d: 332
| Race: white | 15 y | | from 1960-70 | 438±327 | 433±293 | | | | >20 g/d: 220 | | | | “Not Always”: 251
| Enrolled/Evaluate | | | SBP mm/Hg | 142.2±14.1 | 148.9±20.1 | | | | “Always”: 301
| 872/552
| N of control: 510
| Location: Holland
| Sites: 1
Kinjo Y 1999 | Average Age: 55 | Prosp. | Men and women 40–69 y in Dec 1965 | ND | | | | | | [underlined: Questionnaire] | | | | [underlined: Fish n (%)]
| %Male: 50 | Cohort | Exclusion: history of cancer and other diseases except chronic stomach disease. | | | | | | | Fish n (%) | | | | <1/w:13235(5.9%)
| Race: Asian | 15 y | | | | | | | | 1–3 times/w:
| Enrolled/Evaluate | | | | | | | | | 126,765 (56.8%)
| 223,170 | | | | | | | | | >4 /w:
| Location: Japan | | | | | | | | | 83,170 (37.3%)
| Sites: multiple
Kromhout, 1985 (Zutphen Study) | Age: middle age | Prosp. | Random sample of 1088 men selected from 25,000; all | ND | | | | | | Cross-check dietary history | | | | [underlined: Fish consumption g/d n]
| % Male: 100 | Cohort | born 1900-1919 living in Zutphen >5y. | | | | | | | [underlined: Fish consumption] | | | | 0 159
| Race: 100% Dutch | 20 y | | | | | | | | g/d | n
| Enrolled/Evaluate | | | | | | | | | 1–14 | 283
| 1088/ 852 | | | | | | | | | 15–29 | 215
| Location: Netherlands | | | | | | | | | 30–44 | 116
| Sites: 1 | | | | | | | | | ≥ 45 | 79
Kromhout, 1995 | Age: 71 | Prosp. | All men/women 64–87 yr, born before 1907, able to take part in the study | | No Fish intake | | Fish Intake | | | | Cross-check dietary history | | | | [underlined: No Fish intake]
Feskens 1993 (Rotter-dam Study) | % Male: 50% | Cohort | | | | | | | | [underlined: Fish intake] | | | | Men: 54
| Race: ND | 17 y | | | M | W | M | W | | Men: 83 | | | | Women 56
| Enrolled/Evaluate | | | N | 54 | 56 | 83 | 79 | | Women 79
| 272 | | | % Smoking: | 67.9 | 16.1 | 70.7 | 20.3
| N of control: 221 | | | % Alcohol: | 64.8 | 39.3 | 77.1 | 34.2
| Location: Netherlands | | | % MI | 18.5 | 3.6 | 7.2 | 2.5
| Sites: multiple | | | % Angina | 16.7 | 26.8 | 18.1 | 15.2
Mann 1997 | Average Age: 48 | Prosp. | Vegetarian participants. The non-vegetarian controls were their friends and relatives. | | Men | Women | | | | FFQ | | | | [underlined: No Fish ND]
| % Male: 100 | Cohort: | | Current smokers | | | | | | [underlined: Fish intake ND]
| Race: European | 13.3 y | | <10 cig/day: | 531(12.9%) | 487(7.3%) | | | | <1/w
| Enrolled/Evaluate | | | ≥10 cig/day: | 482(11.8%) | 604(9.0%) | | | | >1/w
| 10802 | | | Pre-existing disease?
| Location: UK | | | Yes: | 3832(93.4%) | 6148(91.8%)
| Sites: 1 | | | No: | 270(6.6%) | 582(8.2%)
| | | | Vegeterian | 1568(38.2%) | 1588 (23.7%)
Morris 1995 (Physicians Health Study) | Age: 40–84 | Prosp. | Apparently healthy male physicians who were enrolled in RCT in 1982 to receive either aspirin, beta carotene, both treatments, or both placebos | [underlined: Weekly fish consumption] | | | | | | FFQ | | | | [underlined: Weekly fish consumption (person-yrs)]
| % Male: 100 | cohort | Exclusions: history of MI, stroke, TIA, cancer, liver or renal disease, peptic ulcer, use of aspirin or NSAIDS | | <1 meal/wk | 1 meal/wk | 2–4/wk | >5/wk | | [underlined: Weekly fish consumption (person-yrs)] | | | | <1 meal/w: 22,228
| Race: ND | 4 y | | %HTN | 14 | 13 | 14 | 16 | | 1 meal/w: 40,308 | | | | [underlined: Intake of omega-3g/wk]
| Enrolled/Evaluate | | | % high chol | 5 | 7 | 8 | 9 | | 2–4/w: 39,923 | | | | [underlined: (person-yrs)]
| 21185 | | | %angina | 1 | 1 | 1 | 2 | | >5/w: 5,275 | | | | <0.5 21,441
| Location: USA | | | % hx MI | 12 | 13 | 14 | 16 | | [underlined: Intake of omega-3 g/wk (person-yrs)] | | | | (data derived from those with total CV events)
| Sites: multiple | | | % diabetes | 3 | 2 | 2 | 2 | | 0.5-<1.0 | 20,479
| | | | %obesity | 14 | 14 | 13 | 12 | | 1.0-<1.7 | 23,122
| | | | %vitamin use | 23 | 22 | 25 | 30 | | 1.7-<2.3 | 20,190
| | | | %current smokers | 13 | 12 | 9 | 8 | | >2,3 | 19,501
| | | | | | | | | | (data derived from those with total CV events)
Mozaffarian 2003 (Cardio-vascular Health Study) | Average age: 73 | Prosp. | Noninstitutionalized men and women >65 y randomly selected from Medicare lists of HCFA. Blacks not included due to lack of food frequency questionnaire at baseline. Also excluded: subjects with CVD at baseline | Frequency of non-fried fish intake (tuna/other) | | | | | | FFQ | | | | [underlined: Frequency of fish intake (tuna/other)]
| % Male: 39 | Cohort | | | 1/mo | 1–3/mo | 1/wk | 2/wk | >3/wk | [underlined: Frequency of non-fried fish intake (tuna/other)](person-years) | | | | [underlined: (person-years)]
| Race: 95% W | 9.3 y | | %diabetes | 22 | 21 | 19 | 22 | 17 | 1–3/m: 8156 | | | | <1/m:3324
| Enrolled/Evaluate | | | %smoking | 18 | 13 | 11 | 11 | 10 | 1/w: 7442 | | | | [underlined: Frequency of fish intake (fried fish/sandwich):]
| 5201/3910 | | | cig pack/yrs: | 20 | 19 | 17 | 18 | 15 | 2/w: 5683 | | | | person-years
| Location: USA | | | %aspirin use: | 16 | 15 | 16 | 15 | 16 | >3/w: 11593 | | | | <1/m: 11969
| Sites: multiple | | | %lipid-lowers: | 1.6 | 3.8 | 3.9 | 3.8 | 6.0 | [underlined: Frequency of fish intake (fried fish/sandwich)]
| | | | LDL: | 124 | 127 | 131 | 129 | 135 | person-years
| | | | Frequency of fish intake (fried fish/sandwich): | | | | | | 1–3/m: 17,177
| | | | | <1/mo | 1–3/mo | 2/wk | >3/wk | | 1/w: 1804
| | | | | 18 | 20 | 18 | 22 | 29 | 2/w: 4725
| | | | %smoking: | 13 | 11 | 13 | 13 | 7 | >3/w: 524
| | | | cig pack/yrs: | 18 | 16 | 18 | 18 | 17
| | | | %aspirin use: | 16 | 14 | 20 | 17 | 12
| | | | %lipid lowers: | 3.0 | 5.1 | 3.9 | 4.7 | 5.1
| | | | LDL: | 128 | 131 | 128 | 133 | 139
Nagata 2002 (Takayama Study) | Age: ND | Prosp. | Residents of Takayama, Gifu, Japan, >35 years. | | Men% | Women% | | | | FFQ | | | | [underlined: Median Fish intake g/d (pers-yrs)]
| % Male: 54 | Cohort: | | Current smoker: | 55 | 13.1 | | | | [underlined: Median Fish intake g/d (person-yrs)] | | | | 18,292
| Race: 100% Japanese | 7 y | | Former smoker: | 28.2 | 4.4 | | | | 68.1 | 18,232 | | | [underlined: Median Fish oil intake]
| Enrolled/Evaluate | | | Hypertension: | 18.9 | 17.4 | | | | 86.8 | 18,317 | | | mg/d (person-yrs)
| 29079 | | | Diabetes mellitus: | 5.9 | 2.7 | | | | 111.9 | 18,150 | | | 410 18,281
| Location: Japan | | | | | | | | | 157.8 | 18,945
| Sites: multiple | | | | | | | | | [underlined: Median Fish oil intake]
| | | | | | | | | | [underlined: mg/d person-yrs]
| | | | | | | | | | 602 | 18,315
| | | | | | | | | | 788 | 18,186
| | | | | | | | | | 1051 | 18,138
| | | | | | | | | | 1582 | 18,116
Oomen 2000 (Seven Countries Study) | Average Age: 59 | Prosp. | Men aged 50–69, free of CHD who were originally enrolled 1958-64 and survived the | [underlined: Cholesterol mmol/L %smoking] | | | | | | Cross check dietary history | | | | [underlined: Fish consumption g/d n]
| % Male: 100 | cohort | Seven Countries Study by 1970. | [underlined: Finland:] | | | | | | [underlined: Fish consumption g/d n] | | | | Finland
| Race: 100%W | 20 y | | 0–19 g/d fish | 6.77 | 43.9 | | | | Finland | | | | 0–19: 476
| Enrolled/Evaluate | | | 20–39 | 6.96 | 51.7 | | | | 20–39: 263 | | | | Italy
| 2738 | | | >40 | 7.18* | 56.2 | | | | >40: 349 | | | | 0: 264
| Location: Finland, Italy, | | | [underlined: Italy:] | | | | | | Italy | | | | The Netherlands
| Netherlands, | | | 1–19 g/d fish | 5.67 | 53.6 | | | | 0–19: 347 | | | | 0: 157
| Sites: Multiple | | | 20–39 | 5.75 | 48.0 | | | | 20–39: 323
| | | | >40 | 5.66 | 50.9 | | | | >:40: 163
| | | | [underlined: The Netherlands:] | | | | | | The Netherlands
| | | | 1–19 g/d fish | 6.23 | 55.8 | | | | 1–19: 169 Men
| | | | 20–39 | 6.06 | 54.4 | | | | ≥20 = 227 Men
| | | | >40 | 6.18 | 50.2
Oomen 2001 (Zut-phen Elderly Study) | Mean Age: 71.1 | Prosp. cohort | 367 Men who participated in Zutphen Study in 1960; plus 711 new enrolees. | | Total Grp | <0.45% | 0.48–0.58 | >0.58% | | Cross check dietary history[underlined: ALA intake, % energy] | | | | [underlined: ALA intake, % energy]
| % Male: 100 | 10 y | Exclusion: previously diagnosed CAD | SBP | 151 | 154 | 149 | 150 | | 0.45–0.58%: 223 | | | | <0.45%: 222
| Race: white | | | %smoking: | 32.4 | 26.6 | 34.1 | 36.5 | | >0.58%: 222
| Enrolled/Evaluate | | | %vitamin use:
| 667 | | | | 15.9 | 22.3 | 12.6 | 13.1
| Location: Netherlands | | | %vitamin E: | 8.5 | 8.0 | 8.7 | 8.9
| Sites: multiple | | | % alcohol >20g:
| | | | | 26.7 | 34.7 | 24.2 | 21.2
Orencia 1996 | Age range: 47.6 | Prosp. | Employees of Western Electric Co surveyed from 10/1957-12/1958, followed 30 y | | None | 1–17 g/d | 18–34 g/d | >35 g/d | | Standardized questionnaire prepared by nutritionists | | | | [underlined: Fish consumption (person-yrs):]
Chicago Western Electric Study | % Male: 100 | cohort | Exclusions: | %Smokers | 56.5 | 60.7 | 56.3 | 56.1 | | [underlined: Fish consumption (person-yrs)] | | | | None: 4721
| %Race: 100 W | 30 y | CHD or stroke | %Drinkers | 80.3 | 83.4 | 85.9 | 91.5 | | 1–17 g/d: 16467
| Enrolled/Evaluate | | | Alcohol intake mL/d | | | | | | 18–34 g/d :18980
| 2107/1847 | | | | 15.4 | 14.1 | 16.1 | 20.9 | | >35 g/d: 6258
| Location: USA | | | %Diabetes | 7.6 | 1.4 | 1.5 | 1.6
| Sites: 1 | | | %ECG abnormalities
| | | | | 16.6 | 20.1 | 17 | 18.7
Osler 2003 | Average Age: 48 | Prosp. | Random sample from Copenhagen County, Denmark initially examined in 1982-92 followed until 2000 (MONICA birth cohorts) | 981 men and 622 women in high risk group for CHD: men >50, women >60, current smokers w/cholesterol >6mmol/L, current nonsmokers w/cholesterol >7mmol/L | | | | | | FFQ | | | | [underlined: Fish intake]
| % Male: 62 | Cohort | | | | | | | | Fish intake | M | F | | [underlined: 1 time/wk]
| Race: ND | 18 y | | | | | | | | <1 time/mo | 828 | 777 | | M: 1570
| Enrolled/Evaluate 8497 | | | | | | | | | 2times/mo | 1225 | 1079 | | W: 1383
| Location: Denmark | | | | | | | | | >2 × w | 373 | 294
| Sites: multiple
Pietinen 1997 | Average Age: 59.5 | Prosp. | male, smokers, 50–69 yrs, originally randomized in 1995 to beta-carotene 20 mg, alpha-tocopherol 50 mg, both or placebo for 5–8 yrs. Excluded: prior MI, angina, stroke, diabetes, typical exercise-related chest pain, cancer, other severe illnesses, anti-coagulant use, vitamins E, A or beta-carotene | [underlined: All subjects in original RCT: 29,133] | | | | | | Self-administered dietary history method | | | | [underlined: Omega-3 intake g]
Albanes 1995 (ABCC Prevention Study) | % Male: 100 | Cohort | | %Cigarette/d: 20.4 | | | | | | [underlined: Omega-3 intake [g] person-yrs] | | | | [underlined: person-yrs]
| Race: ND | (5–8 y) | | Yrs smoking: 35.9 | | | | | | 0.3: 25630 | | | | 0.2: 25538
| Enrolled/Evaluate 21930 | 6.1 median | | Chol: 6.2±1.2 | | | | | | 0.4: 25460
| Location: Finland | Follow up of ABC Cancer Prevention Study | | | | | | | | 0.5: 25390
| Sites: multiple | | | | | | | | | 0.8: 24952
Rodriguez, 1996 | Average Age: 55 | Prosp. | Japanese men aged 45 to 68 years living in Oahu. | ND | | | | | | Questionnaire - | | | | [underlined: Frequency of Fish Intake]N (%)
Honolulu Heart Program | % Male: 100 | Cohort | Exclusion: Prevalent cases of CHD, stroke, and cancer at baseline | | | | | | | [underlined: Frequency of Fish Intake] | | | | Almost never
| Race: Japanese-Americans | 23 y | | | | | | | | | N | (%) | | 0.4
| Enrolled/Evaluate | | | | | | | | | <2 times/wk: | 4352 | 54.4 | | [underlined: Fish intake/Current Smoker]
| 8006 | | | | | | | | | 2–4 times/wk: | 3034 | 37.9 | | Almost never
| controls 3310 | | | | | | | | | Almost daily: | 575 | 7.2 | | 19 0.6
| Location: US | | | | | | | | | >once/d: | 11 | 0.1
| Sites: multiple | | | | | | | | | [underlined: Fish intake/Current Smoker]
| | | | | | | | | | <2: | 1257 | 53.1
| | | | | | | | | | 4-Feb | 1251 | 37.8
| | | | | | | | | | Almost daily: | 276 | 8.3
| | | | | | | | | | More than once: | 7 | 0.2
Sasazuki 2001 | Average Age: ND | Case | Consecutive cases of 1^st^ episode of AMI admitted to hospitals w/in 1 mo of onset Sep 1996-Sep 1998 | | Men | | Women | | | FFQ | | | | [underlined: Fish frequency]
Fukuoka Heart Study | % Male: 72.6 | Control | | | Cases | Controls | Cases | Controls | | [underlined: Fish frequency ND] | | | | <2/wk
| Race: Japanese | | | %Curr smokers | 61 | 44 | 21 | 10 | | 2–3 times/w
| Cases: 632 | | | %curr drinkers | 45 | 66 | 9 | 21 | | >4
| Controls: 1214 | | | hyperlipidemic | 38 | 26 | 48 | 46
| Location: Japan | | | %HTN | 30 | 19 | 48 | 26
| Sites: multiple | | | %DM | 16 | 8 | 20 | 5
| | | | %Angina | 8 | 3 | 8 | 3
| | | | %overweight | 26 | 25 | 25 | 26
Seino 1997 | Age range:40–89 | Prosp. | Rural population of Japan >40 y tested for cerebral infarction 7/1977-12/1992 | ND | | | | | | FFQ, monthly diet record 1y | | | | NA
| % Male: 41.7 | cohort | Exclusion: Prior stroke | | | | | | | [underlined: Average intake n-3 g/d:]
| Race:100% Japanese | 15.5 y | | | | | | | | M 40–9: 2.8 | F 40–9: 2.8
| Enrolled/Evaluate | | | | | | | | | M 50–9: 2.6 | F 50–9: 2.6
| 2651/2283 | | | | | | | | | M 60–9: 2.3 | F 60–9: 2.4
| Location: Japan | | | | | | | | | M 70–9: 2.1 | F 70–9: 2.0
| Sites: multiple | | | | | | | | | M 80–9: 1.8 | F 80–9: 1.8
Siscovick 1995 | Average Age: 49.5 | Case-control | Patients aged 25–74 with primary cardiac arrest attended by paramedics | | Cases | controls | | | | Seafood Intake Scale | | | | [underlined: No seafood]
| % Male:45.9 | Oct 1988-July 1994 | Exclusions: history of heart disease or life- threatening co-morbidities (cancer, ESRD) | %Current smoker | 35 | 11 | | | | (Semiquantitative FFQ) | | | | Cases = 34
| Race: ND | | | %Former smoker: | 38 | 43 | | | | intake | cases | control | | Controls = 19
| Cases: 334 | | | %Hypertension : | 28 | 15 | | | | 0.96 g/d | 92 | 91
| Controls: 493 | | | %Diabetes mellitus: | 13 | 4 | | | | 2.94 g/d | 77 | 101
| Location: US | | | %Hypercholesterolemia: | 24 | 22 | | | | 5.54 g/d | 45 | 94
| Sites: 1 | | | %Family hx MI, sudden death | :54 | 41 | | | | 13.65 g/d | 47 | 95
Tavani 2001 | Mean Age: 61 | Case-control | Patients with 1^st^ episode of nonfatal MI | | Cases | control | | | | FFQ | | | | [underlined: n-3 PUFA intake <81 g/wk]
| % Male:69.2 | | | Current smokers | 231 | 146 | | | | [underlined: n-3 PUFA intake] | | | | Men
| Race:100% White | 1995-1999 | | Never smokers | 276 | 331 | | | | | 0.81–1.28 | >128 g/w | | Cases 142
| Cases: 507 | | | Chol >200 | 57 | 96 | | | | Men | | | | Controls 87
| Controls: 478 | | | Chol >200 | 308 | 170 | | | | Cases | 103 | 133 | | Women
| Location: Italy | | | No AMI in 1^st^ relative | 324 | 376 | | | | Controls | 97 | 112 | | Cases 57
| Sites: 1 | | | AMI in 1^st^ relative | 183 | 101 | | | | Women | | | | Controls 61
| | | | | | | | | | Cases | 36 | 36
| | | | | | | | | | Controls | 47 | 73
Yuan 2001 | Age: 55.8 | Prosp. | Age 45–64 years, no history of cancer. | [underlined: Total Cohort] | | | | | | Structured Questionnaire | | | | [underlined: Mean fish/shellfish intake g/w] n
Shanghai Cohort Study | % Male: 100 | cohort: | | % current smoking | | | | | | [underlined: Mean fish/shellfish intake g/w] | | | | 29: 3,789
| Race: 100% Chinese | 9 y | | < 20 cig/d | 25 | | | | | 76 | 124 | 177 | 322
| Enrolled/Evaluate | | | > 20 cig/d | 7 | | | | | 5613 | 3300 | 2606 | 2936
| 18244 | | | % using alcohol
| Location: China | | | none | 57
| Sites: multiple | | | 1–14 drinks/wk | 24
| | | | 15–28 drinks/wk | 12
| | | | >29 drinks/wk | 7
| | | | % Diabetes | 1.3
| | | | % HBP | 24.6

* p≤ .05 for differences in means or proportions;

+ CHD defined as MI or angina pectoris

## Evidence Table 2 - Part B

Evidence Table 2: Observational studies of effects of Omega-3 Fatty Acids and on Mortality and CVD Outcomes: Part B

Author, Year | Outcome Definition | Results | | | | | | | Comments
| | | | | | | | | Funding sources
Albert 1998 (Physician's Health study) | Results defined as death within 1 hour of symptom onset, a witnessed cardiac arrest, or both, or abrupt collapse not preceded by more than 1 h of symptoms that needed the terminal events. | [underlined: Relative Risk of Sudden Death According to Dietary Fish Intake (multivariate)] | | | | | | | NIH, NHLBI
| | Servings: | <1/mo | 1–3/mo | 1-<2/wk | 2-<5/wk | >5/wk | P for trend
| | cases: | 9 | 12 | 38 | 64 | 10
| | Person-years: | 7715 | 15465 | 79561 | 123693 | 27343
| | | 1.0 | 0.64 | 0.47 | 0.51 | 0.39 | 0.11
| | | | (0.26–1.58) | (0.23–0.98) | (0.25–1.04) | (0.15–0.96)
| | [underlined: Relative Risk of Sudden Death According to n-3 FA Intake (multivariate)]
| | Servings: | <0.3 | 0.3-<2.7 | 2.7-<4.9 | 4.9-<7.4 | >7.4 | P for trend
| | cases: | 9 | 40 | 19 | 37 | 28
| | Person-years: | 7715 | 65223 | 56083 | 61936 | 62820
| | | 1.0 | 0.58 | 0.34 | 0.6 | 0.43 | 0.21
| | | (0.28–1.21) | (0.15–0.75) | (0.29–1.27) | (0.20–0.93)
| | [underlined: Relative Risk of MI According to Dietary Fish Intake (multivariate)]
| | Servings: | <1/mo | 1–3/mo | 1-<2/wk | 2-<5/wk | >5/wk | P for trend
| | cases: | 23 | 42 | 232 | 363 | 77
| | Person-years: | 7607 | 15247 | 78056 | 121611 | 26797
| | | 1.0 | 0.91 | 0.99 | 1.03 | 1.00 | 0.67
| | | (0.55–1.53) | (0.64–1.54) | (0.67–1.58) | (0.62–1.60)
| | [underlined: Relative Risk of Other Types of CV and Total Mortality According to Fish Intake (multivariate)]
| | | nonsudden | Coronary Heart | Cardiovascular | Total
| | | Person- | cardiac death | Disease Death | Mortality | Mortality
| | Fish consumed | yrs | (132 Cases) | (308 Cases) | (548 Cases) | (1652 Cases)
| | 1-<2 per wk | 78561 | 1.19 (0.42–3.35) | 0.82 (0.45–1.51) | 0.79 (0.51–1.23) | 0.71(0.55–0.91)
| | 2-<5 per wk | 23693 | 1.32 (0.47–3.66) | 0.91 (0.50–1.66) | 0.84(0.54–1.30) | 0.70(0.54–0.89)
| | ≥5 per wk | 27343 | 1.19 (0.38–3.70) | 0.81 (0.41–1.61) | 0.81 (0.49–1.33) | 0.73(0.55–0.63)
| | P value for trend | | 0.33 | 0.49 | 0.5 | 0.045
| | <1 per mo | 7715 | 1.0 | 1.0 | 1.0 | 1.0
| | 1–3 per mo | 15465 | 0.64 (0.16–2.60) | 1.18 (0.58–2.36) | 0.96 (0.57–1.61) | 0.79(0.59–1.06)
| | ≥1 per wk | 230597 | 1.25 (0.46–3.43) | 0.87 (0.48–1.56) | 0.82 (0.53–1.25) | 0.70(0.55–0.89)
| | P value for trend | | 0.31 | 0.26 | 0.21 | 0.003
Albert 2002 (Physician's Health study) | Results defined as death within 1 hour of symptom onset, a witnessed cardiac arrest, or both, or abrupt collapse not preceded by more than 1 h of symptoms that needed the terminal events. | [underlined: Relative Risk of Sudden Death from Cardiac Causes] | | | | | | | NIH, NHLBI
| | Quartiles (% total FA) | 3.58 | 4.76 | 5.63 | 6.87 | P
| | Multivariate model^1^ | 1.0 | 0.55(0.18–1.70) | 0.28(0.09–0.87) | 0.19(0.05–0.71) | 0.007
| | Multivariate model^2^ | 1.0 | 0.52(0.16–1.72) | 0.19(0.05–0.69) | 0.10(0.02–0.48) | 0.001
Ascherio 1995 (Health ProfessionalFollow up Study) | Stroke was defined as sudden or rapid onset of typical neurological defect of >24 h duration or leading to death attributable to CV event. Strokes were classified as ischemic (embolism or thrombosis), hemorrhagic (subarachnoid and intracerebral), unknown according to National Survey of Stroke. | [underlined: RR of CHD according to dietary intake of omega-3 g/d (multivariate)] | | | | | | | NIH
| | | 0.12–0.19 | 0.20–0.28 | 0.29–0.41 | 0.42–6.52 | p-value
| | Nonfatal MI: | 0.93(0.72–1.21) | 0.89 (0.68–1.16) | 0.78 (0.59–1.03) | 1.09 (0.85–1.41) | 0.44
| | Fatal CHD: | 1.14(0.78–1.66) | 0.95 (0.64–1.41) | 1.03 (0.70–1.52) | 1.03 (0.70–1.52) | 0.94
| | Any MI | 1.00 (0.81–1.25) | 0.92 (0.74–1.15) | 0.86 (0.69–1.08) | 1.09 (0.88–1.35) | 0.48
| | Any CHD | 0.98 (0.83–1.15) | 0.97 (0.83–1.15) | 0.99 (0.96–1.31) | 1.12 (0.96–1.31) | 0.09
| | Adjusted for BMI, smoking, alcohol, history of HTN, history of diabetes, history of hypercholesterolemia, family history of MI, profession, quintile group of intake
| | [underlined: RR of CHD according to dietary fish intake (multivariate)]
| | | 1–3/mo | 1/wk | 2–3/wk | 4–5/wk | >6/wk
| | Nonfatal MI: | 0.62 (0.39–1.00) | 0.80 (0.55–1.17) | 0.67 (0.46–0.97) | 0.69 (0.46–1.04) | 0.96 (0.63–1.47) | p=62
| | Fatal CHD | 0.74 (0.38–1.45) | 0.86 (0.50–1.47) | 0.71 (0.41–1.21) | 0.54 (0.29–1.00) | 0.77(0.41–1.44) | p=14
| | Any MI | 0.66 (0.44–0.97) | 0.82 (0.60–1.12) | 0.69 (0.51–0.94) | 0.65 (0.46–0.92) | 0.90 (0.63–1.28) | p=70
| | Any CHD: | 0.87 (0.64–1.18) | 1.02 (0.79–1.31) | 0.92 (0.71–1.18) | 0.99 (0.76–1.30) | 1.14 (0.86–1.51) | p=19
| | Adjusted for BMI, smoking, alcohol, history of HTN, history of diabetes, history of hypercholesterolemia, family history of MI, profession, quintile group of intake
Caicoya 2002 | Stroke was defined, according to WHO criteria, as rapidly developing clinical symptoms and/or signs of focal and at time global loss of cerebral function with symptoms lasting >24 h or leading to death, with no apparent cause other than vascular. | [underlined: OR of stroke (all categories combined) with increasing fish consumption (multivariate]) | | | | | | | Funding: Spanish Ministry of Education, local and regional hospitals
| | 1–22.5 g/d: | 23–45 g/d: | 46–90 g/d: | 91–250 g/d:
| | 0.30 (0.12–0.7) | 0.44 (0.18–1.41) | 0.59 (0.24–1.47) | 0.76 (0.27–2.10)
| | Adjusted for HTN, alcohol, AF, PAD
| | [underlined: OR of ischemic stroke with increasing fish consumption (multivariate)]
| | 11.3–28.7 g/d: | 28.8–46.5 g/d: | >46.5 g/d:
| | 1.05 (0.64–1.65) | 0.90 (0.55–1.48) | 1.98 (1.08–3.45)
| | [underlined: OR of stroke (all categories combined) with increasing omega-3 intake (multivariate)]
| | 116–319 mg/d: | 320–659 mg/d: | >659 mg/d:
| | 1.14 (0.60–1.88) | 1.37 (0.91–2.20) | 1.76 (0.96–3.26)
| | Adjusted for age, sex, HTN, alcohol, CAD, AF, PAD, energy intake
Daviglus 1997 | Death from MI (ICD-8 code 410, death from CHD (ICD 8 codes 410–414), and death from CVD (ICD codes 400–445). Death from MI was classified as sudden or not sudden according to the duration of the terminal illness and the place of death, as recorded on the death certificate. | [underlined: RR of Death according to fish consumption (multivariate)]
US | | | Total Deaths | Fish Consumption | | | | P for Trend
| | | 0 g/d | 1–17 g/d | 18–34 g/d | ≥35 g/d
| | person-yrs | 4754 | 16681 | 19350 | 6368
| | MI | 293 | 1.0 | 0.88 (0.60–1.28) | 0.76 (0.52–1.12) | 0.56 (0.33–0.93) | 0.017
| | All CHD | 430 | 1.0 | 0.88 (0.63–1.22) | 0.84 (0.61–1.17) | 0.62 (0.40–0.94) | 0.04
| | All CVD | 573 | 1.0 | 0.94 (0.70–1.25) | 0.89 (0.67–1.19) | 0.74 (0.52–1.06) | 0.010
| | All causes | 1042 | 1.0 | 1.02 (0.82–1.27) | 0.98 (0.79–1.22) | 0.85 (0.64–1.10) | 0.175
| | MI
| | Nonsudden Death | 94 | 1.0 | 1.04 (0.54–2.02) | 0.67 (0.35–1.33) | 0.33 (0.12–0.91) | 0.007
| | Nonsudden (>12h) | 70 | 1.0 | 1.31 (0.59–2.90) | 0.77 (0.34–1.76) | 0.51 (0.17–1.52) | 0.053
| | Sudden death: | 196 | 1.0 | 0.78 (0.48–1.24) | 0.80 (0.50–1.28) | 0.68 (0.37–1.25) | 0.337
| | Sudden death <12 h | 164 | 1.0 | 0.13 (0.64–1.99) | 1.04 (0.59–1.85) | 0.99 (0.49–1.99) | 0.827
Djousse 2001 (NHLBI Family Heart Study) | Prevalent CAD was assessed from patients' histories and 12–lead ECG. Individuals were considered to have CAD if they reported history of MI, PTCA, CABG that could be validated, or abnormal Q waves. | [underlined: Prevalence OR of CAD (multivariate)] | | | | | | | Funding: NHLBI, BU School of Medicine
| | [underlined: Age- and energy-adjusted quintiles of linolenic acid intake]
| | | 0.46 g/d | 0.58 | 0.65 | 0.76 | 0.96 | p for trend
| | M n= | 392 | 408 | 414 | 411 | 399
| | Cases | 93 | 76 | 66 | 65 | 62
| | | 1.0 | 0.77 (0.52–1.13) | 0.61 (0.39–0.96) | 0.58 (0.38–0.87) | 0.60 (0.39–0.92) | 0.012
| | W n= | 455 | 484 | 486 | 484 | 473
| | Cases | 27 | 23 | 32 | 20 | 21
| | | 1.0 | 0.57 (0.29–1.10) | 0.52 (0.24–1.13) | 0.30 (0.13–0.68) | 0.42 (0.22–0.84) | 0.014
| | [underlined: Influence of fish consumption of relation of linolenic acid to prevalence ORs of CAD]
| | [underlined: Age- and energy-adjusted quintiles of linolenic acid intake]
| | Fish: | 0.46 g/d | 0.58 | 0.65 | 0.76 | 0.96 | p for trend
| | 0 serving/wk (n=1207)
| | | 1.0 | 0.71 (0.23–2.18) | 0.81 (0.33–2.30) | 0.62 (0.16–2.33) | 0.38 (0.12–1.27) | 0.17
| | 1 serving/wk (n=1976)
| | | 1.0 | 1.11 (0.59–2.11) | 2.19 (1.01–4.78) | 0.71 (0.25–1.96) | 0.94 (0.28–3.12) | 0.67
| | >2servings/wk (n=1223)
| | | 1.0 | 0.70 (0.41–1.23) | 1.01 (0.51–2.03) | 0.47 (0.28–1.00) | 0.35 (0.14–0.92) | 0.05
| | Adjusted for age, risk group, diabetes, alcohol intake, smoking status, LDL, HDL, TG, SBBP, fiber, vitamin use, aspirin use, linoleic acid, P:S, fish intake, waist to hip ratio
Dolecek 1991 | Cause-specific mortality are found on ICD-9. | [underlined: Number of deaths by Cause in the Usual Care Arm of MRFIT RCT] | | | | | | | Funding by NHLBI, MRFIT Research Group
Dolecek 1992 | | Category | | Deaths
MRFIT | | Coronary heart disease | | 175
| | Cardiovascular diseases | | 232
| | Cancer | | 132
| | All causes | | 522
| | [underlined: Cox regression analysis for ALA intake Regression analysis for EPA+DHA intake (multivariate)]
| | Mean g | n | Deaths | RR | Deaths | RR
| | CHD mortality
| | 0.873 | 1251 | 43 | 1.00 | 42 | 1.00
| | 1.273 | 1253 | 40 | 0.98 | 39 | 1.08
| | 1.577 | 1251 | 24 | 0.57 | 35 | 0.91
| | 1.926 | 1251 | 40 | 0.98 | 35 | 0.88
| | 2.802 | 1252 | 28 | 0.68 | 24 | 0.6
| | | p value | 0.146 | | | 0.015
| | CVD mortality
| | 0.873 | 1251 | 58 | 1.00 | 55 | 1.00
| | 1.273 | 1253 | 52 | 0.94 | 51 | 1.06
| | 1.577 | 1251 | 38 | 0.67 | 47 | 0.92
| | 1.926 | 1251 | 49 | 0.9 | 48 | 0.92
| | 2.802 | 1252 | 35 | 0.63 | 31 | 0.59
| | | p value | 0.67 | | | 0.004
| | All cause mortality
| | 0.873 | 1251 | 105 | 1.00 | 99 | 1.00
| | 1.273 | 1253 | 99 | 0.96 | 96 | 1.09
| | 1.577 | 1251 | 73 | 0.69 | 93 | 1.02
| | 1.926 | 1251 | 49 | 0.89 | 80 | 0.85
| | 2.802 | 1252 | 35 | 0.69 | 71 | 0.76
| | | p value | 0.14 | | | 0.01
| | [underlined: RATIO]
| | 18:3n-3/18:2n-6 = 0.122±0.034
| | n-3/n-6 = 0.133±0.051
Egeland 2001 | CHD was determined by ICD-8 codes used in 1985 (410–11, 412–412.3, 413), ICD-9 used from 1986-1992 (410–413, 414–414.1, 414.3,414.9) | [underlined: Hazard Rate Ratio (HR) of CHD Mortality Rates and Cod Liver Oil and Smoking (multi)] | | | | | | | ND
| | | N | person-yrs | deaths | HR
| | Never smokers
| | Cod liver oil - NO | 13,386 | 161002 | 155 | 1.0
| | Cod liver oil - YES | 2382 | 28975 | 27 | 0.7 (0.4–1.5)
| | Former smokers
| | Cod liver oil - NO | 8063 | 98217 | 79 | 1.1 (0.8–1.5)
| | Cod liver oil - YES | 1193 | 14795 | 18 | 1.7 (1.0–2.9)
| | Current smokers
| | Cod liver oil - NO | 15,061 | 183,029 | 392 | 3.1 (2.4–4.0)
| | Cod liver oil - YES | 1693 | 21,237 | 34 | 2.5 (1.6–3.7)
Erkkila, 2003 | Deaths from CAD included codes I20–I25 from ICD-10; deaths from CVD included codes I20–-8, I60–9, G-45, G46. | [underlined: Relative Risk of death and CVD events by fish intake (multivariate)] | | | | | | | ND
| | | 0 g/d (n=103) | 1–57 (n=147) | >57 (n=150) | P for trend
| | All Death | 1.0 (14) | 0.50(0.20,1.28) (11) | 0.37(0.14,1.00) (9) | 0.059
| | CAD death | 1.0 (5) | 1.59(0.39,6.49) (5) | 1.04(0.25,4.310 (6) | 0.731
| | CAD death or AMI | 1.0 [10] | 1.00(0.38, 2.66) (14) | 0.49(0.17, 1.41) (10) | 0.209
| | CVD death, AMI, stroke: | 1.0 [16] | 0.64(0.28, 1.47) (15) | 0.45(0.19, 1.09) (13) | 0.121
| | Revascularization: | 1.0 [7] | 1.89(0.68, 5.25) (17) | 1.09(0.37, 3.17) (14) | 0.226
Fraser 1992 | Diagnosis of nonfatal MI was confirmed if international criteria were met: typical ECG change or elevation of cardiac enzyme levels plus either prolonged cardiac pain or static ECG abnormalities. Fatal CHD was also defined by international diagnostic criteria. Other definite fatal CHD required ICD-9 code 410–414. | [underlined: Hazard ratio of of fish consumption and CHD] | | | | | | | NIH
Adventist Health Study | | | Never | <1/wk | >1/wk
| | Nonfatal MI | 1.0 | 1.11 (0.75–1.16) | 1.04 (0.55–1.96)
| | Definite CHD | 1.0 | 1.01 (0.76–1.35) | 0.74 (0.42–1.33)
Fraser 1997 | ICD-9 codes 410–414 were used for immediate and underlying causes of death. | [underlined: Hazard ratio of of fish consumption and all-causemortality]
Adventist Health Study | | | 1/wk | >1/wk
subset | | Men | 1.0 | 0.89 (0.58–1.38)
| | Women | 1.0 | 0.99 (0.73–1.33)
| | Total | 1.0 | 0.98 (0.76–1.24)
| | [underlined: Hazard ratio of of fish consumption and CHD mortality]
| | | 1/wk | >1/wk
| | Men | 1.0 | 0.88 (0.36–2.18)
| | Women | 1.0 | 0.93 (0.53–1.64)
| | Total | 1.0 | 0.91 (0.56–1.46)
Gartside 1998 | | [underlined: Interaction between fish intake and cholesterol for CHD events] | | | | | | | Limitations: poor methodological processes
NHANES | | | Fish intake | Cholesterol <209 | 209–249 | >249 | | | Funding: Jewish Hospital Medical Research Foundation.
| | | None | 39% | 40% | 45%
| | | <1/wk | 33% | 32% | 41%
| | | >1/wk | 26% | 30% | 38%
| | Subjects with serum cholesterol >249 mg/dl benefited less (p=04) from fish intake than those with 209–249 or <209
Gillum 2000 (NHEFS=NHANES I Epidemiologic Follow up Study) | Deaths from CVD coded by ICD-9, 390–459. Deaths from CHD were defined by ICD-9 410–414. | [underlined: RR for all-cause death, CV death, and cardiac death associated with fish consumption at ages 25–4 years (multivariate)] | | | | | | | Various governmental agencies, including NCI, NHLBI, NIMH, Dept Agriculture
| | Fish Consumption | all-cause death | CV death | cardiac death
| | White men
| | Never | 1.00 | 1.00 | 1.00
| | <1/wk | 0.88 | 0.98 | 0.89
| | 1/wk | 0.76* | 0.87 | 0.86
| | >1/wk | 0.85 | 0.95 | 0.86
| | Black men
| | Never | 1.00 | 1.00 | 1.00
| | <1/wk | 1.01 | 0.96 | 1.20
| | 1/wk | 1.05 | 0.99 | 1.11
| | >1/wk | 1.11 | 1.08 | 1.05
| | White women
| | Never | 1.00 | 1.00 | 1.00
| | <1/wk | 1.02 | 1.11 | 0.91
| | 1/wk | 1.02 | 1.05 | 0.98
| | >1/wk | 0.9 | 1.06 | 0.97
| | Black women
| | Never | 1.00 | 1.00 | 1.00
| | <1/wk | 0.77 | 0.85 | 0.82
| | 1/wk | 0.79 | 0.94 | 0.59
| | >1/wk | 0.82 | 0.99 | 0.90
| | White men aged 25–74 years with fish consumption one time/week had an age-adjusted relative risk (1 time/week relative risk 0.76, 95% confidence interval 0.63–0.91). No additional reduction in risk was seen for consumption >1 time/week (adjusted relative risk 0.85, 95% CI 0.68–1.06). Similar but nonsignificant trends were seen in white and black women, but not black men.
| | In white men, risk of noncardiovascular death but not cardiovascular death was also significantly reduced in those consuming fish once or more a week. No consistent association of fish consumption and coronary heart disease incidence or mortality was seen. White men consuming fish one a week had significantly lower risk of death over a 22-year follow-up then those never consuming fish.
Gillum 1996 (NHANES I Epidemiologic Follow up Study) | Incident stroke cases met the following criteria: death certificate with underlying or nonunderlying cause of death coded according to ICD-9, and/or hospital or nursing home stay during the follow up period with any discharge diagnosis according to ICD-9. Nonhemorrhagic stroke was defined by underlying or nonunderlying cause of death or hospital discharge diagnosis from ICD-9. | [underlined: RR for stroke (both bleeds and ischemic stroke) and fish consumption frequency] | | | | | | | Funding: NIH, NCI, NHLBI
| | Women aged 45–74 <1/wk: | 0.78 | (0.54–1.12) | | | | | The number of cases of hemorrhagic stroke was too small for meaningful analysis.
| | Women aged 45–74 1/wk: | 0.77 | (0.53–1.13)
| | Women aged 45–74 >1/wk: | 0.55* | (0.32–0.93)
| | Men aged 45–74 <1/wk: | 1.27 | (0.83–1.96)
| | Men aged 45–74 1/wk: | 1.23 | (0.79–1.91)
| | Men aged 45–74 >1/wk: | 0.85 | (0.49–1.46)
| | [underlined: RR for stroke incidence, stroke death and fish consumption frequency]
| | | Stroke incidence | | | Stroke death
| | Never | 1.00 | | | 1.00
| | Any | 0.51 | (0.30–0.88) | (p<0.05) | 0.26 | (0.11–0.64) | (p<0.01)
| | Adjusted for age, smoking, diabetes, heart disease, education, SBP, serum albumin, serum cholesterol, BMI, alcohol intake, physical activity
He 2002 (Health Professional Follow up Study) | Stroke was defined as sudden or rapid onset of typical neurological defect of >24 h duration or leading to death attributable to CV event. Strokes were classified as ischemic (embolism or thrombosis), hemorrhagic (subarachnoid and intracerebral), unknown according to National Survey of Stroke | [underlined: RR of total stroke based on Fish consumption (multivariate)] | | | | | | | Funding: NIH
| | | 1–3 servings/mo | 1/wk | 2–4/wk | >5/wk
| | | 0.73 (0.48–1.10) | 0.74 (0.52–1.04) | 0.67 (0.46–0.96) | 0.83 (0.53–1.29)
| | RR of ischemic stroke based on Fish consumption (multivariate analysis)
| | | 0.57 (0.35–0.95) | 0.56 (0.37–0.84) | 0.55 (0.36–0.85) | 0.54 (0.31–0.94)
| | RR of hemorrhagic stroke based on Fish consumption (multivariate analysis)
| | | 1.81 (0.58–5.66) | 1.40 (0.49–3.99) | 0.96 (0.32–2.89) | 1.55 (0.45–5.35)
| | [underlined: RR of total stroke based on omega-3 intake (multivariate)]
| | | 0.05-<0.2 g/d | 0.2–0.4 g/d | 0.4-<0.6 g/d | >0.6 g/d
| | | 0.77 (0.52–1.14) | 0.77 (0.52–1.14) | 0.71 (0.46–1.10) | 0.87 (0.56–1.37)
| | RR of ischemic stroke based on omega-3 intake (multivariate analysis)
| | | 0.56 (0.35–0.88) | 0.63 (0.40–0.98) | 0.54 (0.32–0.91) | 0.73 (0.43–1.25)
| | RR of hemorrhagic stroke based on omega-3 intake (multivariate analysis)
| | | 1.29 (0.45–3.75) | 1.02 (0.35–3.00) | 0.89 (0.27–2.87) | 1.14 (0.34–3.84)
| | Adjusted for BMI, physical activity, history of HTN, smoking, aspirin use, fish oil, total calories, total fat, saturated fat, trans-unsaturated fat, K, Mg, servings of fruits and vegetables, hypercholesterolemia
| | No significant associations were found between fish or omega-3 intake and risk of hemorrhagic stroke.
| | Inverse association between fish intake and risk of ischemic stroke was not materially modified by use of aspirin or vitamin E intake. Tests for interaction were not statistically significant.
Hu 2002 (Nurses' Health Study) | Stroke was confirmed according to the criteria of the National Survey of Stroke which requires a constellation of neurological deficits of sudden or rapid onset lasting at least 24 h or until death. Ischemic stroke included cerebral infarction cause by thrombi or by emboli from extracranial sources. | [underlined: RR for CHD and average frequency of fish intake (multivariate)] | | | | | | | Funding: NIH
16 y follow up | | | 1–3/mo | 1/wk | 2–4/wk | >5/wk | p
| | Total CHD | 0.79 (0.64–0.97) | 0.71 (0.58–0.87) | 0.69 (0.55–0.86) | 0.66 (0.50–0.89) | .001
| | Fatal CHD | 0.81 (0.57–1.15) | 0.66 (0.47–0.92) | 0.73 (0.49–1.08) | 0.55 (0.33–0.90) | .01
| | Nonfatal MI | 0.78 (0.60–1.00) | 0.74 (0.58–0.94) | 0.68 (0.51–0.90) | 0.73 (0.51–1.04) | .03
| | [underlined: RR for CHD according to quintiles of median EPA+DHA g/d (multivariate)]
| | | 0.05 | 0.08 | 0.14 | 0.24 | p
| | Total CHD | 0.93 (0.78–1.09) | 0.78 (0.65–0.93) | 0.68 (0.56–0.82) | 0.67 (0.55–0.81) | <.001
| | Fatal CHD | 0.93 (0.70–1.24) | 0.69 (0.51–0.95) | 0.54 (0.39–0.76) | 0.63 (0.45–0.88) | <.001
| | Nonfatal MI | 0.92 (0.75–1.13) | 0.83 (0.67–1.02) | 0.75 (0.60–0.94) | 0.69 (0.55–0.88) | <.001
| | [underlined: RR of CHD according to quintiles of omega-3 intake, OMEGA 6/OMEGA 3 RATIOS]
| | | 1 | 2 | 3 | 4 | 5
| | [underlined: Low n-6/n-3 ratio (median 5.9)]
| | Multivariate | 1.0 | 1.08 (0.83–1.39) | 0.84 (0.64–1.10) | 0.77 (0.58–1.01) | 0.74 (0.56–0.98)
| | [underlined: High n-6/n-3 ratio (median 9.2)]
| | Multivariate | 1.0 | 0.83 (0.67–1.03) | 0.75 (0.59–0.94) | 0.60 (0.45–0.80) | 0.52 (0.33–0.81)
| | Adjusted for age, smoking, BMI, alcohol, menopausal status & HRT, moderate activity, multivitamin use, hypercholesterolemia, diabetes.
Hu 1999 (Nurses' Health Study) | Primary endpoint was fatal IHD that occurred after the return of the 1984 Q but before 1 June 1994. Fatal IHD was defined as fatal MI if it was confirmed by hospital records or autopsy. Nonfatal MI was confirmed if it met WHO criteria plus either diagnostic electro-cardiographic changes or elevated cardiac enzyme concentrations. | [underlined: RR for IHD according to quintiles of median ALA g/d (multivariate)]
10 y follow up | | | 0.71 | 0.86 | 0.98 | 1.12 | 1.36 | p for trend
| | cases | 49 | 52 | 51 | 41 | 39
| | | 1.0 | 0.99 (0.66–1.48) | 0.90 (0.59–1.39) | 0.67 (0.42–1.09) | 0.55*(0.32–0.94) | .001
| | cases | 121 | 114 | 120 | 131 | 111
| | Nonfatal MI | 1.0 | 0.92 (0.71–1.21) | 0.94 (0.71–1.25) | 1.02 (0.76–1.19) | 0.85 (0.61–1.19) | .05
| | Adjusted for age, BMI, cigarette smoking, alcohol intake, menopausal status and HRT, exercise, aspirin use, vitamin use, history of HTN, history of diabetes, history of hypercholesterolemia, parental history of MI, frequency of fruits and vegetables, dietary intakes of saturated fat, trans-unsaturated fat, linoleic acid, vitamins C & E.
Iso 2001 Nurses' (Health Study) | Stroke was confirmed according to the criteria of the National Survey of Stroke. Ischemic stroke included cerebral infarction cause by thrombi or by emboli from extracranial sources. | [underlined: RR of total stroke and average frequency of fish intake (multivariate)] | | | | | | | Funding: NIH
14 y follow up | | | 1–3/mo | 1/wk | 2–4/wk | >5/wk
| | Total stroke | 0.93 (0.65–1.34) | 0.78 (0.55–1.12) | 0.73 (0.47–1.14) | 0.48 (0.21–1.06)
| | Ischemic stroke | 0.83 (0.50–1.38) | 0.69 (0.42–1.14) | 0.63 (0.34–1.15) | 0.38 (0.121.19)
| | Hemorrhagic | 1.36 (0.67–2.76) | 1.13 (0.56–2.30) | 0.93 (0.39–2.21) | 1.02 (0.26–4.09)
| | [underlined: RR of total stroke according to quintiles of EPA+DHA median intake g/d (multivariate)]
| | | 0.118 | 0.171 | 0.221 | 0.481
| | Total stroke | 0.87 (0.66–1.11) | 0.69 (0.53–0.89) | 0.83 (0.63–1.08) | 0.72 (0.53–0.99)
| | Ischemic stroke | 0.83 (0.59–1.18) | 0.67 (0.47–0.98) | 0.82 (0.57–1.18) | 0.71 (0.46–1.10)
| | Hemorrhagic | 0.94 (0.61–1.43) | 0.66 (0.41–1.05) | 0.93 (0.58–1.49) | 0.76 (0.43–1.37)
| | Adjusted for joules, BMI, alcohol intake, menopause and HRT, exercise, aspirin use, vitamin use, history of HTN, frequency of fruits and vegetables, saturated fat, trans-unsaturated fat, linoleic acid, animal protein, Ca.
Keli 1994 | Stroke was defined as sudden onset of neurological paralysis of >24 h duration or leading to death. Fatal strokes were coded according to ICD-8 | [underlined: Hazard ratios for stroke incidence (bleeds and ischemic stroke) for fish estimates] | | | | | | | Funding: Netherlands Preventive Funds, and Public Health Service Curacao.
8303739 | | Fish consumption | >20 g/d v <20 | 0.49 (0.24–1.01)
(Zutphen Study) | | Fish consumption, Always v Never | 0.71 | (0.38–1.33)
| | Adjusted for age SBP, serum cholesterol, smoking, intake of energy, alcohol, prescribed diet.
Kinjo Y, 1999 | Causes of death coded according to ICD-7: 330–334 | [underlined: Mortality risk of cerebrovascular disease for fish intake] | | | | | | | Funding: Promotion of Cancer Research in Japan
| | | All cerebrovasc Dis. | Hemorrhagic stroke | ischemic stroke
| | | Death | RR | Death | RR | Death | RR
| | <1 time/wk | 713 | 1.00 | 304 | 1.00 | 236 | 1.00
| | 1–3 /wk: | 6369 | 0.98 (0.90–1.06) | 2825 | 1.02 (0.90–1.15) | 2266 | 1.05 (0.91–1.20)
| | >4/wk: | 3948 | 0.86 (0.79–0.94) | 1644 | 0.87 (0.76–0.98) | 1582 | 0.99 (0.86–1.14)
| | Risk of mortality from cerebrovascular disease was inversely associated with fish consumption.
Kromhout, 1985 (Zutphen Study) | Underlying cause of death was coded according to ICD-8. | [underlined: Adjusted Risk Ratios of Death from CHD to fish consumption] | | | | | | | ND on Funding
| | [underlined: Fish Consumption (g/day)]
| | | Deaths | 0 | 1–14 | 15–29 | 30–44 | ≥45
| | | N | 159 | 283 | 215 | 116 | 79
| | 1960-1970 | 27 | 1.00 | 0.65 | 0.82 | 0.00 | 0.47
| | 1971-1980 | 51 | 1.00 | 0.67 | 0.51 | 0.64 | 0.41
| | 1960-1980 | 78 | 1.00 | 0.64 | 0.56 | 0.36* | 0.39
| | | (0.32–1.26) | (0.27–1.15) | (0.14–0.93) | (0.13–1.15)
| | An inverse dose-response relation was observed between fish consumption in 1960 and death from CHD during 20 years of follow-up. This relation persisted after multiple logistic-regression analyses.
Kromhout, 1995 | The underlying cause of death was coded according to ICD-9. CHD deaths derived from ICD 410–414. | [underlined: From Kromhout 1995:] | | | | | | | Funding source: Netherlands Nutrition Council and The Netherlands Prevention Foundation Grant.
Feskens 1993 (Rotterdam Study) | | Logistic regression showed that among fish-eating men the prevalence of MI was 1/3 compared to no fish-eaters (OR=0.34; 0.12–1.02)
| | The difference between fish eaters and no-fish eaters was statistically significant (P<0.001). RR for fish eaters compared with no fish eaters was 0.47, 0.28–0.79)
| | Multivariate Cox proportional hazards analyses showed inverse relation between fish consumption and 17 y CHD mortality.
| | No association was found between fish consumption and total mortality, RR=0.96, 072–1.30.
| | [underlined: From Feskens 1993:]
| | [underlined: Age and sex-adjusted 17 year mortality of CHD in normoglycemic and glucose intolerant elderly subject by fish intake]
| | | Normoglycemic Subjects | Glucose Intolerant
| | [underlined: Non-fish Eaters]
| | N | 78 | 32
| | Events | 23 | 10
| | Mortality rate* | 25.1 | 31.2
| | [underlined: Fish Eaters]
| | N | 111 | 51
| | Events | 14 | 11
| | Mortality rate* | 10.9 | 20.6
| | RR | 0.44 | 0.66
| | 95% CI | (0.22–0.86)* | (0.33–1.84)
Mann 1997 | ICD code 410–414 | Ischaemic Heart Disease | All causes of Death | | | | | | ND
| | | #deaths (64) | Death Rate Ratio | Trend | #deaths (392) | Death rate ratio | Trend
| | Never eaten: | 26 | 100 | NS | 184 | 100 | NS
| | <1 time/wk: | 13 | 121 | NS | 82 | 97(74–126) | NS
| | ≥1 time/wk: | 25 | 123 | NS | 123 | 89(63–121) | NS
| | No prospective effects were observed for fish. Within the study, death rate ratios were increased among those in the upper half of the normal BMI range (22.5 to <25) and those who were overweight (BMI ≥ 25) compared with those with BMI 20-<22.5
Morris 1995 (Physicians Health Study) | Cases of nonfatal MI were confirmed on the basis of WHO criteria. Nonfatal stroke was defined as a typical and sudden neurologic deficit, lasting >24 h and attributable to CV event. CV deaths include AMI, ischemic heart disease, sudden death, stroke, other CV disease (ICD-10). | [underlined: RR of CVD outcomes and level of fish consumption meals/wk (multivariate)] | | | | | | | Funding: NIH, National Institute of Environ Health Sciences
| | fish/meals-wk | <1 | 1 | 2–4 | >5 | trend
| | Total MI | 1.0 | 1.5 (1.1–2.1) | 1.3 (0.9–1.9) | 0.9 (0.4–1.8) | p=0.72
| | Nonfatal MI | 1.0 | 1.4 (0.9–2.0) | 1.2 (0.8–1.8) | 0.8 (0.4–1.7) | p=0.79
| | Stroke | 1.0 | 0.9 (0.6–1.3) | 0.8 (0.5–1.2) | 0.6 (0.3–1.6) | p=0.13
| | CV deaths | 1.0 | 2.6 (1.4–4.8) | 1.7 (0.9–3.4) | 2.2 (0.8–5.9) | p=0.35
| | Total CV events | 1.0 | 1.3 (1.0–1.6) | 1.1 (0.8–1.4) | 0.9 (0.6–1.5) | p=0.65
| | [underlined: RR of CVD outcomes and quintiles of omega–3 intake g/wk (multivariate)]
| | omega-3 intake g/wk | 0.5-<1.0 | 1.0-<1.7 | 1.7-<2.3 | >2.3 | trend
| | Total MI | 1.6 (1.1–2.4) | 1.4 (1.0–2.2) | 1.2 (0.8–1.8) | 1.2 (0.8–1.8) | p=0.98
| | Nonfatal MI | 1.5 (1.0–2.3) | 1.3 (0.9–2.0 ) | 1.2 (0.8–1.9) | 1.1 (0.7–1.8) | p=0.99
| | Stroke | 0.9 (0.6–1.6) | 1.1 (0.7–1.8) | 0.7 (0.4–1.2) | 1.0 (0.6–1.6) | p=0.49
| | CV deaths | 1.6 (0.8–3.0) | 1.6 (0.9–3.0) | 0.9 (0.5–1.9) | 1.5 (0.8–2.9) | p=0.80
| | Total CV events | 1.3 (1.0–1.8) | 1.3 (1.0–1.7) | 0.9 (0.7–1.3) | 1.1 (0.8–1.5) | p=0.63
| | Total CV events include nonfatal MI, nonfatal stroke, CV death
| | Adjusted for age, aspirin and beta-carotene, smoking, alcohol, obesity, diabetes, vigorous exercise, parental history of MI, history of HTN, history of hypercholesterolemia, vitamin use, saturated fat intake
Mozaffarian 2003 (Cardiovas-cular Health Study) | MI was classified as using chest pain, cardiac enzymes & ECGs. Suspected cardiac deaths not meeting all criteria for definite MI were classified as coronary heart disease death if they occurred within 72 hours of chest pain or with an antecedent history of IHD. | [underlined: Frequency of fish intake] | | | | | | | NA
| | (tuna/other fish) | 1–3/mo | 1/wk | 2/wk | >3/wk | Trend | | Funding: VA Health Services, NHLBI
| | Total IHD death | 0.90 (0.57–1.41) | 0.87 (0.54–1.42) | 0.65 (0.39–1.07) | 0.51(0.31–0.83) | p=0.001
| | Arrhythmic IHD death: | 1.09 (0.61–1.97) | 0.98 (0.52–1.87) | 0.71 (0.37–1.37) | 0.42(0.21–0.84) | p=0.001
| | Nonfatal MI | 0.85 (0.57–1.27) | 0.76 (0.50–1.17) | 0.83 (0.55–1.27) | 0.82 (0.56–1.22) | p=0.44
| | Adjusted for age, gender, education, diabetes, current smoking, cigarette packs/year, fish consumption
| | [underlined: Frequency of fish intake (tuna/other fish)]
| | | 1–3/mo | 1/wk | 2/wk | >3/wk | Trend
| | Total IHD death | 78 (0.47–1.28) | 0.77 (0.45–1.32) | 0.53 (0.30–0.96) | 0.47 (0.27–0.82) | p=0.002
| | Arrhythmic IHD death: | 0.86 (0.45–1.63) | 0.81 (0.40–1.66) | 0.50 (0.23–1.07) | 0.32 (0.15–0.70) | p=0.001
| | Nonfatal MI | 0.81 (0.51–1.26) | 0.71 (0.44–1.15) | 0.75 (0.46–1.21) | 0.67 (0.42–1.07) | p=0.10
| | Adjusted for age, gender, education, diabetes, current smoking, cigarette packs/year, fish consumption, BMI, SBP, LDL, HDL, TG, CRP, intake of saturated fat, alcohol, beef/pork, fruits and vegetables
| | [underlined: Frequency of fish intake (fried fish/sandwich)]
| | | 1–3/mo | 1/wk | 2/wk | >3/wk | Trend
| | Total IHD death | 1.13 (0.80–1.60) | 1.40 (0.79–2.48) | 1.19 (0.77–1.84) | 1.24 (0.45–3.45) | p=0.27
| | Arrhythmic IHD death: | 1.24 (0.78–1.96) | 1.54 (0.74–3.19) | 1.49 (0.87–2.58) | single event | p=0.24
| | Nonfatal MI | 1.30 (0.99–1.72) | 1.47 (0.91–2.37) | 1.18 (0.83–1.68) | 2.30 (1.18–4.46) | p=0.08
| | Adjusted for age, gender, education, diabetes, current smoking, cigarette packs/year, fish consumption
| | [underlined: Frequency of fish intake (fried fish/sandwich)]
| | | 1–3/mo | 1/wk | 2/wk | >3/wk | Trend
| | Total IHD death | .23 (0.83–1.83) | 1.61 (0.88–2.94) | 1.14 (0.68–1.91) | 1.37 (0.48–3.90) | p=0.35
| | Arrhythmic IHD death: | 1.22 (0.71–2.08) | 1.95 (0.91–4.18) | 1.54 (0.82–2.90) | single event | p=0.28
| | Nonfatal MI | 1.28 (0.93–1.77) | 1.58 (0.93–2.70) | 1.22 (0.82–1.82) | 1.93 (0.91–4.08) | p=0.11
| | Adjusted for age, gender, education, diabetes, current smoking, cigarette packs/year, fish consumption, BMI, SBP, LDL, HDL, TG, CRP, intake of saturated fat, alcohol, beef/pork, fruits and vegetables
| | After adjustment for potential confounders, consumption of tuna or other broiled or baked fish was associated with lower risk of total IHD death (p for trend =.001) and arrhythmic IHD death (p=.001) but not nonfatal MI (p=.44) with 49% lower risk of total IHD death and 58% lower risk of arrhythmic IHD death among persons consuming tuna/other fish 3 or more times/week compared with less than once a month. Similarly, fried fish-sandwich consumption was not associated with lower risk of total IHD death, arrhythmic IHD death, or nonfatal MI but rather with trend towards higher risk.
Nagata 2002 (Takayama Study) | The major endpoint of this study was all-cause mortality. From ICD-10, we used cardiovascular disease (codes 100–199). For the category of cardiovascular disease, we also selected ischemic heart disease (codes 120, 121, 124, and 125) and cerebrovascular disease (codes 160–164, 167, 169, and Q25–Q28) as disease-specific endpoints. | [underlined: Risk of all-cause mortality in men according to quintile of fish oil intake (mg/d)] | | | | | | | Ministry of Education, Science, Sports , and Culture, Japan
| | Men | Median intake | deaths | person/yrs | Hazards ratio | p for trend
| | 1 (low) | 410 | 205 | 18281 | 1.0
| | 2 | 602 | 198 | 18315 | 0.82 (0.67–0.99)*
| | 3 | 788 | 225 | 18186 | 0.87 (0.72, 1.05)
| | 4 | 1051 | 258 | 18138 | 0.88 (0.73, 1.06)
| | 5(high) | 1582 | 277 | 18116 | 0.87 (0.73, 1.05) | 0.38
| | Women | Median intake | deaths | person/yrs | Hazard ratios
| | 1 (low) | 332 | 216 | 21838 | 1.0
| | 2 | 486 | 179 | 22111 | 0.92 (0.76–1.13)
| | 3 | 635 | 163 | 22032 | 0.84 (0.69–1.04)
| | 4 | 832 | 178 | 22025 | 0.90 (0.73–1.09)
| | 5(high) | 1253 | 163 | 22118 | 0.77*(0.62–0.94) | 0.01
| | [underlined: Risk of cause-specific mortality in men according to quintile of fish oil intake]
| | Fish oil intake | Cardiovascular disease | All other causes
| | Men | # deaths | Hazard Ratio | 95% CI | #deaths | Hazard Ratio | 95% CI
| | 1 (low) | 60 | 1.0 | 72 | 1.0
| | 2 | 53 | 0.74 | 0.51, 1.08 | 70 | 0.82 | 0.59, 1.15
| | 3 | 53 | 0.71 | 0.49, 1.03 | 103 | 1.12 | 0.83, 1.52
| | 4 | 71 | 0.82 | 0.58, 1.15 | 103 | 1.01 | 0.75, 1.37
| | 5 (high) | 71 | 0.76 | 0.54, 1.07 | 107 | 0.98 | 0.72, 1.32
| | Fish oil intake | Cardiovascular disease | All other causes
| | Women | # deaths | Hazard Ratio | 95% CI | #deaths | Hazard Ratio | 95% CI
| | 1 (low) | 85 | 1.0 | 77 | 1.0
| | 2 | 60 | 0.82 | 0.59, 1.15 | 66 | 0.94 | 0.68, 1.31
| | 3 | 57 | 0.79 | 0.58, 1.11 | 60 | 1.87 | 0.62, 1.52
| | 4 | 64 | 0.86 | 0.62, 1.20 | 55 | 1.77 | 0.54, 1.09
| | 5 (high) | 61 | 0.77 | 0.55, 1.00 | 61 | 0.8 | 0.80, 1.23
| | Adjusted for various factors.
| | For women but not for men, n-3 fatty acids from fish were significantly inversely associated with total mortality.
Oomen 2000 (Seven Countries Study) | All mortality data was coded according to WHO, 8^th^ edition. CHD referred to primary or secondary cause of death based on ICD codes 410–414. | [underlined: Relative Risks for 20-year CHD* mortality, according to categories of fish consumption] | | | | | | | Funding source: Unilever Research Laboratory
| | Country, | Fish Intake (g/d) | N | CHD deaths (%) | Mortality Rate | RR
| | [underlined: Finland] | 0–19 | 476 | 100 (21.0) | 13.9 | 1.0
| | | 20–39 | 263 | 52 (19.8) | 13.1 | 0.97 (0.68,1.38)
| | | ≥40 | 349 | 90(25.8) | 18.5 | 1.25 (0.89. 1.76) | p for trend: 0.20
| | [underlined: Italy] | 0 | 264 | 32(12.1) | 8.2 | 1.00
| | | 1–19 | 347 | 37(10.7) | 7.1 | 0.94 (0.55, 1.59)
| | | 20–39 | 323 | 34(10.5) | 6.7 | 0.93 (0.53, 1.63)
| | | ≥40 | 163 | 13(8.0) | 5.0 | 0.67 (0.33, 1.39) | p for trend: 0.33
| | [underlined: The Netherlands]
| | | 0 | 157 | 29(18.5) | 11.7 | 1.00
| | | 1–19 | 169 | 30(17.8) | 11.6 | 1.00 (0.59,1.68)
| | | ≥20 | 227 | 46(20.3) | 13.1 | 1.10 (0.68, 1.79) | p for trend: 0.69
| | Country, | Fish Intake (g/d) | N | CHD deaths | RR
| | [underlined: Finland]
| | Fatty fish | 0 | 697 | 155 | 1.00
| | | >0 | 391 | 87 | 0.80 (0.5–1.26)
| | Lean fish | 0
| | | <20 | 568 | 124 | 1.00
| | | ≥20 | 253 | 51 | 0.95 (0.68–1.33)
| | | ≥40 | 267 | 67 | 1.08 (0.78–1.50) | p for trend: 0.63
| | [underlined: Italy]
| | Fatty fish | 0 | 923 | 106 | 1.00
| | | >0 | 174 | 10 | 0.40 (0.19–0.84)
| | Lean fish | 0 | 318 | 34 | 1.00
| | | <20 | 365 | 41 | 1.09 (0.66–1.81)
| | | ≥20 | 281 | 30 | 0.97 (0.55–1.69)
| | | ≥40 | 133 | 11 | 0.80 (0.38–1.66) | p for trend: 0.57
| | [underlined: The Netherlands]
| | Fatty fish | 0 | 451 | 92 | 1.00
| | | >0 | 102 | 13 | 0.70 (0.38–1.27)
| | Lean fish | 0 | 216 | 38 | 1.00
| | | <20 | 146 | 24 | 0.93 (0.55–1.55)
| | | ≥20 | 191 | 43 | 1.29 (0.82–2.03) | p for trend: 0.27
| | | ≥40
Oomen 2001 (Zutphen Elderly Study) | Causes of death were coded according to ICD-9. After adjustment for age, standard coronary risk factors, and intake of nutrients, | RR of fatal plus nonfatal CAD and fatal CAD | | | | | | | Funding: Netherlands Prevention Foundation; Unilever Research
| | ALA intake, % energy
| | | 0.45–0.58 | >0.58 | P for Trend
| | Fatal + nonfatal CAD
| | Crude RR | 1.68 (0.97–2.89) | 2.24 (1.33–3.77) | p=0.003
| | Age and energy-adjusted | 1.69 (0.98–2.92) | 2.23 (1.32–3.76) | p=0.003
| | Fully adjusted RR | 1.49 (0.82–2.70) | 1.68 (0.86–3.29) | p=0.17
| | Fatal CAD
| | Crude RR | 1.27 (0.59–2.71) | 1.97 (0.97–3.98) | p=0.05
| | Age and energy-adjusted | 1.26 (0.59–2.69) | 1.95 (0.96–3.94) | p=0.05
| | Fully adjusted RR | 0.99 (0.43–2.28) | 1.59 (0.62–4.08) | p=0.26
| | Adjusted for age, BMI, ex-smoking, current smoking, alcohol, vitamin use, saturated fatty acids, protein, energy intake.
| | ALA was not significantly associated with CAD risk. ALA intake from sources containing trans fatty acids was also nonsignificantly, yet positively, associated with CAD risk;
| | ALA intake from foods that did not contain trans fatty acids was not associated with CAD risk.
Orencia 1996 (Western Electric Study) | Only causes of death in Part I of death certificate were considered definitive endpoints. Stroke was defined as any mention of CVD (ICD-9) with exception of TIA . (There are too few ICH to stratify by stroke subtype.) | [underlined: Hazards ratio for fatal stroke (bleeds and ischemic stroke) and fish consumption] | | | | | | | Funding: NHLBI, Chicago Health Research Foundation, Otho Sprague Foundation, St Luke's Hospital, Illini Foundation
| | 1–17 g/d | 0.98 (0.42–2.27)
| | 18–34 g/d | 0.95 (0.42–2.27)
| | >35 g/d | 1.47 (0.60–3.61)
| | [underlined: Hazards ratio for fatal stroke and non fatal and fish consumption]
| | 1–17 g/d | 0.94 (0.58–1.51)
| | 18–34 g/d | 0.89 (0.56–1.43)
| | >35 g/d | 1.28 (0762–2.14)
| | Adjusted for age, SBP, smoking, cholesterol, diabetes, ECG abnormalities, salt, alcohol, vitamin C
Osler 2003 | All cause deaths and fatal and nonfatal incident CHD were verified from ICD-8 codes 410–414, ICD-10 codes I20–I25 | [underlined: Hazard rate ratio estimates by fish intake] | | | | | | | Danish Medical Research Council
| | | <1 time/mo | 2/mo | 1/wk | >2/wk | p value trend
| | All cause deaths
| | All (n=1329) | 0.88(0.76–1.02) | 0.84(0.73–0.96) | 1.0 | 1.06(0.88–1.28) | .02
| | Men (n=826) | 0.80(0.65–0.90) | 0.87(0.73–1.03) | 1.0 | 1.01(0.80–1.28) | .08
| | Women (n=503) | 1.03(0.82–1.30) | 0.80(0.68–1.03) | 1.0 | 1.21(0.90–1.63) | .06
| | High risk (n=562) | 0.83(0.65–1.06) | 0.84(0.68–1.03) | 1.0 | 1.23(0.94–1.61) | .03
| | CHD mortality
| | All (n=247) | 1.09(0.78–1.52) | 0.98(0.64–1.21) | 1.0 | 0.98(0.62–1.52) | .74
| | High risk (n=130) | 1.19(0.75–1.90) | 0.98(0.64–1.50) | 1.0 | 0.92(0.49–1.78) | .86
Pietinen 1997 (ABCC Prevention Study) | ICD-9 codes 410–414 | [underlined: RR of major coronary events by energy-adjusted quintiles of fatty acid intake] | | | | | | | Funding: NCl, Finnish National Public Institute, Hoffman-LaRoche Academy of Finland
| | Quintile | Intake (G) | Cases/pers-yrs | Age-adj RR | Multivariate
| | 1 | 0.2 | 284/25,538 | 1.00 | 1.00
| | 2 | 0.3 | 263/25,630 | 0.94(0.79–1.11) | 0.94(0.80–1.12)
| | 3 | 0.4 | 280/25,460 | 1.01(0.85–1.19) | 1.03(0.87–1.21)
| | 4 | 0.5 | 274/25,471 | 0.98(0.83–1.16) | 1.02(0.86–1.20)
| | 5 | 0.8 | 298/24,952 | 1.10(0.94–1.30) | 1.15(0.97–1.35)
| | [underlined: RR of coronary death by energy-adjusted quintiles of fatty acids intake]
| | Quintile | Intake (G) | Cases/pers-yrs | Age-adj RR | Mult RR
| | 1 | 0.2 | 126/26,032 | 1.00 | 1.00
| | 2 | 0.3 | 114/26,081 | 0.93(0.72–1.19) | 0.93(0.72–1.20)
| | 3 | 0.4 | 120/25,950 | 0.98(0.77–1.26) | 0.98(0.76–1.27)
| | 4 | 0.5 | 130/25,855 | 1.06(0.83–1.35) | 1.07(0.83–1.37)
| | 5 | 0.8 | 145/25,470 | 1.23(0.97–1.56) | 1.24(0.97–1.58)
| | The intake of omega-3 fatty acids from fish was directly related to the risk of coronary death in the multivariate model adjusting also for trans-saturated and cis-monosaturated fatty acids (relative risk [RR] = 1.30, 95% CI 1.01–1.67) (p for trend = 0.06 for men in the highest quintile of intake compared to the lowest). There was no association between intakes of saturated or cis-monosaturated fatty acids, linoleic or linolenic acid, or dietary cholesterol and the risk of coronary deaths. All the associations were similar but somewhat weaker for all major coronary events.
Rodriguez 1996 (Honolulu Heart Study) | Acertainment of death is primarily made from obituaries in island newspapers, supplemented with listings of death certificates filed with the State Department of Health. The medical records are then requested and reviewed by a panel of Honolulu Heart Program physicians to identify incident cases of heart disease and stroke as well as to determine the cause of death on the basis of standardized criteria. | [underlined: Age-Adjusted Incidence Rates per 1000 Person-Years for CHD Morbidity and Mortality by Fish Intake and Smoking Status] | | | | | | | Funding source: National Heart, Lung, and Blood Institute, National Institutes of Health
| | | | CHD Incidence | | CHD Mortality
| | | N | low fish intake | high fish intake | low fish intake | high fish intake
| | Never smokers | 2228 | 4.9 | 5.0 | 1.8 | 2.1
| | Past smokers | 1915 | 4.8 | 5.2 | 2.2 | 2.1
| | Current smokers | 3310 | 7.6 | 7.5 | 3.5 | 3.3
| | <20 cig/day | 750 | 4.5 | 7.8 | 2.3 | 3.8
| | 20–30 cig/day | 2006 | 8.0 | 7.5 | 3.1 | 3.2
| | >30 cig/day | 534 | 11.6 | 8.1 | 6.9 | 3.7
| | Among current smokers whose fish intake was high (≥2times/wk), CHD mortality rates showed no relation with cigarettes/d ) 3.7, 3.2, and 3.7 per 1000 person-years for the corresponding levels of smoking). A Cox proportional hazards model showed that: in the high-smoking group, RR for CHD mortality among those with high fish intake was half that of those with low fish consumption (RR=0.5, 0.28–0.91). A Cox model that adjusted for similar risk factors confirmed a significant interaction of cigarettes/day and fish intake (P<.0.01) on CHD mortality. Analyses for CHD incidence showed similar results.
Sasazuki 2001 | ND | [underlined: RR of AMI for fish consumption] | | | | | | | Funding: Sankyo Co, Fukuoka and local medical associations
| | | <2 times/wk | 2–3/wk | >4/wk | p for trend
| | Men | 1.0 | 0.6 (0.4–0.8) | 0.7 (0.4–1.0) | 0.51
| | Women | 1.0 | 0.8 (0.4–1.7) | 1.3 (0.6–2.9) | 0.09
Seino 1997 | Stroke refers to a case where rapidly developing focal disturbance (or global disturbance in the case of subarachnoid hemorrhage) of the brain due to vascular lesion and its signs and symptoms lasted more than 24 hr or until death. Includes cerebral hemorrhage, cerebral infarction, subarachnoid hemorrhage. TIA is excluded. | [underlined: RR for cerebral infarction by quartile of n-3 intake (multivariate)] | | | | | | | Funding: Department of health Promotion, Shibata Japan and regional and local hospitals
9151243 | | | 2.3 g/d | 2.7 | 3.2
| | | 0.99 (0.52–1.90) | 1.57 (0.77–3.21) | 1.37 (0.54–3.47) | p=0.23
| | Adjusted for sex and age. DPB and AF were adjusted by Cox proportional hazard model.
| | The intake of n-3 was positively associated with development of cerebral infarction but did not reach statistical significance. The lowest risk was seen in the Q4 quartile.
Siscovick 1995 | Cases were defined by the occurrence of a sudden pulseless condition and the absence of evidence of a noncardiac condition as the cause of cardiac arrest. | [underlined: Risk of Primary Cardiac Arrest and n-3 fatty acid intake g/mo] | | | | | | | Funding Source: NHLBI and the University of Washington Clinic Nutrition Research unit. Initial support was provided by the Medic One Foundation
| | | N | Cases (295) | N | Controls (398)
| | No seafood intake | 34 | 1.0 | 19 | 1.0
| | 0.96 g/mo | 92 | 0.9(0.8–1.0) | 91 | 0.8(0.7–1.0)
| | 2.94 g/mo | 77 | 0.7(0.6–0.9) | 101 | 0.6(0.4–0.9)
| | 5.54 g/mo | 45 | 0.5(0.4–0.8) | 94 | 0.4(0.2–0.8)
| | 13.65 g/mo | 47 | 0.4(0.2–0.7) | 95 | 0.2(0.1–0.7)
| | Compared with no intake of EPA + DPA, an intake of 5.5 g/mo n-3 fatty acids (the mean of the third quartile and the equivalent of one fatty fish meal per week) was associated with a 50% reduction in the risk of primary cardiac arrest (OR 0.5; 0.4–0.8), after adjustment for potential confounding factors.
Tavani 2001 | First episode of nonfatal AMI was defined according to WHO criteria | [underlined: Distribution of AMI case and controls with corresponding ORs, according to n-3 PUFA and fish intake (multivariate)] | | | | | | | ND on funding
| | | <0.81 g/wk | 0.81–1.28 | >1.28
| | AMI Cases | 199 | 139 | 169
| | Controls | 148 | 144 | 185
| | OR | 1.0 | 0.71* (0.51–0.98) | 0.67* (0.50–0.91) | p=0.01
| | Total fish | <1/wk | 1-<2 | >2
| | AMI Cases | 179 | 178 | 150
| | Controls | 139 | 171 | 168
| | OR | 1.0 | 0.79 (0.58–1.08) | 0.67* (0.49–0.93) | p=0.02
| | Fresh fish | <1/wk | 1-<2 | >2
| | AMI Cases | 186 | 203 | 118
| | Controls | 142 | 204 | 131
| | OR | 1.0 | 0.75 (0.56–1.01) | 0.68* (0.48–0.95) | p=0.02
| | Canned fish | 0 | 0-<1/wk | >1
| | AMI Cases | 188 | 199 | 120
| | Controls | 156 | 203 | 119
| | OR | 1.0 | 0.82 (0.61–1.10) | 0.77 (0.55–1.09) | p=0.12
| | Adjusted for age, sex, education, BMI, chol, smoking, coffee, alcohol, meat, vegetables, fruit, calorie intake, activity, hyperlipidemia, DM, HTN, family hx of AMI
Yuan 2001 | Causes of death coded according to ICD-9, 410, 411–414, 430–438. Specific endpoints were deaths from AMI that included sudden and non-sudden cardiac death within 28 d, ischemic heart disease other than AMI, and stroke. | RR of CVD mortality, according to dietary seafood intake (multivariate)
Shanghai Cohort Study | | Seafood g/wk | Person-yrs | AMI | | Stroke
| | Fish/shellfish | | Deaths | RR | Deaths | RR
| | <50 | 36892 | 33 | 1.0 | 101 | 1.00
| | 50-<100 | 55115 | 28 | 0.55 (0.33–0.91) | 141 | 0.93 (0.72–1.21)
| | 100-<150 | 32499 | 21 | 0.65 (0.38–1.14) | 70 | 0.79 (0.58–1.07)
| | 150-<200 | 25767 | 17 | 0.66 (0.36–1.19) | 71 | 1.01 (0.74–1.37)
| | ≥200 | 29194 | 14 | 0.41 (0.22–0.78) | 97 | 1.11 (0.83–1.47)
| | [underlined: Fish only]
| | <50 | 32550 | 29 | 1.00 | 91 | 1.00
| | 50-<100 | 39355 | 30 | 0.54 (0.32–0.90) | 142 | 0.84 (0.64–1.09)
| | 100-<150 | 39992 | 28 | 0.72 (0.42–1.21) | 99 | 0.87 (0.65–1.15)
| | 150-<200 | 24293 | 16 | 0.63 (0.34–1.17) | 68 | 0.95 (0.69–1.31)
| | ≥200 | 23277 | 10 | 0.35 (0.17–0.72) | 80 | 1.05 (0.77–1.43)
| | Shellfish only
| | <50 | 63301 | 52 | 1.00 | 183 | 1.00
| | 50-<100 | 34519 | 18 | 0.65 (0.38–1.11) | 80 | 0.86 (0.66–1.12)
| | 100-<150 | 50210 | 28 | 0.66 (0.42–1.05) | 128 | 0.96 (0.77–1.21)
| | 150-<200 | 20505 | 11 | 0.64 (0.33–1.23) | 59 | 1.08 (0.81–1.46)
| | ≥200 | 10932 | 4 | 0.40 (0.14–1.12) | 30 | 1.02 (0.69–1.51)
| | [underlined: RR of CVD disease mortality, according to dietary intake from seafood (multivariate)]
| | Intake | Person-yrs | AMI | | Stroke
| | | | Deaths | RR | Deaths | RR
| | <27 g/wk | 35583 | 33 | 1.0 | 106 | 1.0
| | 0.27–0.43 | 32076 | 12 | 0.39* (0.20–0.75) | 75 | 0.76 (0.57–1.03)
| | 0.44–0.72 | 54769 | 37 | 0.67 (0.42–1.08) | 124 | 0.76* (0.58–0.98)
| | 0.73–1.1 | 28613 | 16 | 0.53* (0.29–0.97) | 81 | 0.93 (0.69–1.24)
| | >1.1 | 28425 | 15 | 0.43* (0.23–0.81) | 94 | 1.00 (0.75–1.33)

1 Multivariate model 1 controlled for assignment to aspirin and beta carotene treatment or BMI (subjects were classified as having values of less than 25, 25–30, or more than 30), history of diabetes, history of hypertension, history of hypercholetserolemia, alcohol consumption (<1/mo, 1–6/wk, daily), frequency of vigorous exercise (<1/wk, >1/wk), and parental history of MI before the age of 60 years.

2 Multivariate model 2 included the variables in multivariate model 1 and the quartile of trans unsaturated fatty acid and monounsaturated fatty acid levels.

* statistically significant