# Appendix A

## A.1 Primary Search Strategy

1. exp cardiovascular diseases/
2. Adhesion molecule expression.mp.
3. Angiographic progression.mp.
4. Angioplast$.mp.
5. (atherogen$ or antiartherogen$).mp.
6. (arrhythmi$ or Antiarrhythmi$).mp.
7. Antithrombo$.mp.
8. endotheli$.mp.
9. exp endothelium, vascular/
10. Beta-thromboglobulin.mp.
11. Cardi$.mp.
12. CHD.mp.
13. Coronary.mp.
14. Hypotens$.mp.
15. Hypotriglyceridem$.mp.
16. heart disease$.mp.
17. Myocardial infarct$.mp.
18. Platelet adhesi$.mp.
19. (postprandial adj (lipemia or lipoprotein$)).mp.
20. Pulmonary Embol$.mp.
21. Heart failure$.mp.
22. Arteriosclerosi$.mp.
23. cardioprotect$.mp.
24. Homocystine/
25. exp Homocysteine/
26. homocyst$.mp.
27. Cystine/
28. cystine.mp.
29. exp Acute-Phase Proteins/
30. acute phase protein$.mp.
31. Acute-Phase Reaction/
32. acute phase react$.mp.
33. exp Blood Coagulation Factor Inhibitors/
34. exp Blood Coagulation Factors/
35. blood coagulation factors$.mp.
36. exp Cell Adhesion Molecules/
37. cell adhesion molecule$.mp.
38. exp Interleukins/
39. interleukin$.mp.
40. Lipid Peroxidation/
41. lipid peroxidat$.mp.
42. exp Hemostasis/
43. hemosta$.mp.
44. haemosta$.mp.
45. exp Diagnostic Techniques, Cardiovascular/
46. or/1–45
47. exp fatty acids, omega-3/
48. fatty acids, essential/
49. Dietary Fats, Unsaturated/
50. linolenic acids/
51. exp fish oils/
52. (n 3 fatty acid$ or omega 3).tw.
53. docosahexa?noic.tw,hw,rw.
54. eicosapenta?noic.tw,hw,rw.
55. alpha linolenic.tw,hw,rw.
56. (linolenate or cervonic or timnodonic).tw,hw,rw.
57. menhaden oil$.tw,hw,rw.
58. (mediterranean adj diet$).tw.
59. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
60. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
61. (fish adj2 oil$).tw.
62. (cod liver oil$ or marine oil$ or marine fat$).tw.
63. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
64. (fish consumption or fish intake or (fish adj2 diet$)).tw.
65. diet$ fatty acid$.tw.
66. or/47–65
67. dietary fats/
68. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
69. random$.tw.
70. exp clinical trials/ or evaluation studies/
71. follow-up studies/ or prospective studies/
72. or/68–71
73. 67 and 72
74. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
75. (omega 3 or n 3).mp.
76. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
77. 75 and 76
78. 66 or 73 or 74 or 77
79. 46 and 78
80. limit 79 to (addresses or bibliography or biography or congresses or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index or review of reported cases)
81. 79 not 80
82. limit 81 to human
83. (guidelines or practice guideline or meta analysis or review or revewi, academic or review, tutorial or review literature).pt.
84. 82 and 83
85. limit 84 to english language
86. 84 not 85
87. (random$ or rct$).tw.
88. exp randomized controlled trials/
89. exp random allocation/
90. exp double-blind method/
91. exp single-blind method/
92. randomized controlled trial.pt.
93. clinical trial.pt.
94. (clin$ adj trial$).tw.
95. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
96. exp placebos/
97. placebo$.tw.
98. exp comparative study/
99. exp clinical trials/
100. follow-up studies/
101. (follow up or followup).tw.
102. exp case-control studies/
103. (case adj20 control).tw.
104. exp longitudinal studies/
105. longitudinal.tw.
106. exp cohort studies/
107. cohort.tw.
108. exp prospective studies/
109. exp evaluation studies/
110. or/87–109
111. (82 and 110) not 83
112. limit 111 to english language
113. 111 not 112
114. 82 not (111 or 83)
115. limit 114 to english language
116. 114 not 115

## A.2 Diabetes Search Strategy

1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw,hw,rw.
8. eicosapenta?noic.tw,hw,rw.
9. alpha linolenic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. (mediterranean adj diet$).tw.
12. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
13. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
14. (fish adj2 oil$).tw.
15. (cod liver oil$ or marine oil$ or marine fat$).tw.
16. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
17. (fish consumption or fish intake or (fish adj2 diet$)).tw.
18. diet$ fatty acid$.tw.
19. menhaden oil$.tw,hw,rw.
20. or/1–19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/ or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22–25
27. 21 and 26
28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
29. (omega 3 or n 3).mp.
30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
31. 29 and 30
32. or/20,27–28,31
33. limit 32 to (addresses or bibliography or biography or congresses or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index or review of reported cases)
34. Case Report/
35. 32 not (33 or 34)
36. exp Diabetes Mellitus/
37. diabet$.af.
38. nd (36 or 37)
39. limit 38 to human
40. limit 39 to english language
41. limit 40 to (guideline or meta analysis or review or review, academic or review, multicase or review, tutorial or review literature)
42. 40 not 41

## A.3 Nut Search Strategy

1. exp Nuts/ 964
2. exp Cardiovascular Diseases/ 1123117
3. (nut or nuts).tw. 1762
4. 1 or 3 2318
5. 4 and 2 145
6. limit 5 to (human and english language) 122

## A.4 Risk Factor Update Search Strategy

1. exp fatty acids, omega-3/
2. exp fish oils/
3. (n 3 fatty acid$ or omega 3).tw.
4. docosahexa?noic.tw,hw,rw.
5. eicosapenta?noic.tw,hw,rw.
6. alpha linolenic.tw,hw,rw.
7. (linolenate or cervonic or timnodonic).tw,hw,rw.
8. (fish adj2 oil$).tw.
9. or/1–8
10. limit 9 to human
11. limit 10 to english language
12. exp “Lipoprotein(a)”/
13. c-reactive protein.mp.
14. insulin.mp.
15. exp Factor VIII/
16. exp von Willebrand Factor/
17. heart rate variab$.mp.
18. ankle brachial index.mp.
19. ankle-arm blood pressure index.mp.
20. exp Hemoglobin A, Glycosylated/
21. glycohemoglobin hgb a1c.mp.
22. hgb a1c.mp.
23. exp Apolipoproteins B/
24. apolipoprotein b-100.tw.
25. intima media thickness.mp.
26. carotid doppler.mp.
27. exp Heart Function Tests/
28. exp PLETHYSMOGRAPHY/
29. exp Ultrasonography, Doppler/
30. glycated hemoglobin.mp.
31. or/12–30
32. 11 and 31