# Appendixes

Appendix A

Appendix B

Appendix C. Evidence Tables

Appendix D. Peer Reviewers

Appendix E

Appendix F