# List of Acronyms/Abbreviations

Abbreviation | Definition
I | Broadly applicable study
II | Study applicable to sub-group of population
III | Narrowly applicable study
Δ% | Difference of the marker's profile (post-treatment minus pre-treatment)
A | Alpha linolenic acid or “good” quality study (see Summary Table footnotes)
AA | Arachidonic acid (20:4 n-6)
AC_50_ | Concentration of collagen giving a 50% decrease in optical density
Ad | Adequate allocation concealment
ADP | Adenosine diphosphate
AHRQ | Agency for Healthcare Research and Quality
AI | Adequate Intake
ALA | Alpha linolenic acid (18:3 n-3)
Allocation Conceal | Allocation concealment
apo | Apolipoprotein
apo A-I | Apolipoprotein A-I
apo B-100 | Apolipoprotein B-100
apo B-48 | Apolipoprotein B-48
apo C-III | Apolipoprotein C-III
B | Fair quality study
Base | Baseline level in treatment arm
BMI | Body mass index
C | Poor quality study
CAB | Commonwealth Agricultural Bureau
CB | Carotid bifurcation
CCA | Common carotid artery
CI | Confidence interval
Cohort Δ | Difference between cohort and reference cohort (cross-sectional)
CR | Control rate
CRP | C-reactive protein
CSFII | Continuing Food Survey of Intakes by Individuals
CVD | Cardiovascular disease
D | Docosahexaenoic acid
DHA | Docosahexaenoic acid (22:6 n-3)
DM | Diabetes mellitus
DM I | Diabetes mellitus, type 1
DM II | Diabetes mellitus, type 2
DPA | Docosapentaenoic acid (DPA, 22:5 n-3)
DysLip | DysLipidemia
E | Eicosapentaenoic acid
ECG | Electrocardiogram
ED | EPA+DHA
EE | Ethyl ester
ELISA | Enzyme-linked immunosorbent assay
EPA | Eicosapentaenoic acid (20:5 n-3)
EPC | Evidence-based practice center
ERD | Energy-restricted diet
ETT | Exercise tolerance test
FA | Fatty acid
FBS | Fasting blood sugar
GEN | General, healthy population
GLA | Gamma-linolenic acid (18:3 n-6)
HDL | High density lipoprotein
Hgb A_1c_ | Hemoglobin A_1c_
I_max_ | Maximal velocity
IC_50_ | Concentration of Iloprost resulting in 50% inhibition of platelet aggregation
ICA | Internal carotid artery
IDDM | Insulin dependent diabetes mellitus
IDL | Intermediate density lipoprotein
IL | Interleukin
IMT | Intima-media thickness
In | Inadequate allocation concealment
Jadad | Jadad score (see Methods)
JNC 7 | Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure
LA | Linoleic acid (18:2 n-6)
LDL | Low density lipoprotein
LDL apo B | LDL apolipoprotein B
LT | Leukotriene
N | Number of subjects analyzed in study arm
n-3 | Omega-3 (fatty acid)
n-6 | Omega-6 (fatty acid)
NCEP | National Cholesterol Education Program
NCEP I | National Cholesterol Education Program step I prudent diet
nd | No data
Net % Δ | Net percent difference in change in omega-3 fatty acids arm compared with the change in control arm
Net Δ | Net difference in change in omega-3 fatty acids arm compared with the change in control arm
NHANES III | The third National Health and Nutrition Examination
NIDDM | Non-insulin dependent diabetes mellitus
NIH | National Institutes of Health
NS | Non-significant
P | P value
PAI | Plasminogen activator inhibitor
PG | Prostaglandin
PL | Phospholipids
Pre Post Δ | Change in omega-3 fatty acid arm (no control)
PTCA | Percutaneous transluminal coronary angioplasty
RBC | Red blood cell
RCT | Randomized controlled trial
REM MA | Random effects model meta-analysis
RPP | Rate-pressure product
RR | Relative risk
SD | Standard deviation
SDNN | Standard deviation of the RR interval
SEM | Standard error of the mean
SFA | Saturated fatty acid
Sp. | Species
Summary | Summary quality score (see Methods)
T | Total omega-3 fatty acids
TEP | Technical Expert Panel
Tg | Triglycerides
TNF-α | Tumor necrosis factor α
TPA | Tissue plasminogen activator
TPR | Total peripheral resistance
Tufts-NEMC | Tufts-New England Medical Center
TX | Thromboxane
Un | Unclear allocation concealment
UO | University of Ottawa
USDA | United States Department of Agriculture
V_a_ | Aggregation velocity
VCAM-1 | Vascular cell adhesion molecule 1
VLDL | Very low density lipoprotein
vWF | von Willebrand factor
WBC | White blood cell
WMD | Weight-maintaining diet
Xover | Cross-over study