# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this evidence synthesis

Technical Expert Panel

William S. Harris, PhD

Daniel Lauer/Missouri Professor of Metabolism and Vascular Research

UMKC School of Medicine

Co-Director, Lipid and Diabetes Research Center

Mid America Heart Institute at Saint Luke's Hospital

4320 Wornall Road, Suite 128

Kansas City, MO 64111

Judith Hinchey, MD

Assistant Professor of Neurology,

Tufts University School of Medicine

Department of Clinical Care Research

Tufts-New England Medical Center

750 Washington Street, Box 63

Boston, MA 02111

Howard Knapp, MD, PhD

Executive Director

Deaconess Billings Clinic Research Division

Deaconess Billings Clinic

1500 Poly Drive, Suite 202

Billings, MT 59102

David A. Lathrop, PhD

Assistant Director

Clinical and Molecular Medicine Program

Division of Heart and Vascular Diseases

National Heart, Lung, and Blood Institute

National Institutes of Health

6701 Rockledge Drive, Room 8136

Bethesda, MD 20892-7936

Michael Miller, MD, FACC, FAHA

Associate Professor of Medicine and Epidemiology

Director, Center for Preventive Cardiology

Division of Cardiology

University of Maryland Medical Center

22 South Greene Street, Room S3B06

Baltimore, MD 21201

Eva Obarzanek, PhD, MPH, RD

Research Nutritionist

Prevention Scientific Research Group

Division of Epidemiology and Clinical Applications

National Heart, Lung, and Blood Institute

National Institutes of Health

6701 Rockledge Drive, Room 8136

Bethesda, MD 20892-7936